# CHAPTER 8 REFERENCES

ACGIH. 2001. Vinylidene chloride. In: Documentation of the TLVs and BEIs for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 1–6.
Aelion CM, Conte BC. 2004. Susceptibility of residential wells to VOC and nitrate contamination. Environ Sci Technol 38(6):1648–1653. 10.1021/es030401p.15074670
Andersen ME, Jenkins LJ. 1977. Oral toxicity of 1,1-dichloroethylene in the rat: effects of sex, age, and fasting. Environ Health Perspect 21:157–163. 10.1289/ehp.7721157.612440
Andersen ME, Jones RA, Jenkins LJ. 1978. The acute toxicity of single, oral doses of 1,1-dichloroethylene in the fasted, male rat: effect of induction and inhibition of microsomal enzyme activities on mortality. Toxicol Appl Pharmacol 46(1):227–234. 10.1016/0041-008x(78)90153-9.725945
Andersen ME, French JE, Gargas ML, . 1979. Saturable metabolism and the acute toxicity of 1,1-dichloroethylene. Toxicol Appl Pharmacol 47(2):385–393. 10.1016/0041-008x(79)90334-x.452030
Anderson D, Hodge MC, Purchase IF. 1977. Dominant lethal studies with the halogenated olefins vinyl chloride and vinylidene dichloride in male CD-1 mice. Environ Health Perspect 21:71–78. 10.1289/ehp.772171.612461
Ashley DL, Bonin MA, Cardinali FL, . 1992. Determining volatile organic compounds in human blood from a large sample population by using purge and trap gas chromatography/mass spectrometry. Anal Chem 64(9):1021–1029. 10.1021/ac00033a011.1590585
Atkinson R, Carter WPL. 1984. Kinetics and mechanisms of the gas-phase reactions of ozone with organic compounds under atmospheric conditions. Chem Rev 84(5):437–470. 10.1021/cr00063a002.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Fed Regist 54(174):37618–37634.
ATSDR. 1990. Health assessment for Waite Park ground water contamination site, Waite Park, Minnesota, Region 5. Atlanta, GA: Agency for Toxic Substances and Disease Registry. PB90107475. MND981002249. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB90107475.xhtml. July 27, 2020.
ATSDR. 1994. Toxicological profile for 1,1-dichloroethene. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 2003. Health consultation: Commodities Incorporated Site (a/k/a) Chemical Commodities Incorporated) - Olathe, Johnson County, Kansas. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 2006. Public health assessment for Valmont TCE Site: Formerly Valmont Industrial Park Site (A/K/A Valmont Industrial Park) - West Hazleton, Luzerne County, Pennsylvania. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/HAC/pha/ValmontTCESite/ValmontTCESitePHA042806.pdf. October 18, 2021.
ATSDR. 2016. Evaluating vapor intrusion pathways: Guidance for ATSDR’s Division of Community Health investigations. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/docs/svi_guidance_508.pdf. October 18, 2021.
ATSDR. 2019. 1,1-Dichloroethene. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry.
Baden JM, Kelley M, Wharton RS, . 1977. Mutagenicity of halogenated ether anesthetics. Anesthesiology 46(5):346–350. 10.1097/00000542-197705000-00010.15474
Baek NH, Jaffé PR, Shingal N. 1990. Simulating the degradation of TCE under methanogenesis. J Environ Sci Health A25(8):987–1005. 10.1080/10934529009375612.
Balmer MF, Rampy LW, Quast JF, . 1976. 90-Day repeated inhalation toxicity study of vinylidene chloride in rats. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0558226. 86960000086S.
Ban M, Hettich D, Huguet N, . 1995. Nephrotoxicity mechanism of 1,1-dichloroethylene in mice. Toxicol Lett 78(2):87–92. 10.1016/0378-4274(94)03237-2.7618182
Ban M, Hettich D, Bonnet P. 2003. Effect of inhaled industrial chemicals on systemic and local immune response. Toxicology 184(1):41–50. 10.1016/s0300-483x(02)00553-x.12505375
Ban M, Langonne I, Huguet N, . 2006. Inhaled chemicals may enhance allergic airway inflammation in ovalbumin-sensitised mice. Toxicology 226(2–3):161–171. 10.1016/j.tox.2006.06.012.16879906
Barnes DG, Dourson M. 1988. Reference dose (RfD): description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486. 10.1016/0273-2300(88)90047-5.3222488
Barrio-Lage G, Parsons FZ, Nassar RS, . 1986. Sequential dehalogenation of chlorinated ethenes. Environ Sci Technol 20(1):96–99. 10.1021/es00143a013.22300158
Bartsch H, Malaveille C, Barbin A, . 1979. Mutagenic and alkylating metabolites of halo-ethylenes, chlorobutadienes and dichlorobutenes produced by rodent or human liver tissues. Evidence for oxirane formation by P450-linked microsomal mono-oxygenases. Arch Toxicol 41(4):249–277. 10.1007/BF00296896.373707
Birkel TJ, Roach JA, Sphon JA. 1977. Determination of vinylidene chloride in Saran films by electron capture gas-solid chromatography and confirmation by mass spectrometry. J Assoc Off Anal Chem 60(5):1210–1213.893335
Boublik T, Fried V, Hala E. 1984. 1,1-Dichloroethylene. In: The vapour pressures of pure substances. 2nd ed. New York, NY: Elsevier Science, 96.
Bove FJ, Fulcomer MC, Klotz JB, . 1995. Public drinking water contamination and birth outcomes. Am J Epidemiol 141(9):850–862. 10.1093/oxfordjournals.aje.a117521.7717362
Bronzetti G, Bauer C, Corsi C, . 1981. Genetic activity of vinylidene chloride in yeast. Mutat Res 89(2):179–185. 10.1016/0165-1218(81)90123-3.7027030
Bruckner JV, White CA, Muralidhara S, . 2010. Influence of exposure route and oral dosage regimen on 1, 1-dichloroethylene toxicokinetics and target organ toxicity. J Pharmacol Exp Ther 333(2):519–527. 10.1124/jpet.109.162479.20130112
Burk T, Zarus G. 2013. Community exposures to chemicals through vapor intrusion: A review of past ATSDR public health evaluations. J Environ Health 75(9):36–41.
Busch JT. 1985. Final report on the safety assessment of p-hydroxyanisole. J Am Coll Toxicol 4(5):31–63. 10.3109/10915818509078686.
Cavelier L, Bonnet P, Morel G, . 1996. Role of cysteine conjugation in vinylidene chloride-induced nephrotoxicity and hepatotoxicity in fasted rats. J Appl Toxicol 16(2):109–113. 10.1002/(SICI)1099-1263(199603)16:2<109::AID-JAT308>3.0.CO;2-9.8935783
CDC. 2017. Fourth national report on human exposure to environmental chemicals. Updated tables, January 2017, volume one. Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/biomonitoring/pdf/FourthReport_UpdatedTables_Volume1_Jan2017.pdf. February 23, 2017.
CDR. 2018. 1-1-Dichloroethene. Chemical data reporting results. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting. February 20, 2019.
Chang HL, Alvarez-Cohen L. 1996. Biodegradation of individual and multiple chlorinated aliphatic hydrocarbons by methane-oxidizing cultures. Appl Environ Microbiol 62(9):3371–3377.8795228
Charbonneau M, Greselin E, Brodeur J, . 1991. Influence of acetone on the severity of the liver injury induced by haloalkane mixtures. Can J Physiol Pharmacol 69(12):1901–1907. 10.1139/y91-281.1802361
Chauhan S, Barbieri P, Wood TK. 1998. Oxidation of trichloroethylene, 1,1-dichloroethylene, and chloroform by toluene/o-xylene monooxygenase from Pseudomonas stutzeri OX1. Appl Environ Microbiol 64(8):3023–3024.9687467
Chieco P, Moslen MT, Reynolds ES. 1981. Effect of administrative vehicle on oral 1,1-dichloroethylene toxicity. Toxicol Appl Pharmacol 57(2):146–155. 10.1016/0041-008x(81)90274-x.7222030
Chopra NM, Campbell BS, Hurley JC. 1978. Systematic studies on the breakdown of endosulfan in tobacco smokes: Isolation and identification of the degradation products from the pyrolysis of endosulfan I in a nitrogen atmosphere. J Agric Food Chem 26(1):255–258. 10.1021/jf60215a017.
Chu W, Chan KH. 2000. The prediction of partitioning coefficients for chemicals causing environmental concern. Sci Total Environ 248(1):1–10. 10.1016/s0048-9697(99)00472-6.10807037
CITI. 1992. 1,1-Dichloroethylene. In: Biodegradation and bioaccumulation data of existing chemicals based on the CSCL Japan. Tokyo, Japan: Chemicals Inspection & Testing Institute, 23. (Japanese)
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131. 10.1177/074823378500100408.3843496
Cline PV, Viste DR. 1985. Migration and degradation patterns of volatile organic compounds. Waste Manag Res 3(4):351–360. 10.1016/0734-242X(85)90128-4.
Cline PV, Delfino JJ. 1987. Abiotic formation and degradation of 1,1-dichloroethene. Prepr Pap Natl Meet Am Chem Soc Div Environ Chem 27(2):577–579.
Cole RH, Frederick RE, Healy RP, . 1984. Preliminary findings of the priority pollutant monitoring project of the National Urban Runoff Program. J Water Pollut Control Fed 56(7):898–908.
Costa AK, Ivanetich KM. 1982. Vinylidene chloride: its metabolism by hepatic microsomal cytochrome P-450 in vitro. Biochem Pharmacol 31(11):2083–2092. 10.1016/0006-2952(82)90425-7.7115426
Cotruvo JA. 1985. Organic micropollutants in drinking water: an overview. Sci Total Environ 47:7–26. 10.1016/0048-9697(85)90316-x.3911422
Cotti G, Maltoni C, Lefemine G. 1988. Long-term carcinogenicity bioassay on vinylidene chloride administered by inhalation to Sprague-Dawley rats. New results. Ann N Y Acad Sci 534:160–168. 10.1111/j.1749-6632.1988.tb30109.x.3389653
Crebelli R, Andreoli C, Carere A, . 1992. The induction of mitotic chromosome malsegregation in Aspergillus nidulans. Quantitative structure activity relationship (QSAR) analysis with chlorinated aliphatic hydrocarbons. Mutat Res 266(2):117–134. 10.1016/0027-5107(92)90179-6.1373821
Crume RV. 1991. The comparison of health risks between different environmental media at Superfund hazardous waste sites. In: Proceedings: papers from the 84th annual meeting and exhibition. Vol. 15A. Pittsburgh, PA: Air & Waste Management Association, 91/109.104.
Dallas CE, Weir FW, Feldman S, . 1983. The uptake and disposition of 1,1-dichloroethylene in rats during inhalation exposure. Toxicol Appl Pharmacol 68(1):140–151. 10.1016/0041-008x(83)90363-0.6845373
Dawson BV, Johnson PD, Goldberg SJ, . 1993. Cardiac teratogenesis of halogenated hydrocarboncontaminated drinking water. J Am Coll Cardiol 21(6):1466–1472. 10.1016/0735-1097(93)90325-u.8473657
Dekant W, Vamvakas S, Anders MW. 1989. Bioactivation of nephrotoxic haloalkenes by glutathione conjugation: formation of toxic and mutagenic intermediates by cysteine conjugate beta-lyase. Drug Metab Rev 20(1):43–83. 10.3109/03602538908994144.2653763
DeLeon IR, Maberry MA, Overton EB, . 1980. Rapid gas chromatographic method for the determination of volatile and semivolatile organochlorine compounds in soil and chemical waste disposal site samples. J Chromatogr Sci 18(2):85–88. 10.1093/chromsci/18.2.85.
DOE. 2018a. Table 3: Protective Action Criteria (PAC) rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. Oak Ridge, TN: U.S. Department of Energy. https://edms.energy.gov/pac/docs/Revision_29A_Table3.pdf. April 12, 2020.
DOE. 2018b. Protective Action Criteria (PAC): Chemicals with AEGLs, ERPGs, & TEELs. Oak Ridge, TN: U.S. Department of Energy. https://edms.energy.gov/pac/. April 12, 2020.
Dolan ME, McCarty PL. 1995. Methanotrophic chloroethene transformation capacities and 1,1-dichloroethene transformation product toxicity. Environ Sci Technol 29(11):2741–2747. 10.1021/es00011a007.22206519
Dowsley TF, Forkert PG, Benesch LA, . 1995. Reaction of glutathione with the electrophilic metabolites of 1,1-dichloroethylene. Chem Biol Interact 95(3):227–244. 10.1016/0009-2797(94)03563-n.7728894
Dowsley TF, Ulreich JB, Bolton JL, . 1996. CYP2E1-dependent bioactivation of 1,1-dichloroethylene in murine lung: formation of reactive intermediates and glutathione conjugates. Toxicol Appl Pharmacol 139(1):42–48. 10.1006/taap.1996.0141.8685907
Dowsley TF, Reid K, Petsikas D, . 1999. Cytochrome P-450-dependent bioactivation of 1,1-dichloroethylene to a reactive epoxide in human lung and liver microsomes. J Pharmacol Exp Ther 289(2):641–648.10215634
Drevon C, Kuroki T. 1979. Mutagenicity of vinyl chloride, vinylidene chloride and chloroprene in V79 Chinese hamster cells. Mutat Res 67(2):173–182. 10.1016/0165-1218(79)90129-0.470972
D’Souza RW, Andersen ME. 1988. Physiologically based pharmacokinetic model for vinylidene chloride. Toxicol Appl Pharmacol 95(2):230–240. 10.1016/0041-008x(88)90159-7.3420614
Easley DM, Kleopfer RD, Carasea AM. 1981. Gas chromatographic - mass spectrometric determination of volatile organic compounds in fish. J Assoc Off Anal Chem 64(3):653–656.7240070
Eichelberger JW, Bellar TA, Donnelly JP, . 1990. Determination of volatile organics in drinking water with USEPA method 524.2 and the ion trap detector. J Chromatogr Sci 28(9):460–467. 10.1093/chromsci/28.9.460.2273069
el-Masri HA, Constan AA, Ramsdell HS, . 1996a. Physiologically based pharmacodynamic modeling of an interaction threshold between trichloroethylene and 1,1-dichloroethylene in Fischer 344 rats. Toxicol Appl Pharmacol 141(1):124–132. 10.1006/taap.1996.0268.8917684
el-Masri HA, Tessari JD, Yang RS. 1996b. Exploration of an interaction threshold for the joint toxicity of trichloroethylene and 1,1-dichloroethylene: utilization of a PBPK model. Arch Toxicol 70(9):527–539. 10.1007/s002040050310.8831903
Ensign SA, Hyman MR, Arp DJ. 1992. Cometabolic degradation of chlorinated alkenes by alkene monooxygenase in a propylene-grown Xanthobacter strain. Appl Environ Microbiol 58(9):3038–3046.1444418
EPA. 1977a. Toxicity studies of selected chemicals: Task II. The development of vinylidene chloride inhaled by rats and mice during gestation. Washington, DC: U.S. Environmental Protection Agency. EPA560677022. PB281713.
EPA. 1977b. Market input/output studies task 1: Vinylidene chloride. Washington, DC: U.S. Environmental Protection Agency. PB273205. EPA560677033. AAI23782379101FR1. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9101377C.txt. May 14, 2020.
EPA. 1977c. Environmental monitoring near industrial sites: Vinylidene chloride. Washington, D.C: U.S. Environmental Protection Agency. EPA560677X26. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=910134EU.txt. May 14, 2020.
EPA. 1979. Status assessment of toxic chemicals: Vinylidene chloride. U.S. Environmental Protection Agency. PB80146442. EPA6002792100.
EPA. 1980a. Fate of toxic and hazardous materials in the air environment. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB80221948. EPA600380084. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000I8BH.txt. July 27, 2020.
EPA. 1980b. Occurrence of volatile organics in drinking water. U.S. Environmental Protection Agency. EPA950R80033. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=94000GWC.txt. May 30, 2018.
EPA. 1981. Treatability manual: Treatability data. Washington, DC: U.S. Environmental Protection Agency. EPA600282001a. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30005R3P.txt. July 27, 2020.
EPA. 1982. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environmental Protection Agency. PB87169090. EPA440481014. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100O12M.txt. May 14, 2020.
EPA. 1983. Atmospheric chemistry of several toxic compounds. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600S382092. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000TSO6.txt. July 27, 2020.
EPA. 1984a. Appendix A to part 136-methods for organic chemical analysis of municipal and industrial wastewater. Method 601-purgeable halocarbons. U.S. Environmental Protection Agency. Fed Regist 49(209):43261–43271. https://www.gpo.gov/fdsys/search/submitcitation.action?publication=FR. June 8, 2018.
EPA. 1984b. Method 1624 revision B - volatile organic compounds by isotope dilution GC/MS. U.S. Environmental Protection Agency. Fed Regist 49(209):43407–43415. https://www.gpo.gov/fdsys/search/submitcitation.action?publication=FR. June 8, 2018.
EPA. 1985. Health assessment documents for vinylidene chloride: Final report. Washington, DC: U.S. Environmental Protection Agency. EPA60088303IF. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30001BLI.txt. May 14, 2020.
EPA. 1986a. Guidelines for carcinogen risk assessment. U.S. Environmental Protection Agency. Fed Regist 51(185):33992–34003.
EPA. 1986b. Halogenated volatile organics - method 8010. Test methods for evaluating solid waste. Washington, DC: U.S. Environmental Protection Agency. SW-846.
EPA. 1986c. Method 8240 test methods for evaluating solid wastes: Laboratory manual physical/chemical methods. U.S. Environmental Protection Agency. SW-846.
EPA. 1987. Health advisory for 1,1-dichloroethylene. Washington, DC: U.S. Environmental Protection Agency. EPA820K87115. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000SOUZ.txt. July 27, 2020.
EPA. 1988a. National ambient volatile organic compounds (VOCs) data base update. Research Triangle Park, NC: U.S. Environmental Protection Agency. https://nepis.epa.gov/Exe/ZyPDF.cgi/2000TSWA.PDF?Dockey=2000TSWA.PDF. June 11, 2018.
EPA. 1988b. Recommendations for and documentation of biological values for use in risk assessment. Cincinnati, OH: U.S. Environmental Protection Agency. PB88179874. EPA600687008. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=34855. June 27, 2018.
EPA. 1994. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington, DC: U.S. Environmental Protection Agency. EPA600890066F. https://www.epa.gov/sites/production/files/2014-11/documents/rfc_methodology.pdf. June 27, 2018.
EPA. 2002. Toxicological review of 1,1-dichloroethylene (CAS No. 75-35-4): In support of summary information on the integrated risk information system (IRIS). Washington, DC: U.S. Environmental Protection Agency. EPA635R02002. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0039tr.pdf. June 11, 2018.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001. https://19january2017snapshot.epa.gov/sites/production/files/documents/ry2004rfi.pdf. May 14, 2020.
EPA. 2009a. Hazardous waste characteristics: A user-friendly reference document. U.S. Environmental Protection Agency. https://archive.epa.gov/epawaste/hazard/web/pdf/hw-char.pdf. June 22, 2018.
EPA. 2009b. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
EPA. 2012. Estimation Programs Interface Suite™ for Microsoft® Windows, v 4.11: 1,1-Dichloroethene. Washington, DC: U.S. Environmental Protection Agency. https://www.epa.gov/tsca-screening-tools/epi-suitetm-estimation-program-interface. June 25, 2018.
EPA. 2014a. 2012 Chemical data reporting results. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/chemical-data-reporting-previously-collected-data. February 20, 2019.
EPA. 2014b. Eden North Carolina coal ash spill surface water results (February 11, 2014). U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2014-06/documents/final-w-maps-2014-0211-surfacewater-team2.pdf. May 14, 2020.
EPA. 2014c. Eden North Carolina coal ash spill surface water results (February 7, 2014). U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2014-08/documents/final-epa-sesd-sw-02-07-14.pdf. May 14, 2020.
EPA. 2014d. Eden North Carolina coal ash spill surface water results (February 6, 2014). U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2014-08/documents/final-epa-sesd-sw-02-06-14.pdf. May 14, 2020.
EPA. 2015. OSWER Technical guide for assessing and mitigating the vapor intrusion pathway from subsurface vapor sources to indoor air. U.S. Environmental Protection Agency. OSWER Publication 9200.2-154. https://www.epa.gov/sites/production/files/2015-09/documents/oswer-vapor-intrusion-technical-guide-final.pdf. May 27, 2021.
EPA. 2016a. Air data: Air quality data collected at outdoor monitors across the U.S. Environmental Protection Agency. U.S. Environmental Protection Agency. https://aqs.epa.gov/aqsweb/airdata/download_files.html. June 25, 2018.
EPA. 2016b. Grenada manufacturing ambient air sampling even: Final report. Athens, GA: U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2016-04/documents/grenada_manufacturing_final_report_16-0152_metadata.pdf. May 14, 2020.
EPA. 2017a. 1,1-Dichloroethylene: Substance registry services (SRS). U.S. Environmental Protection Agency. https://ofmpub.epa.gov/sor_internet/registry/substreg/searchandretrieve/substancesearch/search.do?details=displayDetails&selectedSubstanceId=48931. April 20, 2017.
EPA. 2017b. Air data: Air quality data collected at outdoor monitors across the U.S. Environmental Protection Agency. U.S. Environmental Protection Agency. https://aqs.epa.gov/aqsweb/airdata/download_files.html. June 25, 2018.
EPA. 2017c. Duke energy coal ash spill in Eden, NC: History and response timeline. U.S. Environmental Protection Agency. https://www.epa.gov/dukeenergy-coalash/history-and-response-timeline. May 14, 2020.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. July 25, 2018.
EPA. 2018b. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2020. 2016 CDR Data (updated May 2020). U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/access-cdr-data#2016. July 19, 2021.
Eyre RJ, Stevens DK, Parker JC, . 1995. Renal activation of trichloroethene and S-(1,2-dichlorovinyl)-L-cysteine and cell proliferative responses in the kidneys of F344 rats and B6C3F1 mice. J Toxicol Environ Health 46(4):465–481. 10.1080/15287399509532049.8523472
FDA. 1988. Indirect food additives: Polymers. U.S. Food and Drug Administration. Fed Regist 53:47184–47185. https://www.loc.gov/item/fr053225/. May 14, 2020.
FDA. 2017. Subpart B - Requirements for specific standardized beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. https://www.gpo.gov/fdsys/pkg/CFR-2017-title21-vol2/pdf/CFR-2017-title21-vol2-sec165-110.pdf. September 7, 2017.
FDA. 2019. Vinylidene chloride. List of indirect additives used in food contact substances. Washington, DC: U.S. Food and Drug Administration. https://www.accessdata.fda.gov/scripts/fdcc/index.cfm?set=IndirectAdditives&id=VINYLIDENECHLORIDE. May 13, 2020.
FDA. 2020a. Q3C - Tables and list guidance for industry. U.S. Food and Drug Administration. https://www.fda.gov/downloads/Drugs/Guidances/ucm073395.pdf. May 7, 2020.
FDA. 2020b. Cumulative estimated daily intake. U.S. Food and Drug Administration. https://www.accessdata.fda.gov/scripts/sda/sdNavigation.cfm?filter=vinylidene&sortColumn=&sd=edisrev&page=1&displayAll=false. May 7, 2020.
FDA. 2020c. Substances added to food. Washington, DC: U.S. Food and Drug Administration. https://www.accessdata.fda.gov/scripts/fdcc/?set=FoodSubstances. April 12, 2020.
Ferrario JB, Lawler GC, DeLeon IR, . 1985. Volatile organic pollutants in biota and sediments of Lake Pontchartrain. Bull Environ Contam Toxicol 34(2):246–255. 10.1007/BF01609730.3978262
Fisher JW, Whittaker TA, Taylor DH, . 1989. Physiologically based pharmacokinetic modeling of the pregnant rat: a multiroute exposure model for trichloroethylene and its metabolite, trichloroacetic acid. Toxicol Appl Pharmacol 99(3):395–414. 10.1016/0041-008x(89)90149-x.2749729
Foerst D. 1979. A sampling and analytical method for vinylidene chloride in air. Am Ind Hyg Assoc J 40(10):888–893. 10.1080/15298667991430451.525615
Fogel MM, Taddeo AR, Fogel S. 1986. Biodegradation of chlorinated ethenes by a methane-utilizing mixed culture. Appl Environ Microbiol 51(4):720–724.3085587
Forkert PG. 1999a. 1,1-Dichloroethylene-induced Clara cell damage is associated with in situ formation of the reactive epoxide. Immunohistochemical detection of its glutathione conjugate. Am J Respir Cell Mol Biol 20(6):1310–1318. 10.1165/ajrcmb.20.6.3525.10340951
Forkert PG. 1999b. In vivo formation and localization of 1,1-dichloroethylene epoxide in murine liver: Identification of its glutathione conjugate 2-S-glutathionyl acetate. J Pharmacol Exp Ther 290(3):1299–1306.10454507
Forkert PG. 2001. Mechanisms of 1,1-dichloroethylene-induced cytotoxicity in lung and liver. Drug Metab Rev 33(1):49–80. 10.1081/dmr-100000140.11270662
Forkert PG, Reynolds ES. 1982. 1,1-Dichloroethylene-induced pulmonary injury. Exp Lung Res 3(1):57–68. 10.3109/01902148209115816.7060543
Forkert PG, Boyd SM. 2001. Differential metabolism of 1,1-dichloroethylene in livers of A/J, CD-1, and C57BL/6 mice. Drug Metab Dispos 29(11):1396–1402.11602514
Forkert PG, Sylvestre PL, Poland JS. 1985. Lung injury induced by trichloroethylene. Toxicology 35(2):143–160. 10.1016/0300-483x(85)90028-9.4002240
Foureman P, Mason JM, Valencia R, . 1994. Chemical mutagenesis testing in Drosophila. IX. Results of 50 coded compounds tested for the National Toxicology Program. Environ Mol Mutagen 23(1):51–63. 10.1002/em.2850230109.8125083
Gage JC. 1970. The subacute inhalation toxicity of 109 industrial chemicals. Br J Ind Med 27(1):1–18. 10.1136/oem.27.1.1.5418916
Gilbert J, Shepherd MJ, Startin JR, . 1980. Gas chromatographic determination of vinylidene chloride monomer in packaging films and in foods. J Chromatogr 197(1):71–78. 10.1016/s0021-9673(00)80537-3.7430308
Glisson BT, Craft BF, Nelson JH, . 1986. Production of vinylidene chloride from the thermal decomposition of methyl chloroform. Am Ind Hyg Assoc J 47(7):427–435. 10.1080/15298668691389991.3751891
Gossett JM. 1987. Measurement of Henry’s law constant for C1 and C2 chlorinated hydrocarbons. Environ Sci Technol 21(2):202–208. 10.1021/es00156a012.
Grayson M. 1985. Vinylidene chloride and poly(vinylidene chloride). In: Kirk-Othmer concise encyclopedia of chemical technology. 3^rd^ ed. New York, NY: John Wiley & Sons, 1223–1224.
Greim H, Bonse G, Radwan Z, . 1975. Mutagenicity in vitro and potential carcinogenicity of chlorinated ethylenes as a function of metabolic oxiran formation. Biochem Pharmacol 24(21):2013–2017. 10.1016/0006-2952(75)90396-2.1108881
Grosjean D. 1990. Atmospheric chemistry of toxic contaminants: 1. Reaction rates and atmospheric persistence. J Air Waste Manage Assoc 40(10):1397–4102. 10.1080/10473289.1990.10466792.
Grosse Y, Loomis D, Guyton KZ, . 2017. Some chemicals that cause tumours of the urinary tract in rodents. Lancet Oncol 18(8):1003–1004. 10.1016/S1470-2045(17)30505-3.28666821
Guengerich FP, Kim DH, Iwasaki M. 1991. Role of human cytochrome P-450 IIE1 in the oxidation of many low molecular weight cancer suspects. Chem Res Toxicol 4(2):168–179. 10.1021/tx00020a008.1664256
Haag WR, Mill T. 1988. Effect of a subsurface sediment on hydrolysis of haloalkanes and epoxides. Environ Sci Technol 22(6):658–663. 10.1021/es00171a007.
Hallbourg RR, Defino JJ, Miller WL. 1992. Organic priority pollutants in groundwater and surface water at three landfills in north central Florida. Water Air Soil Pollut 65(3–4):307–322. 10.1007/BF00479894.
Hallen RT, Pyne JW, Molton PM. 1986. Transformation of chlorinated ethenes and ethanes by anaerobic microorganisms. Prepr Ext Abst Div Environ Chem Am Chem Soc 26(2):344–346.
Hansch C, Leo A, Hoekman D. 1995. Octanol LogP. In: Exploring QSAR: Hydrophobic, electronic, and steric constants. Washington, DC: American Chemical Society, 4.
Harkov R, Gianti SJ, Bozzelli JW, . 1985. Monitoring volatile organic compounds at hazardous and sanitary landfills in New Jersey. J Environ Sci Health A20(5):491–501. 10.1080/10934528509375237.
Harkov R, Kebbekus B, Bozzelli JW. 1987. Volatile organic compounds at urban sites in New Jersey. In: Lioy PJ, Daisey JM, eds. Toxic air pollutants. Chelsea, MI: Lewis Publishers, Inc., 69–88.
Hayes SA, Pandiri AR, Ton TV, . 2016. Renal cell carcinomas in vinylidene chloride-exposed male B6C3F1 mice are characterized by oxidative stress and TP53 pathway dysregulation. Toxicol Pathol 44(1):71–87. 10.1177/0192623315610820.26682919
Haynes WM. 2014. Physical constants of organic compounds: 1,1-Dichloroethene. In: CRC handbook of chemistry and physics. 95^th^ ed. Boca Raton, FL: Taylor & Francis Group, 3–162.
Henck JW, Quast JF, Rampy LW. 1979. A comparison of four mouse strains exposed to subchronically inhaled vinylidene chloride (VDC). Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0537299. 88-920002489. 8EHQ-0592-3847.
Hewitt WR, Plaa GL. 1983. Dose-dependent modification of 1,1-dichloroethylene toxicity by acetone. Toxicol Lett 16(1–2):145–152. 10.1016/0378-4274(83)90023-1.6836608
Hong CB, Winston JM, Thornburg LP, . 1981. Follow-up study on the carcinogenicity of vinyl chloride and vinylidene chloride in rats and mice: tumor incidence and mortality subsequent to exposure. J Toxicol Environ Health 7(6):909–924. 10.1080/15287398109530034.7265317
Horvath AL, Getzen FW, Maczynska Z. 1999. IUPAC-NIST solubility data series 67. Halogenated ethanes and ethenes with water. J Phys Chem Ref Data 28(2):395–627. 10.1063/1.556039.
Humiston CG, Quast JF, Wade CE, . 1978. Results of a two-year toxicity and oncogenicity study with vinylidene chloride incorporated in the drinking water of rats. Dow Chemical Company. Chem Mfgs Assn. Submitted to the U.S. Environmental Protection Agency under TSCA section FYI. OTS0000007-0. FYI-AX-0978-0007.
IARC. 2019. Vinylidene chloride. IARC Monographs on the evaluation of carcinogenic risks to humans. Volume 119. Some chemicals that cause tumours of the urinary tract in rodents. Lyon, France: International Agency for Research on Cancer. https://publications.iarc.fr/575. May 12, 2020.
IRIS. 2002. 1,1-Dichloroethylene (1,1-DCE); CASRN 75-35-4. Chemical assessment summary. Washington, DC: Integrated Risk Information System. U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0039_summary.pdf. May 3, 2017.
IRIS. 2005. 1,1-Dichloroethylene (1,1-DCE); CASRN 75-35-4. Chemical assessment summary. Washington, DC: Integrated Risk Information System. U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0039_summary.pdf. May 3, 2017.
Jackson NM, Conolly RB. 1985. Acute nephrotoxicity of 1,1-dichloroethylene in the rat after inhalation exposure. Toxicol Lett 29(2–3):191–199. 10.1016/0378-4274(85)90041-4.3937299
Jaeger RJ. 1977. Effect of 1,1-dichloroethylene exposure on hepatic mitochondria. Res Commun Chem Pathol Pharmacol 18(1):83–94.905636
Jaeger RJ, Conolly RB, Murphy SD. 1973a. Diurnal variation of hepatic glutathione concentration and its correlation with 1,1-dichloroethylene inhalation toxicity in rats. Res Commun Chem Pathol Pharmacol 6(2):465–471.4750096
Jaeger RJ, Trabulus MJ, Murphy SD. 1973b. Biochemical effects of 1,1-dichloroethylene in rats: Dissociation of its hepatotoxicity from a lipoperoxidative mechanism. Toxicol Appl Pharmacol 24(3):457–467. 10.1016/0041-008x(73)90052-5.4350143
Jaeger RJ, Conolly RB, Murphy SD. 1974. Effect of 18 hr fast and glutathione depletion on 1,1-dichloroethylene-induced hepatotoxicity and lethality in rats. Exp Mol Pathol 20(2):187–198. 10.1016/0014-4800(74)90053-7.4824253
Jaeger RJ, Shoner LG, Coffman L. 1977. 1,1-Dichloroethylene hepatotoxicity: proposed mechanism of action and distribution and binding of 14C radioactivity following inhalation exposure in rats. Environ Health Perspect 21:113–119. 10.1289/ehp.7721113.612435
Jeffers PM, Ward LM, Woytowitch LM, . 1989. Homogeneous hydrolysis rate constants for selected chlorinated methanes, ethanes, ethenes, and propanes. Environ Sci Technol 23(8):965–969. 10.1021/es00066a006.
Jenkins LJ, Andersen ME. 1978. 1,1-Dichloroethylene nephrotoxicity in the rat. Toxicol Appl Pharmacol 46(1):131–141. 10.1016/0041-008x(78)90144-8.725939
Jenkins LJ, Trabulus MJ, Murphy SD. 1972. Biochemical effects of 1,1-dichloroethylene in rats: comparison with carbon tetrachloride and 1,2-dichloroethylene. Toxicol Appl Pharmacol 23(3):501–510. 10.1016/0041-008x(72)90052-x.4404420
Jones BK, Hathway DE. 1978a. Differences in metabolism of vinylidene chloride between mice and rats. Br J Cancer 37(3):411–417. 10.1038/bjc.1978.61.638019
Jones BK, Hathway DE. 1978b. Tissue-mediated mutagenicity of vinylidene chloride in Salmonella typhimurium TA1535. Cancer Lett 5(1):1–6. 10.1016/S0304-3835(78)80002-0.99228
Jones BK, Hathway DE. 1978c. The biological fate of vinylidene chloride in rats. Chem Biol Interact 20(1):27–41. 10.1016/0009-2797(78)90078-9.630643
Jones JA, Kaphalia L, Treinen-Moslen M, . 2003. Proteomic characterization of metabolites, protein adducts, and biliary proteins in rats exposed to 1,1-dichloroethylene or diclofenac. Chem Res Toxicol 16(10):1306–1317. 10.1021/tx0340807.14565772
Kainz A, Cross H, Freeman S, . 1993. Effects of 1,1-dichloroethene and of some of its metabolites on the functional viability of mouse hepatocytes. Fundam Appl Toxicol 21(2):140–148. 10.1006/faat.1993.1083.8405776
Kanz MF, Reynolds ES. 1986. Early effects of 1,1-dichloroethylene on canalicular and plasma membranes: ultrastructure and stereology. Exp Mol Pathol 44(1):93–110. 10.1016/0014-4800(86)90037-7.3948981
Kanz MF, Taj Z, Moslen MT. 1991. 1,1-Dichloroethylene hepatotoxicity: hypothyroidism decreases metabolism and covalent binding but not injury in the rat. Toxicology 70(2):213–229. 10.1016/0300-483x(91)90048-6.1763416
Klimisch HJ, Freisberg KO. 1979a. [Report on the determination of acute toxicity (LC50) by inhalation of vinylidene chloride in Chinese striped hamsters (fed) during a 4-hour exposure period]. Ludwigshafen, Germany: BASF Corporation. HSE Translation No. 9M (German)
Klimisch HJ, Freisberg KO. 1979b. [Report on the determination of acute toxicity (LC50) by inhalation of vinylidene chloride in Chinese striped hamsters (fasting) during a 4-hour exposure period]. Ludwigshafen, Germany: BASF Corporation. HSE Translation No. 9M. (German)
Koch R, Schlegelmilch R, Wolf HU. 1988. Genetic effects of chlorinated ethylenes in the yeast Saccharomyces cerevisiae. Mutat Res 206(2):209–216. 10.1016/0165-1218(88)90162-0.3050501
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kwok E, Atkinson R. 1995. Estimation of hydroxyl radical reaction rate constants for gas-phase organic compounds using a structure-reactivity relationship: An update. Atmos Environ 29(14):1685–1695. 10.1016/1352-2310(95)00069-b.
LaRegina J, Bozzelli JW, Harkov R, . 1986. Volatile organic compounds at hazardous waste sites and a sanitary landfill in New Jersey. Environ Prog 5(1):18–27. 10.1002/ep.670050109.
Larranaga MD, Lewis RJ, Lewis RA. 2016. Vinylidene chloride. In: Hawley’s condensed chemical dictionary. Hoboken, NJ: John Wiley & Sons, Inc., 1417.
Lash LH, Fisher JW, Lipscomb JC, . 2000. Metabolism of trichloroethylene. Environ Health Perspect 108(Suppl 2):177–200. 10.1289/ehp.00108s2177.
Lee CC, Bhandari JC, Winston JM, . 1977. Inhalation toxicity of vinyl chloride and vinylidene chloride. Environ Health Perspect 21:25–32. 10.1289/ehp.772125.565702
Lee CC, Bhandari JC, Winston JM, . 1978. Carcinogenicity of vinyl chloride and vinylidene chloride. J Toxicol Environ Health 4(1):15–30. 10.1080/15287397809529640.633405
Lesage S, Jackson RE, Priddle MW, . 1990. Occurrence and fate of organic solvent residues in anoxic groundwater at the Gloucester landfill, Canada. Environ Sci Technol 24(4):559–565. 10.1021/es00074a016.
Liebler DC, Guengerich FP. 1983. Olefin oxidation by cytochrome P-450: evidence for group migration in catalytic intermediates formed with vinylidene chloride and trans-1-phenyl-1-butene. Biochemistry 22(24):5482–5489. 10.1021/bi00293a005.6652073
Liebler DC, Meredith MJ, Guengerich FP. 1985. Formation of glutathione conjugates by reactive metabolites of vinylidene chloride in microsomes and isolated hepatocytes. Cancer Res 45(1):186–193.3965130
Liebler DC, Latwesen DG, Reeder TC. 1988. S-(2-Chloroacetyl)glutathione, a reactive glutathione thiol ester and a putative metabolite of 1,1-dichloroethylene. Biochemistry 27(10):3652–3657. 10.1021/bi00410a020.3408718
Lin SN, Fu FW, Bruckner JV. 1982. Quantitation of 1,1- and 1,2-dichloroethylene in body tissues by purge-and-trap gas chromatography. J Chromatogr 244(2):311–320. 10.1016/s0021-9673(00)85695-2.7119076
Lyman WJ, Reehl WF, Rosenblatt DH. 1990. Rate of hydrolysis. In: Handbook of chemical property estimation methods. Washington, DC: American Chemical Society, 7–4.
Mackay D, Paterson S. 1981. Calculating fugacity. Environ Sci Technol 15(9):1006–1014. 10.1021/es00091a001.22284102
Malaveille C, Planche G, Bartsch H. 1977. Factors for efficiency of the Salmonella/microsome mutagenicity assay. Chem Biol Interact 17(2):129–136. 10.1016/0009-2797(77)90079-5.407008
Maltoni C, Ciliberti A, Carretti D. 1982. Experimental contributions in identifying brain potential carcinogens in the petrochemical industry. Ann N Y Acad Sci 381:216–249. 10.1111/j.1749-6632.1982.tb50389.x.6953792
Maltoni C, Lefemine G, Cotti G, . 1985. Experimental research on vinylidene chloride carcinogenesis. In: Archives of research on industrial carcinogenesis. Vol. III. Princeton: Princeton Scientific Publishers, Inc., 14–98.
Martin EJ, Forkert PG. 2005. 1,1-Dichloroethylene-induced mitochondrial damage precedes apoptotic cell death of bronchiolar epithelial cells in murine lung. J Pharmacol Exp Ther 313(1):95–103. 10.1124/jpet.104.079392.15626720
Masuda Y, Nakayama N. 1983. Protective action of diethyldithiocarbamate and carbon disulfide against acute toxicities induced by 1,1-dichloroethylene in mice. Toxicol Appl Pharmacol 71(1):42–53. 10.1016/0041-008x(83)90043-1.6314603
McDougal JN, Jepson GW, Clewell HJ, 3rd, . 1990. Dermal absorption of organic chemical vapors in rats and humans. Fundam Appl Toxicol 14(2):299–308. 10.1016/0272-0590(90)90209-3.2318354
McGregor D, Brown AG, Cattanach P, . 1991. Responses of the L5178Y mouse lymphoma forward mutation assay: V. Gases and vapors. Environ Mol Mutagen 17(2):122–129. 10.1002/em.2850170209.2009867
McKenna MJ, Watanabe PG, Gehring PJ. 1977. Pharmacokinetics of vinylidene chloride in the rat. Environ Health Perspect 21:99–105. 10.1289/ehp.772199.612464
McKenna MJ, Zempel JA, Madrid EO, . 1978a. The pharmacokinetics of [14C]vinylidene chloride in rats following inhalation exposure. Toxicol Appl Pharmacol 45(2):599–610. 10.1016/0041-008x(78)90121-7.705790
McKenna MJ, Zempel JA, Madrid EO, . 1978b. Metabolism and pharmacokinetic profile of vinylidene chloride in rats following oral administration. Toxicol Appl Pharmacol 45(3):821–835. 10.1016/0041-008x(78)90173-4.725933
McNab WW, Narasimhan TN. 1994. Degradation of chlorinated hydrocarbons and groundwater geochemistry: a field study. Environ Sci Technol 28(5):769–775. 10.1021/es00054a005.22191815
Mortelmans K, Haworth S, Lawlor T, . 1986. Salmonella mutagenicity tests: II. Results from the testing of 270 chemicals. Environ Mutagen 8(Suppl 7):1–119.
Moslen MT, Poisson LR, Reynolds ES. 1985. Cholestasis and increased biliary excretion of inulin in rats given 1,1-dichloroethylene. Toxicology 34(3):201–209. 10.1016/0300-483x(85)90171-4.3975918
Moslen MT, Whitehead RF, Ferguson AE, . 1989a. Protection by L-2-oxothiazolidine-4-carboxylate, a cysteine prodrug, against 1,1-dichloroethylene hepatotoxicity in rats in associated with decreases in toxin metabolism and cytochrome P-450. J Pharmacol Exp Ther 248(1):157–163.2913268
Moslen MT, Dunsford HA, Karnasuta C, . 1989b. Histochemical and immunocytochemical evidence of early, selective bile canaliculi injury after 1,1-dichloroethylene in rats. Am J Pathol 134(5):1099–1112.2541611
Murray FJ, Nitschke KD, Rampy LW, . 1979. Embryotoxicity and fetotoxicity of inhaled or ingested vinylidene chloride in rats and rabbits. Toxicol Appl Pharmacol 49(2):189–202. 10.1016/0041-008x(79)90241-2.494272
Nakahama T, Mizuno M, Otsuka Y, . 2001. Comparative study on the mode of action of chlorinated ethylenes on the expression of rat CYP forms. J Health Sci 47(3):278–287. 10.1248/jhs.47.278.
Nakajima T, Koyama Y, Sato A. 1982. Dietary modification of metabolism and toxicity of chemical substances - with special reference to carbohydrate. Biochem Pharmacol 31(6):1005–1011. 10.1016/0006-2952(82)90335-5.7082357
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council. 15–35.
NIOSH. 1976. National occupational hazard survey. Cincinnati, OH: National Institute of Occupational Safety and Health.
NIOSH. 1984. 1,1-Dichloroethylene. National occupational exposure survey (1981-1983). Cincinnati, OH: National Institute of Occupational Safety and Health. https://web.archive.org/web/20111026175554/http:/www.cdc.gov/noes/noes1/83011sic.html. June 26, 2018.
NIOSH. 1994. NIOSH manual of analytical methods. Method 1015. Cincinnati, OH: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/docs/2003-154/pdfs/1015.pdf. June 28, 2018.
NIOSH. 2016. Vinylidene chloride: NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0661.html. May 29, 2019.
NIOSH. 2019. Vinylidene chloride. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0661.html. May 12, 2020.
Nitschke KD, Smith FA, Quast JF, . 1983. A three-generation rat reproductive toxicity study of vinylidene chloride in the drinking water. Fundam Appl Toxicol 3(2):75–79. 10.1016/s0272-0590(83)80059-1.6873531
NLM. 2018. 1,1-Dichloroethylene. ChemIDplus: A Toxnet database. Bethesda, MD: U.S. National Library of Medicine. https://chem.nlm.nih.gov/chemidplus/name/1%2C1dichloroethene. May 19, 2017.
NTP. 1982. NTP technical report on the carcinogenesis bioassay of vinylidene chloride (Cas No. 75-35-4) in F344 rats and B6C3Fl mice (gavage study). Research Triangle Park, NC: National Toxicology Program. Technical report series No. 228. NIH Publication No. 82-1784. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr228.pdf. February 2, 2017.
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments – February 2013. National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/hat/review/index-2.html. May 14, 2020.
NTP. 2015a. NTP technical report on the toxicology and carcinogenesis studies of vinylidene chloride (CAS No. 75-35-4) in F344/N rats and B6C3F1/N mice (inhalation studies). Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr582_508.pdf. May 8, 2018.
NTP. 2015b. OHAT risk of bias rating tool for human and animal studies. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/pubs/riskofbiastool_508.pdf. March 19, 2019.
NTP. 2016. CASRN Index. Report on carcinogens. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. February 28, 2017.
Odabasi M. 2008. Halogenated volatile organic compounds from the use of chlorine-bleach-containing household products. Environ Sci Technol 42(5):1445–1451. 10.1021/es702355u.18441786
Oesch F, Protic-Sabljic M, Friedberg T, . 1983. Vinylidene chloride: changes in drug-metabolizing enzymes, mutagenicity and relation to its targets for carcinogenesis. Carcinogenesis 4(8):1031–1038. 10.1093/carcin/4.8.1031.6347425
Oki N, Nakano T, Okuno T, . 1990. Emission of volatile chlorinated organic compounds by combustion of waste organochlorine material. Chemosphere 21(6):761–770. 10.1016/0045-6535(90)90263-S.
Okine LK, Gram TE. 1986. In vitro studies on the metabolism and covalent binding of [^14^C]1,1-dichloroethylene by mouse liver, kidney and lung. Biochem Pharmacol 35(16):2789–2795. 10.1016/0006-2952(86)90191-7.3741469
Okine LK, Goochee JM, Gram TE. 1985. Studies on the distribution and covalent binding of 1,1-dichloroethylene in the mouse. Effect of various pretreatments on covalent binding in vivo. Biochem Pharmacol 34(22):4051–4057. 10.1016/0006-2952(85)90386-7.4062975
O’Neil MJ, Heckelman PE, Dobbelaar PH, . 2013. Vinylidene chloride. In: The Merck Index: An encyclopedia of chemicals, drugs, and biologicals. 15th ed. Whitehouse Station, NJ: The Royal Society of Chemistry, 1858.
OSHA. 2019a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1. October 25, 2019.
OSHA. 2019b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000. October 25, 2019.
OSHA. 2019c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55 Appendix A. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55AppA. October 25, 2019.
Ott MG, Fishbeck WA, Townsend JC, . 1976. A health study of employees exposed to vinylidene chloride. J Occup Med 18(11):735–738. 10.1097/00043764-197611000-00009.11279
Pearson CR, McConnell G. 1975. Chlorinated C1 and C2 hydrocarbons in the marine environment. Proc R Soc Lond B Biol Sci 189(1096):305–332. 10.1098/rspb.1975.0059.238199
Pellizzari ED, Zweidinger RA, Sheldon LS. 1985. GC/MS determination of volatile hydrocarbons in breath samples. In: Fishbein L, O’Neill IK, eds. Environmental carcinogens selected methods of analysis. Vol. 7. Lyon, France: World Health Organization, 413–431.
Pleil JD, Oliver KD, McClenny WA. 1988. Ambient air analyses using nonspecific flame ionization and electron capture detection compared to specific detection by mass spectroscopy. JAPCA 38(8):1006–1010. 10.1080/08940630.1988.10466440.3221253
Plumb RH. 1987. A comparison of ground water monitoring data from CERCLA and RCRA sites. Groundwater Monit Remediat 7(4):94–100. 10.1111/j.1745-6592.1987.tb00968.x.
Plummer JL, Hall PM, Ilsley AH, . 1990. Influence of enzyme induction and exposure profile on liver injury due to chlorinated hydrocarbon inhalation. Pharmacol Toxicol 67(4):329–335. 10.1111/j.1600-0773.1990.tb00839.x.2077526
Ponomarkov V, Tomatis L. 1980. Long-term testing of vinylidene chloride and chloroprene for carcinogenicity in rats. Oncology 37(3):136–141. 10.1159/000225422.7360485
Prendergast JA, Jones RA, Jenkins LJ, . 1967. Effects on experimental animals of long-term inhalation of trichloroethylene, carbon tetrachloride, 1,1,1-trichloroethane, dichlorodifluoromethane, and 1,1-dichloroethylene. Toxicol Appl Pharmacol 10(2):270–289. 10.1016/0041-008x(67)90110-x.4962252
Putcha L, Bruckner JV, D’Souza R, . 1986. Toxicokinetics and bioavailability of oral and intravenous 1,1-dichloroethylene. Fundam Appl Toxicol 6(2):240–250.3699314
Quast JF. 1976. Pathology report on male and female rats exposed to vinylidene chloride vapors for 6 hours per day, 5 days per week during a 30-day period. Dow Chemical, USA.
Quast JF, Humiston CG, Wade CE, . 1983. A chronic toxicity and oncogenicity study in rats and subchronic toxicity study in dogs on ingested vinylidene chloride. Fundam Appl Toxicol 3(1):55–62. 10.1016/s0272-0590(83)80173-0.6884624
Quast JF, McKenna MJ, Rampy LW, . 1986. Chronic toxicity and oncogenicity study on inhaled vinylidene chloride in rats. Fundam Appl Toxicol 6(1):105–144. 10.1016/0272-0590(86)90269-1.3710018
Rajagopol R, Li P. 1991. Comparison of two screening methods for the detection of volatile organic compounds in ground water. J Chemometr 5(3):321–331. 10.1002/cem.1180050318.
Rampy LW, Quast JF, Humiston CG, . 1977. Interim results of two-year toxicological studies in rats of vinylidene chloride incorporated in the drinking water or administered by repeated inhalation. Environ Health Perspect 21:33–43. 10.1289/ehp.772133.612457
Raymer JH, Thomas KW, Cooper SD, . 1990. A device for sampling of human alveolar breath for the measurement of expired volatile organic compounds. J Anal Toxicol 14(6):337–344. 10.1093/jat/14.6.337.2128356
Reichert D, Werner HW, Henschler D. 1978. Role of liver glutathione in 1,1-dichloroethylene metabolism and hepatotoxicity in intact rats and isolated perfused rat liver. Arch Toxicol 41(3):169–178. 10.1007/BF00354088.736789
Reichert D, Werner HW, Metzler M, . 1979. Molecular mechanism of 1,1-dichloroethylene toxicity: excreted metabolites reveal different pathways of reactive intermediates. Arch Toxicol 42(3):159–169. 10.1007/BF00353707.475590
Reitz RH, Watanabe PG, McKenna MJ, . 1980. Effects of vinylidene chloride on DNA synthesis and DNA repair in the rat and mouse: a comparative study with dimethylnitrosamine. Toxicol Appl Pharmacol 52(3):357–370. 10.1016/0041-008x(80)90329-4.7368211
RePORTER. 2020. 1,1-Dichloroethene. Research portfolio online reporting tools. National Institutes of Health. http://projectreporter.nih.gov/reporter.cfm. February 28, 2017.
Reynolds ES, Moslen MT. 1977. Damage to hepatic cellular membranes by chlorinated olefins with emphasis on synergism and antagonism. Environ Health Perspect 21:137–147. 10.1289/ehp.7721137.612438
Reynolds ES, Moslen MT, Boor PJ, . 1980. 1,1-Dichloroethylene hepatotoxicity. Time course of GSH changes and biochemical aberrations. Am J Pathol 101(2):331–344.7435541
Reynolds ES, Kanz MF, Chieco P, . 1984. 1,1-Dichloroethylene: an apoptotic hepatotoxin? Environ Health Perspect 57:313–320. 10.1289/ehp.8457313.6499813
Roldan-Arjona T, Garcia-Pedrajas MD, Luque-Romero FL, . 1991. An association between mutagenicity of the Ara test of Salmonella typhimurium and carcinogenicity in rodents for 16 halogenated aliphatic hydrocarbons. Mutagenesis 6(3):199–205. 10.1093/mutage/6.3.199.1881351
Rooney AA, Boyles AL, Wolfe MS, . 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Rossberg M, Lendle W, Tegel A, . 1986. Chlorinated hydrocarbons. In: Ullman’s encyclopedia of industrial chemistry. Vol. A6. New York, NY: UCH Publishers, 294–297.
Rowe BL, Toccalino PL, Moran MJ, . 2007. Occurrence and potential human-health relevance of volatile organic compounds in drinking water from domestic wells in the United States. Environ Health Perspect 115(11):1539–1546. 10.1289/ehp.10253.18007981
Sabljic A, H G. 1990. Predicting the night-time NO3 radical reactivity in the troposphere. Atmos Environ 24(1):73–78. 10.1016/0960-1686(90)90442-P.
Sabljić A, Güsten H, Verhaar H, . 1995. QSAR modelling of soil sorption. Improvements and systematics of log KOC vs. log KOW correlations. Chemosphere 31(11–12):4489–4514. 10.1016/0045-6535(95)00327-5.
Sasaki M, Sugimura K, Mitsuaki AY, . 1980. Cytogenic effects of 60 chemicals on cultured human and Chinese hamster cells. La Kromosomo II 20:574–584.
Sato A, Nakajima T, Koyama Y. 1983. Interaction between ethanol and carbohydrate on the metabolism in rat liver of aromatic and chlorinated hydrocarbons. Toxicol Appl Pharmacol 68(2):242–249. 10.1016/0041-008x(83)90008-x.6857662
Sawada M, Sofuni T, Ishidate M. 1987. Cytogenetic studies on 1,1-dichloroethylene and its two isomers in mammalian cells in vitro and in vivo. Mutat Res 187(3):157–163. 10.1016/0165-1218(87)90083-8.3821769
Short RD, Winston JM, Minor JL, . 1977a. Toxicity of vinylidene chloride in mice and rats and its alteration by various treatments. J Toxicol Environ Health 3(5–6):913–921. 10.1080/15287397709529625.202722
Short RD, Winston JM, Minor JL, . 1977b. Effect of various treatments on toxicity of inhaled vinylidene chloride. Environ Health Perspect 21:125–129. 10.1289/ehp.7721125.612437
Short RD, Minor JL, Winston JM, . 1977c. A dominant lethal study in male rats after repeated exposures to vinyl chloride or vinylidene chloride. J Toxicol Environ Health 3(5–6):965–968. 10.1080/15287397709529630.599591
Siegel J, Jones RA, Coon RA, . 1971. Effects on experimental animals of acute, repeated and continuous inhalation exposures to dichloroacetylene mixtures. Toxicol Appl Pharmacol 18(1):168–174. 10.1016/0041-008x(71)90326-7.5542822
Siletchnik LM, Carlson GP. 1974. Cardiac sensitizing effects of 1,1-dichloroethylene: enhancement by phenobarbital pretreatment. Arch Int Pharmacodyn Ther 210(2):359–364.4441199
Simmonds AC, Reilly CA, Baldwin RM, . 2004. Bioactivation of 1,1-dichloroethylene to its epoxide by CYP2E1 and CYP2F enzymes. Drug Metab Dispos 32(9):1032–1039.15319346
Singh HB, Salas LJ, Stiles RE. 1982. Distribution of selected gaseous organic mutagens and suspect carcinogens in ambient air. Environ Sci Technol 16(12):872–880. 10.1021/es00106a010.22236265
Singh HB, Salas LJ, Smith AJ, . 1981. Measurements of some potentially hazardous organic chemicals in urban environments. Atmos Environ 15(4):601–612. 10.1016/0004-6981(81)90191-8.
Speerschneider P, Dekant W. 1995. Renal tumorigenicity of 1,1-dichloroethene in mice: the role of male-specific expression of cytochrome P450 2E1 in the renal bioactivation of 1,1-dichloroethene. Toxicol Appl Pharmacol 130(1):48–56. 10.1006/taap.1995.1007.7839370
Squillace PJ, Moran MJ, Lapman WW, . 1999. Volatile organic compounds in untreated ambient groundwater of the United States, 1985-1995. Environ Sci Technol 33(23):4176–4187. 10.1021/es990234m.
SRI. 2011. 2011 Directory of chemical producers: United States. Menlo Park, CA: SRI Consulting.
Staples CA, Werner AF, Hoogheem TJ. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4(2):131–142. 10.1002/etc.5620040202.
Strobel K, Grummt T. 1987. Aliphatic and aromatic halocarbons as potential mutagens in drinking water. III. Halogenated ethanes and ethenes. Toxicol Environ Chem 15(1–2):101–128. 10.1080/02772248709357225.
Szabo S, Jaeger RJ, Moslen MT, . 1977. Modification of 1,1-dichloroethylene hepatotoxicity by hypothyroidism. Toxicol Appl Pharmacol 42(2):367–376. 10.1016/0041-008x(77)90014-x.595015
Tabak HH, Quave SA, Mashni CI, . 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53(10):1503–1518.
Teare JP, Greenfield SM, Marway JS, . 1993. Effect of thyroidectomy and adrenalectomy on changes in liver glutathione and malonaldehyde levels after acute ethanol injection. Free Radic Biol Med 14(6):655–660. 10.1016/0891-5849(93)90147-m.8325537
Torkelson TR, Rowe VK. 1981. Halogenated aliphatic hydrocarbons containing chlorine bromine and iodine. In: Clayton GD, Clayton FE, eds. Patty’s industrial hygiene and toxicology. Vol. 2B. 3rd ed. New York: John Wiley & Sons, 3433–3487.
TRI18. 2020. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Toxics Release Inventory. U.S. Environmental Protection Agency. http://www.epa.gov/triexplorer/. May 13, 2020.
Tuazon EC, Atkinson R, Aschmann SM, . 1988. Atmospheric reactions of chloroethenes with the OH radical. Int J Chem Kinet 20(3):241–265. 10.1002/kin.550200305.
USGS. 2006. Investigation of contaminated ground-water contamination at solid waste management unit 12, naval weapons station Charleston, North Charleston, South Carolina. Reston, VA: U.S. Geological Survey. https://pubs.usgs.gov/sir/2009/5166/pdf/sir20095166.pdf. April 20, 2017.
Van Duuren BL, Goldschmidt BM, Loewengart G, . 1979. Carcinogenicity of halogenated olefinic and aliphatic hydrocarbons in mice. J Natl Cancer Inst 63(6):1433–1439.292813
Van’t Hof J, Schairer LA. 1982. Tradescantia assay system for gaseous mutagens. A report of the U.S. Environmental Protection Agency gene-tox program. Mutat Res 99(3):303–315.7177156
Veith GD, De Foe D, Knuth M. 1984. Structure-activity relationships for screening organic chemicals for potential ecotoxicity effects. Drug Metab Rev 15(7):1295–1303. 10.3109/03602538409029961.6534729
Verschueren K. 1983. 1,1-Dichloroethylene. In: Handbook of environmental data of organic chemicals. 2nd ed. New York, NY: Van Nostrand Reinhold Co., 487–488.
Viola PL, Caputo A. 1977. Carcinogenicity studies on vinylidene chloride. Environ Health Perspect 21:45–47. 10.1289/ehp.772145.612458
Vogel TM, McCarty PL. 1985. Biotransformation of tetrachloroethylene to trichloroethylene, dichloroethylene, vinyl chloride, and carbon dioxide under methanogenic conditions. Appl Environ Microbiol 49(5):1080–1083.3923927
Wallace LA. 1991. Comparison of risks from outdoor and indoor exposure to toxic chemicals. Environ Health Perspect 95:7–13. 10.1289/ehp.91957.1821381
Wallace LA, Pellizzari E, Hartwell T, . 1984. Personal exposure to volatile organic compounds. I. Direct measurements in breathing-zone air, drinking water, food, and exhaled breath. Environ Res 35(1):293–319. 10.1016/0013-9351(84)90137-3.6489295
Wang T, Lenahan R, Kanik M. 1985a. Impact of trichloroethylene contaminated groundwater discharged to the main canal and Indian River lagoon, Vero Beach, Florida. Bull Environ Contam Toxicol 34(4):578–586. 10.1007/BF01609779.3986398
Wang TC, Lenahan R, Kanik M, . 1985b. The removal of trichloroethylene contaminated groundwater at Vero Beach, Florida. Arch Environ Contam Toxicol 14(6):719–723. 10.1007/bf01055779.
Warbrick EV, Dearman RJ, Ashby J, . 2001. Preliminary assessment of the skin sensitizing activity of selected rodent carcinogens using the local lymph node assay. Toxicology 163(1):63–69. 10.1016/s0300-483x(01)00380-8.11376865
Waskell L. 1978. A study of the mutagenicity of anesthetics and their metabolites. Mutat Res 57(2):141–153. 10.1016/0027-5107(78)90261-0.351387
Waxweiler RJ. 1981. Epidemiologic problems associated with exposure to several agents. Environ Health Perspect 42:51–56. 10.1289/ehp.814251.7199433
Weiss G. 1986. Vinyl chloride. In: Hazardous chemicals data book. 2nd ed. Park Ridge, NJ: Noyes Data Corporation, 1014.
Westrick JJ, Mello JW, Thomas RF. 1984. The groundwater supply survey. J Am Water Works Assoc 76(5):52–59. 10.1002/j.1551-8833.1984.tb05334.x.
WHO. 2003. 1,1-Dichloroethene (vinylidene chloride). Concise international chemical assessment document. World Health Organization. Document 51. http://www.who.int/ipcs/publications/cicad/en/cicad51.pdf. April 20, 2017.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
WHO. 2018. Vinylidene chloride. International chemical safety card. World Health Organization. http://inchem.org/documents/icsc/icsc/eics0083.htm. June 22, 2018.
Wilson BH, Smith GB, Rees JF. 1986. Biotransformations of selected alkylbenzenes and halogenated aliphatic hydrocarbons in methanogenic aquifer material: a microcosm study. Environ Sci Technol 20(10):997–1002. 10.1021/es00152a005.22257397
WQP. 2017. 1,1-Dichloroethene. Water quality portal. National Water Quality Monitoring Council. https://www.waterqualitydata.us/portal/. May 15, 2017.
WQP. 2020. 1,1-Dichloroethylene. Water quality portal. Nation Water Quality Monitoring Council. https://www.waterqualitydata.us/portal/#characteristicName=1%2C1-Dichloroethylene&mimeType=csv. May 14, 2020.
Wright PB, Moore L. 1991. Potentiation of the toxicity of model hepatotoxicants by acetaminophen. Toxicol Appl Pharmacol 109(2):327–335. 10.1016/0041-008x(91)90179-i.2068730
Yamazaki H, Oda Y, Funae Y, . 1992. Participation of rat liver cytochrome P450 2E1 in the activation of N-nitrosodimethylamine and N-nitrosodiethylamine to products genotoxic in an acetyltransferase-overexpressing Salmonella typhimurium strain (NM2009). Carcinogenesis 13(6):979–985. 10.1093/carcin/13.6.979.1600620
Yasuhara A, Morita M. 1988. Formation of chlorinated aromatic hydrocarbons by thermal decomposition of vinyldene chloride polymer. Environ Sci Technol 22(6):646–650. 10.1021/es00171a005.
Zeller H, Klimisch HJ, Freisberg KO. 1979a. [Report on the determination of acute toxicity (LC50) of vinylidene chloride in Sprague-Dawley rats (fed) during a 4-hour exposure]. Ludwigshafen, Germany: BASF Corporation. HSE Translation No. 9K. (German)
Zeller H, Klimisch HJ, Freisberg KO. 1979b. [Report on the determination of acute toxicity (LC50) by inhalation of vinylidene chloride in vapour form in Sprague Dawley rats (fasting) during a 4 hour exposure]. Ludwigshafen, Germany: BASF Corporation. HSE Translation No. 9L. (German)
Zeller H, Klimisch HJ, Fresbierg KO. 1979c. [Report on the determination of acute toxicity (LC50) by inhalation of vinylidene chloride in NMRI mice (fasting) during a 4-hour exposure]. Ludwigshafen, Germany: BASF Corporation. HSE Translation No. 9P. (German)
Zhang J, Joslyn AP, Chiu PC. 2006. 1,1-Dichloroethene as a predominant intermediate of microbial trichloroethene reduction. Environ Sci Technol 40(6):1830–1836. 10.1021/es051829m.16570604