# VERSION HISTORY

Date | Description
April 2022 | Final toxicological profile released
December 2019 | Draft for public comment toxicological profile released
July 2009 | Addendum to the toxicological profile released
May 1994 | Final toxicological profile released
December 1990 | Final toxicological profile released