# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding 1,1-dichloroethene in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for 1,1-dichloroethene.

Table 7-1 Regulations and Guidelines Applicable to 1,1-Dichloroethene

Agency | Description | Information | Reference
Air
EPA | RfC | 2×10^−1^ mg/m^3^ (0.05 ppm) | IRIS 2005
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018a
EPA | 1-Day health advisory (10-kg child) | 2 mg/L
EPA | 10-Day health advisory (10-kg child) | 1 mg/L
EPA | DWEL | 2 mg/L
EPA | Lifetime health advisory | 0.4 mg/L
EPA | 10^−4^ Cancer risk | 0.006 mg/L
EPA | National primary drinking water regulations | | EPA 2009b
EPA | MCL and public health goal | 0.007 mg/L
EPA | RfD | 5×10^−2^ mg/kg/day | IRIS 2005
WHO | Drinking water quality guidelines | Not established | WHO 2017
FDA | Substances Added to Food | Not listed^a^ | FDA 2020c
| List of Indirect Additives Used in Food Contact Substances | Approved under indirect additives regulations | FDA 2019
| Allowable level in bottled water | 0.007 mg/L | FDA 2017
Cancer
HHS | Carcinogenicity classification | No data | NTP 2016
EPA | Carcinogenicity classification | Group C^b,c^ | IRIS 2005
IARC | Carcinogenicity classification | Group 2B^d^ | IARC 2019
Occupational
ACGIH | TLV (TWA)—air | 5 ppm (20 mg/m^3^) | ACGIH 2001
OSHA | PEL (8-hour TWA) for general industry, shipyards, and construction—air | No data | OSHA 2019a, 2019b, 2019c
NIOSH | REL (up to 10-hour TWA) | Ca^e^ | NIOSH 2019
NIOSH | IDLH | Ca^e^
Emergency Criteria
EPA | AEGLs-air | Not listed | EPA 2018b
DOE | PACs-air | | DOE 2018a
DOE | PAC-1^f^ | 45 ppm
DOE | PAC-2^f^ | 500 ppm
DOE | PAC-3^f^ | 1,000 ppm

a The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited in food, delisted color additives, and some substances “no longer FEMA GRAS”.

b Group C: possible human carcinogen.

c Suggestive evidence of carcinogenicity via the inhalation route, but not sufficient evidence to assess human carcinogenic potential following inhalation exposure. Data are inadequate for an assessment of human carcinogenic potential via the oral route.

d Group 2B: possibly carcinogenic to humans.

e Potential occupational carcinogen.

f Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018b).

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association of the United States; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health concentration; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; MCL = maximum contaminant level; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = Protective Action Criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; TWA = time-weighted average; WHO = World Health Organization