# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Table 4-1 lists common synonyms and other identification information for 1,1-dichloroethene.

Table 4-1 Chemical Identity of 1,1-Dichloroethene

Characteristic | Information | Reference
Chemical name | 1,1-Dichloroethene | NLM 2018
Synonym(s) and registered trade name(s) | 1,1-DCE; 1,1-dichloroethylene; asym-dichloroethylene; VDC; vinylidene chloride; vinylidene chloride (II); vinylidene dichloride; vinylidene chloride | NLM 2018; EPA 2017a; NIOSH 2016
Chemical formula | C_2_H_2_Cl_2_ | EPA 2017a
Chemical structure | 1,1-Dichloroethene chemical structure | NLM 2018
CAS Registry Number | 75-35-4 | EPA 2017a

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

1,1-Dichloroethene is a colorless, volatile liquid at room temperature, has a mild, sweet odor, is flammable, and burns quickly. This chemical readily polymerizes, and commercial products therefore typically contain an inhibitor (Larranaga et al. 2016). 1,1-Dichloroethene does not occur naturally in the environment; it is produced commercially from ethylene chloride. The major use for 1,1-dichloroethene is in the synthesis of various industrial and consumer plastics, such as packaging materials and flexible films (O’Neil et al. 2013). It also has reported use as a filler, binding agent, and adhesive in paints and synthetic fibers (Larranaga et al. 2016). Effective as of August 15, 2000, 1,1-dichloroethene is categorized as a volatile organic compound (VOC) (EPA ID: E761502) and hazardous air pollutant (HAP) (EPA ID: E761346) (EPA 2017b).

Physical and chemical properties of 1,1-dichloroethene are listed in Table 4-2.

Table 4-2 Physical and Chemical Properties of 1,1-Dichloroethene

Property | Information | Reference
Molecular weight | 96.94 | EPA 2017a
Color | Colorless | Larranaga et al. 2016
Physical state | Liquid | Haynes 2014
Melting point | −122.5°C | Haynes 2014
Boiling point | 31.7°C at 760 mmHg | O’Neil et al. 2013
Density at 20°C | 1.213 g/cm^3^ | Haynes 2014
Odor | Mild sweet odor resembling that of chloroform | O’Neil et al. 2013
Odor threshold:
Air | 2,000–5,000 mg/m^3^ | EPA 1987
Solubility:
Water at 25°C | 2,420 mg/L | Horvath et al. 1999
Organic solvents | Soluble in organic solvents | O’Neil et al. 2013
Partition coefficients:
Log K_ow_ | 2.13;; 1.32 | Hansch et al. 1995; WHO 2003
Log K_oc_ | 1.81 | Chu and Chan 2000; Sabljic et al; 1995
Vapor pressure at 25°C | 600 mm Hg | Boublik et al. 1984
Henry’s law constant at 20–25°C | 2.61×10^−2^ atm-m^3^/mol | Gossett 1987
Autoignition temperature | 457°C | Larranaga et al. 2016
Flashpoint | −10°C (open-cup); −19°C (closed-cup) | EPA 1985; Larranaga et al. 2016
Conversion factors | 1 ppm=3.97 mg/m^3^; 1 mg/m^3^=0.25 ppm | Verschueren 1983; Verschueren 1983
Explosive limits | 5.6–11.4% v/v in air | Larranaga et al. 2016