# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,1-Dichloroethene
CAS Numbers: | 75-35-4
Date: | April 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: Available data were not considered adequate for derivation of an acute-duration inhalation MRL for 1,1-dichloroethene.

Rationale for Not Deriving an MRL: No exposure-response human data are available. The lowest LOAEL for acute-duration inhalation exposure of laboratory animals is a serious LOAEL of 15 ppm for a study in which death and maternal body weight loss occurred in rats exposed to 1,1-dichloroethene vapor for 22–23 hours/day during GDs 6–16 (EPA 1977a).

Agency Contacts (Chemical Managers): Malcolm Williams

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,1-Dichloroethene
CAS Numbers: | 75-35-4
Date: | March 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL | 0.001 ppm (1 ppb)
Critical Effect: | Necrosis in nasal olfactory epithelium
Reference: | NTP 2015a
Point of Departure: | BMCL_10_ of 1.59 ppm (BMCL_HEC_ of 0.036 ppm)
Uncertainty Factor: | 30
LSE Graph Key: | 40
Species: | Rat

MRL Summary: An intermediate-duration inhalation MRL of 0.001 ppm (1 ppb) has been derived for 1,1-dichloroethene based on increased incidences of necrosis in nasal olfactory epithelium of male F344/N rats exposed to 1,1-dichloroethene vapor for 6 hours/day, 5 days/week for 14 weeks (NTP 2015a). The MRL is based on a BMCL_10_ of 1.59 ppm, which was adjusted to continuous duration exposure and converted to a human equivalent concentration (BMCL_HEC_) of 0.036 ppm and divided by a total uncertainty factor of 30 (3 for extrapolation from animals to humans with dosimetric adjustment and 10 for human variability).

Selection of the Critical Effect: No exposure-response human data are available. Table A-1 summarizes candidate critical effects from intermediate-duration inhalation studies in laboratory animals. The lowest LOAEL is 6.25 ppm for nasal lesions in male and female rats, depressed body weight gain in female mice, and increased relative kidney weight in female mice exposed to 1,1-dichloroethene vapor for 6 hours/day, 5 days/week for 14 weeks (NTP 2015a). The kidney weight increase at 6.25 ppm in female mice is of questionable toxicological significance because it occurred in the absence of exposure-related increases in histopathologic kidney lesions. Seriously depressed body weight gain was reported at all exposure levels (6.25–100 ppm) among the female mice (27–41% less than that of controls) and at exposure concentrations ≥12.5 ppm among the male mice (24–38% less than that of controls). Mean final body weights of the 6.25, 12.5, 25, 50, and 100 ppm groups of female mice were 12, 9, 12, 18, and 15%, respectively, less than that of controls. Mean final body weights of the 12.5, 25, and 50 ppm groups of male mice were 10, 15, and 16%, respectively, less than that of controls. However, in a similarly designed 105-week study, there were no effects on body weight in the male or female mice during the first 13 weeks of exposures at 6.25, 12.5, or 25 ppm (NTP 2015a). Body weight effects in the female mice of the 14-week study were not considered as a critical effect for MRL derivation because the female mouse body weight data from the 2-year study (for weeks 1–13, 14–52, and 53–103) did not corroborate the result from the 14-week study.

The nasal lesions in the male and female rats were selected to represent the critical effects of intermediate-duration inhalation exposure to 1,1-dichloroethene because they represent the lowest reliable LOAEL (6.25 ppm).

Table A-1 Summary of Candidate Critical Effects for Deriving an Intermediate-Duration Inhalation MRL for 1,1-Dichloroethene

Species | Duration | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference
Body weight effects
B6C3F1/N mouse | 14 weeks; (5 days/week 6 hours/day) | ND F | 6.25 F | Depressed body weight gain | NTP 2015a
Respiratory effects
F344/N rat | 14 weeks; (5 days/week 6 hours/day) | ND | 6.25 | Lesions in olfactory epithelium | NTP 2015a
B6C3F1/N mouse | 14 weeks; (5 days/week 6 hours/day) | 6.25 | 12.5 | Increased lung weight | NTP 2015a
Hepatic effects
F344/N rat | 14 weeks; (5 days/week 6 hours/day) | 6.25 M | 12.5 M | Hepatic centrilobular cytoplasmic alterations | NTP 2015a
Renal effects
B6C3F1/N mouse | 14 weeks; (5 days/week 6 hours/day) | 6.25 M; ND F | 12.5 M; 6.25 F | M: nephropathy; F: increased kidney weight | NTP 2015a

F = female(s); LOAEL = lowest observed adverse effect level; M = male(s); ND = not determined; NOAEL = no-observed-adverse-effect level

Selection of the Principal Study: The 14-week inhalation study in rats (NTP 2015a) identified the lowest less serious LOAEL (6.25 ppm) for 1,1-dichloroethene exposure-related effects considered to be toxicologically significant. Therefore, the 14-week inhalation study of rats (NTP 2015a) was selected as the principal study for deriving an intermediate-duration inhalation MRL.

Summary of the Principal Study:

NTP. 2015a. NTP technical report on the toxicology and carcinogenesis studies of vinylidene chloride (CAS No. 75-35-4) in F344/N rats and B6C3F1/N mice (inhalation studies). NTP TR 582. National Toxicology Program. Research Triangle Park, NC: U.S. Department of Health and Human Services.

Groups of F344/N rats (10/sex/group; 5–7 weeks of age) were exposed (whole body) to 1,1-dichloroethene vapor for 6 hours/day (+10 minutes), 5 days/week for 14 weeks at 0, 6.25, 12.5, 25, 50, or 100 ppm. Evaluations included survival, clinical signs, body weight, hematology, clinical chemistry, selected organ weights, and gross and histopathology. The following targets of toxicity were identified:

- Respiratory: There were no exposure-related effects on lung weight. Significantly increased incidences of selected nasal lesions were observed in both males and females. Incidence data are presented in Table A-2. Olfactory epithelium atrophy, mineralization, and necrosis occurred in males and females at all exposure levels; none of these lesions occurred in control males or females.
- Hepatic: Hepatic centrilobular cytoplasmic alterations were observed in males at 12.5 ppm (6/10 rats) and all males at higher exposure levels. Exposure-related liver lesions in female rats were limited to hepatocellular cytoplasmic vacuolization in all females exposed at 50 and 100 ppm.
- Renal: Slightly increased relative kidney weights were noted in males at 6.25, 12.5, and 100 ppm (3–7% greater than controls), but not at 25 or 50 ppm. Females exhibited exposure concentration-related significantly increased relative kidney weights at exposure levels ≥12.5-ppm (6–16% greater than controls). There was no evidence of exposure-related increased incidences of renal lesions in males or females (NOAEL of 100 ppm).
- Reproductive: At the highest exposure level (100 ppm), males exhibited 5% decreased sperm motility and 15–16% decreased spermatid count.

Table A-2 Selected Nasal Lesion Incidences in Male and Female F344/N Rats Exposed to 1,1-Dichloroethene for 6 Hours/Day, 5 Days/Week for 14 Weeks

Lesion type | 1,1-Dichloroethene exposure level (ppm)
Lesion type | 0 | 6.25 | 12.5 | 25 | 50 | 100
Males
Olfactory epithelium
Atrophy | 0/10^a^ | 4/10^b^ (1.0) | 10/10^c^ (1.0) | 10/10^c^ (1.7) | 10/10^c^ (2.2) | 10/10^c^ (2.7)
Mineralization^d^ | 0/10 | 10/10^c^ (1.3) | 10/10^c^ (2.0) | 10/10^c^ (2.9) | 10/10^c^ (3.0) | 10/10^c^ (2.6)
Necrosis | 0/10 | 2/10 (1.0) | 6/10^c^ (1.0) | 9/10^c^ (1.0) | 7/10^c^ (1.7) | 10/10^c^ (1.6)
Turbinate
Atrophy | 0/10 | 0/10 | 10/10^c^ (1.0) | 10/10^c^ (2.0) | 10/10^c^ (2.3) | 10/10^c^ (3.0)
Females
Olfactory epithelium
Atrophy | 0/10 | 2/10 (1.0) | 10/10^c^ (1.0) | 10/10^c^ (1.3) | 10/10^c^ (1.7) | 10/10^c^ (2.4)
Mineralization^d^ | 0/10 | 5/10^b^ (1.0) | 9/10^c^ (1.3) | 10/10^c^ (1.9) | 10/10^c^ (2.1) | 10/10^c^ (2.3)
Necrosis | 0/10 | 1/10 (1.0) | 3/10 (1.3) | 6/10^c^ (1.5) | 10/10^c^ (2.2) | 10/10^c^ (3.0)
Turbinate
Atrophy | 0/10 | 0/10 | 10/10^c^ (1.0) | 10/10^c^ (2.0) | 10/10^c^ (2.2) | 10/10^c^ (3.0)
Males and females (combined incidences)
Olfactory epithelium
Atrophy | 0/20 | 6/20^e^ | 20/20^f^ | 20/20^f^ | 20/20^f^ | 20/20^f^
Mineralization^d^ | 0/20 | 15/20^f^ | 19/20^f^ | 20/20^f^ | 20/20^f^ | 20/20^f^
Necrosis | 0/20 | 3/20 | 9/20^f^ | 15/20^f^ | 17/20^f^ | 20/20^f^
Turbinate
Atrophy | 0/20 | 0/20 | 20/20^f^ | 20/20^f^ | 20/20^f^ | 20/20^f^

a Incidence (severity;1 = minimal, 2 = mild, 3 = moderate, 4 = marked).

b Significantly different from chamber control incidence by the Poly-3 test (p<0.05).

c Significantly different from chamber control incidence by the Poly-3 test (p<0.01).

d Mineralization was described as “deposits of greyish-blue material in the basement membrane, often underlying an atrophic epithelium or disrupting the epithelium, and most often affecting the lateral walls and turbinates.” The deposits were not actually within the olfactory epithelium and of unknown toxicological significance.

e Significantly different from chamber control incidence by Fisher’s exact test (p<0.05) performed by SRC, Inc.

f Significantly different from chamber control incidence by Fisher’s exact test (p<0.01) performed by SRC, Inc.

Source: NTP 2015a

Selection of the Point of Departure for the MRL: A BMCL_10_ of 1.59 ppm for olfactory epithelium necrosis in male rats estimated from the frequentist-restricted 3-degree Multistage model was selected as the point of departure (POD) for the intermediate-duration inhalation MRL for 1,1-dichloroethene.

The lowest LOAEL identified in the NTP (2015a) 14-week rat study was 6.25 ppm for increased incidence of nasal lesions in males and females. Within olfactory epithelium, atrophy and necrosis were observed at the lowest exposure level tested (6.25 ppm). Deposits of greyish-blue material in the basement membrane, often underlying an atrophic epithelium or disrupting the epithelium, and most often affecting the lateral walls and turbinates, were reported as mineralization in olfactory epithelium. Although these deposits occurred at 100% incidence in all groups of 1,1-dichloroethene-exposed male rats and at 50% in the 6.25 ppm females and 100% in all other exposed groups of females, their occurrence within the region of the basement membrane (rather than the olfactory epithelium) is of questionable toxicological significance. Therefore, mineralization was not considered as a candidate critical effect for deriving an intermediate-duration inhalation MRL for 1,1-dichloroethene. However, atrophy and necrosis are considered reliable exposure-related adverse effects and were considered candidate critical effects. Atrophy in the turbinates was not considered as a candidate critical effect because this lesion was not observed at the lowest exposure level (6.25 ppm).

The incidence data for atrophy and for necrosis in the olfactory epithelium of the male and the female rats were fit to all standard dichotomous models in the EPA Benchmark Dose Software (BMDS, version 3.1.2) using a benchmark response (BMR) of 10% change in incidence from controls. Based on relatively similar male and female exposure concentration-response data for atrophy and for necrosis in olfactory epithelium, incidence data for both sexes were also combined to increase the statistical power of the benchmark result. Analysis of the data for necrosis in males and females using EPA’s Categorical Regression Analysis (Cater 3.1) software confirmed the acceptability of combining male and female incidence data. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), scaled residuals (within ±2 units) at the data points (except the control) closest to the predefined BMR, BMCL values that are not 10 times lower than the lowest non-zero dose, and visual inspection of the proximity of the predicted dose-response curve to the observed data points closest to the BMR. For each dataset, among all models providing adequate fit to the data, the lowest BMCL was selected as the POD when the difference between the BMCLs estimated from these models was >3-fold; otherwise, the BMCL from the model with the lowest Akaike Information Criterion (AIC) was chosen.

Model predictions for nasal olfactory epithelium atrophy in the male rats are presented in Table A-3. Most models provided adequate fit to the data; the multistage 1-degree and Weibull models did not provide adequate fit because the BMDL was 10 times lower than the lowest non-zero concentration and because the lower limited includes zero, respectively. The BMCL_10_ values varied by >3-fold; therefore, the lowest BMCL_10_ (0.73 ppm) considered as a potential POD.

Table A-3 Model Predictions for Incidence of Nasal Olfactory Epithelium Atrophy in Male F344/N Rats Exposed to 1,1-Dichloroethene 6 Hours/Day, 5 Days/Week for 14 Weeks (NTP 2015a)

Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Dose near BMC | Control group
Dichotomous Hill | 4.74 | 2.85 | 0.997 | 17.76 | −6.96×10^−2^ | −3.90×10^−4^
Gamma^d^ | 3.85 | 1.69 | 0.981 | 18.21 | −2.69×10^−1^ | −3.90×10^−4^
Log-Logistic^e^ | 4.74 | 2.85 | 1.000 | 15.76 | −6.96×10^−2^ | −3.90×10^−4^
Multistage Degree 5 ^f^ ^,^ ^g^ | 3.81 | 0.73 | 1.000 | 15.53 | −7.19×10^−2^ | −3.90×10^−4^
Multistage Degree 4^f^ | 3.79 | 0.74 | 1.000 | 15.55 | −8.79×10^−2^ | −3.90×10^−4^
Multistage Degree 3^f^ | 3.55 | 0.83 | 1.000 | 15.72 | −2.30×10^−1^ | −3.90×10^−4^
Multistage Degree 2^f^ | 2.37 | 0.74 | 0.952 | 17.13 | −3.90×10^−4^ | −3.90×10^−4^
Multistage Degree 1^f^ | | | 0.529 | 20.95 | −3.90×10^−4^ | −3.90×10^−4^
Weibull^c^ | | | 0.833 | 19.74 | −4.16×10^−4^ | −4.16×10^−4^
Logistic | 4.46 | 2.26 | 1.000 | 15.54 | −1.02×10^−2^ | −1.14×10^−1^
Log-Probit | 5.35 | 2.85 | 1.000 | 15.46 | −1.13×10^−4^ | −3.90×10^−4^
Probit | 2.16 | 1.37 | 0.673 | 21.26 | −1.09 | −1.09

a BMC and BMCL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals for dose group near the BMC and for the control dose group.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Recommended model. Most models provided adequate fit to the data. BMCLs for models providing adequate fit were not sufficiently close (differed by >3-fold). Therefore, the model with lowest BMCL was selected (Multistage 5 degree model).

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _10_ = exposure concentration associated with 10% extra risk)

Model predictions for nasal olfactory epithelium atrophy in the female rats are presented in Table A-4. The 1-degree Multistage model (the BMCL is 10 times lower than the lowest non-zero dose) and the Weibull model (lower limit includes zero) provided inadequate fit to the data. Visual inspection of the 2-degree Multistage model revealed relatively poor correlation between predicted incidence and observed incidence in the region corresponding to the two experimental data points closest to the control value; therefore, the model fit was considered inadequate. All other models provided adequate fit to the data as judged by goodness-of-fit p-value and scaled residual criteria. The BMCL_10_ of 3.48 ppm from the model with the lowest AIC (Logistic model) was selected as a potential POD based on nasal olfactory epithelium atrophy in the female rats because the BMCL_10_ values estimated from models with adequate varied by <3-fold.

Table A-4 Model Predictions for Incidence of Nasal Olfactory Epithelium Atrophy in Female F344/N Rats Exposed to 1,1-Dichloroethene 6 Hours/Day, 5 Days/Week for 14 Weeks (NTP 2015a)

Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Dose near BMC | Control group
Dichotomous Hill | 5.46 | 4.15 | 0.997 | 12.60 | −1.60×10^−1^ | −3.90×10^−4^
Gamma^d^ | 4.72 | 3.19 | 0.892 | 15.88 | −5.66×10^−1^ | −3.92×10^−4^
Log-Logistic^e^ | 5.46 | 4.15 | 0.989 | 14.60 | −1.60×10^−1^ | −3.90×10^−4^
Multistage Degree 5^f^ | 4.72 | 1.49 | 0.996 | 12.62 | −3.56×10^−1^ | −3.90×10^−4^
Multistage Degree 4^f^ | 4.63 | 1.49 | 0.994 | 12.74 | −4.17×10^−1^ | −3.90×10^−4^
Multistage Degree 3^f^ | 4.05 | 1.68 | 0.950 | 13.66 | −8.21×10^−1^ | −3.90×10^−4^
Multistage Degree 2^f,g^ | 2.76 | 1.26 | 0.661 | 16.59 | −3.90×10^−4^ | −3.90×10^−4^
Multistage Degree 1^f^ | | | 0.152 | 22.55 | −3.90×10^−4^ | −3.90×10^−4^
Weibull^c^ | | | 0.493 | 19.06 | −4.96×10^−4^ | −4.96×10^−4^
Logistic ^h^ | 5.40 | 3.48 | 1.000 | 12.17 | −5.34×10^−2^ | −7.10×10^−2^
Log-Probit | 5.86 | 4.35 | 1.000 | 14.01 | −7.59×10^−4^ | −3.90×10^−4^
Probit | 2.80 | 1.74 | 0.454 | 19.69 | −8.49×10^−1^ | −8.49×10^−1^

a BMC and BMCL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals for dose group near the BMC and for the control dose group.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Visual inspection of the 2-degree Multistage model fit revealed relatively poor correlation between predicted incidence and observed incidence in the region corresponding to the two experimental data points close to the control value and the model fit was considered inadequate.

h Recommended model. Most models provided adequate fit to the data. BMCLs for models providing adequate fit were not sufficiently close (differed by >3-fold). Among the models providing adequate fit, the model with the lowest AIC was selected (Logistic).

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _10_ = exposure concentration associated with 10% extra risk)

Model predictions for combined incidences of nasal olfactory epithelium atrophy in the male and female rats are presented in Table A-5. The 1-degree Multistage model provided inadequate fit to the dataset (goodness-of-fit p-value <0.1). All other models provided adequate fit to the data. The Log-Probit model BMCL_10_ of 4.29 ppm (model with the lowest AIC) was selected as a potential POD based on combined incidences of nasal olfactory epithelium atrophy in the male and female rats.

Table A-5 Model Predictions for Incidence of Nasal Olfactory Epithelium Atrophy in Male and Female F344/N Rats Exposed to 1,1-Dichloroethene 6 Hours/Day, 5 Days/Week for 14 Weeks (NTP 2015a)

Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Dose near BMC | Control group
Dichotomous Hill | 5.07 | 4.15 | 0.981 | 29.25 | −1.42×10^−1^ | −5.52×10^−4^
Gamma^d^ | 4.27 | 3.24 | 0.852 | 30.80 | −5.53×10^−1^ | −5.54×10^−4^
Log-Logistic^e^ | 5.07 | 4.15 | 0.981 | 29.25 | −1.42×10^−1^ | −5.52×10^−4^
Multistage Degree 5^f^ | 4.23 | 1.45 | 0.998 | 26.90 | −2.51×10^−1^ | −5.52×10^−4^
Multistage Degree 4^f^ | 4.18 | 1.50 | 0.997 | 27.00 | −3.00×10^−1^ | −5.52×10^−4^
Multistage Degree 3^f^ | 3.81 | 1.89 | 0.967 | 27.87 | −6.75×10^−1^ | −5.52×10^−4^
Multistage Degree 2 | 2.56 | 1.49 | 0.408 | 34.12 | −5.52×10^−4^ | −5.52×10^−4^
Multistage Degree 1^f^ | | | 0.019 | 43.82 | −5.71×10^−4^ | −5.71×10^−4^
Weibull^c^ | 2.40 | 2.40 | 0.339 | 35.29 | −5.53×10^−4^ | −5.53×10^−4^
Logistic | 4.89 | 3.46 | 1.000 | 26.65 | −3.47×10^−2^ | −1.30×10^−1^
Log-Probit ^g^ | 5.58 | 4.29 | 1.000 | 26.44 | −3.03×10^−4^ | −5.52×10^−4^
Probit | 2.46 | 1.76 | 0.190 | 39.36 | −1.37 | −1.37

a BMC and BMCL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals for dose group near the BMC and for the control dose group.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Recommended model. Most models provided adequate fit to the data. BMCLs for models providing adequate fit were sufficiently close (differed by <3-fold) and the model with the lowest AIC was selected. Therefore, the Log-Probit is the recommended model.

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _10_ = exposure concentration associated with 10% extra risk)

Model predictions for nasal olfactory epithelium necrosis in the male rats are presented in Table A-6. The Gamma, 5-degree Multistage, 1-degree Multistage, Weibull, Logistic, and Probit models provided inadequate fit to the dataset (goodness-of-fit p-value <0.1); the Log-Probit model also did not provide adequate fit (BMCL was 10 times lower than the lowest non-zero dose). Among the models providing adequate fit to the data, the BMCL_10_ of 1.59 ppm from the model with the lowest AIC (2-degree Multistage) was selected as a potential POD because the BMCL_10_ values varied by <3-fold.

Table A-6 Model Predictions for Incidence of Nasal Olfactory Epithelium Necrosis in Male F344/N Rats Exposed to 1,1-Dichloroethene 6 Hours/Day, 5 Days/Week for 14 Weeks (NTP 2015a)

Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Dose near BMC | Control group
Dichotomous Hill | 4.82 | 0.79 | 0.112 | 55.22 | 3.96×10^−2^ | −3.92×10^−4^
Gamma^d^ | | | 0.085 | 53.29 | −3.98×10^−4^ | −3.98×10^−4^
Log-Logistic^e^ | 2.53 | 0.72 | 0.207 | 51.85 | −3.90×10^−4^ | −3.90×10^−4^
Multistage Degree 5^f^ | | | 0.086 | 53.29 | −3.90×10^−4^ | −3.90×10^−4^
Multistage Degree 4^f^ | 2.23 | 1.59 | 0.147 | 51.29 | −3.90×10^−4^ | −3.90×10^−4^
Multistage Degree 3 ^f^ | 2.23 | 1.59 | 0.147 | 51.29 | −3.90×10^−4^ | −3.90×10^−4^
Multistage Degree 2 ^f^ ^,^ ^g^ | 2.23 | 1.59 | 0.147 | 51.29 | −3.90×10^−4^ | −3.90×10^−4^
Multistage Degree 1^f^ | | | 0.085 | 53.29 | −3.91×10^−4^ | −3.91×10^−4^
Weibull^c^ | | | 0.085 | 53.29 | −4.24×10^−3^ | −4.24×10^−3^
Logistic | | | 0.013 | 60.60 | −6.67×10^−1^ | −1.66
Log-Probit | | | 0.119 | 53.91 | −3.90×10^−4^ | −3.90×10^−4^
Probit | | | 0.015 | 60.84 | −6.67×10^−1^ | −1.67

a BMC and BMCL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals for dose group near the BMC and for the control dose group.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Recommended model. Five models provided adequate fit to the data. BMCLs for models providing adequate fit were sufficiently close (differed by <3-fold) and the model with the lowest AIC was selected. Therefore, the 2-degree Multistage is the recommended model.

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _10_ = exposure concentration associated with 10% extra risk)

Model predictions for nasal olfactory epithelium necrosis in the female rats are presented in Table A-7. All models provided adequate fit to the data as judged by goodness-of-fit p-value and scaled residual criteria. However, visual inspection of the 1-degree Multistage fit revealed relatively poor correlation between predicted incidence and observed incidence in the region corresponding to the two experimental data points closest to the control value; therefore, the model fit was considered inadequate. All other models provided adequate fit. The Probit model BMCL_10_ of 5.41 ppm (corresponding to the lowest AIC among models providing adequate fit) was selected as a potential POD based on nasal olfactory epithelium necrosis in the female rats because the BMCL_10_ values varied by <3-fold.

Table A-7 Model Predictions for Incidence of Nasal Olfactory Epithelium Necrosis in Female F344/N Rats Exposed to 1,1-Dichloroethene 6 Hours/Day, 5 Days/Week for 14 Weeks (NTP 2015a)

Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Dose near BMC | Control group
Dichotomous Hill | 7.57 | 4.05 | 0.800 | 38.47 | 4.79×10^−1^ | −3.90×10^−4^
Gamma^d^ | 7.03 | 2.97 | 0.852 | 39.29 | 2.54×10^−1^ | −3.92×10^−4^
Log-Logistic^e^ | 7.57 | 4.05 | 0.800 | 38.47 | 4.79×10^−1^ | −3.90×10^−4^
Multistage Degree 5^f^ | 5.27 | 2.31 | 0.731 | 42.30 | −2.01×10^−1^ | −1.13×10^−3^
Multistage Degree 4^f^ | 5.20 | 2.37 | 0.925 | 40.35 | −2.08×10^−1^ | −4.34×10^−4^
Multistage Degree 3^f^ | 5.44 | 2.49 | 0.974 | 38.45 | −1.58×10^−1^ | −4.08×10^−4^
Multistage Degree 2 | 6.45 | 2.66 | 0.936 | 38.76 | 4.91×10^−2^ | −4.03×10^−4^
Multistage Degree 1^f,g^ ^3^ | 2.52 | 1.75 | 0.542 | 40.86 | −3.91×10^−4^ | −3.91×10^−4^
Weibull^c^ | 6.94 | 3.07 | 0.913 | 38.87 | 1.92×10^−1^ | −4.63×10^−4^
Logistic | 8.80 | 5.74 | 0.897 | 37.70 | 7.16×10^−2^ | −6.21×10^−1^
Log-Probit | 7.40 | 4.16 | 0.831 | 38.16 | 4.98×10^−1^ | −3.90×10^−4^
Probit^h^ | 8.23 | 5.41 | 0.940 | 37.26 | 9.27×10^−2^ | −5.39×10^−1^

a BMC and BMCL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals for dose group near the BMC and for the control dose group.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g The 1-degree Multistage model was judged to provide inadequate fit to the data based on visual inspection of the predicted dose-response curve.

h Recommended model. Among models providing adequate fit to the data, BMCL_10_ values varied by <3-fold; therefore, the model with the lowest AIC was selected as the best-fitting model (Probit).

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _10_ = exposure concentration associated with 10% extra risk)

Model predictions for combined incidences of nasal olfactory epithelium necrosis in the male and female rats are presented in Table A-8. The Logistic and Probit models provided inadequate fit to the dataset (goodness-of-fit p-value <0.1). All other models provided adequate fit to the data. The Log-Probit model BMCL_10_ of 2.57 ppm (corresponding to the lowest AIC) was selected as a potential POD based on combined incidences of nasal olfactory epithelium necrosis in the male and female rats because the BMCL_10_ values varied by <3-fold.

Table A-8 Model Predictions for Incidence of Nasal Olfactory Epithelium Necrosis in Male and Female F344/N Rats Exposed to 1,1-Dichloroethene 6 Hours/Day, 5 Days/Week for 14 Weeks (NTP 2015a)

Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Dose near BMC | Control group
Dichotomous Hill | 4.58 | 2.46 | 0.680 | 91.76 | −1.93×10^−1^ | −5.52×10^−4^
Gamma^d^ | 3.20 | 1.87 | 0.552 | 91.98 | −6.21×10^−1^ | −7.70×10^−3^
Log-Logistic^e^ | 4.58 | 2.46 | 0.680 | 91.76 | −1.93×10^−1^ | −5.84×10^−4^
Multistage Degree 5^f^ | 2.45 | 1.87 | 0.731 | 89.98 | −5.52×10^−4^ | −5.52×10^−4^
Multistage Degree 4^f^ | 2.46 | 1.86 | 0.717 | 90.07 | −5.52×10^−4^ | −5.52×10^−4^
Multistage Degree 3^f^ | 2.47 | 1.85 | 0.539 | 92.15 | −7.06×10^−4^ | −7.06×10^−4^
Multistage Degree 2 | 2.55 | 1.85 | 0.700 | 90.19 | −5.52×10^−4^ | −5.52×10^−4^
Multistage Degree 1^f^ | 2.36 | 1.84 | 0.709 | 90.31 | −6.13×10^−4^ | −6.13×10^−4^
Weibull^c^ | 2.94 | 1.86 | 0.543 | 92.06 | −5.52×10^−4^ | −5.52×10^−4^
Logistic | | | 0.039 | 99.21 | −5.87×10^−1^ | −1.67
Log-Probit ^g^ | 4.66 | 2.57 | 0.841 | 89.51 | −2.26×10^−1^ | −5.52×10^−4^
Probit | | | 0.038 | 99.73 | −5.95×10^−1^ | −1.66

a BMC and BMCL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals for dose group near the BMC and for the control dose group.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Recommended model. Among models providing adequate fit to the data, BMCL_10_ values varied by <3-fold; therefore, the model with the lowest AIC was selected as the best-fitting model (Log-Probit).

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _10_ = exposure concentration associated with 10% extra risk)

Best-fitting model predictions for atrophy and for necrosis in nasal olfactory epithelium of the male and female rats are presented in Table A-9. Among the best-fitting models, the lowest predicted BMC_10_ was 2.23 ppm for incidences of olfactory epithelium necrosis in the male rats estimated from the 2-degree Multistage model; the corresponding BMCL_10_ of 1.59 ppm was selected as the POD. The 2-degree model is presented in Figure A-1.

Table A-9 BMC_10_ and BMCL_10_ Values from the Best-Fitting Models for Selected Nonneoplastic Lesions in Nasal Olfactory Epithelium of Male and Female F344/N Rats Exposed to 1,1-Dichloroethene 6 Hours/Day, 5 Days/Week for 14 Weeks

Lesion type | Sex | Model | BMC_10_ (ppm) | BMCL_10_ (ppm)
Atrophy | Male | Multistage 5-degree | 3.81 | 0.73
Atrophy | Female | Logistic | 5.40 | 3.48
Atrophy | Combined | Log-Probit | 5.58 | 4.29
Necrosis | Male | Multistage 2-degree | 2.23 | 1.59 ^a^
Necrosis | Female | Probit | 8.23 | 5.41
Necrosis | Combined | Log-Probit | 4.66 | 2.57

a The BMCL_10_ of 1.59 ppm for necrosis in the male rats was selected as the preferred POD for deriving an intermediate-duration inhalation MRL for 1,1-dichloroethene because it corresponds to the lowest BMC_10_ (2.23 ppm) among the group of best-fitting models for nasal olfactory epithelium lesions.

BMC = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _10_ = exposure concentration associated with 10% extra risk); POD = point of departure

Figure A-1 Fit of 2-Degree Multistage Model for Nasal Olfactory Epithelium Necrosis in Male F344/N Rats Exposed to 1,1-Dichloroethene 6 Hours/Day, 5 Days/Week for 14 Weeks

Figure A-1 description

Intermittent Exposure: The BMCL_10_ of 1.59 ppm was adjusted from intermittent exposure to a continuous exposure scenario according to the following equation:

BMCL_ADJ_ = BMCL_10_ of 1.59 ppm × ( 6 hours / 24 hours ) × ( 5 days / 7 days ) = 0.28 ppm

Human Equivalent Concentration: To calculate a HEC, the BMCL_ADJ_ was multiplied by the regional gas dose ratio (rat:human) for the extrathoracic region of the respiratory tract (RGDR_ET_). The RGDR_ET_ was calculated using the following equation:

R G D R_E T_ = (( (V_E_)/(S A_E T_) ) A)/(( (V_E_)/(S A_E T_) ) H) RGDRET calculation

where:

- ET = extrathoracic region
- V_E_ = minute volume (mL/minute)
- SA = surface area (cm^2^)
- A = animal (rat)
- H = human

EPA (1994) rat and human respiratory surface area (SA) reference values for the extrathoracic region:

- Human: 200 cm^2^
- Rat: 15.0 cm^2^

EPA (1994) reference values for minute volumes (V_e_):

- Human: 13.8 L/minute
- Rat: 0.1319 L/minute

Therefore:

R G D R_E T_ = (( (V_E_)/(S A_E T_) ) A)/(( (V_E_)/(S A_E T_) ) H) = ((131.9 m L / min)/(15 c m^2^))/((13,800 m L / min)/(200 c m^2^)) = 0.13 RGDRET calculation

BMCL_HEC_ = BMCL_ADJ_ × RGDR_ET_ = 0.28 ppm × 0.13 = 0.036 ppm

Uncertainty Factor: The BMCL_HEC_ of 0.036 ppm was divided by a total uncertainty factor of 30:

- 3 for extrapolation from animals to humans using dosimetric adjustment
- 10 for human variability

MRL = BMCL_HEC_ ÷ UF_S_ 0.036 ppm ÷ ( 3 × 10 ) = 0.0012 ppm ≈ 0.001 ppm ( 1 ppb )

Other Additional Studies or Pertinent Information that Lend Support to this MRL: The nasal cavity was among the most sensitive targets of toxicity in male and female F344/N rats and B6C3F1/N mice intermittently exposed to 1,1-dichloroethene vapor for 14 or 105 weeks (NTP 2015a).

Agency Contacts (Chemical Managers): Malcolm Williams

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,1-Dichloroethene
CAS Numbers: | 75-35-4
Date: | March 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic
MRL | 0.001 ppm (1 ppb)
Critical Effect: | Necrosis of nasal olfactory epithelium
Reference: | NTP 2015a
Point of Departure: | BMCL_10_ of 1.59 ppm (BMCL_HEC_ of 0.036 ppm)
Uncertainty Factor: | 30
LSE Graph Key: | 40
Species: | Rat

MRL Summary: The intermediate-duration inhalation MRL of 0.001 ppm (1 ppb) was adopted as the chronic-duration inhalation MRL for 1,1-dichloroethene. The intermediate MRL is based on a BMCL_10_ of 1.59 ppm for increased necrosis of the nasal olfactory epithelium in rats exposed to 1,1-dichloroethene for 14 weeks. The BMCL_10_ was adjusted to continuous duration exposure and converted to a human equivalent concentration (BMCL_HEC_) of 0.036 ppm and divided by a total uncertainty factor of 30 (for extrapolation from animals to humans with dosimetric adjustment and 10 for human variability).

Selection of the Critical Effect: No exposure-response human data are available. Table A-10 summarizes candidate critical effects from chronic-duration inhalation studies in laboratory animals. Nasal lesions (nasal turbinate atrophy, hyperostosis, metaplasia of respiratory olfactory epithelium) in mice were selected as the critical effects of chronic-duration inhalation exposure to 1,1-dichloroethene because they occurred at the lowest LOAEL (6.25 ppm).

Table A-10 Summary of Candidate Critical Effects for Deriving a Chronic-Duration Inhalation MRL for 1,1-Dichloroethene

Species | Duration | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference
Body weight effects
B6C3F1/N mouse | 105 weeks; (5 days/week 6 hours/day) | 6.25 M; 12.5 F | 12.5 M; 25 F | Depressed body weight | NTP 2015a
Respiratory effects
F344/N rat | 105 weeks; (5 days/week 6 hours/day) | ND | 25^a^ | Multiple types of nasal lesions | NTP 2015a
B6C3F1/N mouse | 105 weeks; (5 days/week 6 hours/day) | ND | 6.25 | Multiple types of nasal lesions | NTP 2015a
Hepatic effects
F344/N rat | 105 weeks; (5 days/week 6 hours/day) | ND | 25^a^ | Chronic inflammation, diffuse fatty change | NTP 2015a
Sprague-Dawley rat | 18 months; (5 days/week 6 hours/day) | ND | 25 | Midzonal fatty change at 12 months | Quast et al. 1986
Renal effects
B6C3F1/N mouse | 105 weeks; (5 days/week 6 hours/day) | ND; 25 F | 6.25 M | Renal tubule hyperplasia at 6.25 ppm; renal cysts at 25 ppm | NTP 2015a
Swiss mouse | 52 weeks; (5 days/week 4 hours/day) | ND | 25 | Unspecified regressive lesions | Maltoni et al. 1985
Swiss mouse | 52 weeks; (4–5 days/week 4 hours/day) | ND | 25 | Abscesses and nephritis | Maltoni et al. 1985

a Lowest exposure concentration tested in the rats of the NTP (2015a) 2-year study.

F = female(s); LOAEL = lowest observed adverse effect level; M = male(s); ND = not determined; NOAEL = no-observed-adverse-effect level

Selection of the Principal Study: The 105-week inhalation study of B6C3F1/N mice (NTP 2015a) was selected as the principal study because it identified the lowest LOAEL for 1,1-dichloroethene toxicity.

Summary of the Principal Study:

NTP. 2015a. NTP technical report on the toxicology and carcinogenesis studies of vinylidene chloride (CAS No. 75-35-4) in F344/N rats and B6C3F1/N mice (inhalation studies). NTP TR 582. National Toxicology Program. Research Triangle Park, NC: U.S. Department of Health and Human Services.

Groups of B6C3F1/N mice (50/sex/group; 5-6 weeks of age) were exposed (whole body) to 1,1-dichloroethene vapor for 6 hours/day (+10 minutes), 5 days/week for 14 weeks at 0, 6.25, 12.5, or 25-ppm. Evaluations included survival, clinical signs, body weight, and gross and histopathology. The following targets of toxicity were identified:

- Death: Survival among the 6.25 and 25 ppm males was significantly greater than that controls; survival among the 6.25 and 25 ppm females was significantly less than that of controls.
- Body weight: Mean body weights of 6.25 ppm males and females were comparable to those of respective controls. Mean body weights for 12.5 and 25 ppm males were comparable to those of controls during the first 13 weeks of exposures; thereafter, mean body weights of 12.5 and 25 ppm males averaged 10–11 and 17–19%, respectively, less than controls. Mean body weight for 12.5 ppm females was within 95% that of controls throughout the study. Mean body weight of 25 ppm females was comparable to controls during the first 13 weeks of exposures and averaged 14–20% less than controls thereafter.
- Respiratory: There were no indications of exposure-related increased incidences of nonneoplastic lesions in the lungs. Significantly increased incidences of selected nasal lesions were observed in both males and females at all exposure levels tested (6.25, 12.5, and 25 ppm). Incidence data are presented in Table A-11.
- Renal: Significantly increased incidences of renal tubule hyperplasia were observed in 6.25, 12.5, and 25 ppm groups of male mice (8/50, 22/50, and 16/50, respectively; no incidences in controls). This lesion was not considered for MRL derivation because it was considered a preneoplastic lesion. At 25 ppm, increased incidence of renal casts was observed in males.
- Cancer: At all 1,1-dichloroethene exposure levels (6.25, 12.5, and 25 ppm), male mice exhibited significantly increased incidences of renal tubule adenoma, carcinoma, and adenoma or carcinoma combined. Female mice exhibited significantly increased incidences of alveolar/bronchiolar carcinoma at 12.5 ppm (but not at 25 ppm), hepatocellular carcinoma at 25 ppm, hepatocellular adenoma or carcinoma combined at 12.5 and 25 ppm, hemangiosarcoma in the liver at 25 ppm, and hemangioma or hemangiosarcoma (combined) in all organs (combined) at 25 ppm.

Table A-11 Selected Nasal Lesion Incidences in Male and Female B6C3F1/N Mice Exposed to 1,1-Dichloroethene for 6 Hours/Day, 5 Days/Week for 105 Weeks

Lesion type | 1,1-Dichloroethene exposure level (ppm)
Lesion type | 0 | 6.25 | 12.5 | 25
Males
Hyperostosis | 1/50^a^ (2.0) | 27/50^b^ (1.3) | 45/49 (2.1) | 48/49 (2.2)
Olfactory epithelium metaplasia | 17/50 (1.2) | 39/50^b^ (1.2) | 47/49^b^ (1.6) | 48/49^b^ (1.8)
Turbinate atrophy | 0/50 | 46/50^b^ (1.1) | 46/49^b^ (2.1) | 47/49^b^ (2.8)
Females
Hyperostosis | 0/50 | 13/50^b^ (1.2) | 45/50^b^ (2.0) | 48/50^b^ (2.2)
Olfactory epithelium metaplasia | 3/50 (1.0) | 29/50^b^ (1.1) | 49/50^b^ (1.6) | 50/50^b^ (1.9)
Turbinate atrophy | 0/50 | 46/50^b^ (1.0) | 50/50^b^ (2.3) | 49/50^b^ (2.8)
Males and females (combined incidences)
Hyperostosis | 1/100 | 40/100^c^ | 90/99^c^ | 96/99^c^
Olfactory epithelium metaplasia | 20/100 | 68/100^c^ | 96/99^c^ | 98/99^c^
Turbinate atrophy | 0/100 | 92/100^c^ | 96/99^c^ | 96/99^c^

a Incidence (severity;1 = minimal, 2 = mild, 3 = moderate, 4 = marked).

b Significantly different from chamber control incidence by the Poly-3 test (p<0.01).

c Significantly different from chamber control incidence by Fisher’s exact test (p<0.01) performed by SRC, Inc.

Source: NTP 2015a

Selection of the Point of Departure for the MRL: A BMCL_10_ of 1.46 ppm for olfactory epithelial metaplasia in female mice estimated using the frequentist unrestricted Probit model was selected as the POD for the chronic-duration inhalation MRL for 1,1-dichloroethene.

The lowest LOAEL identified in the NTP (2015a) 105-week mouse study was 6.25 ppm for increased incidence of nasal lesions in males and females. Both male and female mice exhibited significantly increased incidence of hyperostosis, metaplasia of respiratory olfactory epithelium, and turbinate atrophy at the lowest exposure level tested (6.25 ppm). The incidence data for nasal turbinate hyperostosis and olfactory epithelium metaplasia in the male and female mice were fit to all standard dichotomous models in EPA’s BMDS (version 3.1.2) using a BMR of 10% change in incidence from controls. Based on relatively similar male and female exposure concentration-response data, incidences were combined to increase the statistical power of the benchmark result; this procedure was employed for incidences of hyperostosis as well as olfactory epithelium metaplasia. Turbinate atrophy in the male and female mice was not fit to the models because 92% incidence occurred at the lowest exposure level tested. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), scaled residuals (within ±2 units) at the data points (except the control) closest to the predefined BMR, BMCL values that are not 10 times lower than the lowest non-zero concentration, and visual inspection of the proximity of the predicted dose-response curve to the observed data points closest to the BMR. For each dataset, among all models providing adequate fit to the data, the lowest BMCL was selected as the POD when the difference between the BMCLs estimated from these models was >3-fold; otherwise, the BMCL from the model with the lowest AIC was chosen.

Model predictions for hyperostosis in the nasal cavity of the male mice are presented in Table A-12. The 3-degree Multistage and 1-degree Multistate models provided inadequate fit to the data (goodness-of-fit p-value <0.1 and BMDL 10 times lower than the lowest non-zero dose, respectively). BMCLs for models providing adequate fit differed by <3-fold. Therefore, the lowest AIC was selected as a potential POD.

Table A-12 Model Predictions for Hyperostosis in the Nasal Cavity of Male B6C3F1/N Mice Exposed to 1,1-Dichloroethene Vapor for 6 Hours/Day, 5 Days/Week for 105 Weeks (NTP 2015a)

Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Dose near BMC | Control group
Dichotomous Hill | | | NA | 124.27 | 9.46×10^−7^ | 6.48×10^−7^
Gamma^d^ | | | 0.154 | 124.08 | 1.31×10^−2^ | 1.31×10^−2^
Log-Logistic ^e^ ^,^ ^f^ | 2.84 | 1.66 | 0.573 | 122.57 | 4.63×10^−3^ | 4.63×10^−3^
Multistage Degree 3^g^ | | | 0.106 | 124.91 | 3.29×10^−2^ | 3.29×10^−2^
Multistage Degree 2^g^ | | | 0.106 | 124.91 | 3.29×10^−2^ | 3.29×10^−2^
Multistage Degree 1^g^ | | | 0.215 | 123.53 | 6.77×10^−2^ | 6.77×10^−2^
Weibull^d^ | | | 0.134 | 124.41 | 2.25×10^−2^ | 2.25×10^−2^
Logistic | | | <0.0001 | 128.75 | −1.43 | −1.43
Log-Probit | 2.57 | 1.42 | 0.328 | 123.15 | 9.15×10^−3^ | 9.15×10^−3^
Probit | | | <0.0001 | 134.73 | −1.75 | −1.75

a BMC and BMCL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals for dose group near the BMC and for the control dose group.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Recommended model. Among models providing adequate fit to the data, BMCL_10_ values varied by <3-fold; therefore, the model with the lowest AIC was selected as the best-fitting model (2-degree Multistage).

g Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _10_ = exposure concentration associated with 10% extra risk); NA = not applicable

None of the models provided adequate fit to the incidence data. With the exception of the Dichotomous Hill model, the models failed to meet adequate fit (p-value for goodness of fit <0.01). For the Dichotomous Hill model, the p-value for goodness of fit was near unity (0.999), suggesting a forced fit because it hits a model boundary. Thus, the BMC and BMCL estimated from the Dichotomous Hill model was questionable for use a POD for MRL derivation.

None of the models provided adequate fit to the male and female mice combined incidence data for hyperostosis (i.e., goodness-of-fit p-values <0.1 for all models).

None of the models provided adequate fit to the olfactory epithelium metaplasia data for male mice. For the Logistic and Probit models, the goodness-of-fit p-values were <0.1; for the remaining models, the BMCL was 10 times lower than the lowest non-zero dose.

Model predictions for olfactory epithelium metaplasia in the nasal cavity of the female mice are presented in Table A-13. The 1-degree and 3-degree Multistage model provided inadequate fit to the data (goodness-of-fit p-value <0.1). BMCLs for models providing adequate fit differed by <3-fold. Therefore, the BMCL_10_ of 1.46 ppm was selected as a potential POD because the Probit model provided the lowest AIC among models with adequate fit to the data.

Table A-13 Model Predictions for Olfactory Epithelium Metaplasia in Female B6C3F1/N Mice Exposed to 1,1-Dichloroethene for 6 Hours/Day, 5 Days/Week for 105 Weeks (NTP 2015a)

Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Dose near BMC | Control group
Dichotomous Hill | 3.97 | 2.81 | 0.868 | 106.6 | 7.42×10^-^3 | −6.75×10^−4^
Gamma^d^ | 3.27 | 1.81 | 0.989 | 106.5 | 1.95×10^−4^ | −2.00×10^−5^
Log-Logistic^e^ | 3.96 | 2.81 | 0.869 | 106.6 | 7.06×10^−3^ | −9.07×10^−4^
Multistage Degree 3^f^ | | | NA | 108.5 | 3.72×10^−5^ | 3.72×10^−5^
Multistage Degree 2^f^ | 2.18 | 0.94 | 0.870 | 104.8 | 5.18×10^−2^ | 5.18×10^−2^
Multistage Degree 1^f^ | | | 0.023 | 113.4 | 1.70×10^−1^ | 1.70×10^−1^
Weibull^d^ | 2.53 | 1.39 | 0.996 | 106.5 | 1.07×10^−4^ | 1.07×10^−4^
Logistic | 2.16 | 1.61 | 0.929 | 104.7 | 1.97×10^−1^ | 1.97×10^−1^
Log-Probit | 3.73 | 2.56 | 0.964 | 106.5 | 1.63×10^−3^ | −2.51×10^−4^
Probit ^g^ | 1.91 | 1.46 | 0.988 | 104.6 | 7.35×10^−2^ | 7.35×10^−2^

a BMC and BMCL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals for dose group near the BMC and for the control dose group.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Recommended model. Among models providing adequate fit to the data, BMCL_10_ values varied by <3-fold; therefore, the model with the lowest AIC was selected as the best-fitting model (Probit).

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _10_ = exposure concentration associated with 10% extra risk); NA = not applicable

Model predictions for combined incidences of olfactory epithelium metaplasia in the male and female mice are presented in Table A-14. The LogLogistic model was the only model to provide adequate fit to the data (goodness-of-fit p-value >0.1). The BMCL_10_ of 1.96 ppm was selected as a potential POD.

Table A-14 Model Predictions for Olfactory Epithelium Metaplasia in Male and Female B6C3F1/N Mice Exposed to 1,1-Dichloroethene for 6 Hours/Day, 5 Days/Week for 105 Weeks (NTP 2015a)

Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Dose near BMC | Control group
Dichotomous Hill | | | NA | 271.52 | −1.16×10^−7^ | −1.87×10^−7^
Gamma^d^ | | | 0.0139 | 273.66 | 4.38×10^−2^ | 4.38×10^−2^
Log-Logistic ^e^ ^,^ ^f^ | 2.95 | 1.96 | 0.2450 | 270.62 | 1.62×10^−2^ | 1.62×10^−2^
Multistage Degree 3^g^ | | | 0.0133 | 275.24 | 1.13×10^−1^ | 1.13×10^−1^
Multistage Degree 2^g^ | | | 0.0134 | 275.24 | 1.13×10^−1^ | 1.13×10^−1^
Multistage Degree 1^g^ | | | 0.0553 | 274.05 | 2.12×10^−1^ | 2.12×10^−1^
Weibull^d^ | | | 0.0149 | 274.34 | 7.88×10^−2^ | 7.88×10^−2^
Logistic | | | 0.0024 | 271.95 | −1.58×10^−1^ | −1.58×10^−1^
Log-Probit | | | 0.0742 | 271.99 | 3.37×10^−2^ | 3.37×10^−2^
Probit | | | <0.0001 | 278.41 | −7.91×10^−1^ | −7.91×10^−1^

a BMC and BMCL values for models that do not provide adequate are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals for dose group near the BMC and for the control dose group.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Recommended model. Log-Logistic is the only model which provided adequate fit.

g Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _10_ = exposure concentration associated with 10% extra risk); NA = not applicable

Table A-15 summarizes the BMC_10_ and BMCL_10_ values for the nasal lesion incidences in the male and female mice exposed to 1,1-dichloroethene for 6 hours/day, 5 days/week for 105 weeks (NTP 2015a). The BMC_10_ of 1.91 ppm for olfactory epithelium metaplasia in the female mice was selected because it represents the lowest BMC_10_ among the best-fitting models for nasal lesions. The corresponding BMCL_10_ of 1.46 ppm serves as the POD for deriving a chronic-duration inhalation MRL for 1,1-dichloroethene. The Probit model for olfactory epithelial metaplasia in female mice is presented in Figure A-2.

Table A-15 BMC_10_ and BMCL_10_ Values from the Best-Fitting Models for Selected Nonneoplastic Nasal Lesions in B6C3F1/N Mice Exposed to 1,1-Dichloroethene Vapor 6 Hours/Day, 5 Days/Week for 105 Weeks

Lesion type | Sex | Model | BMC_10_ (ppm) | BMCL_10_ (ppm)
Turbinate; Hyperostosis | Male | Log-Logistic | 2.84 | 1.66
Turbinate; Hyperostosis | Female | NA
Turbinate; Hyperostosis | Combined | NA
Olfactory epithelium; Metaplasia | Male | NA
Olfactory epithelium; Metaplasia | Female | Probit | 1.91 | 1.46 ^a^
Olfactory epithelium; Metaplasia | Combined | Log-Logistic | 2.95 | 1.96

a The BMCL_10_ of 1.46 ppm for olfactory epithelial metaplasia in female mice was selected as the preferred POD for deriving a chronic-duration inhalation MRL for 1,1-dichloroethene because it corresponds to the lowest BMC_10_ (1.91 ppm) among the group of best-fitting models for nasal lesions.

BMC = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., 10 = exposure concentration associated with 10% extra risk); MRL = minimum risk level; NA = not applicable (no model provided adequate fit to the data); POD = point of departure

Figure A-2 Fit of Probit Model for Olfactory Epithelial Metaplasia Female B6C3F1/N Mice Exposed to 1,1-Dichloroethene 6 Hours/Day, 5 Days/Week for 105 Weeks

Figure A-2 description

Intermittent Exposure: The BMCL_10_ of 1.46 ppm was adjusted from intermittent exposure to a continuous exposure scenario according to the following equation:

BMCL_ADJ_ = BMCL_10_ ( 1.46 ppm ) × 6 hours / 24 hours × 5 days / 7 days = 0.261 ppm

Human Equivalent Concentration: To calculate a HEC, the BMCL_ADJ_ was multiplied by the regional gas dose ratio (mouse:human) for RGDR_ET_. The RGDR_ET_ was calculated according to the EPA (1994) equation 4-18:

R G D R_E T_ = (( (V_E_)/(S A_E T_) ) A)/(( (V_E_)/(S A_E T_) ) H) RGDRET calculation

where:

- ET = extrathoracic region
- V_E_ = minute volume (mL/minute)
- SA = surface area (cm^2^)
- A = animal (mouse)
- H = human

SA_ET_ values for the mouse (3 cm^2^) and humans (200 cm^2^) were taken from Table 4-4 of EPA (1994). The chronic minute volume (V_E_) for the male B6C3F1 mouse was taken from Table 1-4 of EPA (1988b) in which it was presented as 0.060 m^3^/day (41.67 mL/minute). According to EPA (1994), the default minute volume for humans is 13,800 mL/minute. Therefore:

R G D R_E T_ = (( (V_E_)/(S A_E T_) ) A)/(( (V_E_)/(S A_E T_) ) H) = ((41.67 m L / min)/(3 c m^2^))/((13,800 m L / min)/(200 c m^2^)) = 0.20 RGDRET calculation

The BMCL_HEC_ = BMCL_ADJ_ × RGDR_ET_ = 0.261 ppm × 0.20 = 0.052 ppm

Uncertainty Factor: The BMCL_HEC_ of 0.052 ppm was divided by a total uncertainty factor of 30:

- 3 for extrapolation from animals to humans using dosimetric adjustment
- 10 for human variability

MRL = BMCL_HEC_ ÷ UF_S_ 0.028 ppm ÷ ( 3 × 10 ) = 0.0017 ppm ≈ 0.002 ppm

This MRL is slightly higher than the intermediate-duration inhalation MRL of 0.001 ppm. Thus, the intermediate-duration inhalation MRL based on increased incidences of necrosis of the nasal olfactory epithelium in male rats was adopted as the chronic MRL.

Other Additional Studies or Pertinent Information that Lend Support to this MRL: The nasal cavity was among the most sensitive targets of toxicity in male and female F344/N rats and B6C3F1/N mice intermittently exposed to 1,1-dichloroethene vapor for 14 or 105 weeks (NTP 2015a).

Agency Contacts (Chemical Managers): Malcolm Williams

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,1-Dichloroethene
CAS Numbers: | 75-35-4
Date: | April 2022
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: Available data were not considered adequate for derivation of an acute-duration oral MRL for 1,1-dichloroethene.

Rationale for Not Deriving an MRL: No dose-response data are available for humans. Many acute-duration studies employed fasted animals which are known to be more sensitive than nonfasted rats to 1,1-dichloroethene-induced adverse effects following oral exposure. The increased sensitivity to 1,1-dichloroethene in fasted animals appears to be related to toxicokinetic parameters. Levels of radioactivity in liver, kidneys, and lungs of fasted rats treated with ^14^C-1,1-dichloroethene were significantly greater than levels in nonfasted rats (McKenna et al. 1978a). 1,1-Dichloroethene-induced hepatic lesions appeared earlier and were more extensive in fasted rats compared to nonfasted rats (Jaeger et al. 1974; McKenna et al. 1978b; Reynolds and Moslen 1977). Liver mixed function oxidase activity in fasted animals following 1,1-dichloroethene exposure was greater than that in similarly treated nonfasted animals (McKenna et al. 1978b; Nakajima et al. 1982). Due to increased sensitivity to 1,1-dichloroethene toxicity among fasted animals, only oral data from nonfasted animals (i.e., normal diet) were considered for MRL derivation. Some studies did not provide dose-response data because only a single dose level was used. Table A-16 summarizes available results from acute-duration oral studies in laboratory animals. Among studies that employed multiple dose levels and nonfasted animals, the lowest LOAEL is 100 mg/kg/day for 11% depressed body weight in female rats administered 1,1-dichloroethene by gavage for 14 days (NTP 1982). Given the limited database of information for the gavage exposure route and no information regarding the effects of acute-duration dietary or drinking water exposure, it is not considered appropriate to derive an acute-duration oral MRL for 1,1-dichloroethene at this time.

Table A-16 Summary of Potential Candidate Critical Effects for Deriving an Acute-Duration Oral MRL for 1,1-Dichloroethene

Species | Duration | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference
Body weight effects
F344/N rat | 14 days; 1 time/day (GO) | 100 M; 50 F | 500 M; 100 F | Depressed body weight | NTP 1982
Respiratory effects
C57BL/6 male mouse | Once (GO) | ND | 100 | Reversible cellular changes in Clara cells (club cells) of bronchiolar epithelium | Forkert and Reynolds 1982
Hepatic effects
F344/N rat | 14 days; 1 time/day (GO) | 500 M; 250 F | 1,000 M; 500 F | Liver necrosis at lethal dose levels | NTP 1982
B6C3F1 mouse | 14 days; 1 time/day (GO) | 100 | 500 | Liver necrosis at lethal dose level | NTP 1982

F = female(s); GO = gavage in oil; LOAEL = lowest observed adverse effect level; M = male(s); NOAEL = no-observed-adverse-effect level

Agency Contacts (Chemical Managers): Malcolm Williams

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,1-Dichloroethene
CAS Numbers: | 75-35-4
Date: | April 2022
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: Available data were not considered adequate for derivation of an intermediate-duration oral MRL for 1,1-dichloroethene.

Rationale for Not Deriving an MRL: No dose-response data are available for humans. Table A-17 summarizes potential candidate critical effect PODs from intermediate-duration oral studies in laboratory animals. The 90-day gavage studies of rats and mice (NTP 1982) were the only available intermediate-duration oral studies in which treatment-related adverse effects were observed. Given the limited database of information for the gavage exposure route and no information regarding the effects of intermediate-duration dietary or drinking water exposure, it is not considered appropriate to derive an intermediate-duration oral MRL for 1,1-dichloroethene at this time.

Table A-17 Summary of Potential Candidate Critical Effects for Deriving an Intermediate-Duration Oral MRL for 1,1-Dichloroethene

Species | Duration | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference
F344/N rat | 90 days; 5 days/week; 1 time/day (GO) | 40 | 100 | Hepatocytomegaly in males; fibrosis, pigmentation, bile duct hyperplasia in females | NTP 1982
B6C3F1 mouse | 90 days; 5 days/week; 1 time/day (GO) | 40 | 100 | Liver necrosis and other cellular changes at lethal dose level | NTP 1982

GO = gavage in oil; LOAEL = lowest observed adverse effect level; NOAEL = no-observed-adverse-effect level

Agency Contacts (Chemical Managers): Malcolm Williams

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,1-Dichloroethene
CAS Numbers: | 75-35-4
Date: | April 2022
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL | 0.05 mg/kg/day
Critical Effect: | Hepatic midzonal fatty change
References: | Humiston et al. 1978; Quast et al. 1983
Point of Departure: | BMDL_10_ of 4.51 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 28
Species: | Rat

MRL Summary: A MRL of 0.05 mg/kg/day has been derived for chronic-duration oral exposure to 1,1-dichloroethene based on hepatic effects (hepatic midzonal fatty change) in female Sprague-Dawley rats receiving 1,1-dichloroethene from the drinking water for up to 2 years (Humiston et al. 1978; Quast et al. 1983). The MRL is based on a BMDL_10_ of 4.51 mg/kg/day and divided by a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: No dose-response human data are available. Relatively limited data are available regarding the effects of chronic-duration oral exposure of animals to 1,1-dichloroethene. Two groups of investigators found no evidence of 1,1-dichloroethene toxicity at the highest dose levels tested, although these doses were ≤20 mg/kg/day (Maltoni et al. 1985; NTP 1982). A single 2-year drinking water study reported increased incidences of hepatocellular hypertrophy and midzonal fatty changes (the only reported adverse effect) in male and female rats at estimated 1,1-dichloroethene doses of 20 and 9 mg/kg/day, respectively (Humiston et al. 1978; Quast et al. 1983). A NOAEL of 10 mg/kg/day was identified for the male rats; the LOAEL of 9 mg/kg/day for the female rats was the lowest dose tested.

Selection of the Principal Studies: The 2-year rat study (Humiston et al. 1978; Quast et al. 1983) was selected as the principal study for deriving a chronic-duration oral MRL for 1,1-dichloroethene because it identified the lowest LOAEL (9 mg/kg/day) for nonneoplastic effects.

Summary of the Principal Studies:

Humiston CG, Quast JF, Wade CE, . 1978. Results of a two-year toxicity and oncogenicity study with vinylidene chloride incorporated in the drinking water of rats. Toxicology Research Laboratory, Health and Environmental Research, Dow Chemical USA . Chem Mfgs Assn. Submitted to the U.S. EPA under TSCA section FYI.

Quast JF, Humiston CG, Wade CE, . 1983. A chronic toxicity and oncogenicity study in rats and subchronic toxicity study in dogs on ingested vinylidene chloride. Fundam Appl Toxicol 3(1):55–62.6884624

In the principal study, groups of Sprague-Dawley rats (48/sex/group; 80/sex for controls; 6–7 weeks of age) were administered 1,1-dichloroethene in the drinking water for 2 years at 50, 100, or 200 ppm (author-estimated doses of 7, 10, and 20 mg/kg/day, respectively, for males, and 9, 14, and 30 mg/kg/day, respectively, for females). Controls consisted of 80 rats/sex that received drinking water without 1,1-dichloroethene. Rats were monitored for survival, clinical signs, body weight, and food intake. Blood and urine were collected from at least five rats/sex/group at 6, 12, 18, and 23 months for hematology and urinalysis. Clinical chemistry evaluations were performed on 5 rats/sex/group at 6, 12, and 18 months, and from all surviving rats from each group in which <10 rats remained at terminal sacrifice. At sacrifice, weights of brain, heart, liver, kidneys, and testes were recorded. Comprehensive gross pathological examinations were performed on all rats. Comprehensive histopathologic examinations were performed on control and high-dose rats; histopathology was also performed on selected target organs and grossly recognized neoplastic changes in low- and mid-dose rats.

There were no significant treatment-related differences from controls in appearance and demeanor, mortality, body weight, food consumption, water consumption, hematology, urinalysis, clinical chemistry, or organ weight. The sole treatment-related observation was microscopic changes in the liver (minimal amount of hepatocellular swelling with midzonal fatty change). The incidences of midzonal fatty change in the controls, low-, mid-, and high-dose rats are presented in Table A-18. Incidences of midzonal fatty change were significantly increased in the high-dose males (20 mg/kg/day) and mid- (14 mg/kg/day) and high-dose (30 mg/kg/day) females. Incidences of minimal hepatocellular swelling, summarized in Table A-18, were significantly increased in females at all 1,1-dichloroethene dose levels. The mid-dose (10 mg/kg/day) and high-dose (20 mg/kg/day) are considered male rat NOAEL and LOAEL levels, respectively, for histopathologic liver effects. The low-dose (9 mg/kg/day) is considered a minimum LOAEL for the female rat, based on the minimal nature of hepatocellular swelling at that dose level.

Table A-18 Incidence Data for Selected Nonneoplastic Liver Lesions in Male and Female Sprague-Dawley Rats Administered 1,1-Dichloroethene in the Drinking Water for up to 2 Years^a^

Lesion type
Males
Time-weighted average dose (mg/kg/day) | 0 | 7 | 10 | 20
Minimal hepatocellular hypertrophy | 0/76 | 0/46 | 1/45 | 3/42^b^
Minimal midzonal fatty change | 12/76 | 4/46 | 13/45 | 18/42^c^
Females
Time-weighted average dose (mg/kg/day) | 0 | 9 | 14 | 30
Minimal hepatocellular hypertrophy | 3/79 | 7/48^b^ | 11/45^c^ | 20/48^c^
Minimal midzonal fatty change | 10/79 | 12/48 | 14/45^b^ | 22/48^c^

a Incidence in animals dying or killed between 13 and 24 months.

b Significantly different from control incidence according to Fisher’s exact test (p<0.05).

c Significantly different from control incidence according to Fisher’s exact test (p<0.01).

Sources: Humiston et al. 1978; Quast et al. 1983

Selection of the Point of Departure for the MRL: A BMDL_10_ of 4.51 mg/kg/day for hepatic midzonal fatty changes in female rats estimated using the frequentist-restricted Gamma model was selected as the POD for the chronic-duration oral MRL for 1,1-dichloroethene.

The lowest LOAEL identified in the 2-year rat study (Humiston et al. 1978; Quast et al. 1983) was 9 mg/kg/day for increased hepatocellular hypertrophy in female rats. Incidence data for these effects are presented in Table A-18.

The incidence data for hepatocellular hypertrophy and for midzonal fatty change in the female rats were fit to all standard dichotomous models in EPA’s BMDS (version 3.1.2) using a BMR of 10% change in incidence from controls. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), scaled residuals (within ±2 units) at the data points (except the control) closest to the predefined BMR, BMDL that was not 10 times lower than the lowest non-zero dose, and visual inspection of the proximity of the predicted dose-response curve to the observed data points closest to the BMR. For each dataset, among all models providing adequate fit to the data, the lowest BMDL was selected as the POD when the difference between the BMDLs estimated from these models was >3-fold; otherwise, the BMDL from the model with the lowest AIC was chosen.

The model predictions for hepatocellular hypertrophy are presented in Table A-19. Most models provided adequate fit to the data; the dichotomous Hill model because the goodness of fit test could not be calculated. BMDLs for models providing adequate fit differed by <3-fold; therefore, the model with the lowest AIC (1-degree Multistage) was selected as a potential POD.

Table A-19 Model Predictions for Hepatocellular Hypertrophy in Female Sprague-Dawley Rats Receiving 1,1-Dichloroethene from the Drinking Water for 2 Years (Humiston et al. 1978; Quast et al. 1983)

Model | BMD_10_^a^ (mg/kg/day) | BMDL_10_^a^ (mg/kg/day) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMD_10_^a^ (mg/kg/day) | BMDL_10_^a^ (mg/kg/day) | p-Value^b^ | AIC | Dose near BMD | Control group
Dichotomous Hill | | | NA | 188.65 | −2.41×10^−5^ | 3.01×10^−6^
Gamma^d^ | 7.33 | 4.82 | 0.711 | 186.78 | −2.21×10^−1^ | 1.30×10^−2^
Log-Logistic^e^ | 7.52 | 4.13 | 0.747 | 186.75 | −1.94×10^−1^ | 1.40×10^−2^
Multistage Degree 3^f^ | 7.02 | 4.81 | 0.685 | 186.81 | −2.72×10^−1^ | 2.38×10^−2^
Multistage Degree 2^f^ | 7.02 | 4.81 | 0.685 | 186.81 | −2.73×10^−1^ | 2.47×10^−2^
Multistage Degree 1^f,g^ | 6.46 | 4.79 | 0.897 | 184.87 | −4.10×10^−1^ | 7.14×10^−2^
Weibull^d^ | 7.27 | 4.81 | 0.706 | 186.79 | −2.32×10^−1^ | 1.51×10^−2^
Logistic | 12.12 | 10.06 | 0.276 | 187.28 | 1.12 | −9.81×10^−1^
Log-Probit ^g^ | 7.79 | 2.66 | 0.793 | 186.71 | −1.51×10^−1^ | 1.17×10^−2^
Probit | 11.25 | 9.33 | 0.372 | 186.64 | 3.48×10^−1^ | −7.95×10^−1^

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals for dose group near the BMD and for the control dose group.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Recommended model. Most models provided adequate fit to the data. BMDLs differed by >3-fold; therefore, the models with the lowest BMDL (Log-Probit) was selected as best-fitting model.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _10_ = exposure dose associated with 10% extra risk); NA = not applicable

The model predictions for midzonal fatty change are presented in Table A-20. The Dichotomous Hill model and Log-Probit models did not provide adequate to the data (saturated model and BMDL 10 times lower than lowest non-zero dose, respectively). The BMDLs for the models providing adequate fit differed by <3-fold; therefore, the model with the lowest AIC was selected (Gamma) and the BMDL_10_ was considered a potential POD.

Table A-20 Model Predictions for Hepatic Midzonal Fatty Change in Female Sprague-Dawley Rats Receiving 1,1-Dichloroethene from the Drinking Water for 2 Years (Humiston et al. 1978; Quast et al. 1983)

Model | BMD_10_^a^ (mg/kg/day) | BMDL_10_^a^ (mg/kg/day) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMD_10_^a^ (mg/kg/day) | BMDL_10_^a^ (mg/kg/day) | p-Value^b^ | AIC | Dose near BMD | Control group
Dichotomous Hill | | | NA | 244.01 | −3.64×10^−3^ | 3.77×10^−4^
Gamma ^d^ ^,^ ^e^ | 6.49 | 4.51 | 0.991 | 240.02 | 5.52×10^−2^ | −3.99×10^−2^
Log-Logistic^f^ | 6.26 | 3.64 | 0.994 | 242.01 | −4.81×10^−3^ | 3.82×10^−4^
Multistage Degree 3^g^ | 6.49 | 4.51 | 0.991 | 240.02 | 5.52×10^−3^ | −3.99×10^−2^
Multistage Degree 2^g^ | 6.49 | 4.51 | 0.991 | 240.02 | 5.52×10^−2^ | −3.99×10^−2^
Multistage Degree 1^g^ | 6.49 | 4.51 | 0.991 | 240.02 | 5.52×10^−2^ | −3.99×10^−2^
Weibull^d^ | 6.49 | 4.51 | 0.991 | 240.02 | 5.52×10^−2^ | −3.99×10^−2^
Logistic | 10.02 | 7.97 | 0.645 | 240.89 | 4.38×10^−1^ | −5.48×10^−1^
Log-Probit | | | 0.978 | 242.01 | 1.59×10^−2^ | −1.50×10^−3^
Probit | 9.53 | 7.55 | 0.698 | 240.72 | 4.08×10^−1^ | −4.71×10^−1^

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals for dose group near the BMD and for the control dose group.

d Power restricted to ≥1.

e Recommended model. Most models provided adequate fit to the data. BMDLs differed by <3-fold; therefore, the models with the lowest AIC (Gamma) was selected as best-fitting model.

f Slope restricted to ≥1.

g Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _10_ = exposure dose associated with 10% extra risk); NA = not applicable

From the best-fitting models, a BMD_10_ of 7.79 mg/kg/day for hepatocellular hypertrophy (Log-Probit model Table A-19) and a BMD_10_ of 6.49 mg/kg/day for midzonal fatty change (Gamma model, Table A-20) were estimated. The BMDL_10_ of 4.51 mg/kg/day for midzonal fatty change in the female rats was selected as the POD for the MRL because it had the lowest BMD_10_. The fit of the Gamma model to the midzonal fatty changes incidence data is presented in Figure A-3.

Figure A-3 Fit Gamma Model for Hepatic Midzonal Fatty Change in Female Sprague-Dawley Rats Receiving 1,1-Dichloroethene from the Drinking Water for 2 Years

Figure A-3 description

Uncertainty Factor: The BMDL_10_ of 4.51 mg/kg/day was divided by a total uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = BMDL_10_ ÷ UF_S_ MRL = 4.51 mg/kg/day ÷ ( 10 × 10 ) = 0.045 mg/kg/day ≈ 0.05 mg/kg/day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Support is limited to similar findings in the male rats of the principal study, albeit at a higher dose level (20 mg/kg/day) than the LOAEL of 9 mg/kg/day observed in the female rats.

Agency Contacts (Chemical Managers): Malcolm Williams