# VERSION HISTORY

Date | Description
June 2022 | Final toxicological profile released
July 2021 | Draft for public comment toxicological profile released
May 2020 | Addendum to the toxicological profile released
December 1998 | Final toxicological profile released
October 1989 | Final toxicological profile released