# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding 3,3’-dichlorobenzidine in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for 3,3’-dichlorobenzidine.

Table 7-1 Regulations and Guidelines Applicable to 3,3’-Dichlorobenzidine

Agency | Description | Information | Reference
Air
EPA | RfC | Not evaluated | IRIS 2006
WHO | Air quality guidelines | No data | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | Not listed | EPA 2018b
EPA | National primary drinking water regulations | Not listed | EPA 2009
EPA | RfD | Reviewed but inadequate data | IRIS 2006
WHO | Drinking water quality guidelines | No data | WHO 2017
FDA | Substances Added to Food^a^ | Not listed | FDA 2021
Cancer
HHS | Carcinogenicity classification | Reasonably anticipated to be a human carcinogen | NTP 2021
EPA | Carcinogenicity classification | Group B2^b^ | IRIS 2006
EPA | Oral slope factor | 4.5X10^-1^ mg/kg-day | IRIS 2006
IARC | Carcinogenicity classification | Group 2B^c^ | IARC 1987
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards and construction | No PEL established; Potential occupational carcinogen; Exposure to be controlled through the required use of engineering controls, work practices, and personal protective equipment | OSHA 2021a, OSHA 2021b
NIOSH | REL (up to 10-hour TWA) | No REL established; Potential occupational carcinogen; Exposures to carcinogens be limited to the lowest feasible concentration | NIOSH 2019
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2018a
DOE | PACs-air | | DOE 2018a (https://www.energy.gov/ehss/protective-action-criteria-pac-aegls-erpgs-teels)
DOE | PAC-1^d^ | 2.1 ppm | DOE 2018a (https://www.energy.gov/ehss/protective-action-criteria-pac-aegls-erpgs-teels)
DOE | PAC-2^d^ | 23 ppm | DOE 2018a (https://www.energy.gov/ehss/protective-action-criteria-pac-aegls-erpgs-teels)
DOE | PAC-3^d^ | 140 ppm | DOE 2018a (https://www.energy.gov/ehss/protective-action-criteria-pac-aegls-erpgs-teels)

a The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited from use in food, delisted color additives, and some substances “no longer FEMA GRAS”.

b Group B2: Probable human carcinogen.

c Group 2B: Possibly carcinogenic to humans.

d Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018b).

AEGL = acute exposure guideline levels; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association of the United States; GRAS = Generally Recognized As Safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = Protective Action Criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; WHO = World Health Organization