# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR 3,3’-DICHLOROBENZIDINE

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to 3,3’-dichlorobenzidine.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen was conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for 3,3’-dichlorobenzidine. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of 3,3’-dichlorobenzidine have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of 3,3’-dichlorobenzidine are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

- Health Effects; - Species; - Human; - Laboratory mammals; - Route of exposure; - Inhalation; - Oral; - Dermal (or ocular); - Parenteral (these studies will be considered supporting data); - Health outcome; - Death; - Systemic effects; - Body weight effects; - Respiratory effects; - Cardiovascular effects; - Gastrointestinal effects; - Hematological effects; - Musculoskeletal effects; - Hepatic effects; - Renal effects; - Dermal effects; - Ocular effects; - Endocrine effects; - Immunological effects; - Neurological effects; - Reproductive effects; - Developmental effects; - Other noncancer effects; - Cancer; - Toxicokinetics; - Absorption; - Distribution; - Metabolism; - Excretion; - PBPK models; - Biomarkers; - Biomarkers of exposure; - Biomarkers of effect; - Interactions with other chemicals; - Potential for human exposure; - Releases to the environment; - Air; - Water; - Soil; - Environmental fate; - Transport and partitioning; - Transformation and degradation; - Environmental monitoring; - Air; - Water; - Sediment and soil; - Other media; - Biomonitoring; - General populations; - Occupation populations

### B.1.1 Literature Search

The current literature search was intended to update the draft toxicological profile for 3,3’-dichlorobenzidine released for public comment in 2021; thus, the literature search was restricted to studies published between January 2018 and November 2021. The following main databases were searched in November 2021:

- PubMed
- National Technical Reports Library (NTRL)
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for 3,3’-dichlorobenzidine. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to 3,3’-dichlorobenzidine were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
11/2021 | (“3,3’-Dichlorobenzidine”[mh] OR “(1,1’-Biphenyl)-4,4’-diamine, 3,3’-dichloro-”[tw] OR “3,3’-Dichloro-(1,1’-biphenyl)-4,4’-diamine”[tw] OR “3,3’-Dichloro-4,4’-biphenyldiamine”[tw] OR “3,3’-Dichloro-4,4’-diamino(1,1-biphenyl)”[tw] OR “3,3’-Dichloro-4,4’-diaminobiphenyl”[tw] OR “3,3’-Dichloro-4,4’-diaminodiphenyl”[tw] OR “3,3’-Dichloro-[1,1’-biphenyl]-4,4’-diamine”[tw] OR “3,3’-Dichloro-p,p’-bianiline”[tw] OR “3,3’-Dichloro[1,1’-biphenyl]-4,4’-diamine”[tw] OR “3,3’-Dichlorobenzidine”[tw] OR “3,3’-Dichlorobiphenyl-4,4’-diamine”[tw] OR “4-(4-amino-3-chlorophenyl)-2-chloroaniline”[tw] OR “4’-Amino-3,3’-dichloro(1,1’biphenyl)-4-ylamine”[tw] OR “4,4’-Diamino-3,3’-dichlorobiphenyl”[tw] OR “4,4’-Diamino-3,3’-dichlorodiphenyl”[tw] OR “4,4′-Bis(2-chloroaniline)”[tw] OR “4,4′-Diamino-3,3′dichlorobiphenyl”[tw] OR “4,4′-Diamino-3,3′-dichlorodiphenyl”[tw] OR “4′-Amino-3,3′dichloro[1,1′-biphenyl]-4-ylamine”[tw] OR “[1,1’-biphenyl]-4,4’-diamine, 3,3’-dichloro-”[tw] OR “Benzidine, 3,3’-dichloro-”[tw] OR “Curithane C 126”[tw] OR “Curithane C126”[tw] OR “Dichlodine H”[tw] OR “Dichlorobenzidine base”[tw] OR “o,o’-Dichlorobenzidine”[tw] OR “ortho,ortho’-Dichlorobenzidine”[tw] OR “Sulfuric acid-3,3’-dichloro[1,1’-biphenyl]-4,4’-diamine (1/1)”[tw] OR “Sulfuric acid-3,3’-dichloro[1,1’-biphenyl]-4,4’-diamine (2/1)”[tw] OR “1,1’-biphenyl-4,4’-diamine, 3,3’-dichloro-”[tw] OR “DICHLOROBENZIDINE”[tw] OR “AC1L3YN5”[tw] OR “AKOS030538069”[tw] OR “CTK5C1212”[tw] OR “LS-32418”[tw] OR “SCHEMBL8641898”[tw]) AND (2018/01/01:3000[dp] OR 2018/12/01:3000[mhda] OR 2018/12/01:3000[crdat] OR 2018/12/01:3000[edat])
NTRL
11/2021 | dichlorobenzidine; “3,3’-Dichloro-(1,1’-biphenyl)-4,4’-diamine”; “3,3’-Dichloro-4,4’-biphenyldiamine”; “3,3’-Dichloro-4,4’-diamino(1,1-biphenyl)”; “3,3’-Dichloro-4,4’-diaminobiphenyl”; “3,3’-Dichloro-4,4’-diaminodiphenyl”; “3,3’-Dichloro-[1,1’-biphenyl]-4,4’-diamine”; “3,3’-Dichloro-p,p’-bianiline”; “3,3’-Dichloro[1,1’-biphenyl]-4,4’-diamine”; “3,3’-Dichlorobiphenyl-4,4’-diamine”; “4’-Amino-3,3’-dichloro(1,1’-biphenyl)-4-ylamine”; “4,4’-Diamino-3,3’-dichlorobiphenyl”; “4,4’-Diamino-3,3’-dichlorodiphenyl”; “4,4′-Bis(2-chloroaniline)”; “4,4′-Diamino-3,3′-dichlorobiphenyl”; “4,4′-Diamino-3,3′-dichlorodiphenyl”; “4-(4-amino-3-chlorophenyl)-2-chloroaniline”; “4′-Amino-3,3′-dichloro[1,1′-biphenyl]-4-ylamine”
Toxcenter
11/2021 | FILE ‘TOXCENTER’ ENTERED AT 14:21:35 ON 22 NOV 2021; CHARGED TO COST=EH038.13.04.LB.04; L1 895 SEA FILE=TOXCENTER 91-94-1 OR 612-83-9 OR 64969-34-2 OR 64414-68-2 OR 74332-73-3; L2 872 SEA FILE=TOXCENTER L1 NOT TSCATS/FS; L4 843 SEA FILE=TOXCENTER L2 NOT PATENT/DT; L5 28 SEA FILE=TOXCENTER L4 AND PY>2017; L6 27 DUP REM L5 (1 DUPLICATE REMOVED); ANSWERS ‘1-27’ FROM FILE TOXCENTER D SCAN L6

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via ChemView
11/2021 | Compounds searched: 91-94-1, 612-83-9, 64969-34-2, 64414-68-2, 74332-73-3
NTP
11/2021 | 91-94-1; 612-83-9; 64969-34-2; 64414-68-2; 74332-73-3; Dichlorobenzidine; “3,3’-Dichloro-(1,1’-biphenyl)-4,4’-diamine” “3,3’-Dichloro-4,4’-biphenyldiamine” “3,3’-Dichloro-4,4’-diamino(1,1-biphenyl)” “3,3’-Dichloro-4,4’-diaminobiphenyl”; “3,3’-Dichloro-4,4’-diaminodiphenyl” “3,3’-Dichloro-[1,1’-biphenyl]-4,4’-diamine” “3,3’-Dichloro-p,p’-bianiline” “3,3’-Dichloro[1,1’-biphenyl]-4,4’-diamine”; “3,3’-Dichlorobiphenyl-4,4’-diamine” “4’-Amino-3,3’-dichloro(1,1’-biphenyl)-4-ylamine”; “4,4’-Diamino-3,3’-dichlorobiphenyl” “4,4’-Diamino-3,3’-dichlorodiphenyl”; “4,4′-Bis(2-chloroaniline)” “4,4′-Diamino-3,3′-dichlorobiphenyl” “4,4′-Diamino-3,3′-dichlorodiphenyl” “4-(4-amino-3-chlorophenyl)-2-chloroaniline”; “4′-Amino-3,3′-dichloro[1,1′-biphenyl]-4-ylamine”
Regulations.gov
11/2021 | 91-94-1; 612-83-9; 64969-34-2; 64414-68-2; 74332-73-3; dichlorobenzidine; “3,3’-Dichloro-(1,1’-biphenyl)-4,4’-diamine”; “3,3’-Dichloro-4,4’-biphenyldiamine”; “3,3’-Dichloro-4,4’-diamino(1,1-biphenyl)”; “3,3’-Dichloro-4,4’-diaminobiphenyl”; “3,3’-Dichloro-4,4’-diaminodiphenyl”; “3,3’-Dichloro-[1,1’-biphenyl]-4,4’-diamine”; “3,3’-Dichloro-p,p’-bianiline”; “3,3’-Dichloro[1,1’-biphenyl]-4,4’-diamine”; “3,3’-Dichlorobiphenyl-4,4’-diamine”; “4’-Amino-3,3’-dichloro(1,1’-biphenyl)-4-ylamine”; “4,4’-Diamino-3,3’-dichlorobiphenyl”; “4,4’-Diamino-3,3’-dichlorodiphenyl”; “4,4′-Bis(2-chloroaniline)”; “4,4′-Diamino-3,3′-dichlorobiphenyl”; “4,4′-Diamino-3,3′-dichlorodiphenyl”; “4-(4-amino-3-chlorophenyl)-2-chloroaniline”; “4′-Amino-3,3′-dichloro[1,1′-biphenyl]-4-ylamine”
NIH RePORTER
12/2021 | Fiscal Year: Active Projects Text Search: “(1,1’-Biphenyl)-4,4’-diamine, 3,3’-dichloro-” OR “3,3’-Dichloro-(1,1’-biphenyl)-4,4’-diamine” OR “3,3’-Dichloro-4,4’-biphenyldiamine” OR “3,3’-Dichloro-4,4’-diamino(1,1-biphenyl)” OR “3,3’-Dichloro-4,4’-diaminobiphenyl” OR “3,3’-Dichloro-4,4’-diaminodiphenyl” OR “3,3’-Dichloro-[1,1’-biphenyl]-4,4’-diamine” OR “3,3’-Dichloro-p,p’-bianiline” OR “3,3’-Dichloro[1,1’-biphenyl]-4,4’-diamine” OR “3,3’-Dichlorobenzidine” OR “3,3’-Dichlorobiphenyl-4,4’-diamine” OR “4-(4-amino-3-chlorophenyl)-2-chloroaniline” OR “4’-Amino-3,3’-dichloro(1,1’-biphenyl)-4-ylamine” OR “4,4’-Diamino-3,3’-dichlorobiphenyl” OR “4,4’-Diamino-3,3’-dichlorodiphenyl” OR “4,4′-Bis(2-chloroaniline)” OR “4,4′-Diamino-3,3′-dichlorobiphenyl” OR “4,4′-Diamino-3,3′dichlorodiphenyl” OR “4′-Amino-3,3′-dichloro[1,1′-biphenyl]-4-ylamine” OR “[1,1’-biphenyl]-4,4’-diamine, 3,3’-dichloro-” OR “Benzidine, 3,3’-dichloro-” OR “Curithane C 126” OR “Curithane C126” OR “Dichlodine H” OR “Dichlorobenzidine base” OR “o,o’-Dichlorobenzidine” OR “ortho,ortho’-Dichlorobenzidine” OR “Sulfuric acid-3,3’-dichloro[1,1’-biphenyl]-4,4’-diamine (1/1)” OR “Sulfuric acid-3,3’-dichloro[1,1’-biphenyl]-4,4’-diamine (2/1)” OR “1,1’-biphenyl-4,4’-diamine, 3,3’-dichloro-” OR “DICHLOROBENZIDINE” (advanced) Limit to: Project Title, Project Terms, Project Abstracts
Other | Identified throughout the assessment process

The 2021 results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 28
- Number of records identified from other strategies: 14
- Total number of records to undergo literature screening: 42

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on 3,3’-dichlorobenzidine:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 42
- Number of studies considered relevant and moved to the next step: 15

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 15
- Number of studies cited in the pre-public draft of the toxicological profile: 157
- Total number of studies cited in the profile: 158

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 November 2021 Literature Search Results and Screen for 3,3’-Dichlorobenzidine

Figure B-1 description