# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3,3’-Dichlorobenzidine
CAS Numbers: | 91-94-1
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL due to the lack of quantitative exposure-response data for humans or animals.

Rationale for Not Deriving an MRL: Only a single review study describes acute inhalation exposure in animals and humans (Gerarde and Gerarde 1974). The animal study reported in the review is severely limited due to lack of detailed reporting of the results. The reported human results in Gerarde and Gerarde (1974) are limited due to non-reporting of exposure concentration, concurrent exposure to other carcinogens, and failure to use control groups. Additionally, the primary endpoint examined was cancer, which is not used to derive an MRL.

Agency Contacts (Chemical Managers): Custodio Muianga

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3,3’-Dichlorobenzidine
CAS Numbers: | 91-94-1
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL due to the lack of studies examining this exposure duration in humans and animals.

Rationale for Not Deriving an MRL: No human or animal studies were located that examined intermediate duration inhalation exposure to 3,3’-dichlorobenzidine. Subsequently, no MRL has been derived.

Agency Contacts (Chemical Managers): Custodio Muianga

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3,3’-Dichlorobenzidine
CAS Numbers: | 91-94-1
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL due to the lack of animal studies examining chronic duration inhalation exposure to 3,3’-dichlorobenzidine, and the lack of quantitative human data.

Rationale for Not Deriving an MRL: The available chronic-inhalation studies in humans do not provide quantitative exposure information and primarily evaluate cancer as an endpoint, which cannot be used to derive an MRL (Gadian 1975; Gerarde and Gerarde 1974; MacIntyre 1975; Myslak et al. 1991). No animal studies were located that examined chronic inhalation to 3,3’-dichlorobenzidine.

Agency Contacts (Chemical Managers): Custodio Muianga

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3,3’-Dichlorobenzidine
CAS Numbers: | 91-94-1
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for 3,3’-dichlorobenzidine due to the lack of quantitative exposure-response data in humans or animals.

Rationale for Not Deriving an MRL: No human studies examined acute-duration oral exposure to 3,3’-dichlorobenzidine; therefore, insufficient data exist to derive an MRL. The available animal studies evaluate genotoxicity (Ashby and Mohammed 1988; Cihak and Vontorkova 1987; Ghosal and Iba 1990). Gerarde and Gerarde (1974) and Gaines and Nelson (as cited in EPA 1980a) only reported LD_50_ values in animals following acute-duration oral exposure. There was an overall lack of suitable data to derive an MRL.

Agency Contacts (Chemical Managers): Custodio Muianga

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3,3’-Dichlorobenzidine
CAS Numbers: | 91-94-1
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL for 3,3’-dichlorobenzidine due to the lack of studies on humans and the lack of exposure-response data in animals.

Rationale for Not Deriving an MRL: No human studies were located examining oral intermediate-duration exposure to 3,3’-dichlorobenzidine. Oral intermediate-duration studies on animals primarily evaluated the cancer endpoint, with no other effects reported (Griswold et al. 1968; Ito et al. 1983; Osanai 1976; Pliss 1959, 1963). No MRL is derived due to the lack of suitable data.

Agency Contacts (Chemical Managers): Custodio Muianga

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3,3’-Dichlorobenzidine
CAS Numbers: | 91-94-1
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for 3,3’-dichlorobenzidine due to the lack of studies in humans and animals examining noncancer endpoints.

Rationale for Not Deriving an MRL: No human studies were located that examined noncancer endpoints in humans following chronic-duration oral exposure to 3,3’-dichlorobenzidine. Chronic-duration oral studies in animals examine carcinogenic effects in rats and dogs (Stula et al. 1975, 1978). Stula et al. (1978) reported convulsions and neuronal degeneration in one of six dogs; however, this endpoint is a serious LOAEL, and therefore, no MRL can be derived using this endpoint.

Agency Contacts (Chemical Managers): Custodio Muianga