# 9 REFERENCES

* Cited in text

*Aaron CK, Howland MA, eds. 1994. Goldfrank's toxicologic emergencies. Norwalk, CT: Appleton and Lange.
*ACGIH. 1996. Threshold limit values for chemical substances and physical agents and biological indices for 1995/1996. Dichlorobenzenes. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 18–19.
*ACGIH. 2001. Documentation of the threshold limit values and biological exposure indices. 7th ed. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
*ACGIH. 2005. Threshold limit values for chemical substances and physical agents and biological exposure indices. 2003 TLVs and BEIs. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 25.
*Adgate JL, Eberly LE, Stroebel C, 2004. Personal, indoor, and outdoor VOC exposures in a probability sample of children. J Expo Anal Environ Epidemiol 14:S4–S13.15118740
*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect 103(7):103–112.
*Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Atlanta, GA: Agency for Toxic Substances and Disease Registry, Division of Toxicology.
*Agency for Toxic Substances and Disease Registry/CDC. 1990. Subcommittee report on biological indicators of organ damage. Atlanta, GA: Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention.
*Aiso S. 2006. Written communication (June 28) to Stephen Bosch, Syracuse Research Corporation, regarding testicular mineralization in mice in 2-year inhalation study of 1,4-DCB.
*Aiso S, Arito H, Nishizawa T, 2005a. Thirteen-week inhalation toxicity of p-dichlorobenzene in mice and rats. J Occup Health 47(3):249–260.15953847
*Aiso S, Takeuchi T, Arito H, 2005b. Carcinogenicity and chronic toxicity in mice and rats exposed by inhalation to para-dichlorobenzene for two years. Toxicology 67:1019–1029.
Alarie Y, Nielsen GD, Andonian-Haftvan J, 1995. Physicochemical properties of nonreactive volatile organic chemicals to estimate RD50: Alternatives to animal studies. Toxicol Appl Pharmacol 134(1):92–99.7676461
Alarie Y, Schaper M, Nielsen GD, 1996. Estimating the sensory irritating potency of airborne nonreactive volatile organic chemicals and their mixtures. SAR QSAR Environ Res 5:151–165.9114512
Alarie Y, Schaper M, Nielsen GD, 1998. Structure-activity relationships of volatile organic chemicals as sensory irritants. Arch Toxicol 72(3):125–140.9520136
*Albrechtsen H-J, Smith PM, Nielsen P, 1997. Importance of sediment fines in laboratory studies on the degradation of organic chemicals in aquifers. Water Res 31(9):2287–2299.
Alexander M, Lustigman BK. 1966. Effects of chemical structure on microbial degradation of substituted benzenes. J Agric Food Chem 14:410–413.
*Allis JW, Simmons JE, House DE, 1992. The differential hepatotoxicity and cytochrome P450 responses of Fischer-344 rats to the three isomers of dichlorobenzene. J Biochem Toxicol 7(4):257–264.1293313
Almeida CM, Boas LV. 2003. Analysis of BTEX and other substituted benzenes in water using headspace SPME-GC-FID: Method validation. J Environ Monit 6(1):80–88.14737474
*Altman PK, Dittmer DS. 1974. In: Biological handbooks: Biology data book, Volume III, second edition. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
Ambre J, Ruo TI, Smith-Coggins R. 1986. Mothball composition: Three simple tests for distinguishing paradichlorobenzene from naphthalene. Ann Emerg Med 15:724–726.3706864
*Amoore JE, Hautala E. 1983. Odor as an aid to chemical safety: Odor thresholds compared with threshold limit values and volatilities for 214 industrial chemicals in air and water dilution. J Appl Toxicol 3:272–290.6376602
*Andersen ME, Krishman K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives. New York, NY: Marcel Dekker, Inc., 9–25.
*Andersen ME, Clewell HJ III, Gargas ML, 1987. Physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York: Marcel Dekker Inc., 9–25.
*Andersen ME, MacNaughton MG, Clewell HJ, 1987. Adjusting exposure limits for long and short exposure periods using a physiological pharmacokinetic model. Am Ind Hyg Assoc J 48(4):335–343.3591649
*Anderson D. 1976. Paradichlorobenzene: Estimation of its mutagenic potential in the Salmonella typhimurium plate incorporation mutagenicity assay. ICI Report No. CTL/P/298.
Anderson EL. 1983a. Quantitative approaches in use to assess cancer risk. Risk Anal 3:377–295.
Anderson GE. 1983b. Human exposure to atmospheric concentrations of selected chemicals. Vol. 2. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB83265249.
*Anderson D, Hodge MC. 1976. Paradichlorobenzene: Dominant lethal study in the mouse. ICI Report No. CTL/P/296.
*Anderson D, Richardson CR. 1976. Paradichlorobenzene: Cytogenic study in the rat. ICI Report No. CTL/P/293.
*Anderson BE, Zeigler E, Shelby MD, 1990. Chromosome aberration and sister chromatid exchange test results with 42 chemicals. Environ Mol Mutagen 16(18):55–137.2091924
Anderson KJ, Leighty EG, Takahashi MT. 1972. Evaluation of herbicides for possible mutagenic properties. J Agric Food Chem 20:649–656.4561194
Anonymous. 1988. Ortho-, meta, and para-dichlorobenzene. Rev Environ Contam Toxicol 106:51–68.3059415
Anonymous. 1992. Notice of intended changes- o-dichlorobenzene, dimethylamine, and dinitrotoluene. Appl Occup Environ Hyg 7(1):55–58.
Anonymous. 2004. Safety assessment of MIBK (methyl isobutyl ketone). Int J Toxicol 23(Suppl 1):29–57.15162837
Antoine SR, DeLeon IR, O'Dell-Smith RM. 1986. Environmentally significant volatile organic pollutants in human blood. Bull Environ Contam Toxicol 36:364–371.3955247
APHA. 1977. Methods of air sampling and analysis. 2nd ed. Washington, DC: American Public Health Association, 894–902.
APHA. 1989. Standard methods for the examination of water and wastewater. 17th ed. Washington, DC: American Public Health Association.
*APHA. 1995a. Standard methods for the examination of water and wastewater. 19th ed. Washington, DC: American Public Health Association. 6210 B.
APHA. 1995b. Standard methods for the examination of water and wastewater. 19th ed. Washington, DC: American Public Health Association. 6210 C.
APHA. 1995c. Standard methods for the examination of water and wastewater. 19th ed. Washington, DC: American Public Health Association. 6210 D.
APHA. 1995d. Standard methods for the examination of water and wastewater. 19th ed. Washington, DC: American Public Health Association. 6220 B.
APHA. 1995e. Standard methods for the examination of water and wastewater. 19th ed. Washington, DC: American Public Health Association. 6220 C.
APHA. 1995f. Standard methods for the examination of water and wastewater. 19th ed. Washington, DC: American Public Health Association. 6230 B.
APHA. 1995g. Standard methods for the examination of water and wastewater. 19th ed. Washington, DC: American Public Health Association. 6230 C.
APHA. 1995h. Standard methods for the examination of water and wastewater. 19th ed. Washington, DC: American Public Health Association. 6230 D.
*APHA. 1998. Standard methods for the examination of water and wastewater. 20th ed. Washington, DC: American Public Health Association. 6200B. Purge and trap capillary-column gas chromatographic/mass spectrometric method.
*Apodaca LE, Bails JB, Smith CM. 2002. Water quality in shallow alluvial aquifers, upper Colorado River Basin, Colorado, 1997. J Am Water Res Assoc 38(1):133–149.
*Ariyoshi T, Ideguchi K, Iwasaki K, 1975. Relationship between chemical structure and activity. II. Influences of isomers of dichlorobenzene, trichlorobenzene and tetrachlorobenzene on the activities of drug-metabolizing enzymes. Chem Pharm Bull 23:824–830.
*Ashley DL, Bonin MA, Cardinali FL, 1992. Determining volatile organic compounds in human blood from a large sample population by using purge and trap gas chromatography/mass spectrometry. Anal Chem 64(9):1021–1029.1590585
*Ashley DL, Bonin MA, Cardinali FL, 1994. Blood concentrations of volatile organic compounds in a nonoccupationally exposed US population and in groups with suspected exposure. Clin Chem 40(7):1401–1404.8013127
*Ashley DL, Bonin MA, Cardinali FL, 1996. Measurement of volatile organic compounds in human blood. Environ Health Perspect 104:871–877.8933028
*Ashley DL, Bonin MA, Hamar B, 1995. Removing the smoking confounder from blood volatile organic compounds measurements. Environ Res 71(1):39–45.8757237
*ASTER. 1995. ASTER (Assessment Tools for the Evaluation of Risk) ecotoxicity profile. Duluth, MN: U.S. Environmental Protection Agency. Environmental Research Laboratory.
*ASTM. 1994. Standard test method for purgeable organic compounds in water using headspace sampling. Section 11. Water and Environmental Technology. 11.02:204–207.
Astrand I. 1975. Uptake of solvents in the blood and tissues of man: A review. Scand J Work Environ Health 1:199–208.779027
*Atkinson R. 1989. Kinetics and mechanisms of the gas-phase reactions of the hydroxyl radical with organic compounds. J Phys Chem Ref Data 1:218–219.
Axelrad DA, Morello-Frosch RA, Woodruff TJ, 1999. Assessment of estimated 1990 air toxics concentrations in urban areas in the United States. Environ Sci Policy 2:397–411.
*Azouz WM, Parke DV, Williams RT. 1955. Studies in detoxication. The metabolism of halogenobenzenes. Ortho- and para-dichlorobenzenes. Biochem J 59:410–415.14363109
*Backer LC, Egeland GM, Ashley DL, 1997. Exposure to regular gasoline and ethanol oxyfuel during refueling in Alaska. Environ Health Perspect 105(8):850–855.9347900
Baehr AL, Stackelberg PE, Baker RJ. 1999. Evaluation of the atmosphere as a source of volatile organic compounds in shallow groundwater. Water Resource Res 35:127–136.
*Bahnick DA, Doucette WJ. 1988. Use of molecular connectivity indices to estimate soil sorption coefficients for organic chemicals. Chemosphere 17:1703–1715.
Bahrami F, Bergman U, Brittebo EB, 2000. Persistent olfactory mucosal metaplasia and increased olfactory bulb glial fibrillary acidic protein levels following a single dose of methylsulfonyl-dichlorobenzene in mice: Comparison of the 2,4- and 2,5-dichlorinated isomers. Toxicol Appl Pharmacol 162(1):49–59.10631127
Bahrami F, Brittebo EB, Bergman A, 1999. Localization and comparative toxicity of methylsulfonyl-2,5- and 2,6-dichlorobenzene in the olfactory mucosa of mice. Toxicol Sci 49(1):116–123.10367349
Bahrami F, van Hezik C, Bergman A, 2000. Target cells for methylsulphonyl-2,6-dichlorobenzene in the olfactory mucosa in mice. Chem Biol Interact 128:97–113.11024450
Ballschmiter K, Scholz C. 1980. Microbial decomposition of chlorinated aromatic substances. VI. Formation of dichlorophenols and dichloropyrocatechol from dichlorobenzenes in a micromolar solution by Pseudomonas species. Chemosphere 9:457–467.
Ban M, Hettich D, Goutet M, 1998. Serum-borne factor(s) of 1,1-dichloroethylene and 1,2-dichlorobenzene-treated mice inhibited in vitro antibody forming cell response and natural killer cell activity. Toxicol Lett 94:93–101.9574806
Banerjee S, Yalkowsky SH, Valvani SC. 1980. Water solubility and octanol/water coefficients of organics. Limitations of the solubility-partition coefficient correlation. Environ Sci Technol 14(10):1227–1229.
Barkley J, Bunch J, Bursey JT, 1980. Gas chromatography mass spectrometry computer analysis of volatile halogenated hydrocarbons in man and his environment - A multimedia environmental study. Biomed Mass Spectrom 7(4):139–147.7448328
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Barter JA, Sherman JH. 1999. An evaluation of the carcinogenic hazard of 1,4-dichlorobenzene based on internationally recognized criteria. Regul Toxicol Pharmacol 29:64–79.10051419
Bellar TA, Lichtenberg JJ, Kroner RC. 1974. The occurrence of organohalides in chlorinated drinking waters. J Am Water Works Assoc 66:703–706.
*Ben-Dyke R, Sanderson DM, Noakes DN. 1970. Acute toxicity for pesticides (1970). World Rev Pest Control 9:119–127.
*Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis. Advanced management and surgical techniques. New York, NY: Springer-Verlag.
*Bevan MA J, Proctor CJ, Baker-Rogers J, 1991. Exposure to carbon monoxide, respirable suspended particulates, and volatile organic compounds while commuting by bicycle. Environ Sci Technol 25:788–791.
*Bio/dynamics. 1989. An inhalation two-generation reproduction study in rats with orthodichlorobenzene. Project No. 87–3157. Washington, DC: Chemical Manufacturers Association.
*Bogaards JJ P, VanOmmen B, Wolf CR, 1995. Human cytochrome P450 enzyme selectives in the oxidation of chlorinated benzenes. Toxicol Appl Pharmacol 132:44–52.7747284
*Bomhard E, Luckhaus G, Voight WH, 1988. Induction of light hydrocarbon nephropathy by p-dichlorobenzene. Arch Toxicol 61:433–439.2903729
Bomhard EM, Schmidt U, Loser E. 1998. Time course of enzyme induction in liver and kidneys and absorption, distribution and elimination of 1,4-dichlorobenzene in rats. Toxicology 131:73–91.9928623
*Bonanno LJ, Freeman NCG, Greenberg M, 2001. Multivariate analysis on levels of selected metals, particulate matter, VOC, and household characteristics and activities from the midwestern states NHEXAS. Appl Occup Environ Hyg 16(9):859–874.
*Bonnet P, Morele Y, Raoult G, 1982. Determination de la concentration lethale_50_ des principaux hydrocarbures aromatiques chez le rat. Arch Mal Prof 43:261–265.
*Borghoff SJ, Andersen ME, Conolly RB. 1991. Protein nephropathy and kidney cancer in male rats: Qualitative and quantitative issues and human relevance. CIIT Activities 11(1):107.
*Bornatowicz N, Antes A, Winker N. 1994. 2-generational reproduction study with 1,4-dichlorobenzol in rats. Wierner klinische Wochenschrift [Vienna Clinical Weekly] 106/11:345–353.
*Bosma TMP, te Wescher RAG, Schraa G. 1990. Microbial aspects of the behaviour of chlorinated compounds during soil passage. Proceedings of the 6^th^ European Symposium on organic micropollutants in the aquatic environment. Lisbon, Portugal, May 22–24, 1990.
*Bouwer EJ, McCarty PL. 1982. Removal of trace chlorinated organic compounds by activated carbon and fixed-film bacteria. Environ Sci Technol 16:836–843.22236258
*Bouwer EJ, McCarty PL. 1983. Transformations of halogenated organic compounds under dentrification conditions. Appl Environ Microbiol 45:1295–1299.6859850
*Bouwer EJ, McCarty PL. 1984. Modeling of trace organics biotransformation in the subsurface. Ground Water 22:433–440.
*Bozzelli JW, Kebbekus BB. 1979. Analysis of selected volatile organic substances in ambient air. New Jersey Department of Environmental Protection, Program on Environmental Cancer and Toxic Substances.
Bozzelli JW, Kebbekus BB. 1982. A study of some aromatic and halocarbon vapors in the ambient atmosphere of New Jersey. J Environ Sci Health A 17:693–713.
Brantley AS, Townsend TG. 1999. Leaching of pollutants from reclaimed asphalt pavement. Environ Eng Sci 16(2):105–116.
*Bristol DW, Crist HL, Lewis RG, 1982. Chemical analysis of human blood for assessment of environmental exposure to semivolatile organochlorine chemical contaminants. J Anal Toxicol 6:269–275.6819409
Brodzinsky R, Singh HB. 1983. Volatile organic chemicals in atmosphere: An assessment of available data. Research Triangle Park, NC: U.S. Environmental Protection Agency, Environmental Research Laboratory. EPA600383027(A).
Brondeau MT, Ban M, Bonnet P, 1986. Concentration-related changes in blood and tissue parameters of hepatotoxicity and their interdependence in rats exposed to bromobenzene and 1,2-dichlorobenzene. Toxicol Lett 31:159–166.3012827
Brondeau MT, Ban M, Bonnet P, 1989. Acetone compared to other ketones in modifying the hepatotoxicity of inhaled 1,2-dichlorobenzene in rats and mice. Toxicol Lett 49:69–78.2554539
Brondeau MT, Bonnet P, Gueniuer JP, 1983. Short-term inhalation test for evaluating industrial hepatotoxicants in rats. Toxicol Lett 19:139–146.6658818
*Brondeau MT, Bonnet P, Guenier JP, 1990. Adrenal-dependent leucopenia after short-term exposure to various airborne irritants in rats. J Appl Toxicol 10(2):83–86.2362083
Brondeau MT, Hesbert A, Beausoleil C, 1999. To what extent are biomonitoring data available in chemical risk assessment? Hum Exp Toxicol 18:322–326.10372754
*Brown KW, Donnelly KC. 1988. An estimation of the risk associated with the organic constituents of hazardous and municipal waste landfill leachates. Haz Waste Haz Mater 5:1–30.
*Brown SK, Sim MR, Abramson MJ, 1994. Concentrations of volatile organic compounds in indoor air- a review. Indoor Air 4:123–134.
*Bruce BW, McMahon PB. 1996. Shallow ground-water quality beneath a major urban center: Denver, Colorado, USA. J Hydrol 186:129–151.
Brunce N, Kumar Y, Ravanal L, 1978. Photochemistry of chlorinated byphenyls in iso-octane solution. J Chem Soc Perkin Transact II, 880–884.
*Buckley TJ, Liddle J, Ashley DL, 1997. Environmental and biomarker measurements in nine homes in the lower Rio Grande Valley: Multimedia results for pesticides, metals, PAHs, and VOCs. Environ Int 23(5):705–732.
*Bush B, Smith RM, Narang AS, 1984. Photoionization conductivity detection limits for environmental pollutants with and without chromophores. Anal Lett 17:467–547.
*Campbell DM, Davidson RJ. 1970. Toxic haemolytic anemia in pregnancy due to a pica for paradichlorobenzene. J Obstet Gynaecol Br Commonw 77:657–659.5270568
*Canonero R, Campart GB, Mattioli F, 1997. Testing of p-dichlorobenzene and hexachlorobenzene for their ability to induce DNA damage and micronucleus formation in primary cultures of rat and human hepatocytes. Mutagenesis 12(1):35–39.9025095
*Carbonell E, Puig N, Creus A, 1991. Sister-chromatid exchanges (SCE) induced by p-dichlorobenzene in cultured human lymphocytes. Mutat Res 263:57–59.2034241
*Carlson GP. 1977. Chlorinated benzene induction of hepatic porphyria. Experientia 33:1627–1629.590457
*Carlson GP, Tardiff R. 1976. Effect of chlorinated benzenes on the metabolism of foreign organic compounds. Toxicol Appl Pharmacol 36:383–394.1273854
Carlsson C, Fredriksson A, Brandt I. 2003. 2,6-Dichlorophenyl methylsulphone induced behavioural impairments in rats and mice in relation to olfactory mucosal metaplasia. Pharmacol Toxicol 93(4):156–168.14629739
CCRIS. 1990. Chemical Carcinogenesis Research Information Systems. Bethesda, MD: National Library of Medicine. July 6, 1990.
CESARS. 1990. Chemical Evaluation Search and Retrieval System. Baltimore, MD: Chemical Information Systems, Inc. July 26, 1990.
*Chan CC, Valner L, Martin JW, 1990. Determination of organic contaminants in residential indoor air using an adsorption-thermal desorption technique. J Air Waste Manage Assoc 40:62–67.2306363
*Chapman PM, Downie J, Maynard A. 1996a. Coal and deodorizer residues in marine sediments contaminants or pollutants. Environ Toxicol Chem 15(5):638–642.
*Chapman PM, Paine MD, Arthur AD, 1996b. A triad study of sediment quality associated with a major, relatively untreated marine sewage discharge. Mar Pollut Bull 32(1):47–64.
*Charbonneau M, Short B, Lock E, 1987. Mechanism of petroleum-induced sex-specific protein droplet nephropathy and renal cell proliferation in Fischer-344 rats: Relevance to humans. In: Hemphill DD, ed. Trace substances in environmental health, 21st Annual Conference, St. Louis, MO. Columbia, MO: University of Missouri, 263–273.
*Charbonneau M, Strasser J, Lock EA, 1989a. 1,4-Dichlorobenzene-induced nephrotoxicity: Similarity with unleaded gasoline (UG)-induced renal effects. In: Bach P, Lock EA, eds. Nephrotoxicity: In vitro to in vivo. Animals to man. New York, NY: Plenum Press, 557–562.
*Charbonneau M, Strasser J, Lock EA, 1989b. Involvement of reversible binding to α2μ-globulin in 1,4-dichlorobenzene-induced nephrotoxicity. Toxicol Appl Pharmacol 99:122–132.2471290
Chemline. 1990. Chemical dictionary online. Bethesda, MD: National Library of Medicine, National Toxicology Information Program. July 5, 1990.
*Chen CS, Zoltek J. 1995. Organic priority pollutants in wetland-treated leachates at a landfill in central Florida. Chemosphere 31(6):3455–3464.
*Chiou CT. 1985. Partition coefficients of organic compounds in lipid-water systems and correlations with fish bioconcentration factors. Environ Sci Technol 19:57–62.
Chiou CT, Freed VH, Schmedding DW, 1977. Partition coefficient and bioaccumulation of selected organic chemicals. Environ Sci Technol 11:475–478.
*Chiou CT, Porter PE, Schmedding DW. 1983. Partition equilibria of nonionic organic compounds between soil organic matter and water. Environ Sci Technol 17:227–231.22304639
*Chung HY. 1999. Volatile components in crabmeats of Charybdis feriatus. J Agric Food Chem 47:2280–2287.10794623
*CITI. 1992. o-Dichlorobenzene and 1,3-Dichlorobenzene. In: Biodegradation and bioaccumulation data of existing chemicals based on the CSCL Japan. Chemicals Inspection and Testing Institute, 3-11–3-12.
Clayton GD, Clayton FE, eds. 1981. Patty's industrial hygiene and toxicology. 3rd ed. Vol. 2B, Toxicology. New York: John Wiley and Sons, Inc., 3617.
*Clewell HJIII, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1:111–113.3843496
CLPSD. 1990. Contract Laboratory Program Statistical Database. Viar and Company, Management Service Division, Alexandria, VA. July 1990.
*CMR. 1990. Chemical profile: p-dichlorobenzene. Chemical Marketing Reporter, July 16, 1990.
*CMR. 1996. Chemical profile. o-dichlorobenzene. Chemical Marketing Reporter. September 09, 1996.
*CMR. 1999. Chemical profile. p-dichlorobenzene. Chemical Market Reporter. June 07, 1999.
Cohen S, Svrjcek A, Durborrow T, 1999. Ground water quality: Water quality impacts by golf courses. J Environ Qual 28:798–809.
*Colacci A, Bartoli S, Bonora B, 1990. In vivo and in vitro interaction of 1,2-dichlorobenzene with nucleic acids and proteins of mice and rats. Tumori 76:339–344.1697992
*Colborn T, Clement C, eds. 1992. Chemically-induced alterations in sexual and functional development: The wildlife human connection. In: Advances in modern environmental toxicology, Vol. XXI, Princeton, NJ: Princeton Scientific Publishing.
*Colborn T, vom Saal FS, Soto AM. 1993. Developmental effects of endocrine-disrupting chemicals in wildlife and humans. Environ Health Perspect 101(5):378–384.8080506
*Cole RH, Frederick RE, Healy RP, 1984. Preliminary findings of the priority pollutant monitoring project of the nationwide urban runoffprogram. J Water Pollut Control Fed 56:898–908.
Coleman WE, Lingg RD, Melton RG, 1975. The occurrence of volatile organics in five drinking water supplies using gas chromatography/mass spectrometry. In: Keith LW, ed. Identification and analysis of organic pollutants in water. Ann Arbor, MI: Ann Arbor Science Publishers, Inc., 305–327.
Cone MV, Baldauf MF, Opresko DM, 1983. Chemicals identified in human breast milk, a literature search. Oak Ridge National Laboratory report under EPA/DOE IAG No. DW930139–01-1. Office of Pesticides and Toxic Substances. EPA560583009.
*Coniglio WA, Miller K, MacKeever D. 1980. The occurrence of volatile organics in drinking water. Washington, DC: U.S. Environmental Protection Agency, Criteria and Standards Division.
*Connor TH, Theiss JC, Hanna HA, 1985. Genotoxicity of organic chemicals frequently found in the air of mobile homes. Toxicol Lett 25:33–40.3887653
*Cotter LH. 1953. Paradichlorobenzene poisoning from insecticides. NY State J Med (July 15):1690–1692.
Cramer PH, Boggess KE, Hosenfeld JM, 1988. Determination of organic chemicals in human whole blood: Preliminary method development for volatile organics. Bull Environ Contam Toxicol 40:612–618.3370355
CRIS/USDA. 1990. Current Research Information System. Palo Alto, CA: U.S. Department of Agriculture. Dialog Information Systems, Inc. July 6, 1990.
*Crisp TM, Clegg ED, Cooper RL, 1998. Environmental endocrine disruption: An effects assessment and analysis. Environ Health Perspect 106(1):11–56.9539004
Cuppit LT. 1980. Fate of toxic and hazardous materials in the air environment. Research Triangle Park, NC: U.S. Environmental Protection Agency, Environmental Sciences Research Laboratory. PB80221948.
Daft JL. 1989. Determination of fumigants and related chemicals in fatty and nonfatty foods. J Agric Food Chem 37:560–564.
*Daston GP, Gooch JW, Breslin WJ, 1997. Environmental estrogens and reproductive health: A discussion of the human and environmental data. Reprod Toxicol 11(4):465–481.9241667
*Daubert TE, Danner RP. 1992. 1,4-Dichlorobenzene. In: Physical and thermodynamic properties of pure chemicals. Part 3. Philadelphia, PA: Taylor & Francis.
*Davies K. 1988. Concentrations and dietary intake of selected organochlorines, including PCBs, PCDDs and PCDFs in fresh food composites grown in Ontario, Canada. Chemosphere 17(2):263–276.
Deceaurriz J, Gagnaire F, Ban M, 1988. Assessment of the relative hazard involved with airborne irritants with additional hepatotoxic or nephrotoxic properties in mice. J Appl Toxicol 8:417–422.2852685
Deichmann WB, Mergard EG. 1948. Comparative evaluation of methods employed to express the degree of toxicity of a compound. J Ind Hyg Toxicol 30:373–378.18100368
*Delfino RJ, Gong H Jr., Linn WS, 2003. Asthma symptoms in Hispanic children and daily ambient exposures to toxic and criteria air pollutants. Environ Health Perspect 111(4):647–656.12676630
*DeMarini DM, Brooks HG. 1992. Induction of phophage lambda by chlorinated organics: Detection of some single-species/single-site carcinogens. Environ Mol Mutagen 19:98–111.1531793
*Den Besten C, Ellenbroek M, Van Der Ree MAE, 1992. The involvement of primary and secondary metabolism in the covalent binding of 1,2 and 1,4,-dichlorobenzenes. Chem Biol Interact 84:259–275.1423744
*Den Besten C, Jurgen JRM, Besselink HT, 1991. The liver, kidney, and thyroid toxicity of chlorinated benzenes. Toxicol Appl Pharmacol 111:69–81.1949037
*DHHS. 1995. Report to Congress on workers' home contamination study conducted under the workers' family protection act (29 USC. 671a). Cincinnati, OH: U.S. Department of Health and Human Services. National Institute for Occupational Safety and Health.
*Dietrich DR, Swenberg JA. 1991. NCI-black-Reiter (NBR) male rats fail to develop renal disease following exposure to agents that induce delta-2μ-globulin (2μ) nephropathy. Fundam Appl Toxicol 16:749–762.1715830
DOT. 1990a. Department of Transportation. Code of Federal Regulations. 49 CFR 172.101.
DOT. 1990b. Department of Transportation. Code of Federal Regulations. 49 CFR 172.101, App. A.
DOT. 1990c. Department of Transportation. Code of Federal Regulations. 49 CFR 172.101, App. B.
Dowty BJ, Carlisle DR, Laseter JL. 1975. New Orleans drinking water sources tested by gas chromatography-mass spectrometry. Environ Sci Technol 9:762–765.
*Dreisbach RH, ed. 1987. Handbook of poisoning. Norwalk, CT: Appleton and Lange.
*Dressman RC, Fair J, McFarren EF. 1977. Determinative method for analysis of aqueous sample extracts for bis(2-chloro)ethers and dichlorobenzenes. Environ Sci Technol 11:719–721.
Dunovant VS, Clark CS, Que Hee SS, 1986. Volatile organics in the wastewater and airspaces of three wastewater treatment plants. J Water Pollut Control Fed 58:886–895.
*DuPont. 1982. Comparative toxicity of ortho dichlorobenzene (ODCB) and trichlorobenzene (TCB). E.I. DuPont Denemours and Company, Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0215033.
*Edelman P, Osterloh J, Pirkle J, 2003. Biomonitioring of chemical exposure among New York City firefighters responding to the world trade center fire and collapse. Environ Health Perspect 111(16):1906–1911.14644665
*Eganhouse RP, Cozarelli IM, Scholl MA, 2001. Natural attenuation of volatile organic compounds (VOC's) in the leachate plume of a municipal landfill: Using alkylbenzenes as process probes. Ground Water 39:192–202.11286066
Eguchi K, Ozawa M, Endoh YS, 2003. Validity test for a yeast two-hybrid assay to screen for estrogenic activity and its application to insecticides and disinfectants for veterinary use. Bull Environ Contam Toxicol 70(2):226–232.12545352
*Eitzer BD. 1995. Emissions of volatile organic chemicals from municipal solid waste composting facilities. Environ Sci Technol 29:896–902.22176396
*Eklund B, Anderson EP, Walker BL, 1998. Characterization of landfill gas composition at the fresh kills municipal solid-waste landfill. Environ Sci Technol 32(32):2233–2237.
Elcombe CR, Odum J, Foster JR, 2002. Prediction of rodent nongenotoxic carcinogenesis: evaluation of biochemical and tissue changes in rodents following exposure to nine nongenotoxic NTP carcinogens. Environ Health Perspect 110(4):363–375.
*Elder VA, Proctor BL, Hites RA. 1981. Organic compounds found near dump sites in Niagara Falls, NY. Environ Sci Technol 15:1237–1243.22299705
*Eldridge SR, Goldsworthy TL, Popp JA. 1992. Mitogenic stimulation of hepatocellular proliferation in rodents following 1,4 dichlorobenzene administration. Carcinogenesis 13(3):409–415.1547531
*Eldridge SR, Tilbury LF, Goldsworthy TL, 1990. Measurement of chemically induced cell proliferation in rodent liver and kidney: A comparison of 5-bromo-2'-deoxyuridine and [3H]thymidine administered by injection or osmotic pump. Carcinogenesis 11(12):2245–2251.2265476
Elkilani AS, Baker CGJ, Al-Shammari QH, 2003. Sorption of volatile organic compounds on typical carpet fibers. Environ Int 29:575–585.12742400
*Elkins HB. 1950. The chemistry of industrial toxicology. New York, NY: John Wiley and Sons, Inc., 147, 205–206, 221–223. (As cited in Hollingsworth et al. 1958)
*Ellenhorn MJ, Barceloux DG, eds. 1997. Medical toxicology: Diagnosis and treatment of human poisoning. New York, NY: Elsevier Publishing.
*Elliot L, Longnecker MP, Kissling GE, 2006. Volatile organic compounds and pulmonary function in the Third National Health and Nutrition Examination Survey, 1988–1994. Environ Health Perspect 114(8):1210–1214.16882527
*Elovaara E. 1998. Dichlorobenzenes. The Nordic expert group for criteria documentation of health risks from chemicals. In: Arbete och Halsa. Soina, Sverige: Arbetslivsinstitutet & Forfattarna, 1–76.
EPA. 1975. Identification of organic compounds in effluents from industrial sources. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances.
EPA. 1977. Investigation of selected potential environmental contaminants: Halogenated benzenes. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA560277004.
EPA. 1978. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4.
EPA. 1979a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 401.15.
EPA. 1979b. Water-related environmental fate of 129 priority pollutants. Vol. I. Introduction and technical background, metals and inorganics, pesticides and PCBs. Washington, DC: U.S. Environmental Protection Agency, Office of Water Planning and Standards. EPA440479029A. PB80204373.
*EPA. 1980a. Ambient water quality criteria for dichlorobenzenes. Washington, DC: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office for the Office of Water Regulations and Standards. EPA440580039.
EPA. 1980b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.33.
*EPA. 1981a. An exposure and risk assessment for dichlorobenzenes. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards.
*EPA. 1981b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 413.02.
*EPA. 1981c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, App. VII.
EPA. 1982a. Chlorinated hydrocarbons. Test method - method 612. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory.
EPA. 1982b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 712.30.
EPA. 1982c. Purgeables. Test method - method 624. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory.
EPA. 1982d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 423.17 and Appendix A.
EPA. 1982e. Purgeable halocarbons: Test method - method 601. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory.
EPA. 1982f. Test method - Base/neutrals and acids. Method-625. In: Method for determination of organic compounds in drinking water. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory. EPA600782039.
EPA. 1982g. U.S. Environmental Protection Agency. Fed Regist 47:26992, 27007–27008.
EPA. 1982h. 1,4-Dichlorobenzene. In: Kayser R, Sterling D, Viviani D, eds. Intermedia priority pollutant guidance documents. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances.
EPA. 1982i. Purgeable aromatics. Test method - method 602. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory.
*EPA. 1983a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 60.489.
*EPA. 1983b. Chemicals identified in human breast milk. A literature search. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances. EPA560583009.
EPA. 1983c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 122, App. D.
EPA. 1983d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 433.11.
EPA. 1983e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, App. III.
EPA. 1983f. Methods for chemical analysis of water and wastes. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development, Environmental Monitoring and Support Laboratory. EPA600479020.
EPA. 1983g. Treatability manual. Vol. I. Treatability data. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. EPA600282001a.
*EPA. 1984a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 125.
*EPA. 1984b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136, App. A.
*EPA. 1984c. Method 612. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136.
*EPA. 1984d. Method 624. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136.
EPA. 1984e. Method 601. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136.
EPA. 1984f. Method 602. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136.
*EPA. 1985a. Health assessment document for chlorinated benzenes. Final report. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA600884015F.
*EPA. 1985b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3.
*EPA. 1985c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
*EPA. 1985d. Atmospheric fates of organic chemicals: Prediction of ozone and hydroxyl radical reaction rates and mechanisms. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development. EPA600385063.
EPA. 1986a. Aromatic volatile organics - method 8020. In: Test methods for evaluating solid waste. 3rd ed. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1986b. Gas chromatography/mass spectrometry for semivolatile organics: Capillary column technique-method 8270. In: Test methods for evaluating solid waste. 3rd ed. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
*EPA. 1986c. Halogenated volatile organics - method 8010. In: Test methods for evaluating solid waste. 3rd ed. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
*EPA. 1986d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 403. App. B.
EPA. 1986e. Identification of wastes to be evaluated by May 8, 1990. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.12.
EPA. 1986f. Broad scale analysis of the FY 82 national human adipose tissue survey specimens. Volume II: Volatile organic compounds. Washington, DC: U.S. Environmental Protection Agency. Office of Toxic Substances. EPA560586036.
EPA. 1986g. Superfund public health evaluation manual. Washington, DC: U.S. Environmental Protection Agency: Office of Emergency and Remedial Response. EPA540186060.
EPA. 1986h. Volatile aromatic and unsaturated organic compounds in water by purge and gas trap chromatography. Method 503.1. In: Methods for the determination of organic compounds in drinking water. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory. EPA600488039.
*EPA. 1987a. Health effects assessment for dichlorobenzene. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. EPA600888028. PB88179387.
EPA. 1987b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.32.
*EPA. 1987c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 414.25.
*EPA. 1987d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 414.35.
*EPA. 1987e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 414.45.
*EPA. 1987f. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 414.55.
*EPA. 1987g. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 414.65.
*EPA. 1987h. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 414.75.
*EPA. 1987i. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 414.85.
*EPA. 1987j. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 414.91.
*EPA. 1987k. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 414.101.
EPA. 1987l. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264, App. IX.
EPA. 1987m. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268, App. III.
EPA. 1987n. Preliminary use and substitutes analysis of para-dichlorobenzene. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances.
EPA. 1987o. The total exposure assessment methodology (TEAM) study: Summary and analysis: Volume I. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. EPA600687002a.
EPA. 1987p. Final draft criteria document for ortho-dichlorobenzene, meta-dichlorobenzene, para-dichlorobenzene. Washington, DC: U.S. Environmental Protection Agency. Criteria and Standards Division, Office of Drinking Water.
*EPA. 1988a. Method T014–1. Compendium of methods for the determination of toxic organic compounds in ambient air. U.S. Department of Commerce. EPA600489017.
*EPA. 1988b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, App. VIII.
*EPA. 1988c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65.
*EPA. 1988d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 716.120.
*EPA. 1988e. Recommendations for and documentation of biological values for use in risk assessment. Cincinnati, OH: U.S. Environmental Protection Agency. PB88179874.
EPA. 1989a. Interim methods for development of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA600888066F.
EPA. 1989b. Measurement of purgeable organic compounds in water by capillary column gas chromatography/mass spectrometry-method 524.2. In: Methods for the determination of organic compounds in drinking water. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory. EPA600488039.
EPA. 1989c. Measurement of purgeable organic compounds in water by packed column gas chromatography/mass spectrometry-method 524.1 In: Methods for the determination of organic compounds in drinking water. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory. EPA600488039.
EPA. 1989d. NHATS broad scan analysis: Population estimates from fiscal year 1982 specimens. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA560590001.
EPA. 1989e. Volatile halogenated organic compounds in water by purge and trap gas chromatography-method 502.1. In: Methods for the determination of organic compounds in drinking water. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring System Laboratory. EPA600488039.
EPA. 1989f. Volatile organic compounds in water by purge and trap capillary column gas chromatography with protoionization and electrolytic conductivity detectors in series-method 502.2. In: Methods for the determination of organic compounds in drinking water. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory. EPA600488039.
EPA. 1990a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.24.
EPA. 1990b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.35.
EPA. 1990c. Standards of performance for volatile organic compounds (VOC) emissions from synthetic organic chemical manufacturing industry (SOCMI) distillation operation. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 60.667.
*EPA. 1990d. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066A.
*EPA. 1991a. Method 502.1. Methods for the determination of organic compounds in drinking water. U.S. Department of Commerce. U.S. Environmental Protection Agency. EPA600488039.
*EPA. 1991b. Method 502.2. Methods for the determination of organic compounds in drinking water. U.S. Department of Commerce. U.S. Environmental Protection Agency. EPA600488039.
*EPA. 1991c. Method 503.1. Methods for the determination of organic compounds in drinking water. U.S. Department of Commerce. U.S. Environmental Protection Agency. EPA600488039.
EPA. 1991d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 258, App. I.
EPA. 1991e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 258, App. II.
EPA. 1991f. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266, App. IV.
EPA. 1991g. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266, App. VII.
EPA. 1991h. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268, App. IV.
*EPA. 1991i. α2μ-Globulin: Association with chemically induced renal toxicity and neoplasia in the male rat. Washington, DC. U.S. Environmental Protection Agency. Risk Assessment Forum. EPA625391019F.
EPA. 1991j. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.61.
EPA. 1991k. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 142.62.
EPA. 1991l. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 257, App. I.
*EPA. 1992a. Method 524.2. Methods for determination of organic compounds in drinking water. Supplement II. U. S. Department of Commerce. EPA600R92129.
EPA. 1992b. Health effects assessment summary tables. Washington, DC: U.S. Environmental Protection Agency, 1–25; 3–12. OERR 9200.6–303(92–1).
EPA. 1993. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 455.50, Tables 4, 5, and 6.
*EPA. 1994a. Method 5030A. Purge-and-trap. U.S. Environmental Protection Agency.
*EPA. 1994b. Method 8010B. Halogenated volatile organics by gas chromatography. U.S. Environmental Protection Agency.
EPA. 1994c. Method 8020A. Aromatic volatile organics by gas chromatography. U.S. Environmental Protection Agency.
EPA. 1994d. Method 8021A. Halogenated volatiles by gas chromatography using photoionization and electrolytic conductivity detectors in series: Capillary column technique. U. S. Environmental Protection Agency, 1–22.
EPA. 1994e. Method 8120A. Chlorinated hydrocarbons by gas chromatography. U.S. Environmental Protection Agency.
*EPA. 1994f. Method 0010. Modified method 5 sampling train. U.S. Environmental Protection Agency.
EPA. 1994g. Method 8260A. Volatile organic compounds by gas chromatography/mass spectrometry (GC/MS): Capillary column technique. U.S. Environmental Protection Agency.
*EPA. 1994h. Method 0030. Volatile organic sampling train. U.S. Environmental Protection Agency.
*EPA. 1994i. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 63.106.
*EPA. 1994j. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 63.110, Appendix, Table 9.
*EPA. 1994k. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. .U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. EPA600890066F
*EPA. 1994l. Method 8121. Chlorinated hydrocarbons by gas chromatography: Capillary column technique. On-line test methods for evaluating solid wastes physical/chemical methods. SW-846. U.S. Environmental Protection Agency. http://www.epa.gov/epaoswer/hazwaste/test/main.htm. October 3, 2005.
*EPA. 1996a. Drinking water regulations and health advisories. Office of Water. U.S. Environmental Protection Agency.
*EPA. 1996b. Data Evaluation Record (DER) for p-dichlorobenzene – chronic oral toxicity in dogs (MRID# 439888–01 and -02) for Section 6 (a) (2) and reregistration need. U.S. Environmental Protection Agency, Office of Prevention, Pesticides and Toxic Substances.
*EPA. 1996c. Method 5035. Closed-system purge-and-trap and extraction for volatile organics in soil and waste samples. On-line test methods for evaluating solid wastes physical/chemical methods. SW-846. U.S. Environmental Protection Agency. http://www.epa.gov/epaoswer/hazwaste/test/main.htm. September 23, 2005.
*EPA. 1996d. Method 8021B. Aromatic and halogenated volatiles by gas chromatography using photoionization and/or electrolytic conductivity detectors. On-line test methods for evaluating solid wastes physical/chemical methods. SW-846. U.S. Environmental Protection Agency. http://www.epa.gov/epaoswer/hazwaste/test/main.htm. September 26, 2005.
EPA. 1996e. Method 8121. U.S. Environmental Protection Agency Office of Solid Waste.
EPA. 1997a. Land disposal restrictions: Correction of tables; Treatment standards for hazardous wastes and universal treatment standards. (Technical amendment to final rule). U.S. Environmental Protection Agency. Fed Regist 62:7502.
*EPA. 1997b. Toxic chemical release inventory reporting form R and instructions (revised 1996 version). Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. EPA745K97001.
*EPA. 1997c. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
EPA. 1997d. Automated Form R for Windows: User’s guide (RY97). Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics.
*EPA. 2002a. Method 624- Purgeables. Methods for organic chemical analysis of municipal and industrial wastewater. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136, Appendix A.
*EPA. 2002b. Method 612- Chlorinated hydrocarbons in water by GCECD. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136, Appendix A.
*EPA. 2002c. Method 601-Purgeable halocarbons. Washington, DC: U.S. Environmental Protection Agency Code of Federal Regulations. 40 CFR 136, Appendix A.
*EPA. 2002d. Method 602- Purgeable aromatics. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136, Appendix A.
*EPA. 2002e. Inventory Update Rule (IUR). Toxic Substances Control Act (TSCA) Inventory Update Database. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/oppt/uiru/iur02/index.htm.
*EPA. 2004a. 2004 edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822R04005. www.epa.gov/waterscience/drinking/standards/dwstandards. June 06, 2004.
*EPA. 2004b. Designation, reportable quantities, and notification: Designation of hazardous substances. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40CFR 302.4. www.epa.golv/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004c. Identification and listing of hazardous waste: Hazardous constituents. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, Appendix VIII. www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004d. National primary drinking water regulations: Maximum contaminant level goals for organic contaminants. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.50. www.epa.gov/epahome/cfr.htm. June 06, 2004.
EPA. 2004e. National primary drinking water regulations: Maximum contaminant levels for inorganic contaminants. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40CFR 141.62. www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004f. National primary drinking water regulations: Maximum contaminant levels for organic contaminants. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40CFR 141.61. www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004g. National primary drinking water regulations: Public notification. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40CFR 141.32. www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004h. Program and activities: Hazardous air pollutants. Washington, DC: U.S. Environmental Protection Agency. United States Code. 42USC7412. www.epa.gov/epahome/cfr40.htm. June 06, 2004.
EPA. 2004i. Standards for the management of specific hazardous wastes and specific types of hazardous waste management facilities: Reference air concentrations. Washington, DC: U.S. Environmental Protection Agency. www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004j. Toxic chemical release reporting: Community right-to-know: Chemicals and chemical categories to which this part applies. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40CFR 372.65. www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004k. Toxic Substances Control Act: Chemical information rules: Chemical lists and reporting periods. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40CFR 712.30. www.epa.gov/epahome/cfr40.htm. June 06, 2004.
EPA. 2004l. Toxic Substances Control Act: Health and safety data reporting: Substances and listed mixtures to which this subpart applies. Washington, DC: U.S. Environmental Protection Agency.
*EPA. 2004m. Water programs: Designation of hazardous substances. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40CFR 116.4. www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. Office of Environmental Information. EPA260B05001.
*Erickson MD, Harris BS, Pellizzari ED, 1980. Acquisition and chemical analysis of mother's milk for selected toxic substances. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances. EPA5601380029.
Fabbri A, Crescentini G, Mangani F, 1987. Advances in the determination of volatile organic solvents and other organic pollutants by gas chromatography with thermal desorption sampling and injection. Chromatographia 23:856–860.
*Farm Chemicals Handbook. 1983. Directory of chemicals. Willoughby, OH: Meister Publishing Company.
*FDA. 2003. Bottled water. Washington, DC: U.S. Food and Drug Administration. Code of Federal Regulation. 21CFR165.110.
*FDA. 2004. CFR Title 40: Protection of environment. Washington, DC: U.S. Food and Drug Administration.
*FEDRIP. 2005. Dichlorobenzenes. Federal Research in Progress. Dialog Information Service. October 12, 2005.
*Fellin P, Otson R. 1994. Assessment of the influence of climatic factors on concentration levels of volatile organic compounds (VOCs) in Canadian homes. Atmos Environ 28(22):3581–3586.
Fernandez-Villarrenga V, Lopez-Mahia P, Muniategui-Lorenzo S, 2004. C1 to C9 volatile organic compound measurements in urban air. Sci Total Environ 334–335:167–176.
*Field RA, Phillips JL, Goldstone ME, 1992. Indoor/outdoor interactions during an air pollution event in Central London. Environ Technol 13:391–408.
*Fisher R, Barr J, Zuloski CF, 1991a. In-vitro hepatotoxicity of three dichlorobenzene isomers in human liver slices. Hum Exp Toxicol 10:357–363.1683550
Fisher R, McCarthy S, Sipes IG, 1991b. Metabolism of dichlorobenzenes in organ cultured liver slices. Adv Exp Med Biol 283:717–723.2069046
Fisher R, Smith PF, Sipes IG, 1990. Toxicity of chlorobenzenes in cultured rat liver slices. J Mol Cell Toxicol 3:181–194.
Fisher RL, Gandolfi AJ, Sipes IG, 1993. Culture medium composition affects the relative toxicities of chlorobenzenes in rat liver slices and the isolated perfused liver. Drug Chem Toxicol 16(4):321–339.8281887
*Fisher RL, Hasal SJ, Sipes IG, 1995. Comparative metabolism and toxicity of dichlorobenzenes in Sprague-Dawley, Fischer-344 and human liver slices. Hum Exp Toxicol 14:414–421.7612303
*Foman SJ. 1966. Body composition of the infant (Part I: The male reference infant). In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
*Foman SJ, Haschke F, Ziegler EE, 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Foureman P, Mason JM, Valencia R, 1994. Chemical mutagenesis testing in Drosophila, IX. Results of 50 coded compounds tested for the National Toxicology Program. Environ Mol Mutagen 23(1):51–63.8125083
*Frank SB, Cohen HJ. 1961. Fixed drug eruption due to paradichlorobenzene. NY State J Med 61:4079.
*Fraser MP, Cass GR, Simoneit RT, 1998. Air quality model evaluation data for organics. 5. C_6_-C_22_ nonpolar and semipolar aromatic compounds. Environ Sci Technol 32:1760–1770.
FSTRAC. 1995. Summary of state and federal drinking water standards and guidelines. Washington, DC: U.S. Environmental Protection Agency.
Gaffney PE. 1976. Carpet and rug industry case study II: Biological effects. J Water Pollut Contr Fed 48:2731–2737.
*Gaines TB, Linder RE. 1986. Acute toxicity of pesticides in adult and weanling rat. Fundam Appl Toxicol 7:299–308.3758548
*Garcia JP, Beyne-Masclet S, Mouvier G. 1992. Emissions of volatile organic compounds by coal-fired power stations. Atmos Environ 26A(9):1589–1597.
*Garrison AW, Hill DW. 1972. Organic pollutants from mill persist in downstream waters. Am Dyestuff Rep (February):21–24.
Ghassemi M, Quinlivan S, Bachmaier J. 1984. Characteristics of leachates from hazardous waste landfills. J Environ Sci Health A 19:579–620.
*Ghittori S, Imbriani M, Pezzagno G, 1985. Urinary elimination of p-dichlorobenzene (p-DCB and weighted exposure concentration. Ital Med Lav 7:59–63.
*Giavini E, Broccia ML, Prati M, 1986. Teratologic evaluation of p-dichlorobenzene in the rat. Bull Environ Contam Toxicol 37:164–168.3742069
*Giwercman A, Carlsen E, Keiding N, 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Gobba F, Ghitorri S, Imbriani M, 1997. The urinary excretion of solvents and gases for the biological monitoring of occupational exposure: A review. Sci Total Environ 199:3–12.9200842
Goldberg MS, Al-Homsi N, Goulet L, 1995. Incidence of cancer among persons living near a municipal solid waste landfill site in Montreal, Quebec. Arch Environ Health 50:416–424.8572719
Gosselin RE, Smith RP, Hodge HC, 1984. Clinical toxicology of commercial products. 5th ed. Baltimore, MD: Williams and Wilkins, II-170.
*Grosjean D. 1991. Atmospheric fate of toxic aromatic compounds. Sci Total Environ 100:367–414.
*Grossel TA, Bricker JD. 1994. Principles of clinical toxicology. 3rd edition, New York, NY: Raven Press.
Gunawardhana L, Sipes IG. 1991. Dichlorobenzene hepatotoxicity strain differences and structure activity relationships. Adv Exp Med Biol 283(731–734)
Gunawardhana L, Morley SA, Sipes IG. 1993. Modulation of 1,2-dichlorobenzene hepatotoxicity in the Fischer-344 rat by a scavenger of superoxide anions and an inhibitor of kupffer cells. Toxicol Appl Pharmacol 119(2):205–213.8386865
Gupta KC. 1972. Effects of some antimitotics on the cytology of fenugreek roots in vivo and in vitro. Cytobios 5:179–187.5044628
Gustafson DL, Coulson AL, Feng L, 1998. Use of a medium-term liver focus bioassay to assess the heptocarcinogenicity of 1,2,4,5-tetrachlorobenzene and 1,4-dichlorobenzene. Cancer Lett 129:39–44.9714333
Gustafson DL, Long ME, Thomas RS, 2000. Comparative hepatocarcinogenicity of hexachlorobenzene pentachlorobenzene, 1,2,4,5-tetrachlorobenzene, and 1,4-dichlorobenzene: Application of a medium-term liver focus bioassay and molecular and cellular indices. Toxicol Sci 53:245–252.10696772
*Guzelian PS, Henry CJ, Olin SS. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Haag WR, Yao CCD. 1992. Rate constants for reaction of hydroxyl radicals with several drinking water contaminants. Environ Sci Technol 26:1005–1013.
*Haider K, Jagnow G, Kohnen R, 1974. Degradation of chlorinated benzenes, phenols, and cyclohexane derivatives by benzene and phenol utilizing soil bacteria under aerobic conditions. Arch Microbiol 96:183–200.4134769
*Haddad LM, Winchester JF, eds. 1990. Clinical management of poisoning and drug overdose. 2nd edition, Philadelphia, PA: WB Saunders.
*Hallbourg RR, Delfino JJ, Miller WL. 1992. Organic priority pollutants in groundwater and surface water at three landfills in North Central Florida. Water Air Soil Pollut 65:307–322.
*Hallowell M. 1959. Acute haemolytic anaemia following the ingestion of paradichlorobenzene. Arch Dis Child 34:74–75.13628236
Hamar GB, McGeehin MA, Phifer BL, 1996. Volatile organic compound testing of a population living near a hazardous waste site. J Expo Anal Environ Epidemiol 6(2):247–251.8792300
*Hansch C, Leo A, Hoekman D. 1995. o-Dichlorobenzenes and p-dichlorobenzenes. In: Exploring QSAR. Hydrophobic, electronic, and steric constants. Washington, DC: American Chemical Society.
*Harkov R, Gianti SJ, Bozzelli JW, 1985. Monitoring volatile organic compounds at hazardous and sanitary landfills in New Jersey. J Environ Sci Health 5:491–501.
*Harkov R, Kebbekus B, Bozzelli JW, 1984. Comparison of selected volatile organic compounds during the summer and winter at urban sites in New Jersey. Sci Total Environ 38:259–274.
*Hartwell TD, Perritt RL, Pelizzari ED, 1992. Results from the 1987 total exposure assessment methodology (team) study in Southern California. Atmos Environ 26a:1519–1527.
Hasmall SC, Roberts RA. 1997. Hepatic ploidy, nuclearity, and distribution of DNA synthesis: A comparison of nongenotoxic hepatocarcinogens with noncarcinogenic liver mitogens. Toxicol Appl Pharmacol 144:287–293.9194412
*Hasmall SC, Pyrah ITG, Soames AR, 1997. Expression of the immediate-early genes, c-fos, c-jun, and c-myc: A comparison in rats of nongenotoxic hepatocarcinogens with noncarcinogenic liver mitogens. Fundam Appl Toxicol 40:129–137.9398495
*Hauser TR, Bromberg SM. 1982. EPA's monitoring program at Love Canal 1980. Environ Monit Assess 2:249–271.24264296
*Hawkins DR, Chasseaud LF, Woodhouse RN, 1980. The distribution, excretion and biotransformation of p-dichloro[_14_C]benzene in rats after repeated inhalation, oral and subcutaneous doses. Xenobiotica 10:81–95.7395268
*Haworth S, Lawlor T, Mortelmans K, 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen (Suppl 1):3–142.
*Hayes WC, Hanley TR Jr, Gushow TS, 1985. Teratogenic potential of inhaled dichlorobenzenes in rats and rabbits. Fundam Appl Toxicol 5:190–202.3987993
*HazDat. 2005. 1,2-Dichlorobenzene, 1,3-dichorobenzene, and 1,4-dichlorobenzene. HazDat Database. ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry. www.atsdr.cdc.gov/hazdat.html. September 12, 2005.
Hazelton Labs. 1984. Toxicity and primary dermal irritation study. Hazelton Labs Amer Inc. TSCA. OTS0535865.
HEAST. 1990. Health Effects Assessment Summary Tables. 3rd quarter FY-1990. Washington, DC: U.S. Environmental Protection Agency.
HEAST. 1992. Health Effects Assessment Summary Tables. 3rd quarter FY-1992. Washington, DC: U.S. Environmental Protection Agency.
*Heavner DL, Morgan WT, Ogden MW. 1996. Determination of volatile organic compounds and respirable suspended particulate matter in New Jersey and Pennsylvania homes and workplaces. Environ Int 22:159–183.
*Heavner DL, Ogden MW, Nelson PR. 1992. Multisorbent thermal desorption/gas selective detection method for the determination of target volatile organic compounds in indoor air. Environ Sci Technol 26:1737–1746.
*Heikes DL, Jensen SR, Fleming-Jones ME. 1995. Purge and trap extraction with GC-MS determination of volatile organic compounds in table-ready foods. J Agric Food Chem 43:2869–2875.
*Hendler AH, Crow WL. 1992. Preliminary results of the Chemical Manufacturers Association urban baseline VOC measurement program. Proceedings of the Annual Meeting of the Air and Waste Management Association. 85th Meeting, Vol 2B.
Henry B, Grant SG, Klopman G, 1998. Induction of forward mutations at the thymidine kinase locus of mouse lymphoma cells: evidence for electrophilic and non-electrophilic mechanisms. Mutat Res 397(2):313–335.9541657
*Herbold B. 1986a. Investigation of p-dichlorobenzene for clastogenic effects in mice using the micronucleus test. Institute of Toxicology. Report No. 14694.
*Herbold B. 1986b. Investigation of 2,5-dichlorophenol for clastogenic effects in mice using the micronucleus test. Institute of Toxicology. Report No. 14693.
Herr DW, Boyes WK. 1997. A comparison of the acute neuroactive effects of dichloromethane, 1,3-dicloropropane, and 1,2-dichlorobenzene on rat flash evokes potentials (FEPs)1,2. Fundam Appl Toxicol 35:31–48.9024671
Hiatt MH. 1999. Leaves as an indicator of exposure to airborne volatile organic compounds. Environ Sci Technol 33:4126–4133.
*Hill RH, Ashley DL, Head SL, 1995. p-Dichlorobenzene exposure among 1000 adults in the United States. Arch Environ Health 50(4):277–280.7677426
*Hill RH, To T, Holler JS, 1989. Residues of chlorinated phenols and phenoxy acid herbicides in the urine of Arkansas children. Arch Environ Contam Toxicol 18:469–474.2774664
Hissink AM, Dunnewijk R, Van Ommen B, 1997a. Kinetics and metabolism of 1,4-dichlorobenzene in male Wistar rats: No evidence for quinone metabolites. Chem Biol Interact 103:17–33.9051121
*Hissink AM, Oudshoorn MJ, Van Ommen B, 1996b. Differences in cytochrome P450-mediated biotransformation of 1,2-dichlorobenzene by rat and man: Implications for human risk assessment. Chem Res Toxicol 9:1249–1256.8951226
*Hissink AM, Oudshoorn MJ, Van Ommen B, 1997b. Species and strain differences in the hepatic cytochrome P450-mediated biotransformation of 1,4-dichlorobenzene. Toxicol Appl Pharmacol 149:1–9.
Hissink AM, Van Ommen B, Kruse J, 1997c. A physiologically based pharmacokinetic (PB-PK) model for 1,2-dichlorobenzene linked to two possible parameters of toxicity. Toxicol Appl Pharmacol 145:301–310.9266803
*Hissink AM, Van Ommen B, Van Bladeren PJ. 1996a. Dose-dependent kinetics and metabolism of 1,2-dichlorobenzene in rat: effect of pretreatment with phenobarbital. Xenobiotica 26(1):89–105.8851824
*Hissink E, Van Ommen B, Bogaards JJ, 1996c. Hepatic epoxide concentrations during biotransformation of 1,2 and 1,4,-dichlorobenzene. Biological reactive intermediates V. New York: Plenum Press.
*Hodge MCE, Palmer S, Wilson J, 1977. Paradichlorobenzene: Teratogenicity study in rats. ICI Report No. CRL/P/340. July 27, 1976.
Hoekstra PF, Braune BM, O'Hara TM, 2003. Organochlorine contaminant and stable isotope profiles in Arctic fox (Alopex lagopus) from the Alaskan and Canadian Arctic. Environ Pollut 122:422–433.
*Hoel DG, Davis DL, Miller AB, 1992. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst 84(5):313–320.1738181
*Hollingsworth RL, Rowe VK, Oyen F, 1956. Toxicity of paradichlorobenzene: Determinations on experimental animals and human subjects. AMA Arch Ind Health 14:138–147.13353999
*Hollingsworth RL, Rowe VK, Oyen F, 1958. Toxicity of o-dichlorobenzene. AMA Arch Ind Health 17:180–187.13507721
Holmes TJ, Rainsford KD. 2001. Differential effects of non-genotoxic carcinogens and proliferating agents on cell growth, survival and apoptosis in hepatic cells in vitro. Life Sci 69(25–26):2975–2992.11758825
Houk VS, Demarini DM. 1988. Use of the microscreen phage-induction assay to assess the genotoxicity of 14 hazardous industrial wastes. Environ Mol Mutagen 11(1):13–30.2962869
Hovander L, Malmberg T, Athanasiadou M, 2002. Identification of hydroxylated PCB metabolites and other phenolic halogenated pollutants in human blood plasma. Arch Environ Contam Toxicol 42:105–117.11706375
*Howard PH. 1989. 1,4-dichlorobenzene. In: Handbook of environmental fate and exposure data for organic chemicals. Chelsea, MI: Lewis Publishers, Inc.,1, 250–262.
Howd RA, Brown JP, Morry DW, 2000. Development of California public health goals (PHGs) for chemicals in drinking water. J Appl Toxicol 20:365–380.11139167
*HSDB. 1996. Hazardous Substances Data Bank. Bethesda, MD: National Library of Medicine. National Toxicology Program.
*HSDB. 2005. 1,4-Dichlorobenzene. Hazardous Substances Data Bank. Bethesda, MD: National Library of Medicine http://toxnet.nlm.nih.gov. September 2, 2005.
Hughes CS. 1983. CEH product review: Chlorobenzenes. In: Chemical Economics Handbook. Menlo Park, CA: SRI International, 633.5030A-633.5031M.
*IARC. 1982. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans: Some industrial chemicals and dyestuffs. Vol. 29. Lyon, France: International Agency for Research on Cancer.
*IARC. 1987. IARC monographs on the evaluation of carcinogenic risks to humans. Overall evaluations of carcinogenicity: An updating of IARC monographs volumes 1 to 42. Supplement 7. Lyon, France: International Agency for Research on Cancer.
*IARC. 1999. IARC monographs on the evaluation of carcinogenic risks to humans. Some chemicals that cause tumours of the kidney or urinary bladder in rodents and some other substances-Dichlorobenzenes. Lyon, France: International Agency for Research on Cancer.
*ICF. 1987. ICF Incorporated. Preliminary use and substitutes analysis of para-dichlorobenzene. Draft. Washington, DC: U.S. Environmental Protection Agency. July 1987.
IJC. 1983. An inventory of chemical substances identified in the Great Lakes ecosystem. Vol. I Summary. Windsor, Ontario: International Joint Commission, Great Lakes Water Quality Board.
*IJC. 1989. 1989 Report on Great Lakes water quality. Presented at Hamilton, Ontario, October 1989. Windsor, Ontario: International Joint Commission, Great Lakes Water Quality Board.
*Instituto di Ricerche Biomediche. 1986a. Study of the capacity of the test article para-dichlorobenzene to induce "unscheduled DNA synthesis" in cultured HeLa cells. Experiment No. M1032/1–2.
*Instituto di Ricerche Biomediche. 1986b. Study of the capacity of the test article para-dichlorobenzene to induce gene mutation in V79 Chinese hamster lung cells. Experiment No. 1030.
*Instituto di Ricerche Biomediche. 1987. Study of the capacity of the test article para-dichlorobenzene to induce chromosome aberrations in human lymphocytes cultured in vitro. Experiment No. 1031.
*IRIS. 2004. RfDs and RfCs for 1,2-dichlorobenzene, 1,3-dichlorobenzene and 1,4-dichlorobenzene. Integrated Risk Information System. http://www-cie.iarc.fr/htdocs/monographs/vol71/032-111trich.html. June 06, 2004.
*IRIS. 2005. Dichlorobenzenes. Washington, DC: Integrated Risk Information System. U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/. October 15, 2005.
*IRPTC. 1985. IRPTC data profile on: DCB. Geneva, Switzerland: International Register of Potentially Toxic Chemicals, United Nations Environment Programme. January 1989.
Jackson JA, Diliberto JJ, Burnbaum LS. 1993. Estimation of octanol-water partition coefficients and correlation with dermal absorption for several polyhalogenated aromatic hydrocarbons. Fundam Appl Toxicol 21:334–344.8258387
*Jacobs LW, Zabik MJ. 1983. Importance of sludge-borne organic chemicals for land application programs. Sixth Annual Madison Conference on Application, Research, Practices, Municipalities and Industrial Waste. University of Wisconsin.
James NH, Soames AR, Roberts RA. 1998. Suppression of hepatocyte apoptosis and induction of DNA synthesis by the rat and mouse hepatocarcinogen diethylhexylphlathate (DEHP) and the mouse hepatocarcinogen 1,4-dichlorobenzene (DCB). Arch Toxicol 72:784–790.9950075
*Jan J. 1983. Chlorobenzene residues in human fat and milk. Bull Environ Contam Toxicol 30:595–599.6860813
*Jan J, Malnersic S. 1980. Chlorinated benzene residues in fish in Slovenia (Yugoslavia). Bull Environ Contam Toxicol 24:824–827.7397417
*Japan Bioassay Research Center. 1995. Toxicology and carcinogenesis studies of p-dichlorobenzene in 344/DuCrj rats and Crj:BDF1 mice. Two-year inhalation studies. Japan Industrial Safety and Health Association. This study was carried under contract with the Ministry of Labour of Japan.
*Jay K, Stieglitz L. 1995. Identification and quantification of volatile organic components in emissions of waste incineration plants. Chemosphere 30(7):1249–1260.
*Jerina DM, Daly JW. 1974. Arene oxides: A new aspect of drug metabolism. Science 185:573–582.4841570
*Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
*Jori A, Calamari D, Cattabeni F, 1982. Ecotoxicological profile of p-dichlorobenzene. Ecotoxicol Environ Saf 6:413–432.7169034
Kanerva RL, Ridder GM, Lefever FR, 1987. Comparison of short-term renal effects due to oral administration of decalin or d-limonene in young adult male Fisher-344 rats. Food Chem Toxicol 25:345–353.3609973
Kato Y, Kimura R. 1997. Role of 3,4-dichlorophenyl methyl sulfone, a metabolite of o-dichlorobenzene, in the changes in hepatic microsomal drug-metabolizing enzymes caused by o-dichlorobenzene administration in rats. Toxicol Appl Pharmacol 145:277–284.9266800
Kato Y, Kogure T, Sato M. 1986. Evidence that methylsulfonyl metabolites on m-dichlorobenzene are causative substances of induction of hepatic microsomal drug-metabolizing enzymes by the parent compound in rats. Toxicol Appl Pharmacol 82:505–511.3952733
Kato Y, Kogure T, Sato M, 1988a. Contribution of methylsulfonyl metabolites of m-dichlorobenzene to the heme metabolic enzyme induction by the parent compound in rat liver. Toxicol Appl Pharmacol 96:550–559.3206531
Kato Y, Kogure T, Sato M, 1988b. Effects of chlorobenzenes and their methyl sulfone metabolites on microsomal enzymes associated with drug metabolism in rat liver. J Pharmacobiodyn 11(11):758–762.3148707
*Kelly TJ, Mukund R, Spicer CW, 1994. Concentrations and transformations of hazardous air pollutants. Environ Sci Technol 28(8):378–387.
Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotox Environ Saf 4:26–38.
*Kimura R, Hayashi T, Sato M, 1979. Identification of sulfur-containing metabolites of p-dichlorobenzene and their disposition in rats. J Pharm Dyn 2:237–244.
Kimura R, Kawai M, Sato M, 1983. Induction of hepatic microsomal drug-metabolizing enzymes by sulfur-containing metabolites of chlorinated benzenes in rats. Toxicol Appl Pharmacol 67:338–345.6845363
Kimura R, Kawai M, Kato Y, 1985. Role of 3,5-dichlorophenyl methyl sulfone, a metabolite of m-dichlorobenzene, in the induction of hepatic microsomal drug-metabolizing enzymes by m-dichlorobenzene in rats. Toxicol Appl Pharmacol 78:300–309.4035682
*Kimura R, Ohishi N, Kato Y, 1992. Identification of biliary metabolites of m-dichorobenzene in rats. Drug Metab Dispos 20:161–171.1352205
King JW. 1989. Fundamentals and applications of supercritical fluid extraction in chromatographic science. J Chromatogr Sci 27:355–364.
*Kinney PL, Chillrud SN, Ramstrom S, 2002. Exposures to multiple air toxics in New York City. Environ Health Perspect 110(Suppl. 4):539–546.12194883
*Klos C, Dekant W. 1994. Comparative metabolism of the renal carcinogen 1,4-dichlorobenzene in rat: Identification and quantitation of metabolites. Xenobiotica 24(10):965–976.7900412
*Kolpin DW, Furlong ET, Meyer MT, 2002. Pharmaceuticals, hormones, and other organic wastewater contaminants in US streams, 1999–2000: A national reconnaissance. Environ Sci Technol 36:1202–1211.11944670
Kolpin DW, Squillace PJ, Zogorski JS, 1997. Pesticides and volatile organic compounds in shallow urban groundwater of the United States. In: Chilton et al. Groundwater in the urban environment: Processes and management. 1. Iowa City: U.S. Geological Survey, 469–474.
*Komori M, Nishio K, Kitada M, 1990. Fetus-specific expression of a form of cytochrome P-450 in human liver. Biochemistry 29:4430–4433.2350547
*Kondo M, Nishihara T, Shimamoto T, 1988. Biodegradation test of chemicals by cultivation method. Eisei Kagaku 34(2):188–195.
Kong JT, Schmiesing C. 2005. Concealed mothball abuse prior to anesthesia: Mothballs, inhalants, and their management. Acta Anaesthesiol Scand 49(1):113–116.15675996
Kool HJ, Van Kreijl CF, Zoeteman BC. 1982. Toxicology assessment of organic compounds in drinking water. CRC Crit Rev Environ Control 12:307–350.
Kopfler FC, Melton RG, Mullaney JL, 1977. Human exposure to water pollutants. Adv Environ Sci Technol 8:419–433.
Kopperman HL, Keuhl DW, Glass GE. 1978. Chlorinated compounds found in waste treatment effluents and their capacity to bioaccumulate. In: Jolley RL, ed. Water chlorination: Environmental impact and health effects. Volume 1. Ann Arbor, MI: Ann Arbor Science Publishers, Inc., 311–328.
*Kostianen R. 1995. Volatile organic compounds in the indoor air of normal and sick houses. Atmos Environ 29(6):693–702.
Kraaij H, Connell DW. 1997. Bioconcentration and uptake kinetics of chlorobenzenes in soy-bean roots. Chemosphere 34(12):2607–2620.
*Krishnamurti R. 2001. Chlorinated benzenes. In: Kirk Othmer’s encyclopedia of chemical technology. John Wiley & Sons, Inc. http://www.mrw.interscience.wiley.com/kirk/kirk_search_fs.html. July 13, 2003.
*Krishnan K, Andersen ME. 1994. Physiologically-based pharmacokinetic modeling in toxicology. In: Hayes W, ed. Principles and methods of toxicology. 3rd edition. New York, NY: Raven Press, Ltd.
*Krishnan K, Andersen ME, Clewell HJ III, 1994. Physiologically-based pharmacokinetic modeling of chemical mixtures. In: Yang RSA, ed. Toxicology of chemical mixtures. New York, NY: Academic Press.
Krzymien M, Day M, Shaw K, 1999. An investigation of odors and volatile organic compounds released during composting. J Air Waste Manage Assoc 49:804–813.
Kulkarni SG, Mehendale HM. 1995. The equalized outcome of liver injury induced by 1,2-dichlorobenzene in Fischer 344 and Sprague-Dawley rats is due to differential tissue repair. FASEB J 9:A695.
Kulkarni SG, Harris AJ, Casciano DA, 1999. Differential protooncogene expression in Sprague Dawley and Fischer 344 rats during 1,2-dichlorobenzene-induced hepatocellular regeneration. Toxicology 139:119–127.10614693
Kulkarni SG, Warbritton A, Bucci TJ, 1997. Antimitotic intervention with colchicine alters the outcome of o-DCB-induced hepatotoxicity in Fischer 344 rats. Toxicology 120:79–88.9184194
*Kumagai S, Matsunaga I. 1995. Identification of urinary metabolites of human subjects exposed to o-dichlorobenzene. Int Arch Occup Environ Health 67:207–209.7591180
*Kumagai S, Matsunaga I. 1997. Quantitative determination of urinary metabolites of o-dichlorobenzene using a gas chromatograph. Ind Health 35:399–403.9248225
*Lake BG, Cunninghame ME, Price RJ. 1997. Comparison of the hepatic and renal effects of 1,4-dichlorobenzene in the rat and mouse. Fund Appl Toxicol 39:67–75.
*Langhorst ML, Nestrick TJ. 1979. Determination of chlorobenzenes in air and biological samples by gas chromatography with photoionization detection. Anal Chem 51:2018–2025.539657
Langner HJ, Hillinger HG. 1971. [Taste variation of the egg caused by the deodorant p-dichlorobenzene. Analytical proof.] Berlin Muenchen Tierairztl 84:851. (German)
*Laniewski K, Boren H, Grimvall A. 1999. Fractionation of halogenated organic matter present in rain and snow. Chemosphere 38(2):392–409.
*LaRegina J, Bozzelli JW, Harkov R, 1986. Volatile organic compounds at hazardous waste sites and a sanitary landfill in New Jersey: An up-to-date review of the present situation. Environ Prog 5:18–27.
Larsen GL, Bakke JE, Huwe JK. 1990. Methylsulphone metabolites of m-dichlorobenzene as ligands for α2μ-globulin in rat kidney and urine. Xenobiotica 20(1):7–17.1691566
*Lattanzi G, Bartoli S, Bonora B, 1989. The different genotoxicity of p-dichlorobenzene in mouse and rat: Measurement of the in vivo and in vitro covalent interaction with nucleic acids. Tumori 75:305–310.2479159
*Leber AP, Bus JS. 2001. Halogenated benzenes. In: Bingham E, Cohrssen B, Powell CH, eds. Patty’s toxicology. John Wiley & Sons, Inc. http://www.mrw.interscience.wiley.com/pattys/tox/articles/tox067/sect1_2.html. April 16, 2001.
Lebret E, Van de Wiel H, Bos H, 1986. Volatile organic compounds in Dutch homes. Environ Int 12:323–332.
*Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44:55–77.9057784
Lehman-McKeeman LD, Rivera-Torres MI, Caudill D. 1990. Lysosomal degradation of α2μ-globulin and α2μ-globulin-xenobiotic conjugates. Toxicol Appl Pharmacol 103:539–554.1692643
*Leo A, Hansch C, Elkins D. 1971. Partition coefficients and their uses. Chem Rev 71:525,568.
*Leung H. 1993. Physiologically-based pharmacokinetic modeling. In: Ballantine B, Marro T, Turner T, eds. General and applied toxicology. Vol. I. New York, NY: Stockton Press,153–164.
*Lewis RG, Mulik JD, Coutant RW, 1985. Thermally desorbable passive sampling device for volatile organic chemicals in ambient air. Anal Chem 57:214–219.
*Lewis RJ. 1997. m-dichlorobenzene, p-dichlorobenzene and o-dichlorobenzene. In: Hawley’s condensed chemical dictionary. New York, NY: John Wiley & Sons, Inc., 362.
*Li X, Weber LWD, Rozman KK. 1995. Toxicokinetics of 2,3,7,8 tetrachlorodibenzo-p-dioxin (TCDD) in female Sprague-Dawley rats including placental and lactational transfer to fetuses and neonates. Fundam Appl Toxicol 234:70–76.
*Lide DR, ed. 2000. Physical constants of organic compounds- o-dichlorobenzene, m-dichlorobenzene, and p-dichlorobenzene. In: CRC handbook of chemistry and physics. 81st edition. Boca Raton, FL: CRC Press, 3–39.
*Lide DR, Frederikse HPR. 1994. CRC handbook of chemistry and physics. 74th edition. CRC Press, 83.
*Ligocki MP, Levenberger C, Pankow JF. 1985. Trace organic compounds in rain. II. Gas scavenging of neutral organic compounds. Atmos Environ 19:1609–1617.
*Litton Bionetics. 1985. Evaluation of 2,5-dichlorophenol in the in vitro transformation of BALB/3T3 cells assay. West Germany: Bayer AG Institut Fuer Toxicology.
*Litton Bionetics. 1986a. Mutagenicity evaluation of 2,5-dichlorophenol in the CHO HGPRT forward mutation assay. West Germany: Bayer AG Institut Fuer Toxicology.
Litton Bionetics. 1986b. Mutagenicity evaluation of p-dichlorobenzene in the CHO HGPRT forward mutation assay. West Germany: Bayer AG Institut Fuer Toxicology.
Liu W, Zheng M, Wang D, 2004. Formation of PCDD/Fs and PCBs in the process of production of 1,4-dichlorobenzene. Chemosphere 57(10):1317–1323.15519376
Liu W, Zheng M, Xing Y, 2004. Polychlorinated dibenzo-p-dioxins and polychlorinated dibenzofurans in 1,4-dichlorobenzene mothballs. Bull Environ Contam Toxicol 73(1):93–97.15386077
*Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
*Loeser E, Litchfield MH. 1983. Review of recent toxicology studies on p-dichlorobenzene. Food Chem Toxicol 21:825–832.6363233
*Lopes TJ, Furlong ET. 2001. Occurrence and potential adverse effects of semivolatile organic compounds in streambed sediment, United States, 1992–1995. Environ Toxicol Chem 20(4):727–737.11345447
Lopes TJ, Furlong ET, Pritt JW. 1997. Occurrence and distribution of semivolatile organic compounds in stream bed sediments, United States, 1992–95. In: Little EE, Greenberg BM, DeLonay AJ, eds. Environmental toxicology and risk assessment: Seventh volume. West Conshohocken, PA, 105–119.
*Loscutoff WV, Poore MW. 1993. Ambient air toxics data from California’s toxic air contaminant monitoring program. In: Chow W, Conner KK, Mueller P, Wyzga R, Porcella D, Levin L, Chang R, eds. Managing hazardous air pollutants: State of the art. Boca Raton, FL: Lewis Publishers, 191–203.
*Loveday KS, Anderson BE, Resnick BE, 1990. Chromosome aberration and sister chromatid exchange tests in Chinese hamster ovary cells in vitro: V. Results with 46 chemicals. Environ Mol Mutagen 16(4):272–303.2253606
Lowenheim FA, Morgan MK. 1975. Faith, Keyes and Clark's industrial chemicals. 4th ed. New York, NY: John Wiley and Sons, 258–265.
Lu P, Metcalf RL. 1975. Environmental fate and biodegradability of benzene derivatives as studied in a model aquatic ecosystem. Environ Health Perspect 10:269–284.1157796
Mabey WR, Smith JH, Podoll RT, 1982. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards. EPA440481014.
*Macleod M, Mackay D. 1999. An assessment of the environmental fate and exposure of benzene and the chlorobenzenes in Canada. Chemosphere 38(8):1777–1796.10101848
*Mage DT, Allen RH, Gondy G, 2004. Estimating pesticide dose from urinary pesticide concentration data by creatinine correction in the Third National Health and Nutrition Examination Survey. J Expo Anal Environ Epidemiol 14(6):457–465.15367927
*Makita Y. 2005. Effects of perinatal combined exposure to 1,4-dichlorobenzene and 1,1-dichloro-2,2-bis (p-chlorophenyl)ethylene on rat male offspring. Basic Clin Pharmacol Toxicol 96(5):361–365.15853928
Makita Y, Omura M, Ogata R. 2004. Effects of perinatal simultaneous exposure to tributyltin (TBT) and p,p'-DDE (1,1-dichloro-2,2-bis(p-chlorophenyl) ethylene) on male offspring of Wistar rats. J Toxicol Environ Health A 67(5):385–395.14718175
Mally A, Chipman JK. 2002. Non-genotoxic carcinogens: Early effects on gap junctions, cell proliferation and apoptosis in the rat. Toxicology 180:233–248.12393293
*Masunaga S, Susarla S, Yonezawa Y. 1996. Dechlorination of chlorobenzenes in anaerobic estuarine sediment. Water Sci Technol 33(6):173–180.
Matsushima T, Nagano K, Nishizawa T, 1998. Long term inhalation toxicity studies of five chlorinated hydrocarbons in F344 rats and BDF1 mice [Abstract]. J Toxicol Sci 23(Suppl II):296.
*Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
*McCauley PT, Robinson M, Daniel FB, 1995. Toxicity studies of 1,3-dichlorobenzene in Sprague-Dawley rats. Drug Chem Toxicol 18(2 & 3):201–221.7497912
*McGregor DB, Brown A, Cattanach P, 1988. Responses of L5178Y tk^+^/tk^−^ mouse lymphoma cell forward mutation assay: III. 72 Coded chemicals. Environ Mol Mutagen 12:85–154.3383842
*McKinney JD, Fishbein L, Fletcher CE, 1970. The electron-capture gas chromatography of paradichlorobenzene metabolites as a measure of exposure. Bull Environ Contam Toxicol 5:354–361.
*Meek MA, Giddings M, Gomes R. 1994. 1,2-Dichlorobenzene: Evaluation of risks to health from environmental exposure in Canada. J Environ Sci Health C Environ Carcinog Ecotoxicol Rev 12:269–275.
*Meharg AA, Wright J, Osborn D. 2000. Chlorobenzenes in rivers draining industrial catchments. Sci Total Environ 251/252:243–253.10847165
Meister RT, ed. 1989. Farm chemicals handbook. Willoughby, OH: Meister Publishing Company, C219.
*Mes J. 1992. Organochlorine residues in human blood and biopsy fat and their relationship. Bull Environ Contam Toxicol 48:815–820.1568057
*Mes J, Davies DJ, Turton D, 1986. Levels and trends of chlorinated hydrocarbon contaminants in the breast milk of Canadian women. Food Addit Contam 3:313–322.3803638
*Michael LC, Erickson MD, Parks SP, 1980. Volatile environmental pollutants in biological matrices with a headspace purge technique. Anal Chem 52:1836–1841.7435989
Michael LC, Pellizzari ED, Wiseman RW. 1988. Development and evaluation of a procedure for determining volatile organics in water. Environ Sci Technol 26:265–570.
*Miller MM, Ghoodbane S, Wasik SP, 1984. Aqueous solubilities, octanol/water partition coefficients, and entropies of melting of chlorinated benzenes and biphenyls. J Chem Eng 29:184–190.
Mio T, Sumino K. 1988. Mechanism of biosynthesis of methylsulfones from PCBs and related compounds. Environ Health Perspect 59:129–135.
Miranda CL, Wang JL, Henderson MC, 1984. Effects of chlorobenzenes on hepatic porphyrin and drug metabolism in chick embryo and day-old chick. Res Commun Chem Pathol Pharmacol 46:13–24.6505383
MIS. 1990. Agency for Toxic Substances and Disease Registry. Office of External Affairs, Exposure and Disease Registry Branch, Atlanta, GA. September 24, 1990.
Mitchell AD. 1993. Does the in situ approach yield a more accurate assessment of induced mutation frequencies than the standard L5178Y tk-/-mouse lymphoma assay? Environ Mol Mutagen 21:49.
*Miyai I, Hirono N, Fujita M, 1988. Reversible ataxia following chronic exposure to para-dichlorobenzene. J Neurol Neurosurg Psychiatry 51:453–454.3361344
*Mizutani T, Nakohori Y, Yamamoto K. 1994. p-Dichlorobenzene-induced hepatotoxicity in mice depleted of glutathione by treatment with buthionine sulfoximine. Toxicology 94:57–67.7801330
Mohtashamipur E, Norpoth K. 1987. Chromosome damaging effects of alkylated and halogenated benzenes on bone marrow of mice [abstract]. Environ Mutagen 9:75.
*Mohtashamipur E, Triebel R, Straeter H, 1987. The bone marrow clastogenicity of eight halogenated benzenes in male NMRI mice. Mutagenesis 2:111–113.3331700
*Monsanto Co. 1980. Toxicity data on chlorinated benzenes and m-dichlorobenzene. St. Louis, MO: Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0206232.
Monsanto Co. 1986. Material safety data sheet for Santochlor (para-dichlorobenzene). St. Louis, MO: Monsanto Company.
*Monsanto Co. 1989. Health effects assessment for ortho-dichlorobenzene at the Krummrich Plant. St. Louis, MO: Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0521597.
*Moran MJ, Lapham WW, Rowe BL, 2004. Volatile organic compounds in ground water from rural private wells, 1986 to 1999. J Am Water Resour Assoc 40(5):1141–1157.
*Morita M, Ohi G. 1975. Para-dichlorobenzene in human tissue and atmosphere in Tokyo metropolitan area. Environ Pollut 8:269–274.
*Morita M, Mimura S, Ohi G, 1975. A systematic determination of chlorinated benzenes in human adipose tissue. Environ Pollut 9:175–179.
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants. Clin Pharmacokin 5:485–527.
Mortimer MR, Connell DW. 1995. Effect of exposure to chlorobenzenes on growth rates of the crab Portunus pelagicus (L) Environ Sci Technol 29:1881–1886.22191332
Mottram DS, Edwards RA, MacFie HJH. 1982. A comparison of the flavour volatiles from cooked beef and pork meat systems. J Sci Food Agric 33:934–944.
Muelenberg CJW, Vijverberg HPM. 2000. Empirical relations predicting human and rat tissue: Air partition coefficients of volatile organic compounds. Toxicol Appl Pharmacol 165(3):206–216.10873711
Muller J, Greff G. 1984. Research on the relations between toxicity of molecules of industrial interest and physicohemical properties: irritation test of the upper respiratory tract applied to four families of chemicals. Food Chem Toxicol 22:661–664.6540741
*Murthy RC, Migally N, Doye A, 1987. Effect of para-dichlorobenzene on testes of rats. Adv Contracept Delivery Syst 3:35–40.
*Myhr BC, Caspary WJ. 1991. Chemical mutagenesis at the thymidine kinase locus in L5178Y mouse lymphoma cells: Results for 31 coded compounds in the National Toxicology Program. Environ Mol Mutagen 18:51–83.1864269
*Nakamura S, Oda Y, Shimada T, 1987. SOS-inducing activity of chemical carcinogens and mutagens in Salmonella typhimurium TA1535/pSK1002: Examination with 151 chemicals. Mutat Res 192:239–246.3317033
*Nalbandian RM, Pearce JS. 1965. Allergic purpura induced by exposure to 1,4-dichlorobenzene. JAMA 194:238–239.
NAS. 1977. Drinking water and health. Washington, DC: National Academy of Sciences, 681–686.
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
NATICH. 1989. National Air Toxics Information Clearinghouse: NATICH database report on state, local and EPA air toxics activities. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. EPA45038929.
NATICH. 1992. National Air Toxics Information Clearinghouse. Report on state, local, and EPA air toxics activities. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. December 1992.
*Naylor MW, Stout LD. 1996. One year study of p-dichlorobenzene administered orally via capsule to beagle dogs. Environmental Health Laboratory, Monsanto Company, St. Louis, MO. Study No. ML-94–210, March 25, 1996. MRID43988802. Unpublished study.
*Nedelcheva V, Gut I, Soucek P, 1998. Cytochrome P450 catalyzed oxidation of monochlorobenzene, 1, 2- and 1,4-dichlorobenzene in rat, mouse, and human liver microsomes. Chem Biol Interact 115:53–70.9817075
Neptune D. 1980. Descriptive statistic for detected priority pollutants and tabulation listings. Washington, DC: U.S. Environmental Protection Agency, Office of Water Planning and Standards. TRDB-0280–001.
*Nerin C, Polo T, Domeno C, 1996. Determination of some organochlorine compounds in the atmosphere. Int J Environ Anal Chem 65:83–94.
*Newsom JM. 1985. Transport of organic compounds dissolved in ground water. Ground Water Monit Rev 5:28–36.
*NFPA. 1994. Fire protection guide to hazardous materials. 11th Edition. Quincy, MA: National Fire Protection Association.
*Nielsen PH, Bjerg PL, Nielsen P, 1996. In situ and laboratory determined first-order degradation rate constants of specific organic compounds in aerobic aquifer. Environ Sci Technol 30:31–37.
NIOSH. 1984. NIOSH manual of analytical methods. 3rd ed. Vol. 2. Cincinnati, OH: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health.
NIOSH. 1985. NIOSH pocket guide to chemical hazards. Washington, DC: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health.
NIOSH. 1990. U.S. Department of Health and Human Services. National Institute for Occupational Safety and Health.
NIOSH. 1992. NIOSH Recommendations for occupational safety and health-compendium of policy document and statements. Cincinnati, OH: National Institute for Occupational Safety and Health. Department of Health and Human Services. Publication No. 92–100.
*NIOSH. 1994. Method 1003. NIOSH manual of analytical methods. 4th edition. U.S. Department of Health and Human Services. National Institute for Occupational Safety and Health.
*NIOSH. 1997. NIOSH pocket guide to chemical hazards. U.S. Department of Health and Human Services. Public Health Services. Centers for Disease Control and Prevention. National Institute for Occupational Safety and Health.
*NIOSH. 2004. NIOSH pocket guide to chemical hazards. U.S. Department of Health and Human Services. Public Health Services. Centers for Disease Control and Prevention. National Institute for Occupational Safety and Health.
*NIOSH. 2005. NIOSH pocket guide to chemical hazards. U.S. Department of Health and Human Services. Public Health Services. Centers for Disease Control and Prevention. National Institute for Occupational Safety and Health.
NIOSH/OSHA. 1981. Occupational health guidelines for chemical hazards, p-dichlorobenzene. DHHS (NIOSH) Publication No. 81–123.
*Nishihara T, Nishikawa J, Kanayama T, 2000. Estrogenic activities of 517 chemicals by yeast two-hybrid assay. J Health Sci 46(4):282–298.
*NOES. 1990. National Occupational Exposure Survey. Cincinnati, OH: National Institute of Occupational Safety and Health. July 16, 1990.
NOES. 1996. National Occupational Exposure Survey 1981–1983. Cincinnati, OH: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health.
*NRC. 1993. Pesticides in the diets of infants and children. National Research Council. Washington DC: National Academy Press.
*NTP. 1985. Toxicology and carcinogenesis studies of 1,2-dichlorobenzene (o-dichlorobenzene) in F344/N rats and B6C3F_1_ mice (gavage studies). Research Triangle Park, NC: National Toxicology Program. NTP TR 255. NIH Publication No. 86–2511.
*NTP. 1987. Toxicology and carcinogenesis studies of 1,4-dichlorobenzene in F344/N rats and B6C3F_1_ mice (gavage studies). Research Triangle Park, NC: National Toxicology Program. NTP TR 319. NIH Publication No. 87–2575.
*NTP. 1989. National Toxicology Program. Fifth annual report on carcinogens: Summary 1989. Research Triangle Park, NC: National Institute of Environmental Health Sciences, 103–106. NTP 89239.
*NTP. 1995. Printed long term technical reports and short term toxicity study reports. Division of Toxicology Research and Testing. Research Triangle Park, NC: National Toxicology Program. National Institute of Environmental Health Sciences.
*NTP. 2002. 1,4-Dichlorobenzene. Tenth report on carcinogens. National Toxicology Program. National Institute of Environmental Health Sciences.
*NTP. 2005. NTP. 2005. Report on carcinogens. 11^th^ edition. U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program, Research Triangle Park, NC. http://ntp-server.niehs.nih.gov/ntp/roc/toc11.html. February 15, 2004.
Odin M, Bosch S, Osier M, 2003. Evaluation of mode of action in assessment of cancer risk associated with exposure to 1,4-dichlorobenzene. Toxicol Sci 72(S-1):138–139.
*OECD. 1981. OECD guidelines for the testing of chemicals. Section 4: Health effects. Test No. 413: Subchronic inhalation toxicity: 90-day study. Organisation for Economic Co-operation and Development. http://caliban.sourceoecd.org/vl=1117056/cl=38/nw=1/rpsv/home.htm. September 29, 2005.
Ogata M, 1981. Effects of chlorinated mono aromatic hydrocarbons on mitochondrial oxidative phosphorylation in rats liver. Ind Health 19:31–36.7216839
OHM/TADS. 1990. Oil and Hazardous Materials/Technical Assistance Data System. Baltimore, MD: Chemical Information Systems, Inc. July 26, 1990.
Oikawa S, Kawanishi S. 1996. Copper-mediated DNA damage by metabolites of p-dichlorobenzene. Carcinogenesis 17(12):2733–2739.9006113
*Oliver BG, Nicol KD. 1982a. Chlorobenzenes in sediments, water and selected fish from Lakes Superior, Huron, Erie and Ontario. Environ Sci Technol 16:532–536.
*Oliver BG, Nicol KD. 1982b. Gas chromatographic determination of chlorobenzenes and other chlorinated hydrocarbons in environmental samples using fused silica capillary columns. Chromatrographia 16:336–340.
*Oliver BG, Niimi AJ. 1983. Bioconcentration of chlorobenzenes from water by rainbow trout: Correlations with partition coefficients and environmental residues. Environ Sci Technol 17:287–291.
*Oliver KD, Adams JR, Daughtrey EH, 1996. Technique for monitoring ozone precursor hydrocarbons in air at photochemical assessment monitoring stations: Sorbent preconcentration, closed-cycle cooler cryofocusing, and GC-FID analysis. Atmos Environ 30(15):2751–2757.
*Olson MJ, Johnson JT, Reidy CA. 1990. A comparison of male rat and human urinary proteins: Implications for human resistance to hyaline droplet nephropathy. Toxicol Appl Pharmacol 102:524–536.1690459
*Oltmanns RH, Rast HG, Reineke W. 1988. Degradation of 1,4-dichlorobenzene by enriched and constructed bacteria. Appl Environ Microbiol 28:609–616.
*O’Neil MJ, ed. 2001. o-Dichlorobenzene and p-dichlorobenzene. In: The Merck index. An encyclopedia of chemicals, drugs, and biologicals. Whitehouse Station, NJ: Merck Research Laboratories, 537–538.
Ono Y, Somiya I, Kawamura M. 1991. Genotoxicity of the by-products produced in chlorination and ozonation processes. Mutat Res 252:102.
*OSHA. 1974. U.S. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000.
OSHA. 1986. Occupational Safety and Health Administration. OSHA Computerized Information System (OCIS), SIC IH information file for p-dichlorobenzene. Salt Lake City, Utah: U.S. Department of Labor, Occupational Safety and Health Administration.
*OSHA. 1989. Air Contaminants. Occupational Safety and Health Administration: Part III. Fed Regist 54:2332–2335, 2923–2933.
OSHA. 1993. Air contaminants. U.S. Department of Labor. Occupational Safety and Health Administration. Fed Regist 58:35338.
*OSHA. 2004a. Air contaminants. U.S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000.
*OSHA. 2004b. Gases, vapors, fumes, dusts, and mists. U.S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 40 CFR 1926.55.
*OSHA. 2004c. Limits for air contaminants- Table Z-1. U.S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000.
*OTA. 1990. Neurotoxicology: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment. OTA-BA-438.
*Otson R, Williams DT, Bothwell PD. 1982. Volatile organic compounds in water at thirty Canadian potable water treatment facilities. J Assoc Off Anal Chem 65(6):1370–1374.
Ott WR, Roberts JW. 1998. Everyday exposure to toxic pollutants. Sci Am 278:86–91.
Ou YC, Conolly RB, Thomas RS, 2003. Stochastic simulation of hepatic preneoplastic foci development for four chlorobenzene congeners in a medium-term bioassay. Toxicol Sci 73(2):301–314.12700395
Overcash MR, Weber JB, Tucker WP. 1986. Toxic and priority organics in municipal sludge land treatment systems. Cincinnati, OH: U.S. Environmental Protection Agency, Wastewater Research Division. EPA600286010. PB86150208.
*Owen GM, Brozek J. 1966. Influence of age, sex, and nutrition on body composition during childhood ad adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: Saunders, 222–238.
*Page DB, Lacroix GM. 1995. On-line distillation/purge and trap analysis of halogenated, nonpolar, volatile contaminants in foods. J Assoc Off Anal Chem Int 78(6):1416–1428.
*Page GW. 1981. Comparison of groundwater and surface water for patterns and levels of contamination by toxic substances. Environ Sci Technol 15:1475–1481.
*Pagnotto LD, Walkley JE. 1965. Urinary dichlorophenol as an index of para-dichlorobenzene exposure. J Am Ind Hyg Assn 26:137–142.
*Pankow JF, Rosen ME. 1988. Determination of volatile compounds in water by purging directly to a capillary column with whole column cryotrapping. Environ Sci Technol 22:398–405.
*Pankow JF, Ligocki MP, Rosen ME, 1988. Adsorption/thermal desorption with small cartridges for the determination of trace aqueous semivolatile organic compounds. Anal Chem 60:40–47.
*Paolini M, Pozetti L, Silingardi P, 1998. Isolation of a novel metabolizing system enriched in phase-II enzymes for short-term genotoxicity bioassays. Mutat Res 413:205–217.9651530
*Parke DV, Williams RT. 1955. Studies in detoxification: The metabolism of halogenobenzenes. (a) Meta-dichlorobenzene. (b) Further observations on the metabolism of chlorobenzene. Biochem J 59:415–422.14363110
Paschke A, Popp P. 2004. Diffusion-based calibration for solid-phase microextraction of benzene, toluene, ethylbenzene, p-xylene and chlorobenzenes from aqueous samples. J Chromatogr A 1025:11–16.14753665
*Pellizzari ED, Hartwell TD, Benjamin SH. 1982. Purgeable organic compounds in mother’s milk. Bull Environ Contam Toxicol 28:322–328.7082873
*Pellizzari ED, Hartwell TD, Perritt RL, 1986. Comparison of indoor and outdoor residential levels of volatile organic chemicals in five USA geographical areas. Environ Int 12(6):619–624.
*Pellizzari ED, Sheldon LS, Bursey JT. 1985. GC/MS determination of volatile halocarbons in blood and tissue. Method 25. In: Fishbein L, O'Neal IK, eds. Environmental carcinogens selected methods of analysis. Vol. 7. Lyon, France: International Agency for Research on Cancer, 435–444.
*Pellizzari ED, Smith DJ, Clayton CA, 2001. An assessment of the data quality for NHEXAS-Part I: exposure to metals and volatile organic chemicals in Region 5. J Expo Anal Environ Epidemiol 11:140–154.11409006
*Pereira WE, Rostad CE, Chiou CT, 1988. Contamination of estuarine water, biota, and sediment by halogenated organic compounds: A field study. Environ Sci Technol 22(7):772–778.22195660
*Perocco P, Bolognesi S, Alberghini W. 1983. Toxic activity of seventeen industrial solvents and halogenated compounds on human lymphocytes cultured in vitro. Toxicol Lett 16:69–75.6836616
*Perry DL, Chuang CC, Jungclaus GA, 1979. Identification of organic compounds in industrial effluent discharges. Athens, GA: U.S. Environmental Protection Agency, Office of Research and Development. EPA600479016.
Petit G, Champeix J. 1948. [Does an intoxication caused by paradichlorobenzene exist?] Arch des Malad Prof de Med 9:311–312. (French)
*Phillips LJ, Birchard GF. 1991. Regional variations in human toxics exposure in the USA: An analysis based on the national human adipose tissue survey. Arch Environ Contam Toxicol 21:159–168.1958071
*Plumb RH. 1991. The occurrence of Appendix IX organic constituents in disposal site ground water. Ground Water Monit Rev 11:157–164.
*Prasad I. 1970. Mutagenic effects of the herbicide 3,4-dichloroproprionanilide and its degradation products. Can J Microbiol 16:369–372.5419803
Prasad I, Pramer D. 1968. Mutagenic activity of some chloroanilines and chlorobenzenes. Genetics 20:212–213.
Pratt GC, Bock D, Stock TH, 2005. A field comparison of volatile organic compound measurement using passive organic vapor monitors and stainless steel canisters. Environ Sci Technol 39(9):3261–3268.15926577
*Pratt GC, Palmer K, Wu CY, 2000. An assessment of air toxics in Minnesota. Environ Health Perspect 108:815–825.11017885
Preston BD, Miller JA, Miller EC. 1983. Non-arene oxide aromatic ring hydroxylation of 2,2,5,5'-tetrachlorobiphenyl as the major metabolic pathway catalyzed by phenobarbital-induced rat liver microsomes. J Biol Chem 258:8304–8311.6408087
Quack B, Suess E. 1999. Volatile halogenated hydrocarbons over the western Pacific between 43˚ and 4˚ N. J Geophys Res 104(D1):1663–1678.
Rall DP. 1987. Carcinogenicity of p-dichlorobenzene. Science 236:897–898.
Rautio AW. 1988. Chlorobenzene Producers Association comments on the draft toxicological profile for 1,4-dichlorobenzene. Agency for Toxic Substances and Disease Registry. March 7, 1988.
*Redmond MS, Crocker PA, McKenna KM, 1996. Sediment toxicity testing with the amphipod Ampelisca abdita in Calcasieu Estuary, Louisiana. Arch Environ Contam Toxicol 30:53–61.
*Reichrtova E, Ciznar P, Prachar V, 1999. Cord serum immunoglobin E related to the environmental contamination of human placentas with organochlorine compounds. Environ Health Perspect 107(11):895–899.10544157
*Reichrtova E, Prachar V, Palkovicova L, 2001. Contamination of human placentas with organochlorine compounds in five Slovak regions related to different environmental characteristics. Fresenius Environ Bull 10(10):772–776.
*Reygagne A, Garnier R, Chataigner D, 1992. Encephalopathie due a l'inhalation volontaire repetee de paradichlorobenzene. Presse Med 21:267.
*Riley RA, Chart IS, Doss A, 1980a. para-Dichlorobenzene: Long-term inhalation study in the rat. ICI Report No. CTL/P/447. Imperial Chemical Industries Limited, Central Toxicology Laboratory, Alderly Park, Macclesfield, Chesire, UK.
*Riley RA, Chart IS, Gaskell B, 1980b. para-Dichlorobenzene. Long-term inhalation study in the mouse. Report No CTL/P448. Imperial Chemical Industries Limited, Central Toxicology Laboratory, Alderly Park, Macclesfield, Chesire, UK. (As cited in Loeser and Litchfield 1983)
*Rimington GE, Ziegler G. 1963. Experimental porphyria in rats induced by chlorinated benzenes. Biochem Pharmacol 12:1387–1397.14096426
Rippen G, Klopffer W, Frische R, 1984. The environmental model segment approach for estimating potential environmental concentrations. Ecotoxicol Environ Saf 8:363–377.6479083
*Robbiano L, Carrozzino R, Porta Puglia CP, 1999. Correlation between induction of DNA fragmentation and micronuclei formation in kidney cells from rats and humans and tissue-specific carcinogenic activity. Toxicol Appl Pharmacol 161:153–159.10581209
*Robinson M, Bercz JP, Ringhand HP, 1991. Ten and ninety-day toxicity studies of 1,2-dichlorobenzene administered by oral gavage to Sprague-Dawley rats. Drug Chem Toxicol 14(1&2):83–112.1889379
*Rossberg M, Aktiengesellschaft H, Lendle W, 2002. Chlorinated hydrocarbons. In: Ullmann’s encyclopedia of industrial chemistry. Weinheim, Germany: Wiley-VCH-Verlag.
RTECS. 1990. Registry of Toxic Effects of Chemical Substances. Bethesda, MD: National Library of Medicine, National Toxicology Information Program. July 18, 1990.
*RTECS. 2004. Registry of Toxic Effects of Chemical Substances. Bethesda, MD: National Library of Medicine, National Toxicology Information Program.
*Ruddick JA, Black WD, Villeneuve DC, 1983. A teratological evaluation following oral administration of trichloro- and dichlorobenzene isomers to the rat. Teratology 27(2):73A–74A.6845221
*Ryan TJ, Hart EM, Kappler LL. 2002. VOC exposures in a mixed-use university art building. Am Ind Hyg Assoc J 63:703–708.
*Safe SH, Zacharewski T. 1997. Organochlorine exposure and risk for breast cancer. In: Aldaz CM, Gould MN, McLachlan, , eds. Etiology of breast and gynecological cancers. New York, NY: John Wiley & Sons, 133–145.
Saito K, Kaneko H, Isobe N, 1992. Differences in α_2μ_- globulins increased in male rat kidneys following treatment with several α_2μ_-globulin accumulating agents: Cystein protease(s) play(s) an important role in production of kidney-type-α_2μ_-globulin. Toxicology 76:177–186.1281346
*Saito K, Uwagawa S, Kaneko H, 1996. α_2μ_-Globulins in the urine of male rats: A reliable indicator for α2μ-globulin accumulation in the kidney. Toxicology 106:149–157.8571386
Salkinoja-Salonen MS, Jokela JK. 1991. Measurement of organic halogen compounds in urine as an indicator of exposure. Scand J Work Environ Health 17(1):75–78.
*Sarbhoy RK. 1980. Effect of para-dichlorobenzene on the somatic chromosomes and mitosis of Lens esculenta (L.) Moench. Cytologia 45:381–388.
Saunders M, Fox DJ, Salisbury C, 2004. Placental transfer and fetal uptake of pesticides. Toxicol Appl Pharmacol 197(3):341.
*Sax NI, Lewis RJ Sr. 1987. Hawley's condensed chemical dictionary. 11th ed. New York, NY: Van Nostrand Reinhold Company, 376.
*Sax SN, Bennett DH, Chillrud SN, 2004. Differences in source emission rates of volatile organic compounds in inner-city residences of New York City and Los Angeles. J Expo Anal Environ Epidemiol 14(Supp 1):S95–S109.15118751
Schaeffer V. 1991. Briefing package: Hazard evaluation of consumer products containing 1,4-dichlorobenzene. Washington, DC: U.S. Consumer Product Safety Commission, Division of Health Effects. Directorate for Health Sciences.
Schlede E, Mischke U, Roll R, 1992. A national validation study of the acute-toxic-class method-an alternative to the LD50 test. Arch Toxicol 66(7):455–470.1444812
*Schraa G, Boone ML, Jetten MSM, 1986. Degradation of 1,4 dichlorobenzene by Alcaligenes sp. strain A175. Appl Environ Microbiol 52(6):1374–1381.3789724
*Schwarzenbach RP, Westall J. 1981. Transport of nonpolar organic compounds from surface water to groundwater. Laboratory sorption studies. Environ Sci Technol 15:1360–1367.
*Schwartzenbach RP, Giger W, Hoehn E, 1983. Behavior of organic compounds during infiltration of river valley to groundwater. Field Studies. Environ Sci Technol 17(8):472–479.22283166
*Scuderi R. 1986. Determination of para-dichlorobenzene releases from selected consumer products. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances.
Serrano-Trespalacios PI, Ryan L, Spengler JD. 2004. Ambient, indoor and personal exposure relationship of volatile organic compounds in Mexico City Metropolitan Area. J Expo Anal Environ Epidemiol 14:S118–S132.15118753
*Setchell BP, Waites GMH. 1975. The blood testis barrier. In: Creep RO, Astwood EB, eds., Geiger SR, executive ed. Handbook of physiology: Endocrinology V (Chapter 6). Washington DC: American Physiological Society.
*Seto Y. 1994. Determination of volatile substances in biological samples by headspace gas chromatography. J Chromatogr A 674:25–62.
*Sexton K, Adgate JL, Church TR, 2005. Children's exposure to volatile organic compounds as determined by longitudinal measurements in blood. Environ Health Perspect 113(3):342–349.15743726
*Sexton K, Adgate JL, Ramachandran G, 2004. Comparison of personal, indoor, and outdoor exposures to hazardous air pollutants in three urban communities. Environ Sci Technol 38:423–430.14750716
*Shah JJ, Heyerdahl EK. 1988. National ambient volatile organic compounds (VOCs): Data base update. Research Triangle Park, NC: U.S. Environmental Protection Agency, Atmospheric Sciences Research Laboratory. EPA600388010A.
Shah JJ, Singh HB. 1988. Distribution of volatile organic chemicals in outdoor and indoor air: A national VOCs data base. Environ Sci Technol 22:1381–1388.22200458
*Sharma AK, Battacharya NK. 1956. Chromosome breakage through paradichlorobenzene treatment. Cytologia 21:353–360.
Sharma AK, Sarkar SK. 1957. A study of the comparative effect of chemicals on chromosomes of roots, pollen mother cells and pollen grains. Proc Ind Acad Sci B 45:288–293.
*Shelby MD, Witt KL. 1995. Comparison of results from mouse bone marrow chromosome aberration and micronucleus tests. Environ Mol Mutagen 25:302–313.7607185
Shelby MD, Erexson GL, Hook GJ, 1993. Evaluation of a three-exposure mouse bone marrow micronucleus protocol: Results with 49 chemicals. Environ Mol Mutagen 21(2):160–179.8444144
Sheldon LS, Hites RA. 1978. Organic compounds in the Delaware River. Environ Sci Technol 12:1188–1194.
*Shelton JL, Burow KR, Belitz K, 2000. Low-level volatile organic compounds in active public supply wells as ground-water tracers in the Los Angeles physiographic basin, California, 2000. California State Water Resources Control Board. Water Resources Investigation Report 01–4188.
Shen TT. 1982. Estimation of organic compound emissions from waste lagoons. J Air Pollut Control Assoc 32:79–82.
*Shendell DG, Winer AM, Stock TH, 2004. Air concentrations of VOCs in portable and traditional classrooms: Results of a pilot study in Los Angeles County. J Expo Anal Environ Epidemiol 14:44–59.14726944
*Sherman JH, Nair RS, Steinmetz KL, 1998. Evaluation of unscheduled DNA synthesis (UDS) and replicative DNA synthesis (RDS) following treatment of rats and mice with p-dichlorobenzene. Teratog Carcinog Mutagen 18:309–318.10052566
*Shimizu N, Yasui Y, Matsumoto N. 1983. Structural specificity of aromatic compounds with special reference to mutagenic activity in Salmonella typhimurium - a series of chloro- or fluoro-nitrobenzene derivatives. Mutat Res 116:217–238.6339893
Shiraishi H, Pilkington NH, Otsuki A, 1985. Occurrence of chlorinated polynuclear aromatic hydrocarbons in tap water. Environ Sci Technol 19:585–590.22148299
*Shiu W-Y, Mackay D. 1997. Henry’s law constants on selected aromatic hydrocarbons, alcohols, and ketones. J Chem Eng Data 42:27–30.
Siegel E, Wason S. 1986. Mothball toxicity. Pediatr Clin North Am 33:369–374.3515301
Simmon VF, Riccio ES, Peirce MV. 1979. In vitro microbiological genotoxicity tests of chlorobenzene, m-dichlorobenzene, o-dichlorobenzene, and p-dichlorobenzene. Final Report. U.S. Environmental Protection Agency. EPA68022947.
Singh HB, Salas LJ, Smith A, 1980. Atmospheric measurements of selected hazardous organic chemicals. Research Triangle Park, NC: U.S. Environmental Protection Agency, Environmental Sciences Research Laboratory.
*Singh HB, Salas LJ, Smith AJ, 1981a. Measurements of some potentially hazardous organic chemicals in urban environments. Atmos Environ 15:601–612.
*Singh HB, Salas LJ Smith R, 1981b. Atmospheric measurements of selected hazardous organic chemicals. Research Triangle Park, NC: U.S. Environmental Protection Agency. Environmental Science Research Laboratory.
Sinkkonen S, Welling L, Vattulainen A, 1996. Short chain aliphatic halocarbons and polychlorinated biphenyls in pine needles: Effects of metal scrap plant emissions. Chemosphere 32(10):1971–1982.
Sittig M. 1985. Handbook of toxic and hazardous chemicals and carcinogens. 2nd ed. Park Ridge, NJ: Noyes Publications, 313–316.
*Spain JC, Nishino SF. 1987. Degradation of 1,4-dichlorobenzene by a Pseudomonas sp. Appl Environ Microbiol 53:1010–1019.3606087
Spicer CW, Riggin RM, Holdren MW, 1985. Atmospheric reaction products from hazardous air pollutant degradation. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development. EPA600385028. PB85185841.
*Spiess E, Sommer C, Gorisch H. 1995. Degradation of 1,4-dichlorobenzene by Xanthobacter flavus 14 p1. Appl Environ Microbiol 61(11):3884–3888.8526500
Spirtas R, Stewart PA, Lee JS, 1991. Retrospective cohort mortality study of workers at an aircraft maintenance facility. I. Epidemiological results. Br J Ind Med 8:515–530.
*Squillace PJ, Moran MJ, Lapham WW, 1999. Volatile organic compounds in untreated ambient groundwater of the United States, 1985–1995. Environ Sci Technol 33(23):4176–4187.
*SRI. 1984. Directory of chemical producers. United States of America. Menlo Park, CA: SRI International, 525–526
SRI. 1987. Directory of chemical producers: United States of America. Menlo Park, CA: SRI International, 568–569.
*SRI. 1988. Directory of chemical producers: United States of America. Menlo Park, CA: SRI International, 558–559.
*SRI International. 1995. 1995 Directory of chemical producers - United States of America. Menlo Park, CA: SRI International, 542.
*SRI. 1996. 1996 Directory of chemical producers - United States of America. Menlo Park, CA: SRI International, 536.
*SRI International. 1997. 1997 Directory of chemical producers - United States of America. Menlo Park, CA: Stanford Research Institute International, 542.
SRI International. 1998. 1998 Directory of chemical producers- United States of America. Menlo Park, CA: Stanford Research Institute, 548.
*SRI International. 1999. 1999 Directory of chemical producers- United States of America. Menlo Park, CA: SRI, 549.
SRI International. 2000. 2000 Directory of chemical producers- United States of America. Menlo Park, CA: SRI International, 548.
*SRI International. 2001. 2001 Directory of chemical producers- United States of America. Menlo Park, CA: SRI International, 544.
SRI International. 2002. 2002 Directory of chemical producers- United States of America. Menlo Park, CA: SRI International, 543–544.
*SRI International. 2003. 2003 Directory of chemical producers- United States of America. Menlo Park, CA: SRI International, 538.
*SRI. 2005. 2005 Directory of Chemical Producers. Menlo Park, California: SRI Consulting.:317,368–369,546.
*Srivastava LM. 1966. Induction of mitotic abnormalities in certain genera of tribe Vicieae by paradichlorobenzene. Cytologia 31:166–171.
*Stackelberg PE, Kauffman LJ, Ayers MA, 2001. Frequently co-occurring pesticides and volatile organic compounds in public supply and monitoring wells, Southern New Jersey, USA. Environ Toxicol Chem 20(4):853–865.11345463
*Stanley JS. 1986. Broad scan analysis of the FY 82 National Human Adipose Tissue Survey specimens. Vol. I - Executive summary. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA560586035.
*Staples CA, Werner AF, Hoogheen TJ. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4:131–142.
*Staudinger J, Roberts PV. 1996. A critical review of Henry’s law constants for environmental applications. Crit Rev Environ Sci Tech 26(3):205, 268–269.
*Stauffer TB, Antworth CP, Boggs JM, 1994. A natural gradient tracer experiment in an heterogeneous aquifer with measured in situ biodegradation rates: A case for natural attenuation. Symposium on intrinsic bioremediation in ground water, 73–84.
*Stefaniak AB, Breysse PN, Murray MPM, 2000. An evaluation of employee exposure to volatile organic compounds in three photocopy centers. Environ Res 83:162–173.10856189
*Steinmetz KL, Spanggord RJ. 1987a. Examination of the potential of p-dichlorobenzene to induce unscheduled DNA synthesis or DNA replication in the in vivo - in vitro mouse hepatocyte DNA repair assay. Final Report. SRI International.
*Steinmetz KL, Spanggord RJ. 1987b. Evaluation of the potential of p-dichlorobenzene to induce unscheduled DNA synthesis or DNA replication in the in vivo-in vitro rat kidney DNA repair assay. Final Report. SRI International.
Stewart PA, Lee JS, Marano DE, 1991. Retrospective cohort mortality study of workers at an aircraft maintenance facility. II. Exposures and their assessment. Br J Ind Med 48:531–537.1878309
*Stine ER, Gunawardhana L, Sipes IG. 1991. The acute hepatotoxicity of the isomers of dichlorobenzene in Fischer 344 and Sprague-Dawley rats: Isomer specific and strain specific differential toxicity. Toxicol Appl Pharmacol 109:472–481.1853346
*Stubin AI, Brosnan TM, Porter KD, 1996. Organic priority pollutants in New York City municipal wastewaters: 1989–1993. Water Environ Res 68:1037–1044.
*Suzuki A, Nagai H, Hiratsuka H, 1991. [Effects of 1,4-dichlorobenzene on antibody production in guinea pigs.] Oyo Yakuri 42(2):197–208. (Japanese)
Symons JM, Bellar TA, Carswell JK, 1975. National organics reconnaissance survey for halogenated organics. J Am Water Works Assoc (November):634–648.
*Tabak HH, Quave SA, Mashni CI, 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53:1503–1518.
Tananaki C, Zotou A, Thrasyvoulou A. 2005. Determination of 1,2-dibromoethane, 1,4-dichlorobenzene and naphthalene residues in honey by gas chromatography--mass spectrometry using purge and trap thermal desorption extraction. J Chromatogr A 1083(1–2):146–152.16078701
*Tansel B, Eyma RR. 1999. Volatile organic contaminant emissions from wastewater treatment plants during secondary treatments. Water Air Soil Pollut 112:315–325.
*Taylor LA, Chapman PM, Miller RA, 1998. The effects of untreated municipal sewage discharge to the marine environment off Victoria, British Columbia, Canada. Water Sci Technol 38(10):282–292.
Tegethoff K, Herbold BA, Bomhard EM. 2000. Investigations on the mutagenicity of 1,4-dichlorobenzene and its main metabolite 2,5-dichlorophenol in vivo and in vitro. Mutat Res 470:161–167.11027971
*Thomas KW, Pellizzari ED, Cooper SD. 1991. A canister based method for collection and GC/MS analysis of volatile organic compounds in human breath. J Anal Toxicol 15:54–59.2051745
*Topping B. 1987. The biodegradability of para-dichlorobenzene and its behaviour in model activated sludge plants. Water Res 21(3):293–300.
*TRI03. 2005. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access, Offices of Environmental Information, U.S. Environmental Protection Agency. Toxic Release Inventory. http://www.epa.gov/triexplorer/. August, 2005.
*Trieff NM, Ficklen D, Gan J. 1993. In vitro inactivation of glucose-6-phosphate dehydrogenase from human red blood cells by acrolein: A possible biomarker of exposure. Toxicol Lett 69:121–127.8212054
*Trieff NM, Ramanujam VMS, Stara JF, 1991. Water quality criteria assessment for chlorinated benzenes using the quantitative structure activity relation approach and porphyrogenic endpoint in rats. Int J Environ Health Res 1:215–230.
*Tyl RW, Neeper-Bradley TL. 1989. Paradichlorobenzene: Two generation reproductive study of inhaled paradichlorobenzene in Sprague-Dawley (CD) rats. Laboratory Project 86–81-90605. Washington, DC: Chemical Manufacturers Association, Chlorobenzene Producers Association.
*Umemura T, Saito M, Takagi A, 1996. Isomer-specific acute toxicity and cell proliferation in livers of B6C3F1 mice exposed to dichlorobenzene. Toxicol Appl Pharmacol 137:268–274.8661352
Umemura T, Takada K, Ogawa Y, 1990. Sex difference in inhalation toxicity of p-dichlorobenzene (p-DCB) in rats. Toxicol Lett 52:209–214.2378004
*Umemura T, Takada K, Schulz C, 1998. Cell proliferation in the livers of male mice and rats exposed to the carcinogen p-dichlorobenzene: Evidence for thresholds. Drug Chem Toxicol 21(1):57–66.9530531
*Umemura T, Tokumo K, Williams GM. 1992. Cell proliferation induced in the kidneys and livers of rats and mice by short term exposure to the carcinogen p-dichlorobenzene. Arch Toxicol 66(7):503–507.1359854
*U.S. Congress. 1986. Superfund amendments and reauthorization act of 1986. Title III-Emergency Planning and Community Right-to-Know. Ninety-ninth Congress of the United States of America.
*U.S. Congress. 1990. Clean Air Amendments. Title III, Hazardous Air Pollutants, Section 112(b), Hazardous Air Pollutants as Amended, October 26, 1990. One Hundred and First Congress of the United States of America, 2nd Session Report 101–952.
*USGS. 2002. Trace elements and organic compounds in streambed sediment and fish tissue of coastal New England streams, 1998–1999. Pembroke, NH: U.S. Geological Survey. Report 024179.
USITC. 1987. Synthetic organic chemicals: United States production and sales, 1987. Washington, DC: U.S. International Trade Commission. USITC publication 2118, 3–2, 3–7.
Valentovic MA, Ball JG, Anestis D, 1993a. Acute hepatic and renal toxicity of dichlorobenzene isomers in Fischer 344 rats. J Appl Toxicol 13(1):1–7.8440869
Valentovic MA, Ball JG, Anestis D, 1993b. Modification of P450 activity and its effect on 1,2-dichlorobenzene toxicity in Fischer 344 rats. Toxicology 79:169–180.8316947
*van der Meer JR, Bosma TNP, de Bruin WP, 1992. Versatility of soil column experiments to study biodegradation of halogenated compounds under environmental conditions. Biodegradation 3:265–284.
Van Wezel AP, DeVries DAM, Sijm DTHM, 1996. Use of the lethal body burden in the evaluation of mixture toxicity. Ecotoxicol Environ Saf 35(3):236–241.9006999
van Wezel AP, Sijm DTHM, Seinen W. 1995. Use of lethal body burdens to indicate species differences in susceptibility to narcotic toxicants. Chemosphere 31(5):3201–3209.7493161
*Verschueren K. 1983. Handbook of environmental data on organic chemicals. 2nd ed. New York, NY: Van Nostrand Reinhold Company, 477–478.
*Verschueren K. 2001. o-dichlorobenzene, m-dichlorobenzene and p-dichlorobenzene. In: Handbook of environmental data on organic chemicals. Volume 1. New York, NY: John Wiley & Sons, Inc.
*Versonnen BJ, Arijs K, Verslycke T, 2003. In vitro and in vivo estrogenicity and toxicity of o-, m-, and p-dichlorobenzene. Environ Toxicol Chem 22(2):329–335.12558164
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
*Wakeham SG, Davis AC, Karas JL. 1983. Mesocosm experiments to determine the fate and persistence of volatile organic compounds in coastal seawater. Environ Sci Technol 17:611–617.22288706
*Wallace L, Buckley T, Pellizzari E, 1996. Breath measurements as volatile organic compound biomarkers. Environ Health Perspect 104(Suppl 5):861–869.8933027
*Wallace L, Pellizzari E, Hartwell T, 1986c. Concentrations of 20 volatile organic compounds in the air and drinking water of 350 residents of New Jersey compared with concentrations in their exhaled breath. J Occup Med 28(8):603–608.3746480
*Wallace L, Pellizzari E, Sheldon L, 1986a. The total exposure assessment methodology (TEAM) study: Direct measurement of personal exposures through air and water for 600 residents of several U.S. cities. In: Cohen Y, ed. Pollutants in a multimedia environment. New York, NY: Plenum Publishers Corporation, 289–315.
*Wallace LA. 1986. Personal exposures, indoor and outdoor air concentrations, and exhaled breath concentrations of selected volatile organic compounds measured for 600 residents of New Jersey, North Dakota, North Carolina and California. Toxicol Environ Chem 12:215–236.
*Wallace LA. 1987. The total exposure assessment methodology (TEAM) study: Summary and analysis: volume I. U.S. Environmental Protection Agency. Office of Research and Development. 600687002a.
Wallace LA. 1991. Personal exposure to 25 volatile organic compounds. EPA’s 1987 team study in Los Angeles, California. Toxicol Ind Health 7(5/6):203–208.1780860
Wallace LA, Pellizzari E, Hartwell T, 1985. Personal exposures, indoor-outdoor relationships, and breath levels of toxic air pollutants measured for 335 persons in New Jersey. Atmos Environ 19:1651–1661.
*Wallace LA, Pellizzari ED, Hartwell TD, 1986b. Total exposure assessment methodology (TEAM) study: Personal exposures, indoor-outdoor relationships, and breath levels of volatile organic compounds in New Jersey. Environ Int 12:369–387.
*Wallace LA, Pellizzari ED, Hartwell TD, 1987. The team study: Personal exposures to toxic substances in air, drinking water, and breath of 400 residents of New Jersey, North Carolina, and North Dakota. Environ Res 43:290–307.3608934
*Wallace LA, Pellizzari ED, Hartwell TD, 1988. The California team study: Breath concentrations and personal exposures to 26 volatile compounds in air and drinking water of 188 residents of Los Angeles, Antioch, and Pittsburg, CA. Atmos Environ 22:2141–2163.
*Wallace LA, Pellizzari ED, Hartwell TD, 1989. The influence of personal activities on exposure to volatile organic compounds. Environ Res 50:37–55.2792060
Wang L, Zhou Q, Zhang BS, 2003. The biodegradation of 1,3-dichlorobenzene by an adapted strain Bacillus cereus PF-11 derived from town-gas industrial effluent. J Environ Sci Health Part A 38(9):1837–1848.
*Wang M-J, Jones KC. 1994a. Behavior and fate of chlorobenzenes in spiked and sewage sludge-amended soil. Environ Sci Technol 28:1843–1852.22175924
*Wang M-J, Jones KC. 1994d. Occurrence of chlorobenzenes in nine United Kingdom retail vegetables. J Agric Food Chem 42:2332–2338.
*Wang M-J, Jones KC. 1994b. The chlorobenzene content of contemporary U.K. sewage sludges. Chemosphere 28(6):1201–1210.
*Wang M-J, Jones KC. 1994c. Uptake of chlorobenzenes by carrots from spiked and sewage sludge-amended soil. Environ Sci Technol 28:1260–1267.22176317
*Wang M-J, Bokern M, Boehmen C, 1996. Phytotoxicity uptake and metabolism of 1,4-dichlorobenzene by plant cells. Environ Toxicol Chem 15(7):1109–1114.
*Wang M-J, McGrath SP, Jones KC. 1995. Chlorobenzenes in field soil with a history of multiple sewage sludge applications. Environ Sci Technol 29(2):356–362.22201381
*Washall JW, Wampler TP. 1988. Purge and trap analysis of aqueous samples with cryofocusing. Am Lab (July):70–74.
*Waters MD, Snadhu SS, Simmon VF, 1982. Study of pesticide genotoxicity. Basic Life Sci 21:275–326.7150196
Weintraub E, Gandhi D, Robinson C. 2000. Medical complications due to mothball abuse. South Med J 91(4):427–429.
*Weller RW, Crellin AJ. 1953. Pulmonary granulomatosis following extensive use of paradichlorobenzene. Arch Intern Med 91:408–413.
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32a:10–18.
*Westrick JJ, Mello JW, Thomas RF. 1984. The groundwater supply survey. J Am Water Works Assoc 76:52–59.
*WHO. 1996. Guidelines for drinking-water quality. Second Edition. Volume 2. Health criteria and other supporting information. Geneva, Switzerland: World Health Organization.
*WHO. 2000. Air quality guidelines. 2nd edition. World Health Organization. Geneva, Switzerland. http://www.euro.who.int/document/aiq/3summary.pdf. September 7, 2005.
*WHO. 2004. Guidelines for drinking-water quality. 3rd edition. World Health Organization. Geneva, Switzerland. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/index.html. August 31, 2005.
*Widdowson EM, Dickerson JWT. 1964. Chapter 17: Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise, volume II - the elements part A. New York: Academic Press.
Williams RT. 1959. The metabolism of halogenated aromatic hydrocarbons. In: Detoxication mechanisms. 2nd ed. New York, NY: John Wiley and Sons, 237–258.
*Williams GM, Mori H, McQueen CA. 1989. Structure-activity relationships in the rat hepatocyte DNA-repair test for 300 chemicals. Mutat Res 221:263–286.2682231
*Wilson JT, Enfield CG, Dunlap WJ, 1981. Transport and fate of selected organic pollutants in a sandy soil. J Environ Qual 10:501–506.
Witt KL, Knapton A, Wehr CM, 2000. Micronucleated erythrocyte frequency in peripheral blood of B6C3F1 mice from short-term, prechronic, and chronic studies on the NTP Carcinogenesis Bioassay Program. Environ Mol Mutagen 36:163–194.11044899
Won D, Corsi RL, Rynes M. 2001. Sorptive interactions between VOCs and indoor materials. Indoor Air 11:246–256.11761600
Woodruff TJ, Axelrad DA, Caldwell J, 1998. Public health implications of 1990 air toxics concentrations across the United States. Environ Health Perspect 106:245–251.9518474
*Yalkowsky SH, He Y. 2003. 1,4-dichlorobenzene and 1,3-dichlorobenzene. In: Handbook of aqueous solubility data. Boca Raton, FL: CRC Press, 207–208.
Yang KH, Peterson Re. 1977. Differential effects of halogenated aromatic hydrocarbons on pancreatic excretory function in rats. Fed Proc 36:356.
Yasunaga K, Kiyonari A, Oikawa T, 2004. Evaluation of the Salmonella umu test with 83 NTP chemicals. Environ Mol Mutagen 44(4):329–345.15476194
Yoshida T, Andoh K, Fukuhara M. 1998. Estimation of absorption of environmental contaminants in low-level exposure by pharmacokinetic analysis. J Toxicol Environ Health A 54(2):145–158.9652550
Yoshida T, Andoh K, Fukuhara M. 2002a. Urinary 2,5-dichlorphenol as biological index for p-dichlorobenzene exposure in the general population. Arch Environ Contam Toxicol 43:481–485.12399920
Yoshida T, Andoh K, Kosaka H, 2002b. Inhalation toxicokinetics of p-dichlorobenzene and daily absorption and internal accumulation in chronic low-level exposure to humans. Arch Toxicol 76(5–6):306–315.12107648
*Young DR, Heesen TC. 1978. DDT, PCB and chlorinated benzenes in the marine ecosystem off Southern California. In: Jolley RL, Gorchev H, Hamilton DH Jr., eds. Water chlorination: Environmental impact and health effects, Volume 2. Ann Arbor, MI: Ann Arbor Science Publishers, Inc., 267–290.
*Young DR, Gossett RW, Baird RB, 1981. Wastewater inputs and marine bioaccumulation of priority pollutant organics off Southern California. In: Jolley RL, Brungs WA, Cotruvo JA, , eds. Water chlorination environmental impact and health effects, Vol. 4, Book 2. Ann Arbor, MI: Ann Arbor Science Publishers, Inc., 871–884.
*Young DR, Heesen TC, Gossett RW. 1980. Chlorinated benzenes in Southern California municipal wastewaters and submarine discharge zones. In: Jolley RL, Brungs WA, Cumming RB, eds. Water chlorination: Environmental impact and health effects, Volume 3. Ann Arbor, MI: Ann Arbor Science Publishers, Inc., 471–486.
Young WF, Horth H, Crane R, 1996. Taste and odour threshold concentrations of potential potable water contaminants. Water Res 30(2):331–340.
*Younis HS, Hoglen NC, Kuester RK, 2000. 1,2-Dichlorobenzene-mediated hepatocellular oxidative stress in Ficher-344 and Sprague-Dawley rats. Toxicol Appl Pharmacol 163:141–148.10698672
Zapata-Gayon C, Zapata-Gayon N, Gonzalex-Angulo A. 1982. Clastogenic chromosomal aberrations in 26 individuals accidentally exposed to ortho dichlorobenzene vapors in the National Medical Center in Mexico City. Arch Environ Health 37:231–235.7114904
*Zenser L-P, Lang A, Knecht U. 1997. N-Acetyl-S-(dichlorophenyl)cysteines as suitable biomarkers for the monitoring of occupational exposure to 1,2-dichlorobenzene. Int Arch Occup Environ Health 69:252–254.9137999
*Zhang J, Zhao W, Pan J, 2005. Tissue-dependent distribution and accumulation of chlorobenzenes by vegetables in urban area. Environ Int 31(6):855–860.16002141
*Zhu J, Newhook R, Marro L, 2005. Selected volatile organic compounds in residential air in the city of Ottawa, Canada. Environ Sci Technol 39(11):3964–3971.15984771
Ziegler EE, Edwards BB, Jensen RL, 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
*Zielinska B, Fujita E, Sagebiel J, 1998. Arizona hazardous air pollutants monitoring program. J Air Waste Manage Assoc 48:1038–1050.
*Zielinska B, Sagebiel J, Harshfield G, 2001. Volatile organic compound measurements in the California/Mexico border region during SCOS97. Sci Total Environ 276:19–31.11516136
*Zissu D. 1995. Histopathological changes in the respiratory tract of mice exposed to ten families of airborne chemicals. J Appl Toxicol 15(3):207–213.7560741
Zupko A, Edwards L. 1949. A toxicological study of p-dichlorobenzene. J Am Pharm Assoc 38:124–131.