# 8 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines pertaining to dichlorobenzenes in air, water, and other media are summarized in Table 8-1.

ATSDR has derived an MRL of 2 ppm for acute-duration inhalation exposure to 1,4-DCB. The acute inhalation MRL is based on a NOAEL of 15 ppm for irritant effects in humans exposed to 1,4-DCB in the workplace (Hollingsworth et al. 1956). An uncertainty factor of 10 for human variability was applied.

ATSDR has derived an MRL of 0.2 ppm for intermediate-duration inhalation exposure to 1,4-DCB. The intermediate inhalation MRL is based on benchmark dose analysis of liver weight increases in male rats exposed to 1,4-DCB vapors for 6 hours/day for 15 weeks (Tyl and Neeper-Bradley 1989). The resulting BMCL_1sd_ of 92.45 ppm was duration-adjusted from intermittent to continuous exposure, converted to a human equivalent concentration (23 ppm), and divided by an uncertainty factor of 100 (10 for extrapolating from animals to humans and 10 for human variability).

ATSDR has derived an MRL of 0.01 ppm for chronic-duration inhalation exposure to 1,4-DCB. The chronic inhalation MRL is based on benchmark dose analysis of incidences of nasal lesions in female rats exposed to 1,4-DCB vapors for 6 hours/day, 5 days/week for 104 weeks (Aiso et al. 2005b). The resulting BMCL_10_ of 9.51 ppm was duration-adjusted from intermittent to continuous exposure, converted to a human equivalent concentration (0.27 ppm), and divided by an uncertainty factor of 30 (3 for extrapolating from animals to humans and 10 for human variability).

ATSDR has derived an MRL of 0.7 mg/kg/day for acute-duration oral exposure to 1,2-DCB. The acute oral MRL is based on benchmark dose analysis of liver weight increases in female rats administered 1,2-DCB by daily oral gavage for 10 days (Robinson et al. 1991). The resulting BMDL_1sd_ of 67.73 mg/kg/day was divided by an uncertainty factor of 100 (10 for extrapolating from animals to humans and 10 for human variability).

ATSDR has derived an MRL of 0.6 mg/kg/day for intermediate-duration oral exposure to 1,2-DCB. The intermediate oral MRL is based on benchmark dose analysis of liver weight increases in female rats administered 1,2-DCB by oral gavage on 5 days/week for 13 weeks (NTP 1985). The resulting BMDL1sd of 89.27 mg/kg/day was duration-adjusted from intermittent to daily exposure (63.76 mg/kg/day) and divided by an uncertainty factor of 100 (10 for extrapolating from animals to humans and 10 for human variability).

ATSDR has derived an MRL of 0.3 mg/kg/day for chronic-duration oral exposure to 1,2-DCB. The chronic oral MRL is based on benchmark dose analysis of incidences of kidney lesions in male mice administered 1,2-DCB by oral gavage on 5 days/week for 103 weeks (NTP 1985). The resulting BMDL_10_ of 43.04 mg/kg/day was duration-adjusted from intermittent to daily exposure (30.74 mg/kg/day) and divided by an uncertainty factor of 100 (10 for extrapolating from animals to humans and 10 for human variability).

ATSDR has derived an MRL of 0.4 mg/kg/day for acute-duration oral exposure to 1,3-DCB. The acute oral MRL is based on benchmark dose analysis of liver weight increases in female rats administered 1,3-DCB by oral gavage for 10 days (McCauley et al. 1995). The resulting BMDL_1sd_ of 36.32 mg/kg/day was divided by an uncertainty factor of 100 (10 for extrapolating from animals to humans and 10 for human variability).

ATSDR has derived an MRL of 0.02 mg/kg/day for intermediate-duration oral exposure to 1,3-DCB. The intermediate oral MRL is based on benchmark dose analysis of incidences of pituitary lesions in male rats administered 1,3-DCB by daily oral gavage for 90 days (McCauley et al. 1995). The resulting BMDL_10_ of 2.1 mg/kg/day was divided by an uncertainty factor of 100 (10 for extrapolating from animals to humans and 10 for human variability).

ATSDR has derived an MRL of 0.07 mg/kg/day for intermediate-duration oral exposure to 1,4-DCB. The intermediate oral MRL is based on benchmark dose analysis of serum alkaline phosphatase levels in female dogs administered 1,4-DCB by capsule on a presumed 5 days/week for 6 months (Naylor and Stout 1996). The resulting BMDL_1sd_ of 9.97 mg/kg/day was duration-adjusted from intermittent to daily exposure (7 mg/kg/day) and divided by an uncertainty factor of 100 (10 for extrapolating from animals to humans and 10 for human variability).

ATSDR has derived an MRL of 0.07 mg/kg/day for chronic-duration oral exposure to 1,4-DCB. The chronic oral MRL is based on benchmark dose analysis of serum alkaline phosphatase levels in female dogs administered 1,4-DCB by capsule on a presumed 5 days/week for 1 year (Naylor and Stout 1996). The resulting BMDL1sd of 10 mg/kg/day was duration-adjusted from intermittent to daily exposure (7 mg/kg/day) and divided by an uncertainty factor of 100 (10 for extrapolating from animals to humans and 10 for human variability).

EPA has verified an oral reference dose (RfD) of 0.09 mg/kg/day for 1,2-DCB based on a NOAEL of 85.7 mg/kg/day for kidney effects in rats and an uncertainty factor of 1,000 (IRIS 2005). EPA also verified an inhalation reference concentration (RfC) of 0.8 mg/m^3^ (0.1 ppm) for 1,4-DCB based on a NOAEL of 75 mg/m^3^ for liver effects in rats and an uncertainty factor of 100 (IRIS 2005).

EPA has determined that 1,2-DCB and 1,3-DCB are not classifiable as to human carcinogenicity and assigned them cancer weight-of-evidence classification Group D (IRIS 2005). IARC similarly determined that 1,2-DCB and 1,3-DCB are not classifiable as to carcinogenicity to humans (Group 3) (IARC 1999). IARC additionally determined that 1,4-DCB is possibly carcinogenic to humans (Group 2B) (IARC 1999). The Department of Health and Human Services (DHHS) concluded that 1,4-DCB is reasonably anticipated to be a human carcinogen (NTP 2005).

Table 8-1 Regulations and Guidelines Applicable to Dichlorobenzenes

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification
| 1,2-Dichlorobenzene | Group 3^a^ | IARC 1999
| 1,3-Dichlorobenzene | Group 3^a^ | IARC 1999
| 1,4-Dichlorobenzene | Group 2B^b^
WHO | Air quality guideline | No data | WHO 2000
| Drinking water guideline | | WHO 2004
| 1,2-Dichlorobenzene | 1 mg/L^c^ | WHO 2004
| 1,3-Dichlorobenzene | Toxicological data are insufficient to permit derivation of health-based guideline value | WHO 2004
| 1,4-Dichlorobenzene | 0.3 mg/L^c^ | WHO 2004
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV (8-hour TWA) | | ACGIH 2003
| 1,2-Dichlorobenzene | 25 ppm | ACGIH 2003
| STEL | 50 ppm | ACGIH 2003
| Carcinogenicity classification | A4^d^ | ACGIH 2003
| 1,4-Dichlorobenzene | 10 ppm | ACGIH 2003
| Carcinogenicity classification | A3^e^ | ACGIH 2003
EPA | Hazardous air pollutant | | EPA 2004h 42USC7412
| 1,4-Dichlorobenzene | Yes | EPA 2004h 42USC7412
NIOSH | REL (10-hour TWA) | | NIOSH 2004
| 1,2-Dichlorobenzene (ceiling limit) | 50 ppm | NIOSH 2004
| 1,4-Dichlorobenzene | Carcinogen | NIOSH 2004
| IDLH | | NIOSH 2004
| 1,2-Dichlorobenzene | 200 ppm | NIOSH 2004
| 1,4-Dichlorobenzene | 150 ppm | NIOSH 2004
OSHA | PEL (8-hour TWA) for general industry | | OSHA 2004c 29CFR1910.1000, Table Z-1
| 1,2-Dichlorobenzene (ceiling limit) | 50 ppm | OSHA 2004c 29CFR1910.1000, Table Z-1
| 1,4-Dichlorobenzene | 75 ppm | OSHA 2004c 29CFR1910.1000, Table Z-1
| PEL (8-hour TWA) for construction industry | | OSHA 2004b 29CFR1926.55, Appendix A
| 1,2-Dichlorobenzene (ceiling limit) | 50 ppm | OSHA 2004b 29CFR1926.55, Appendix A
| 1,4-Dichlorobenzene | 75 ppm | OSHA 2004b 29CFR1926.55, Appendix A
| PEL (8-hour TWA) for shipyard industry | | OSHA 2004a 29CFR1915.1000, Table Z
| 1,2-Dichlorobenzene (ceiling limit) | 50 ppm | OSHA 2004a 29CFR1915.1000, Table Z
| 1,4-Dichlorobenzene | 75 ppm | OSHA 2004a 29CFR1915.1000, Table Z
b. Water
EPA | Designated as a hazardous substances pursuant to Section 311(b) of the Clean Water Act | | EPA 2004m 40CFR116.4
| 1,2-Dichlorobenzene | Yes | EPA 2004m 40CFR116.4
| 1,4-Dichlorobenzene | Yes
| Drinking water standard | | EPA 2004g 40CFR141.32
| 1,2-Dichlorobenzene | 0.6 mg/L | EPA 2004g 40CFR141.32
| 1,4-Dichlorobenzene | 0.075 mg/L | EPA 2004g 40CFR141.32
| Drinking water standards and health advisories
| 1,2-Dichlorobenzene and 1,3-dichlorobenzene
| 1-Day HA for a 10-kg child | 9 mg/L
| 10-Day HA for a 10-kg child | 9 mg/L
| DWEL | 3 mg/L | EPA 2004a
| Lifetime HA (70-kg adult) | 0.6 mg/L
| 1,4-Dichlorobenzene
| 1-Day HA for a 10-kg child | 11 mg/L
| 10-Day HA for a 10-kg child | 11 mg/L
| DWEL | 4 mg/L
| Lifetime HA (70-kg adult) | 0.075 mg/L
| MCL | | EPA 2004f 40CFR141.61
| 1,2-Dichlorobenzene | 0.6 mg/L | EPA 2004f 40CFR141.61
| 1,4-Dichlorobenzene | 0.075 mg/L | EPA 2004f 40CFR141.61
| MCLG | | EPA 2004d 40CFR141.50
| 1,2-Dichlorobenzene | 0.6 mg/L | EPA 2004d 40CFR141.50
| 1,4-Dichlorobenzene | 0.075 mg/L | EPA 2004d 40CFR141.50
FDA | Bottled water | | FDA 2003 21CFR165.110
| 1,2-Dichlorobenzene | 0.6 mg/L | FDA 2003 21CFR165.110
| 1,4-Dichlorobenzene | 0.075 mg/L | FDA 2003 21CFR165.110
c. Food
| No data
d. Other
EPA | Carcinogenicity classification | | IRIS 2004
| 1,2-Dichlorobenzene | Group D^f^
| 1,3-Dichlorobenzene | Group D^f^
| 1,4-Dichlorobenzene | No data
| RfC
| 1,2-Dichlorobenzene | No data
| 1,3-Dichlorobenzene | No data
| 1,4-Dichlorobenzene | 8×10^−1^ mg/m^3^
EPA | RfD
| 1,2-Dichlorobenzene | 9×10^−2^ mg/kg/day | IRIS 2004
| 1,3-Dichlorobenzene | No data | IRIS 2004
| 1,4-Dichlorobenzene | No data
| Community right-to-know; toxic chemical release reporting; effective date | | EPA 2004j 40CFR372.65
| 1,2-Dichlorobenzene | 01/01/1987
| 1,3-Dichlorobenzene | 01/01/1987
| 1,4-Dichlorobenzene | 01/01/1987
| Hazardous waste identification | | EPA 2004c 40CFR261, Appendix VIII
| 1,2-Dichlorobenzene | U070 | EPA 2004c 40CFR261, Appendix VIII
| 1,3-Dichlorobenzene | U071 | EPA 2004c 40CFR261, Appendix VIII
| 1,4-Dichlorobenzene | U072 | EPA 2004c 40CFR261, Appendix VIII
| Chemical information rules; manufacturers reporting period for 1,2-dichlorobenzene and 1,4-dichlorobenzene | | EPA 2004k 40CFR712.30
| Effective date | 08/04/1995 | EPA 2004k 40CFR712.30
| Sunset date | 10/03/1995 | EPA 2004k 40CFR712.30
| Superfund; reportable quantity
| 1,2-Dichlorobenzene^g^ | 100 pounds | EPA 2004b 40CFR302.4
| 1,3-Dichlorobenzene^h^ | 100 pounds | EPA 2004b 40CFR302.4
| 1,4-Dichlorobenzene^i^ | 100 pounds
NTP | Carcinogenicity classification | | NTP 2005
| 1,2-Dichlorobenzene | No data | NTP 2005
| 1,3-Dichlorobenzene | No data | NTP 2005
| 1,4-Dichlorobenzene | Reasonably anticipated to be a human carcinogen | NTP 2005
[underlined: STATE]
a. Air
| No data
b. Water
| Drinking water standards and guidelines | | HSDB 2005
Arizona | 1,2-Dichlorobenzene | 620 μg/L
| 1,3-Dichlorobenzene | 620 μg/L
| 1,4-Dichlorobenzene | 75 μg/L
California | 1,3-Dichlorobenzene | 130 μg/L
| 1,4-Dichlorobenzene | 5 μg/L
Florida | 1,3-Dichlorobenzene | 10 μg/L
Maine | 1,2-Dichlorobenzene | 63 μg/L
| 1,4-Dichlorobenzene | 21 μg/L
Massachusetts | 1,4-Dichlorobenzene | 5 μg/L
Minnesota | 1,2-Dichlorobenzene | 600 μg/L
| 1,4-Dichlorobenzene | 10 μg/L
New Jersey | 1,2-Dichlorobenzene | 600 μg/L
| 1,3-Dichlorobenzene | 600 μg/L
Wisconsin | 1,3-Dichlorobenzene | 1,250 μg/L
c. Food
| No data
d. Other
| No data

a Group 3: Not classifiable as to its carcinogenicity to humans.

b Group 2B: Possibly carcinogenic to humans.

c Concentrations of the substance at or below the health-based guideline value may affect the appearance, taste or odor of the water, leading to consumer complaints.

d Group A4: Not classifiable as a human carcinogen.

e Group A3: Confirmed animal carcinogen with unknown relevance to humans.

f Group D: Not classifiable as to human carcinogenicity.

g Designated as a hazardous substance pursuant to Section 311(b)(2) of the Clean Water Act, Section 307(a) of the Clean Water Act, and Section 3001 of RCRA.

h Designated as a hazardous substance pursuant to Section 307(a) of the Clean Water Act and Section 3001 of RCRA.

i Designated as a hazardous substance pursuant to Section 311(b)(2) of the Clean Water Act, Section 307(a) of the Clean Water Act, Section 112 of the Clean Air Act, and Section 3001 of RCRA.

ACGIH = American Conference of Governmental Industrial Hygienists; CFR = Code of Federal Regulations; DWEL = drinking water equivalent level; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; HA = health advisory; HSDB = Hazardous Substances Data Bank; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; MCLG = maximum contaminant level goal; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; RCRA = Resource Conservation and Recovery Act; REL = recommended exposure limit; RfC = reference concentration; RfD = reference dose; STEL = short-term exposure limit; TLV = threshold limit values; TWA = time-weighted average; USC = United States Codes; WHO = World Health Organization