# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Dichlorobenzenes (DCBs) are chlorinated aromatic compounds. 1,2-DCB is used primarily as a precursor for 3,4-dichloroaniline herbicides (CMR 1996). 1,3-DCB is used in the production of various herbicides, insecticides, pharmaceuticals, and dyes (Krishnamurti 2001). 1,4-DCB is used as a deodorant for restrooms (Howard 1989), for moth control (O’Neil 2001), and as an insecticide (Farm Chemicals Handbook 1983). Information regarding the chemical identity of 1,2-, 1,3-, and 1,4-DCB is located in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

The dichlorobenzene isomers, 1,2-DCB and 1,3-DCB, are colorless volatile liquids at room temperature (EPA 1985a). 1,2-DCB has a pleasant odor, while the odor of 1,3-DCB is unspecified (EPA 1985a; NIOSH 2005). 1, 4-DCB is a combustible crystalline solid that tends to sublime at ordinary room temperatures. It possesses a distinctive odor reportable to be noticeable at airborne concentrations between 30 and 60 ppm (by weight [ppm-w] or by volume [ppm-v] not specified; presumably "ppm" would refer to ppm by weight). Information regarding the physical and chemical properties of 1,2-, 1,3-, and 1,4-DCB is located in Table 4-2.

Table 4-1 Chemical Identity of 1,2-, 1,3-, and 1,4-Dichlorobenzene

Characteristic | Value | Reference | Value | Reference | Value | Reference
Chemical name | 1,2-Dichlorobenzene | Lide 2000 | 1,3-Dichlorobenzene | Lide 2000; HSDB 2005 | 1,4-Dichlorobenzene | Lide 2000
Synonyms | o-Dichlorobenzene; o-dichlorobenzol; orthodichlorobenzene | RTECS 2005 | m-Dichlorobenzene; m-DCB; m-dichlorobenzol; m-phenylene dichloride | RTECS 2005 | para-Dichlorobenzene; p-dichlorobenzene; p-chlorophenyl chloride; PDB; PDCB; p-dichlorobenzol | RTECS 2005
Trade names | Chloroben; Cloroben; Dilatin DB; Dowtherm E; Dizene; Special termite fluid; Termitkil | HSDB 2005; RTECS 2005 | No data | | Paracide; Paradow; Paradi; Santochlor; Paramoth; Paranuggets; Parazene; Persia-perazol; Para crystals; Global; Evola; Di-chloricide | RTECS 2005
Chemical formula | C_6_H_4_Cl_2_ | RTECS 2005 | C_6_H_4_Cl_2_ | RTECS 2005 | C_6_H_4_Cl_2_ | RTECS 2005
Chemical structure | [image] | | [image] | | [image]
Identification numbers:
CAS Registry | 95-50-1 | Lide 2000 | 541-73-1 | Lide 2000 | 106-46-7 | Lide 2000
NIOSH RTECS | CZ4500000 | RTECS 2005 | CZ4499000 | RTECS 2005 | CZ4550000 | RTECS 2005
EPA Hazardous Waste | U070; F002 | HSDB 2005 | U071 | HSDB 2005 | U072; D027 | HSDB 2005
OHM/TADS | No data | | No data | | No data
DOT/UN/NA/IMCO Shipping | UN 1591; IMO 6.1 | HSDB 2005 | No data | | UN 1592; IMO 6.1 | HSDB 2005
HSDB | 521 | HSDB 2005 | 522 | HSDB 2005 | 523 | HSDB 2005
NCI | NCI-C54944 | RTECS 2005 | No data | | NCI-C54955 | RTECS 2005

CAS = Chemical Abstracts Service; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/Intergovernmental Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of 1,2-, 1,3-, and 1,4-Dichlorobenzene

Property | Value | Reference | Value | Reference | Value | Reference
Chemical name | 1,2-Dichlorobenzene | Lide 2000 | 1,3-Dichlorobenzene | Lide 2000 | 1,4-Dichlorobenzene | Lide 2000
Molecular weight | 147.00 | Lide 2000 | 147.00 | Lide 2000 | 147.00 | Lide 2000
Color | Colorless to pale yellow | NIOSH 2005 | Colorless | Lewis 1997 | Colorless or white | NIOSH 2005
Physical state | Liquid | Lewis 1997 | Liquid | Lewis 1997 | Solid | Lewis 1997
Melting point | −16.7 °C | Lide 2000 | −24.8 °C | Lide 2000 | 52.7 °C | Lide 2000
Boiling point | 180 °C | Lide 2000 | 173 °C | Lide 2000 | 174 °C | Lide 2000
Density at 20 °C | 1.3059 g/mL | Lide 2000 | 1.2884 g/mL | Lide 2000 | 1.46 g/mL | O’Neil 2001
Odor | Pleasant, aromatic | NIOSH 2005 | No data | | Mothball-like; penetrating | Lewis 1997; NIOSH 2005
Odor threshold:
Water | 0.01 mg/L | Verschueren 2001 | 0.02 mg/L | Verschueren 2001 | 0.011 mg/L | Amoore and Hautala 1983
Air | 50 ppm (301 mg/m^3^) | Verschueren 2001 | No data | | 0.18 ppm (1.1 mg/m^3^) | Amoore and Hautala 1983
Solubility:
Water | 156 mg/L at 25 °C | Banerjee et al. 1980 | 125 mg/L at 20 °C | Miller et al. 1984 | 80.0 mg/L | Yalkowsky and He 2003
Organic solvents | Miscible with alcohol, ether, benzene | O’Neil 2001 | Soluble in alcohol, ether | O’Neil 2001 | Soluble in alcohol, ether, benzene, chloroform, carbon disulfide | O’Neil 2001
Partition coefficients:
Log octanol/water | 3.43 | Hansch et al. 1995 | 3.53 | Hansch et al. 1995 | 3.44 | Hansch et al. 1995
Log K_oc_ | 2.51 | Chiou et al. 1983 | 2.47 | Chiou et al. 1983 | 2.44 | Chiou et al. 1983
Vapor pressure at 25 °C | 1.36 mm Hg | Daubert and Danner 1992 | 2.15 mm Hg | Daubert and Danner 1992 | 1.77 mm Hg | Daubert and Danner 1992
Henry’s law constant at 25 °C | 1.92×10^−3^ atm m^3^/mol | Shiu and Mackay 1997 | 2.8×10^−3^ atm m^3^/mol | Staudinger and Roberts 1996 | 2.41×10^−3^ atm m^3^/mol | Shiu and Mackay 1997
Autoignition temperature | 640 °C | Krishnamurti 2001 | >500 °C | Krishnamurti 2001 | >500 °C | Krishnamurti 2001
Flashpoint | 28 °C (closed cup) | Krishnamurti 2001 | No data | | 67 °C (closed cup) | Krishnamurti 2001
Flammability limits | No data | | No data | | 6.2–16% | Leber and Bus 2010
Conversion factors | 1 mg/m^3^=0.116 ppm at 25 °C and 760 mm Hg; 1 ppm=6.01 mg/m^3^ at 25 °C and 760 mm Hg | Verschueren 2001 | 1 mg/m^3^=0.116 ppm at 25 °C and 760 mm Hg; 1 ppm=6.01 mg/m^3^ at 25 °C and 760 mm Hg | HSDB 2005 | 1 ppm=6.01 mg/m^3^ at 25 °C and 760 mm Hg; 1 mg/m^3^=0.166 ppm at 25 °C and 760 mm Hg | Verschueren 2001
Explosion limits | 2–9% by volume in air | Leber and Bus 2010 | No data | | No data