# CHAPTER 8 REFERENCES

Abdel-Maksoud FM, Knight R, Waler K, 2018. Exposures of male rats to environmental chemicals [bisphenol A and di (2-ethylhexyl) phthalate] affected expression of several proteins in the developing epididymis. Andrology 6(1):214–222. 10.1111/andr.12451.29280353
Abdel-Maksoud FM, Ali FA Z, Akingbemi BT. 2019. Prenatal exposures to bisphenol A and di (2-ethylhexyl) phthalate disrupted seminiferous tubular development in growing male rats. Reprod Toxicol 88:85–90. 10.1016/j.reprotox.2019.07.017.31369804
Abe S, Sasaki M. 1977. Chromosome aberrations and sister chromatid exchanges in Chinese hamster cells exposed to various chemicals. J Natl Cancer Inst 58:1635–1641.864744
Absalan F, Saremy S, Mansori E, 2017. Effects of mono-(2-ethylhexyl) phthalate and di-(2-ethylhexyl) phthalate administrations on oocyte meiotic maturation, apoptosis and gene quantification in mouse model. Cell J 18(4):503–513. 10.22074/cellj.2016.4717.28042535
ACGIH. 2001. Di(2-ethylhexyl)phthalate. In: Documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 1–6.
ACGIH. 2016. Di(2-ethylhexyl)phthalate. In: TLVs and BEIs based on the documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 27, 77.
Adachi K, Suemizu H, Murayama N, 2015. Human biofluid concentrations of mono(2-ethylhexyl)phthalate extrapolated from pharmacokinetics in chimeric mice with humanized liver administered with di(2-ethylhexyl)phthalate and physiologically based pharmacokinetic modeling. Environ Toxicol Pharmacol 39(3):1067–1073. 10.1016/j.etap.2015.02.011.25867688
Adibi JJ, Whyatt RM, Williams PL, 2008. Characterization of phthalate exposure among pregnant women assessed by repeat air and urine samples. Environ Health Perspect 116(4):467–473. 10.1289/ehp.10749.18414628
Adibi JJ, Hauser R, Williams PL, 2009. Maternal urinary metabolites of di-(2-ethylhexyl) phthalate in relation to the timing of labor in a US multicenter pregnancy cohort study. Am J Epidemiol 169(8):1015–1024. 10.1093/aje/kwp001.19251754
Adibi JJ, Lee MK, Naimi AI, 2015. Human chorionic gonadotropin partially mediates phthalate association with male and female anogenital distance. J Clin Endocrinol Metab 100(9):E1216–E1224. 10.1210/jc.2015-2370.26200238
Agarwal DK, Agarwal S, Seth PK. 1982. Interaction of di-(2-ethylhexyl) phthalate with the pharmacological response and metabolic aspects of ethanol in mice. Biochem Pharmacol 31:3419–3423.6756415
Agarwal DK, Lawrence WH, Nunez LJ, 1985. Mutagenicity evaluation of phthalic acid esters and metabolites in Salmonella typhimurium cultures. J Toxicol Environ Health 16(1):61–69. 10.1080/15287398509530719.3906141
Agarwal DK, Eustis S, Lamb JC, 1986. Effects of di(2-ethylhexyl) phthalate on the gonadal pathophysiology, sperm morphology, and reproductive performance of male rats. Environ Health Perspect 65:343–350.3709461
Agay-Shay K, Martinez D, Valvi D, 2015. Exposure to endocrine-disrupting chemicals during pregnancy and weight at 7 years of age: A multi-pollutant approach. Environ Health Perspect 123(10):1030–1037. 10.1289/ehp.1409049.25956007
Ahmad S, Khan MF, Parvez S, 2017. Molecular docking reveals the potential of phthalate esters to inhibit the enzymes of the glucocorticoid biosynthesis pathway. J Appl Toxicol 37(3):265–277. 10.1002/jat.3355.27427409
Ahmed RS, Price SC, Grasso P, 1989. Effects of intermittent feeding of rats with di-2-ethylhexylphthalate. Biochem Soc Trans 17(6):1073–1074.2628086
Akingbemi BT, Youker RT, Sottas CM, 2001. Modulation of rat Leydig cell steroidogenic function by di(2-ethylhexyl)phthalate. Biol Reprod 65(4):1252–1259. 10.1095/biolreprod65.4.1252.11566751
Akingbemi BT, Ge R, Klinefelter GR, 2004. Phthalate-induced Leydig cell hyperplasia is associated with multiple endocrine disturbances. Proc Natl Acad Sci U S A 101(3):775–780. 10.1073/pnas.0305977101.14715905
Albert O, Jégou B. 2014. A critical assessment of the endocrine susceptibility of the human testis to phthalates from fetal life to adulthood. Hum Reprod Update 20(2):231–249. 10.1093/humupd/dmt050.24077978
Albro PW. 1986. Absorption, metabolism, and excretion of di(2-ethylhexyl) phthalate by rats and mice. Environ Health Perspect 65:293–298.3086077
Albro PW, Thomas RO. 1973. Enzymatic hydrolysis of di-(2-ethylhexyl) phthalate by lipases. Biochim Biophys Acta 360(3):380–390.
Albro PW, Corbett JT. 1978. Distribution of di-and mono-(2-ethylhexyl) phthalate in human plasma. Transfusion 18:750–755.83042
Albro PW, Lavenhar SR. 1989. Metabolism of di(2-ethylhexyl)phthalate. Drug Metab Rev 21(1):13–34. 10.3109/03602538909029953.2696633
Albro PW, Hass JR, Peck CC, 1981. Identification of the metabolites of di-(2-ethylhexyl) phthalate in urine from the African green monkey. Drug Metab Dispos 9(3):223–225.6113930
Albro PW, Corbett JT, Schroeder JL, 1982a. Pharmacokinetics, interactions with macromolecules and species difference in metabolism of DEHP. Environ Health Perspect 45:19–25.7140694
Albro PW, Hass JR, Peck CC, 1982b. Applications of isotope differentiation for metabolic studies with di-(2-ethylhexyl) phthalate. J Environ Sci Health B 17(6):701–714.7166629
Albro PW, Tondeur I, Marbury D, 1983. Polar metabolites of di-(2-ethylhexyl)phthalate in the rat. Biochim Biophys Acta 760:283–292.6626575
Alexander BM, Baxter CS. 2016. Flame-retardant contamination of firefighter personal protective clothing- a potential health risk for firefighters. J Occup Environ Hyg 13(9):D148–D155.27171467
Al-Omran LA, Preston MR. 1987. The interactions of phthalate esters with suspended particulate material in fresh and marine waters. Environ Pollut 46:177–186.15092728
Al-Saleh I, Coskun S, Al-Doush I, 2019a. The relationships between urinary phthalate metabolites, reproductive hormones and semen parameters in men attending in vitro fertilization clinic. Sci Total Environ 658:982–995. 10.1016/j.scitotenv.2018.12.261.30678022
Al-Saleh I, Coskun S, Al-Doush I, 2019b. Exposure to phthalates in couples undergoing in vitro fertilization treatment and its association with oxidative stress and DNA damage. Environ Res 169:396–408. 10.1016/j.envres.2018.11.018.30529141
Al-Saleh I, Coskun S, Al-Doush I, 2019c. Supplemental material: Exposure to phthalates in couples undergoing in vitro fertilization treatment and its association with oxidative stress and DNA damage. Environ Res 169. 10.1016/j.envres.2018.11.018.
Al-Saleh I, Coskun S, Al-Doush I, 2019d. Couples exposure to phthalates and its influence on in vitro fertilization outcomes. Chemosphere 226:597–606. 10.1016/j.chemosphere.2019.03.146.30954894
Andersen C, Krais AM, Eriksson AC, 2018. Inhalation and dermal uptake of particle and gas-phase phthalates—a human exposure study. Environ Sci Technol 52(21):12792–12800. 10.1021/acs.est.8b03761.30264993
Anderson SP, Cattley RC, Corton JC. 1999. Hepatic expression of acute-phase protein genes during carcinogenesis induced by peroxisome proliferators. Mol Carcinog 26:226–238.10569800
Anderson WA C, Castle L, Scotter MJ, 2001. A biomarker approach to measuring human dietary exposure to certain phthalate diesters. Food Addit Contam 18(12):1068–1074. 10.1080/02652030110050113.11761117
Anderson WA, Castle L, Hird S, 2011. A twenty-volunteer study using deuterium labelling to determine the kinetics and fractional excretion of primary and secondary urinary metabolites of di-2-ethylhexylphthalate and di-iso-nonylphthalate. Food Chem Toxicol 49(9):2022–2029. 10.1016/j.fct.2011.05.013.21609750
Andrade AJ, Grande SW, Talsness CE, 2006a. A dose response study following in utero and lactational exposure to di-(2-ethylhexyl) phthalate (DEHP): Reproductive effects on adult male offspring rats. Toxicology 228(1):85–97. 10.1016/j.tox.2006.08.020.16996189
Andrade AJ, Grande SW, Talsness CE, 2006b. A dose-response study following in utero and lactational exposure to di-(2-ethylhexyl)-phthalate (DEHP): Non-monotonic dose-response and low dose effects on rat brain aromatase activity. Toxicology 227(3):185–192. 10.1016/j.tox.2006.07.022.16949715
Andrade AJ, Grande SW, Talsness CE, 2006c. A dose-response study following in utero and lactational exposure to di-(2-ethylhexyl) phthalate (DEHP): Effects on androgenic status, developmental landmarks and testicular histology in male offspring rats. Toxicology 225(1):64–74. 10.1016/j.tox.2006.05.007.16806631
Araki A, Ait Bamai Y, Bastiaensen M, 2020. Combined exposure to phthalate esters and phosphate flame retardants and plasticizers and their associations with wheeze and allergy symptoms among school children. Environ Res 183:109212. 10.1016/j.envres.2020.109212.32058144
Arbuckle TE, MacPherson S, Barrett E, 2019. Do stressful life events during pregnancy modify associations between phthalates and anogenital distance in newborns? Environ Res 177:108593. 10.1016/j.envres.2019.108593.31357157
Arcadi FA, Costa C, Imperatore C, 1998. Oral toxicity of bis(2-ethylhexyl) phthalate during pregnancy and suckling in the Long-Evans rat. Food Chem Toxicol 36(11):963–970. 10.1016/s0278-6915(98)00065-9.9771559
Arzuaga X, Smith MT, Gibbons CF, 2019. Proposed key characteristics of male reproductive toxicants as an approach for organizing and evaluating mechanistic evidence in human health hazard assessments. Environ Health Perspect 127(6):065001. 10.1289/ehp5045.31199676
Ashari S, Karami M, Shokrzadeh M, 2020. The implication of mitochondrial dysfunction and mitochondrial oxidative damage in di (2-ethylhexyl) phthalate induced nephrotoxicity in both in vivo and in vitro models. Toxicol Mech Methods 30(6):427–437. 10.1080/15376516.2020.1758980.32312132
Ashley-Martin J, Dodds L, Levy AR, 2015. Prenatal exposure to phthalates, bisphenol A and perfluoroalkyl substances and cord blood levels of IgE, TSLP and IL-33. Environ Res 140:360–368. 10.1016/j.envres.2015.04.010.25913155
Astill BD. 1989. Metabolism of DEHP: Effects of prefeeding and dose variation, and comparative studies in rodents and the cynomolgus monkey (CMA studies). Drug Metab Rev 21(1):35–53.2696635
Astill B, Barber E, Lington A, 1986. Chemical industry voluntary test program for phthalate esters: Health effects studies. Environ Health Perspect 65:329–336.3709458
Atlas E, Giam CS. 1981. Global transport of organic pollutants: Ambient concentrations in the remote marine atmosphere. Science 211:163–165.17757266
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Subtances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 2010. Health consultation. Evaluation of contaminants in private residential well water, Fremont County, Pavillion, Wyoming. Agency For Toxic Substances and Disease Registry.
ATSDR. 2017. Di-(2-ethylhexyl)phthalate. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/SPL/resources/index.html. January 16, 2018.
ATSDR. 2019. Di-2-ethylhexyl phthalate. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry.
Attina TM, Trasande L. 2015. Association of exposure to di-2-ethylhexylphthalate replacements with increased insulin resistance in adolescents from NHANES 2009–2012. J Clin Endocrinol Metab 100(7):2640–2650. 10.1210/jc.2015-1686.25993640
Autian J. 1982. Antifertility effects and dominant lethal assays for mutagenic effects of DEHP. Environ Health Perspect 45:115–118.7140683
Axelsson J, Rylander L, Rignell-Hydbom A, 2015. Phthalate exposure and reproductive parameters in young men from the general Swedish population. Environ Int 85:54–60. 10.1016/j.envint.2015.07.005.26318515
Aydemir D, Karabulut G, Şimşek G, 2018. Impact of the di(2-ethylhexyl) phthalate administration on trace element and mineral levels in relation of kidney and liver damage in rats. Biol Trace Elem Res 186(2):474–488. 10.1007/s12011-018-1331-0.29654488
Babich MA, Bevington C, Dreyfus MA. 2020. Plasticizer migration from children’s toys, child care articles, art materials, and school supplies. Regul Toxicol Pharmacol 111:104574. 10.1016/j.yrtph.2019.104574.31917999
Balalian AA, Whyatt RM, Liu X, 2019. Prenatal and childhood exposure to phthalates and motor skills at age 11 years. Environ Res 171:416–427. 10.1016/j.envres.2019.01.046.30731329
Barakat R, Lin PP, Rattan S, 2017. Prenatal exposure to DEHP induces premature reproductive senescence in male mice. Toxicol Sci 156(1):96–108. 10.1093/toxsci/kfw248.28082598
Barakat R, Lin PC, Park CJ, 2018. Prenatal exposure to DEHP induces neuronal degeneration and neurobehavioral abnormalities in adult male mice. Toxicol Sci 164(2):439–452. 10.1093/toxsci/kfy103.29688563
Barakat R, Lin PC, Park CJ, 2020. Germline-dependent transmission of male reproductive traits induced by an endocrine disruptor, di-2-ethylhexyl phthalate, in future generations. Sci Rep 10(1):5705. 10.1038/s41598-020-62584-w.32235866
Barber ED, Astill BD, Moran EJ, 1987. Peroxisome induction studies on seven phthalate esters. Toxicol Ind Health 3(2):7–24. 10.1177/074823378700300203.3617071
Barber ED, Teetsel NM, Kolberg KF, 1992. A comparative study of the rats of in vitro percutaneous absorption of eight chemicals using rat and human skin. Fundam Appl Toxicol 19:493–497.1426706
Barber ED, Fox JA, Giordano CJ. 1994. Hydrolysis, absorption and metabolism of di(2-ethylhexyl) terephthalate in the rat. Xenobiotica 24(5):441–450.8079503
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Barrett ES, Parlett LE, Wang C, 2014. Environmental exposure to di-2-ethylhexyl phthalate is associated with low interest in sexual activity in premenopausal women. Horm Behav 66(5):787–792. 10.1016/j.yhbeh.2014.10.003.25448532
Barrett ES, Parlett LE, Sathyanarayana S, 2016. Prenatal stress as a modifier of associations between phthalate exposure and reproductive development: Results from a multicentre pregnancy cohort study. Paediatr Perinat Epidemiol 30(2):105–114. 10.1111/ppe.12264.26576028
Barrows ME, Petrocelli SR, Macek KJ. 1980. Bioconcentration and elimination of selected water pollutants by bluegill sunfish (Lepomis macrochirus). In: Haque R, ed. Dynamics, exposure and hazard assessment of toxic chemicals. Ann Arbor, MN: Ann Arbor Science Publishers, Inc., 379–392.
Barry YA, Labow RS, Keon WJ, 1990. Atropine inhibition of the cardiodepressive effect of mono(2-ethylhexyl)phthalate on human myocardium. Toxicol Appl Pharmacol 106:48–52.2251683
Bartles JR, Khuon S, Lin XH, 1990. Peroxisome proliferator-induced alterations in the expression and modification of rat hepatocyte plasma membrane proteins. Cancer Res 50(3):669–676.2404574
Basak S, Das MK, Duttaroy AK. 2020. Plastics derived endocrine-disrupting compounds and their effects on early development. Birth Defects Research 112(17):1308–1325. 10.1002/bdr2.1741.32476245
Bastos Sales L, van Esterik JC J, Hodemaekers HM, 2018. Analysis of lipid metabolism, immune function, and neurobehavior in adult C57BL/6JxFVB mice after developmental exposure to di(2-ethylhexyl) phthalate. Front Endocrinol 9:684. 10.3389/fendo.2018.00684.
Bauer MJ, Herrmann R. 1997. Estimation of the environmental contamination by phthalic acid esters leaching from household wastes. Sci Total Environ 208:49–57.9496648
Beko G, Callesen M, Weschler CJ, 2015. Phthalate exposure through different pathways and allergic sensitization in preschool children with asthma, allergic rhinoconjunctivitis and atopic dermatitis. Environ Res 137:432–439. 10.1016/j.envres.2015.01.012.25625823
Bell FP. 1976. Inhibition of hepatic sterol and squalene biosynthesis in rats fed di-2-ethylhexyl phthalate. Lipids 11(10):769–773. 10.1007/bf02533053.994746
Bell FP. 1980. Effect of di-2-ethylhexyl phthalate in the female rat: Inhibition of hepatic and adrenal sterologenesis in vitro. Bull Environ Contam Toxicol 24:54–58.7357111
Bell FP. 1982. Effects of phthalate esters on lipid metabolism in various tissues, cells and organelles in mammals. Environ Health Perspect 45(0):41–50.7140695
Bell FP, Buthala DA. 1983. Biochemical changes in liver of rats fed the plasticizer di (2-ethylhexy) phthalate. Bull Environ Contam Toxicol 31(2):177–182. 10.1007/bf01607890.6616088
Bellavia A, Hauser R, Seely EW, 2017. Urinary phthalate metabolite concentrations and maternal weight during early pregnancy. Int J Hyg Environ Health 220:1347–1355.28939183
Berger K, Eskenazi B, Kogut K, 2018. Association of prenatal urinary concentrations of phthalates and bisphenol A and pubertal timing in boys and girls. Environ Health Perspect 126(9):97004. 10.1289/EHP3424.30203993
Berk M, Williams LJ, Andreazza A, 2014. Pop, heavy metal and the blues: secondary analysis of persistent organic pollutants (POP), heavy metals and depressive symptoms in the NHANES National Epidemiological Survey. Br Med J 4(7):e005142. 10.1136/bmjopen-2014-005142.
Berman E, Schlicht M, Moser VC, 1995. A multidisciplinary approach to toxicological screening: I. Systemic toxicity. J Toxicol Environ Health 45(2):127–143. 10.1080/15287399509531986.7783250
Bertelsen RJ, Carlsen KC, Calafat AM, 2013. Urinary biomarkers for phthalates associated with asthma in Norwegian children. Environ Health Perspect 121(2):251–256. 10.1289/ehp.1205256.23164678
Binder AM, Corvalan C, Calafat AM, 2018a. Childhood and adolescent phenol and phthalate exposure and the age of menarche in Latina girls. Environ Health 17(1):32. 10.1186/s12940-018-0376-z.29615064
Binder AM, Corvalan C, Calafat AM, 2018b. Supplemental material: Childhood and adolescent phenol and phthalate exposure and the age of menarche in Latina girls. Environ Health 17. 10.1186/s12940-018-0376-z.
Bloom MS, Whitcomb BW, Chen Z, 2015a. Associations between urinary phthalate concentrations and semen quality parameters in a general population. Hum Reprod 30(11):2645–2657. 10.1093/humrep/dev219.26350610
Bloom MS, Whitcomb BW, Chen Z, 2015b. Supplemental material: Associations between urinary phthalate concentrations and semen quality parameters in a general population. Hum Reprod 30. 10.1093/humrep/dev219.
Bloom MS, Wenzel AG, Brock JW, 2019a. Racial disparity in maternal phthalates exposure; Association with racial disparity in fetal growth and birth outcomes. Environ Int 127:473–486. 10.1016/j.envint.2019.04.005.30981018
Bloom MS, Wenzel AG, Brock JW, 2019b. Supplemental material: Racial disparity in maternal phthalates exposure; Association with racial disparity in fetal growth and birth outcomes. Environ Int 127. 10.1016/j.envint.2019.04.005.
Bluthgen A. 2000. Organic migration agents into milk at farm level (illustrated with diethylhexylphthalate). Bull IDF 356:39–42.
Blystone C, Kissling G, Bishop J, 2010. Determination of the di-(2-ethylhexyl) phthalate NOAEL for reproductive development in the rat: importance of the retention of extra animals to adulthood. Toxicol Sci 116(2):640–646. 10.1093/toxsci/kfq147.20484383
Boas M, Frederiksen H, Feldt-Rasmussen U, 2010. Childhood exposure to phthalates: Associations with thyroid function, insulin-like growth factor I, and growth. Environ Health Perspect 118(10):1458–1464. 10.1289/ehp.0901331.20621847
Boerrigter ME. 2004. Mutagenicity of the peroxisome proliferators clofibrate, Wyeth 14,643 and di-2-ethylhexyl phthalate in the lacZ plasmid-based transgenic mouse mutation assay. J Carcinog 3(1):7. 10.1186/1477-3163-3-7.15128457
Bolling AK, Holme JA, Bornehag CG, 2013. Pulmonary phthalate exposure and asthma - is PPAR a plausible mechanistic link? EXCLI J 12:733–759.26622216
Borch J, Metzdorff SB, Vinggaard AM, 2006. Mechanisms underlying the anti-androgenic effects of diethylhexyl phthalate in fetal rat testis. Toxicology 223(1–2):144–155. 10.1016/j.tox.2006.03.015.16690193
Bornehag CG, Lundgren B, Weschler CJ, 2005. Phthalates in indoor dust and their association with building characteristics. Environ Health Perspect 113(10):1399–1404. 10.1289/ehp.7809.16203254
Bornehag CG, Carlstedt F, Jonsson BA, 2015. Prenatal phthalate exposures and anogenital distance in Swedish boys. Environ Health Perspect 123(1):101–107. 10.1289/ehp.1408163.25353625
Braun JM, Smith KW, Williams PL, 2012. Variability of urinary phthalate metabolite and bisphenol A concentrations before and during pregnancy. Environ Health Perspect 120(5):739–745. 10.1289/ehp.1104139.22262702
Braun JM, Kalkbrenner AE, Just AC, 2014. Gestational exposure to endocrine-disrupting chemicals and reciprocal social, repetitive, and stereotypic behaviors in 4- and 5-year-old children: the HOME study. Environ Health Perspect 122(5):513–520. 10.1289/ehp.1307261.24622245
Braun JM, Bellinger DC, Hauser R, 2017a. Prenatal phthalate, triclosan, and bisphenol A exposures and child visual-spatial abilities. Neurotoxicology 58:75–83. 10.1016/j.neuro.2016.11.009.27888119
Braun JM, Bellinger DC, Hauser R, 2017b. Supplemental material: Prenatal phthalate, triclosan, and bisphenol A exposures and child visual-spatial abilities. Neurotoxicology 58. 10.1016/j.neuro.2016.11.009.
Brehm E, Rattan S, Gao L, 2018. Prenatal exposure to di(2-ethylhexyl) phthalate causes long-term transgenerational effects on female reproduction in mice. Endocrinology 159(2):795–809. 10.1210/en.2017-03004.29228129
Brown KW, Donnelly KC. 1988. An estimation of risk associated with the organic constituents of hazardous and municipal waste landfill leachates. Haz Waste Haz Mater 5(1):1–30.
Buck Louis GM, Peterson CM, Chen Z, 2013. Bisphenol A and phthalates and endometriosis: The Endometriosis: Natural History, Diagnosis and Outcomes Study. Fertil Steril 100(1):162–169. 10.1016/j.fertnstert.2013.03.026.23579005
Buck Louis GM, Sundaram R, Sweeney AM, 2014. Urinary bisphenol A, phthalates, and couple fecundity: the Longitudinal Investigation of Fertility and the Environment (LIFE) Study. Fertil Steril 101(5):1359–1366. 10.1016/j.fertnstert.2014.01.022.24534276
Buckley JP, Engel SM, Braun JM, 2016a. Prenatal phthalate exposures and body mass index among 4- to 7-year-old children: A pooled analysis. Epidemiology 27(3):449–458. 10.1097/ede.0000000000000436.26745610
Buckley JP, Engel SM, Mendez MA, 2016b. Prenatal phthalate exposures and childhood fat mass in a New York City cohort. Environ Health Perspect 124(4):507–513. 10.1289/ehp.1509788.26308089
Buser MC, Murray HE, Scinicariello F. 2014. Age and sex differences in childhood and adulthood obesity association with phthalates: Analyses of NHANES 2007–2010. Int J Hyg Environ Health 217(6):687–694. 10.1016/j.ijheh.2014.02.005.24657244
Busser MT, Lutz WK. 1987. Stimulation of DNA synthesis in rat and mouse liver by various tumor promoters. Carcinogenesis 8(10):1433–1437.2443263
Bustamante-Montes LP, Hernández-Valero MA, Flores-Pimentel D, 2013. Prenatal exposure to phthalates is associated with decreased anogenital distance and penile size in male newborns. J Dev Orig Health Dis 4(4):300–306. 10.1017/s2040174413000172.24349678
Butterworth BE. 1984. The genetic toxicology of di(2-ethylhexyl)phthalate (DEHP). CIIT Activities 4(10):1–8.
Butterworth BE, Bermudez E, Smith-Oliver T, 1984. Lack of genotoxic activity of di(2-ethylhexyl)phthalate (DEHP) in rat and human hepatocytes. Carcinogenesis 5(10):1329–1335.6488454
Cadogan DF, Howick C. 2001. Plasticizers. In: Kirk-Othmer encyclopedia of chemical technology. John Wiley & Sons, 10.1002/0471238961.1612011903010415.a01.
Cadogan DF, Papez M, Poppe AC, 1994. An assessment of the release, occurrence and possible effects of plasticisers in the environment. Prog Rubber Plast Technol 10:1–19.
Cahill TM, Cousins I, Mackay D. 2003. Development and application of a generalized physiologically based pharmacokinetic model for multiple environmental contaminants. Environ Toxicol Chem 22(1):26–34. 10.1002/etc.5620220104.12503743
Cakmak S, Dales RE, Hebbern C, 2014. The association between urinary phthalates and lung function. J Occup Environ Med 56(4):376–381. 10.1097/jom.0000000000000137.24709763
Calafat AM, Slakman AR, Silva MJ, 2004. Automated solid phase extraction and quantitative analysis of human milk for 13 phthalate metabolites. J Chromatogr 805(1):49–56. 10.1016/j.jchromb.2004.02.006.
Calafat AM, Brock JW, Silva MJ, 2006. Urinary and amniotic fluid levels of phthalate monoesters in rats after the oral administration of di(2-ethylhexyl) phthalate and di-n-butyl phthalate. Toxicology 217(1):22–30. 10.1016/j.tox.2005.08.013.
Calafat AM, Longnecker MP, Koch HM, 2015. Optimal exposure biomarkers for nonpersistent chemicals in environmental epidemiology. Environ Health Perspect 123(7):A166–A168.26132373
Caldwell JC. 2012. DEHP: Genotoxicity and potential carcinogenic mechanisms-A review. Mutat Res 751(2):82–157. 10.1016/j.mrrev.2012.03.001.
Camacho L, Latendresse JR, Muskhelishvili L, 2020. Effects of intravenous and oral di(2-ethylhexyl) phthalate (DEHP) and 20% Intralipid vehicle on neonatal rat testis, lung, liver, and kidney. Food Chem Toxicol 144:111497. 10.1016/j.fct.2020.111497.
Camann DE, Schultz ST, Yau AY, 2013. Acetaminophen, pesticide, and diethylhexyl phthalate metabolites, anandamide, and fatty acids in deciduous molars: potential biomarkers of perinatal exposure. J Expo Sci Environ Epidemiol 23(2):190–196. 10.1038/jes.2012.71.22805989
Canter LW, Sabatini DA. 1994. Contamination of public ground water supplies by Superfund sites. Int J Environ Stud 46:35–57.
Cantonwine DE, Meeker JD, Ferguson KK, 2016. Urinary concentrations of bisphenol A and phthalate metabolites measured during pregnancy and risk of preeclampsia. Environ Health Perspect 124(10):1651–1655. 10.1289/EHP188.27177253
Cao XL. 2010. Phthalate esters in foods: Sources, occurrence, and analytical methods. Compr Rev Food Sci Food Saf 9(1):21–43. 10.1111/j.1541-4337.2009.00093.x.33467808
Carbone S, Szwarcfarb B, Ponzo O, 2010. Impact of gestational and lactational phthalate exposure on hypothalamic content of amino acid neurotransmitters and FSH secretion in peripubertal male rats. Neurotoxicology 31(6):747–751. 10.1016/j.neuro.2010.06.006.
Carbone S, Samaniego YA, Cutrera R, 2012. Different effects by sex on hypothalamic-pituitary axis of prepubertal offspring rats produced by in utero and lactational exposure to di-(2-ethylhexyl) phthalate (DEHP). Neurotoxicology 33(1):78–84. 10.1016/j.neuro.2011.11.009.
Carbone S, Ponzo OJ, Gobetto N, 2013. Antiandrogenic effect of perinatal exposure to the endocrine disruptor di-(2-ethylhexyl) phthalate increases anxiety-like behavior in male rats during sexual maturation. Horm Behav 63(5):692–699. 10.1016/j.yhbeh.2013.01.006.23399322
Carpenter CP, Weil CS, Smyth HF. 1953. Chronic oral toxicity of di-(2-ethylhexyl) phthalate of rats, guinea pigs, and dogs. AMA Arch Ind Hyg Occup Med 8(3):219–226.
Carrara SM, Morita DM, Boscov ME. 2011. Biodegradation of di(2-ethylhexyl)phthalate in a typical tropical soil. J Hazard Mater 197:40–48. 10.1016/j.jhazmat.2011.09.058.22014440
Cartwright CD, Thompson IP, Burns G. 2000. Degradation and impact of phthalate plasticizers on soil microbial communities. Environ Toxicol Chem 19(5):1253–1261.
Casas M, Valvi D, Ballesteros-Gomez A, 2016. Exposure to bisphenol A and phthalates during pregnancy and ultrasound measures of fetal growth in the INMA-Sabadell Cohort. Environ Health Perspect 124(4):521–528. 10.1289/ehp.1409190.26196298
Caserta D, Bordi G, Ciardo F, 2013. The influence of endocrine disruptors in a selected population of infertile women. Gynecol Endocrinol 29(5):444–447. 10.3109/09513590.2012.758702.23347089
Castillo M, Oubina A, Barcelo D. 1998. Evaluation of ELISA kits followed by liquid chromatography-atmospheric pressure chemical ionization-mass spectrometry for the determination of organic pollutants in industrial effluents. Environ Sci Technol 32:2180–2184.
Castle L, Mayo A, Gilbert J. 1989. Migration of plasticizers from printing inks into foods. Food Addit Contam 6(4):437–443.2792462
Cathey A, Watkins DJ, Sánchez BN, 2020a. Onset and tempo of sexual maturation is differentially associated with gestational phthalate exposure between boys and girls in a Mexico City birth cohort. Environ Int 136:105469. 10.1016/j.envint.2020.105469.31931345
Cathey A, Watkins DJ, Sánchez BN, 2020b. Supplemental material: Onset and tempo of sexual maturation is differentially associated with gestational phthalate exposure between boys and girls in a Mexico City birth cohort. Environ Int 136. 10.1016/j.envint.2020.105469.
Cattley RC, Glover SE. 1993. Elevated 8-hydroxydeoxyguanosine in hepatic DNA of rats following exposure to peroxisome proliferators: relationship to carcinogenesis and nuclear localization. Carcinogenesis 14(12):2495–2499.8269617
Cattley RC, Richardson KK, Smith-Oliver T, 1986. Effect of peroxisome proliferator carcinogens on unscheduled DNA synthesis in rat hepatocytes determined by autoradiography. Cancer Lett 33(3):269–277. 10.1016/0304-3835(86)90066-2.3802057
Cattley RC, Conway JG, Popp JA. 1987. Association of persistent peroxisome proliferation and oxidative injury with hepatocarcinogenicity in female F-344 rats fed di(2-ethylhexyl)phthalate for 2 years. Cancer Lett 38(1–2):15–22. 10.1016/0304-3835(87)90195-9.3690505
Cattley RC, Smith-Oliver T, Butterworth BE, 1988. Failure of the peroxisome proliferator WY-14,643 to induce unscheduled DNA synthesis in rat hepatocytes following in vivo treatment. Carcinogenesis 9(7):1179–1183. 10.1093/carcin/9.7.1179.3383337
Cavanagh JE, Trought K, Mitchell C, 2018. Assessment of endocrine disruption and oxidative potential of bisphenol-A, triclosan, nonylphenol, diethylhexyl phthalate, galaxolide, and carbamazepine, common contaminants of municipal biosolids. Toxicol in Vitro 48:342–349. 10.1016/j.tiv.2018.02.003.29427707
CDC. 2015. Fourth national report on human exposure to environmental chemicals. February 2015. Atlanta, GA: Centers for Disease Control and Prevention.
CDC. 2016. Biomonitoring summary. Phthalates overview. Centers for Disease Control and Prevention. https://www.cdc.gov/biomonitoring/DEHP_BiomonitoringSummary.html. June 06, 2017.
CDC. 2018. Fourth national report on human exposure to environmental chemicals. Updated Tables, March 2018, Volume One. Centers for Disease Control and Prevention.
CDR. 2016. Chemical data reporting: 2016 data. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/access-cdr-data#2016. July 9, 2020.
Cerbulis J, Byler DM. 1986. Isolation and detection of dialkyl phthalates from pork. J Agric Food Chem 34:198–200.
Cha S, Jung K, Lee MY, 2018. Nonmonotonic effects of chronic low-dose di(2-ethylhexyl) phthalate on gonadal weight and reproductive. Dev Reprod 22(1):85–94. 10.12717/dr.2018.22.1.085.29707687
Chang BV, Liao CS, Yuan SY. 2005. Anaerobic degradation of diethyl phthalate, di-n-butyl phthalate, and di-(2-ethylhexyl) phthalate from river sediment in Taiwan. Chemosphere 58(11):1601–1607. 10.1016/j.chemosphere.2004.11.031.15694480
Chang WH, Li SS, Wu MH, 2015. Phthalates might interfere with testicular function by reducing testosterone and insulin-like factor 3 levels. Hum Reprod 30(11):2658–2670. 10.1093/humrep/dev225.26385792
Chang WH, Wu MH, Pan HA, 2017a. Semen quality and insulin-like factor 3: Associations with urinary and seminal levels of phthalate metabolites in adult males. Chemosphere 173:594–602. 10.1016/j.chemosphere.2017.01.056.28152410
Chang WH, Wu MH, Pan HA, 2017b. Supplemental material: Semen quality and insulin-like factor 3: Associations with urinary and seminal levels of phthalate metabolites in adult males. Chemosphere 173. 10.1016/j.chemosphere.2017.01.056.
Chang YJ, Tseng CY, Lin PY, 2017c. Acute exposure to DEHP metabolite, MEHP cause genotoxicity, mutagenesis and carcinogenicity in mammalian Chinese hamster ovary cells. Carcinogenesis 38(3):336–345. 10.1093/carcin/bgx009.28426879
Chang WH, Tsai YS, Wang JY, 2019a. Sex hormones and oxidative stress mediated phthalate-induced effects in prostatic enlargement. Environ Int 126:184–192. 10.1016/j.envint.2019.02.006.30798199
Chang WH, Tsai YS, Wang JY, 2019b. Supplemental material: Sex hormones and oxidative stress mediated phthalate-induced effects in prostatic enlargement. Environ Int 126. 10.1016/j.envint.2019.02.006.
Chang JW, Liao KW, Huang CY, 2020. Phthalate exposure increased the risk of early renal impairment in Taiwanese without type 2 diabetes mellitus. Int J Hyg Environ Health 224:113414. 10.1016/j.ijheh.2019.10.009.31784327
Chang-Liao WL, Hou ML, Chang LW, 2013. Determination and pharmacokinetics of di-(2-ethylhexyl) phthalate in rats by ultra performance liquid chromatography with tandem mass spectrometry. Molecules 18(9):11452–11466. 10.3390/molecules180911452.24043141
Chaudhary BI, Liotta CL, Cogen JM, 2016. Plasticized PVC. In: Reference module in materials science and materials engineering. Elsevier Inc., 1–6.
Chauvigné F, Menuet A, Lesné L, 2009. Time- and dose-related effects of di-(2-ethylhexyl) phthalate and its main metabolites on the function of the rat fetal testis in vitro. Environ Health Perspect 117(4):515–521. 10.1289/ehp.11870.19440488
Chen S, Chen J, Cai X, 2010. Perinatal exposure to di-(2-ethylhexyl) phthalate leads to restricted growth and delayed lung maturation in newborn rats. J Perinat Med 38(5):515–521. 10.1515/jpm.2010.083.20629491
Chen J, Wu S, Wen S, 2015. The mechanism of environmental endocrine disruptors (DEHP) induces epigenetic transgenerational inheritance of cryptorchidism. PLoS ONE 10(6):e0126403. 10.1371/journal.pone.0126403.26035430
Chen SY, Hwang JS, Sung FC, 2017. Mono-2-ethylhexyl phthalate associated with insulin resistance and lower testosterone levels in a young population. Environ Pollut 225:112–117. 10.1016/j.envpol.2017.03.037.28359975
Chen CC, Wang YH, Chen WJ, 2019. A benchmark dose study of prenatal exposure to di(2-ethylhexyl) phthalate and behavioral problems in children. Int J Hyg Environ Health 222(6):971–980. 10.1016/j.ijheh.2019.06.002.31221485
Cheng HF, Lin JG. 2000. Biodegradation of di-(2-ethylhexyl)phthalate in sewage sludge. Water Sci Technol 41(12):1–6.
Cheon YP. 2020. Di-(2-ethylhexyl) phthalate (DEHP) and uterine histological characteristics. Dev Reprod 24(1):1–17. 10.12717/dr.2020.24.1.1.32411914
Chevrier C, Petit C, Philippat C, 2012. Maternal urinary phthalates and phenols and male genital anomalies. Epidemiology 23(2):353–356. 10.1097/EDE.0b013e318246073e.22317818
Chiang C, Flaws JA. 2019. Subchronic exposure to di(2-ethylhexyl) phthalate and diisononyl phthalate during adulthood has immediate and long-term reproductive consequences in female mice. Toxicol Sci 168(2):620–631. 10.1093/toxsci/kfz013.30649530
Chiang C, Lewis LR, Borkowski G, 2020a. Late-life consequences of short-term exposure to di(2-ethylhexyl) phthalate and diisononyl phthalate during adulthood in female mice. Reprod Toxicol 93:28–42. 10.1016/j.reprotox.2019.12.006.31904422
Chiang C, Lewis LR, Borkowski G, 2020b. Exposure to di(2-ethylhexyl) phthalate and diisononyl phthalate during adulthood disrupts hormones and ovarian folliculogenesis throughout the prime reproductive life of the mouse. Toxicol Appl Pharmacol 393:114952. 10.1016/j.taap.2020.114952.32165126
Ching NP, Jham GN, Subbarayan C, 1981. Gas chromatographic-mass spectrometric detection of circulating plasticizers in surgical patients. J Chromatogr 222(2):171–177. 10.1016/s0378-4347(00)81050-6.7251735
Chiu YH, Bellavia A, James-Todd T, 2018a. Evaluating effects of prenatal exposure to phthalate mixtures on birth weight: A comparison of three statistical approaches. Environ Int 113:231–239. 10.1016/j.envint.2018.02.005.29453090
Chiu YH, Bellavia A, James-Todd T, 2018b. Supplemental material: Evaluating effects of prenatal exposure to phthalate mixtures on birth weight: A comparison of three statistical approaches. Environ Int 113 10.1016/j.envint.2018.02.005.
Chiu CY, Sun SC, Chiang CK, 2018c. Plasticizer di(2-ethylhexyl)phthalate interferes with osteoblastogenesis and adipogenesis in a mouse model. J Orthop Res 36(4):1124–1134. 10.1002/jor.23740.28921615
Choi S, Park S, Jeong J, 2010. Identification of toxicological biomarkers of di(2-ethylhexyl) phthalate in proteins secreted by HepG2 cells using proteomic analysis. Proteomics 10(9):1831–1846. 10.1002/pmic.200900674.20198640
Choi K, Joo H, Campbell JL, 2012. In vitro metabolism of di(2-ethylhexyl) phthalate (DEHP) by various tissues and cytochrome P450s of human and rat. Toxicol in Vitro 26(2):315–322. 10.1016/j.tiv.2011.12.002.22186153
Choi K, Joo H, Campbell JL, 2013. In vitro intestinal and hepatic metabolism of di(2-ethylhexyl) phthalate (DEHP) in human and rat. Toxicol in Vitro 27(5):1451–1457. 10.1016/j.tiv.2013.03.012.23545481
Christiansen S, Scholze M, Dalgaard M, 2009. Synergistic disruption of external male sex organ development by a mixture of four antiandrogens. Environ Health Perspect 117(12):1839–1846. 10.1289/ehp.0900689.20049201
Christiansen S, Boberg J, Axelstad M, 2010. Low-dose perinatal exposure to di(2-ethylhexyl) phthalate induces anti-androgenic effects in male rats. Reprod Toxicol 30(2):313–321. 10.1016/j.reprotox.2010.04.005.20420898
Chu I, Dick D, Bronaugh R, 1996. Skin reservoir formation and bioavailability of dermally administered chemicals in hairless guinea pigs. Food Chem Toxicol 34(3):267–276.8621108
Chuang SC, Chen HC, Sun CW, 2020. Phthalate exposure and prostate cancer in a population-based nested case-control study. Environ Res 181:108902. 10.1016/j.envres.2019.108902.31785779
Cimini AM, Sulli A, Stefanini S, 1994. Effects of di-(2-ethylhexyl)phthalate on peroxisomes of liver, kidney and brain of lactating rats and their pups. Cell Mol Biol 40(8):1063–1076.7873979
Clara M, Windhofer G, Hartl W, 2010. Occurrence of phthalates in surface runoff, untreated and treated wastewater and fate during wastewater treatment. Chemosphere 78(9):1078–1084. 10.1016/j.chemosphere.2009.12.052.20096917
Clark KE, David RM, Guinn R, 2011. Modeling human exposure to phthalate esters: A comparison of indirect and biomonitoring estimation methods. Hum Ecol Risk Assess 17(4):923–965. 10.1080/10807039.2011.588157.23087593
Clayton GD, Clayton FE. 1981. Diethyl phthalate. In: Patty’s industrial hygiene and toxicology. Vol. 2A. 3rd ed. New York, NY: John Wiley & Sons, 2344–2345.
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Clewell RA, Campbell JL, Ross SM, 2010. Assessing the relevance of in vitro measures of phthalate inhibition of steroidogenesis for in vivo response. Toxicol in Vitro 24(1):327–334. 10.1016/j.tiv.2009.08.003.19699292
CMA. 1986. Analysis of bis(2-ethylhexyl) phthalate (DEHP) by gas chromatography-mass spectrometry in dairy and meat products. Washington, DC: Chemical Manufacturer’s Association.
Cobellis L, Latini G, De Felice C, 2003. High plasma concentrations of di-(2-ethylhexyl)-phthalate in women with endometriosis. Hum Reprod 18(7):1512–1515. 10.1093/humrep/deg254.12832380
Cohen H, Charrier C, Sarfaty J. 1991. Extraction and identification of a plasticizer, di-(2-ethylhexyl)phthalate, from a plastic bag containing contaminated corn. Arch Environ Contam Toxicol 20:437–440.
Cole RS, Tocchi M, Whe E, 1981. Contamination of commercial blood products by di-2-ethylhexyl phthalate and mono-2-ethylhexyl phthalate. Vox Sang 40:317–322.7245717
Cole RH, Frederick RE, Healy RP, 1984. Preliminary findings of the priority pollutant monitoring project of the National Urban Runoff Program. J Water Pollut Control Fed 56(7):898–908.
Contreras TJ, Sheibley RH, Valeri CR. 1974. Accumulation of di-2-ethylhexyl phthalate (DEHP) in whole blood, platelet concentrates and platelet-poor plasma. Transfusion 14:34–46.4812057
Conway JG, Tomaszewski KE, Olson MJ, 1989. Relationship of oxidative damage to the hepatocarcinogenicity of the peroxisome proliferators di(2-ethylhexyl)phthalate and Wy-14,643. Carcinogenesis 10(3):513–519. 10.1093/carcin/10.3.513.2924396
Corton JC, Peters JM, Klaunig JE. 2018. The PPARa-dependent rodent liver tumor response is not relevant to humans: Addressing misconceptions. Arch Toxicol 92:83–119.29197930
CPSC. 1999. CPSC releases study on phthalates in teethers, rattles and other children’s products. U.S. Consumer Product Safety Commission. http://cpsc.gov/cpscpub/prerel/prhtml99/99031.html. March 19, 2000.
CPSC. 2001. Chronic Hazard Advisory Panel on diisononyl phthalate (DINP). U.S. Consumer Product Safety Commission.
CPSC. 2010a. Memorandum to Michael Babich from Kent Carlson regarding the toxicity review of di(2-ethylhexyl) phthalate (DEHP). Bethesda, MD: U.S. Consumer Product Safety Commission.
CPSC. 2010b. Review of exposure and toxicity data for phthalate substitutes. Bethesda, MD: U.S. Consumer Product Safety Commission. https://www.cpsc.gov/s3fs-public/phthalsub.pdf. July 13, 2021.
CPSC. 2014. Report to the U.S. Consumer Product Safety Commission by the Chronic Hazard Advisory Panel on phthalates and phthalate alternatives. Bethesda, MD: U.S. Consumer Product Safety Commission.
CPSIA. 2008. Consumer Product Safety Improvement Act of 2008. Public Law 11–314, 110th Congress. Title I- Children’s product safety. Consumer Product Safety Improvement Act.
Culty M, Thuillier R, Li W, 2008. In utero exposure to di-(2-ethylhexyl) phthalate exerts both short-term and long-lasting suppressive effects on testosterone production in the rat. Biol Reprod 78(6):1018–1028. 10.1095/biolreprod.107.065649.18322279
Dales RE, Kauri LM, Cakmak S. 2018. The associations between phthalate exposure and insulin resistance, β-cell function and blood glucose control in a population-based sample. Sci Total Environ 612:1287–1292. 10.1016/j.scitotenv.2017.09.009.28898934
Dalgaard M, Ostergaard G, Lam HR, 2000. Toxicity study of di(2-ethylhexyl)phthalate (DEHP) in combination with acetone in rats. Pharmacol Toxicol 86(2):92–100. 10.1034/j.1600-0773.2000.pto860208.x.10728921
Dalsenter PR, Santana GM, Grande SW, 2006. Phthalate affect the reproductive function and sexual behavior of male Wistar rats. Hum Exp Toxicol 25(6):297–303. 10.1191/0960327105ht624oa.16866186
Daniel JW, Bratt H. 1974. The absorption, metabolism and tissue distribution of di(2-ethylhexyl)phthalate in rats. Toxicology 2(1):51–65.4823738
Daniel S, Balalian AA, Whyatt RM, 2020. Perinatal phthalates exposure decreases fine-motor functions in 11-year-old girls: Results from weighted Quantile sum regression. Environ Int 136:105424. 10.1016/j.envint.2019.105424.31881420
David RM, Moore MR, Cifone MA, 1999. Chronic peroxisome proliferation and hepatomegaly associated with the hepatocellular tumorigenesis of di(2-ethylhexyl)phthalate and the effects of recovery. Toxicol Sci 50(2):195–205.10478855
David RM, Moore MR, Finney DC, 2000a. Chronic toxicity of di(2-ethylhexyl)phthalate in rats. Toxicol Sci 55(2):433–443.10828276
David RM, Moore MR, Finney DC, 2000b. Chronic toxicity of di(2-ethylhexyl)phthalate in mice. Toxicol Sci 58(2):377–385.11099649
Deisinger PJ, Perry LG, Guest D. 1998. In vivo percutaneous absorption of [14C]DEHP from [14C]DEHP-plasticized polyvinyl chloride film in male Fischer 344 rats. Food Chem Toxicol 36:521–527.9674960
DeLeon IR, Byrne CJ, Peuler EA, 1986. Trace organic and heavy metal pollutants in the Mississippi River. Chemosphere 15:795–805.
Deng T, Xie X, Duan J, 2019. Di-(2-ethylhexyl) phthalate induced an increase in blood pressure via activation of ACE and inhibition of the bradykinin-NO pathway. Environ Pollut 247:927–934. 10.1016/j.envpol.2019.01.099.30823347
Deng T, Du Y, Wang Y, 2020. The associations of urinary phthalate metabolites with the intermediate and pregnancy outcomes of women receiving IVF/ICSI treatments: A prospective single-center study. Ecotoxicol Environ Saf 188:109884. 10.1016/j.ecoenv.2019.109884.31706241
Desdoits-Lethimonier C, Albert O, Le Bizec B, 2012. Human testis steroidogenesis is inhibited by phthalates. Hum Reprod 27(5):1451–1459. 10.1093/humrep/des069.22402212
Desideri PG, Lepri L, Checchini L, 1994. Organic compounds in surface and deep Antarctic snow. Int J Environ Anal Chem 55:33–46.
Desideri PG, Lepri L, Udisti R, 1998. Analysis of organic compounds in Antarctic snow and their origin. Int J Environ Anal Chem 7(3–4):331–351.
DeVault DS. 1985. Contaminants in fish from Great Lakes harbors and tributary mouths. Arch Environ Contam Toxicol 14:587–594.
Dhanya CR, Indu AR, Deepadevi KV, 2003. Inhibition of membrane Na(+)-K+ ATPase of the brain, liver and RBC in rats administered di(2-ethyl hexyl) phthalate (DEHP) a plasticizer used in polyvinyl chloride (PVC) blood storage bags. Indian J Exp Biol 41(8):814–820.15248477
Dine T, Luyckx M, Cazin M, 1991. Rapid determination by high performance liquid chromatography of di-2-ethylhexyl phthalate in plasma stored in plastic bags. Biomed Chromatogr 5:94–97.1868266
Dine T, Luychx M, Gressier B, 2000. A pharmacokinetic interpretation of increasing concentrations of DEHP in haemodialysed patients. Med Eng Phys 22:157–165.10964036
Ding Y, Gao K, Liu Y, 2019. Transcriptome analysis revealed the mechanism of the metabolic toxicity and susceptibility of di-(2-ethylhexyl)phthalate on adolescent male ICR mice with type 2 diabetes mellitus. Arch Toxicol 93(11):3183–3206. 10.1007/s00204-019-02590-8.31606821
Dirinck E, Dirtu AC, Geens T, 2015. Urinary phthalate metabolites are associated with insulin resistance in obese subjects. Environ Res 137:419–423. 10.1016/j.envres.2015.01.010.25622280
Dirtu AC, Geens T, Dirinck E, 2013. Phthalate metabolites in obese individuals undergoing weight loss: Urinary levels and estimation of the phthalates daily intake. Environ Int 59:344–353. 10.1016/j.envint.2013.06.023.23892227
Dirven HA, Theuws JL, Jongeneelen FJ, 1991. Non-mutagenicity of 4 metabolites of di(2-ethylhexyl)phthalate (DEHP) and 3 structurally related derivatives of di(2-ethylhexyl)adipate (DEHA) in the Salmonella mutagenicity assay. Mutat Res 260(1):121–130. 10.1016/0165-1218(91)90088-4.2027336
Diwan BA, Ward JM, Rice JM, 1985. Tumor-promoting effects of di(2-ethylhexyl)phthalate in JB6 mouse epidermal cells and mouse skin. Carcinogenesis 6(3):343–347. 10.1093/carcin/6.3.343.3919955
Do RP, Stahlhut RW, Ponzi D, 2012. Non-monotonic dose effects of in utero exposure to di(2-ethylhexyl) phthalate (DEHP) on testicular and serum testosterone and anogenital distance in male mouse fetuses. Reprod Toxicol 34(4):614–621. 10.1016/j.reprotox.2012.09.006.23041310
DOE. 2018a. Table 3: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. Oak Ridge, TN: U.S. Department of Energy. https://edms.energy.gov/pac/docs/Revision_29A_Table3.pdf. April 12, 2020.
DOE. 2018b. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. Oak Ridge, TN: U.S. Department of Energy. https://edms.energy.gov/pac/. April 12, 2020.
Doherty BT, Engel SM, Buckley JP, 2017. Prenatal phthalate biomarker concentrations and performances on the Bayles Scales of infant development-II in a population of young urban children. Environ Res 152:51–58.27741448
Dombret C, Capela D, Poissenot K, 2017. Neural mechanisms underlying the disruption of male courtship behavior by adult exposure to di(2-ethylhexyl) phthalate in mice. Environ Health Perspect 125(9):097001. 10.1289/ehp1443.28934723
Dong X, Dong J, Zhao Y, 2017. Effects of long-term in vivo exposure to di-2-ethylhexylphthalate on thyroid hormones and the TSH/TSHR signaling pathways in Wistar rats. Int J Environ Res Public Health 14:44. 10.3390/ijerph14010044.28054989
Dong J, Cong Z, You M, 2019. Effects of perinatal di (2-ethylhexyl) phthalate exposure on thyroid function in rat offspring. Environ Toxicol Pharmacol 67:53–60. 10.1016/j.etap.2019.01.012.30716676
Dorman DC, Chiu W, Hales BF, 2018. Systematic reviews and meta-analyses of human and animal evidence of prenatal diethylhexyl phthalate exposure and changes in male anogenital distance. J Toxicol Environ Health 21(4):207–226. 10.1080/10937404.2018.1505354.
Dostal LA, Jenkins WL, Schwetz BA. 1987. Hepatic peroxisome proliferation and hypolipidemic effects of di(2-ethylhexyl) phthalate in neonatal and adult rats. Toxicol Appl Pharmacol 87:81–90.3798454
Dostal LA, Chapin RE, Stefanski SA, 1988. Testicular toxicity and reduced Sertoli cell numbers in neonatal rats by di(2-ethylhexyl) phthalate and the recovery of fertility as adults. Toxicol Appl Pharmacol 95(1):104–121. 10.1016/s0041-008x(88)80012-7.3413790
Douglas GR, Hugenholtz AP, Blakey DH. 1986. Genetic toxicology of phthalate esters: Mutagenic and other genotoxic effects. Environ Health Perspect 65:255–262.3709450
Doull J, Cattley R, Elcombe C, 1999. A cancer risk assessment of di(2-ethylhexyl)phthalate: Application of the new U.S. EPA Risk Assessment Guidelines. Regul Toxicol Pharmacol 29(3):327–357. 10.1006/rtph.1999.1296.10388618
Doyle TJ, Bowman JL, Windell VL, 2013. Transgenerational effects of di-(2-ethylhexyl) phthalate on testicular germ cell associations and spermatogonial stem cells in mice. Biol Reprod 88(5):112. 10.1095/biolreprod.112.106104.23536373
Du YY, Fang YL, Wang YX, 2016. Follicular fluid and urinary concentrations of phthalate metabolites among infertile women and associations with in vitro fertilization parameters. Reprod Toxicol 61:142–150. 10.1016/j.reprotox.2016.04.005.27067915
Du ZP, Feng S, Li YL, 2020. Di-(2-ethylhexyl) phthalate inhibits expression and internalization of transthyretin in human placental trophoblastic cells. Toxicol Appl Pharmacol 394:114960. 10.1016/j.taap.2020.114960.32201330
Eckel W, Ross B, Isensee R. 1993. Pentobarbitol found in ground water. Ground Water 31:801–804.
Edlund C, Ericsson J, Dallner G. 1987. Changes in hepatic dolichol and dolichyl monophosphate caused by treatment of rats with inducers of the endoplasmic reticulum and peroxisomes and during ontogeny. Chem Biol Interact 62(2):191–208. 10.1016/0009-2797(87)90090-1.3594641
Egestad B, Sjoberg P. 1992. Glucosidation as a new conjugation pathway for metabolites of bis(2-ethylhexyl) phthalate. Drug Metab Dispos 20(3):470–472.1355727
Egestad B, Green G, Sjoberg P, 1996. Chromatographic fractionation and analysis by mass spectrometry of conjugated metabolites of bis(2-ethylhexyl)phthalate in urine. J Chromatogr 677(1):99–109. 10.1016/0378-4347(95)00439-4.
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15(1):30–38.
Ellington JJ. 1999. Octanol/water partition coefficients and water solubilities of phthalate esters. J Chem Eng Data 44:1414–1418.
Elliott BM, Elcombe CR. 1987. Lack of DNA damage or lipid peroxidation measured in vivo in the rat liver following treatment with peroxisomal proliferators. Carcinogenesis 8(9):1213–1218. 10.1093/carcin/8.9.1213.3621460
Elsisi AE, Carter DE, Sipes IG. 1989. Dermal absorption of phthalate diesters in rats. Fundam Appl Toxicol 12:70–77.2925020
Emoto C, Murayama N, Rostami-Hodjegan A, 2009. Utilization of estimated physicochemical properties as an integrated part of predicting hepatic clearance in the early drug-discovery stage: Impact of plasma and microsomal binding. Xenobiotica 39(3):227–235. 10.1080/00498250802668863.19280521
Engel SM, Villanger GD, Nethery RC, 2018. Prenatal phthalates, maternal thyroid function, and risk of attention-deficit hyperactivity disorder in the Norwegian mother and child cohort. Environ Health Perspect 126(5):057004. 10.1289/EHP2358.29790729
EPA. 1979. Water-related environmental fate of 129 priority pollutants. Vol. II. Halogenated aliphatic hydrocarbons, halogenated ethers, monocyclic aromatics, phthalate esters, polycyclic aromatic hydrocarbons, nitrosamines, and miscellaneous compounds. Washington, DC: U.S. Environmental Protection Agency. EPA440479029a. PB80204373.
EPA. 1980. Ambient water quality criteria for phthalate esters. Washington, DC: U.S. Environmental Protection Agency. EPA440479029a. PB80204373.
EPA. 1981. An exposure and risk assessment for phthalate esters: Di(2-ethylhexyl) phthalate, di-n-butyl phthalate, dimethyl phthalate, diethyl phthalate, di-n-octyl phthalate, butyl benzyl phthalate. Washington, DC: U.S. Environmental Protection Agency. EPA440481020. PB85211936.
EPA. 1984. GC/MS analysis of organics in drinking water concentrates and advanced waste treatment concentrates: Volume I: Analysis results for 17 drinking water, 16 advanced waste treatment and 3 process blank concentrates. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600184020a. PB85128221.
EPA. 1986. Method 8060: Phthalate esters. Test methods for evaluating solid waste. U.S. Environmental Protection Agency. SW–846.
EPA. 1990. Table 1-11: Pollutant concentration estimates from the National Sewage Sludge Survey. U.S. Environmental Protection Agency. Fed Regist 55:47229.
EPA. 1995. Method 525.2. Determination of organic compounds in drinking water by liquid-solid extraction and capillary column gas chromatography/mass spectrometry. Selected analytical methods for environmental remediation and recovery (SAM). Cincinnati, OH: U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2015-06/documents/epa-525.2.pdf. April 15, 2021.
EPA. 1996. Method 8061A. Phthalate esters by gas chromatography with electron capture detection (GC/ECD). Test methods for evaluation solid waste. U.S. Environmental Protection Agency. SW–846.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001.
EPA. 2009a. Targeted national sewage sludge survey sampling and analysis technical report. Washington, DC: U.S. Environmental Protection Agency. EPA822R08016. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P1003RL8.txt. July 31, 2020.
EPA. 2009b. The analysis of regulated contaminant occurrence data from public water systems in support of the second six-year review of National Primary Drinking Water Regulations. U.S. Environmental Protection Agency.
EPA. 2009c. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
EPA. 2012. Phthalates action plan. Revised 3/14/2012. Washington, DC: U.S. Environmental Protection Agency. https://www.epa/gov/sites/production/files/2015-09/documents/phthalates_actionplan_revised2012-03-14.pdf. July 9, 2018.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. July 25, 2018.
EPA. 2018b. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
Eriksson P, Darnerud PO. 1985. Distribution and retention of some chlorinated hydrocarbons and a phthalate in the mouse brain during the preweaning period. Toxicology 37:189–203.3934796
Erkekoğlu P, Rachidi W, De Rosa V, 2010a. Protective effect of selenium supplementation on the genotoxicity of di(2-ethylhexyl)phthalate and mono(2-ethylhexyl)phthalate treatment in LNCaP cells. Free Radic Biol Med 49(4):559–566. 10.1016/j.freeradbiomed.2010.04.03.20466057
Erkekoglu P, Giray B, Durmaz E, 2010b. Evaluation of the correlation between plasma amylase and lipase levels and phthalate exposure in pubertal gynecomastia patients. Turk Pediatri Arsivi 45(4):366–370. 10.4274/tpa.45.366.
Erythropel HC, Maric M, Nicell JA, 2014. Leaching of the plasticizer di(2-ethylhexyl)phthalate (DEHP) from plastic containers and the question of human exposure. Appl Microbiol Biotechnol 98(24):9967–9981. 10.1007/s00253-014-6183-8.25376446
Exxon Chemical Americas. 1990. An investigation of the effect of di-(2-ethylhexyl) phthalate on rat hepatic peroxisomes with cover letter. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0530399. 86–91000007729. TSCATS/414999.
Factor-Litvak P, Insel B, Calafat AM, 2014. Persistent associations between maternal prenatal exposure to phthalates on child IQ at age 7 years. PLoS ONE 9(12):e114003. 10.1371/journal.pone.0114003.25493564
Fahrig R, Steinkamp-Zucht A. 1996. Co-recombinogenic and anti-mutagenic effects of diethylhexylphthalate, inactiveness of pentachlorophenol in the spot test with mice. Mutat Res 354(1):59–67. 10.1016/0027-5107(96)00036-x.8692207
Fallon ME, Horvath FJ. 1985. Preliminary assessment of contaminants in soft sediments of the Detroit River. J Great Lakes Res 11:373–378.
Fan Y, Qin Y, Chen M, 2020. Prenatal low-dose DEHP exposure induces metabolic adaptation and obesity: Role of hepatic thiamine metabolism. J Hazard Mater 385:121534. 10.1016/j.jhazmat.2019.121534.31706747
Faouzi MA, Dine T, Luyckx M, 1994. Leaching of diethylhexyl phthalate from PVC bags into intravenous teniposide solution. Int J Pharm 105(1):89–93.
Faouzi MA, Dine T, Gressier B, 1999. Exposure of hemodialysis patients to di-2-ethylhexyl phthalate. Int J Pharm 180(1):113–121. 10.1016/s0378-5173(98)00411-6.10089298
Fayad NM, Sheikheldin SY, Al-Malack MH, 1997. Migration of vinyl chloride monomer (VCM) and additives into PVC bottled drinking water. J Environ Sci Health A Environ Sci Eng Toxic Hazard A32(4):1065–1083.
FDA. 1999a. Subpart B-Substances for use only as components of adhesives. Adhesives. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 175.105.
FDA. 1999b. Cellophane. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 177.1200.
FDA. 1999c. Acrylic and modified acrylic plastics, semirigid and rigid. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 177.1010.
FDA. 1999d. Surface lubricants used in the manufacture of metallic articles. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 178.3910.
FDA. 1999e. Defoaming agents used in the manufacture of paper and paper-board. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 176.210.
FDA. 1999f. Plasticizers. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 181.27.
FDA. 1999g. Resinous and polymeric coatings. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 175.300.
FDA. 2001. Safety assessment of di(2-ethylhexyl)phthalate (DEHP) released from PVC medical devices. Rockville, MD: U.S. Food and Drug Administration.
FDA. 2016. Subpart B- Requirements for specific standardized beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55AppA. June 06, 2017.
FDA. 2019a. Di(2-ethylhexyl) phthalate. Indirect additives used in food contact substances. Washington, DC: U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/index.cfm?set=IndirectAdditives&id=DIPHTHALATE. August 26, 2020.
FDA. 2019b. Subpart B - Requirements for specific standardized beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. https://www.govinfo.gov/content/pkg/CFR-2019-title21-vol2/pdf/CFR-2019-title21-vol2-part165.pdf. December 5, 2019.
FDA. 2020. Substances added to food. Washington, DC: U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/?set=FoodSubstances. April 12, 2020.
Feng W, Liu Y, Ding Y, 2020. Typical neurobehavioral methods and transcriptome analysis reveal the neurotoxicity and mechanisms of di(2-ethylhexyl) phthalate on pubertal male ICR mice with type 2 diabetes mellitus. Arch Toxicol 94(4):1279–1302. 10.1007/s00204-020-02683-9.32303808
Ferguson KK, Loch-Caruso R, Meeker JD. 2012. Exploration of oxidative stress and inflammatory markers in relation to urinary phthalate metabolites: NHANES 1999–2006. Environ Sci Technol 46(1):477–485. 10.1021/es202340b.22085025
Ferguson KK, Peterson KE, Lee JM, 2014a. Prenatal and peripubertal phthalates and bisphenol A in relation to sex hormones and puberty in boys. Reprod Toxicol 47:70–76. 10.1016/j.reprotox.2014.06.002.24945889
Ferguson KK, McElrath TF, Meeker JD. 2014b. Environmental phthalate exposure and preterm birth. JAMA Pediatrics 168(1):61. 10.1001/jamapediatrics.2013.3699.24247736
Ferguson KK, McElrath TF, Ko Y, 2014c. Variability in urinary phthalate metabolite levels across pregnancy and sensitive windows of exposure for the risk of preterm birth. Environ Int 70:118–124. 10.1016/j.envint.2014.05.016.24934852
Ferguson KK, Peterson KE, Lee JM, 2014d. Supplemental material: Prenatal and peripubertal phthalates and bisphenol A in relation to sex hormones and puberty in boys. Reprod Toxicol 47. 10.1016/j.reprotox.2014.06.002.
Ferguson KK, McElrath TF, Chen YH, 2015. Urinary phthalate metabolites and biomarkers of oxidative stress in pregnant women: A repeated measures analysis. Environ Health Perspect 123(3):210–216. 10.1289/ehp.1307996.25402001
Ferguson KK, Chen YH, VanderWeele TJ, 2017. Mediation of the relationship between maternal phthalate exposure and preterm birth by oxidative stress with repeated measurements across pregnancy. Environ Health Perspect 125(3):488–494. 10.1289/ehp282.27352406
Ferguson KK, Rosen EM, Barrett ES, 2019a. Joint impact of phthalate exposure and stressful life events in pregnancy on preterm birth. Environ Int 133(Pt B):105254. 10.1016/j.envint.2019.105254.31675562
Ferguson KK, Rosen EM, Barrett ES, 2019b. Supplemental material: Joint impact of phthalate exposure and stressful life events in pregnancy on preterm birth. Environ Int 133. 10.1016/j.envint.2019.105254.
Ferguson KK, Rosen EM, Rosario Z, 2019c. Environmental phthalate exposure and preterm birth in the PROTECT birth cohort. Environ Int 132:105099. 10.1016/j.envint.2019.105099.31430608
Fernandez-Canal C, Pinta PG, Eljezi T, 2018. Patients’ exposure to PVC plasticizers from ECMO circuits. Expert Rev Med Devices 15(5):377–383. 10.1080/17434440.2018.1462698.29658331
Fernández-González V, Moscoso-Pérez C, Muniategui-Lorenzo S, 2017. Reliable, rapid and simple method for the analysis of phthalates in sediments by ultrasonic solvent extraction followed by head space-solid phase microextraction gas chromatography mass spectrometry determination. Talanta 162:648–653. 10.1016/j.talanta.2016.10.068.27837884
Fiandanese N, Borromeo V, Berrini A, 2016. Maternal exposure to a mixture of di(2-ethylhexyl) phthalate (DEHP) and polychlorinated biphenyls (PCBs) causes reproductive dysfunction in adult male mouse offspring. Reprod Toxicol 65:123–132. 10.1016/j.reprotox.2016.07.004.27417426
Fong JP, Lee FJ, Lu IS, 2015. Relationship between urinary concentrations of di(2-ethylhexyl) phthalate (DEHP) metabolites and reproductive hormones in polyvinyl chloride production workers. Occup Environ Med 72(5):346–353. 10.1136/oemed-2014-102532.25637220
Franken C, Lambrechts N, Govarts E, 2017. Phthalate-induced oxidative stress and association with asthma-related airway inflammation in adolescents. Int J Hyg Environ Health 220(2 Pt B):468–477. 10.1016/j.ijheh.2017.01.006.28174042
Friedman GM, Mukhopadhyay PK, Moch A, 2000. Waters and organic-rich waste near dumping grounds in New York Bight. Int J Coal Geol 42:325–355.
Furr JR, Lambright CS, Wilson VS, 2014. A short-term in vivo screen using fetal testosterone production, a key event in the phthalate adverse outcome pathway, to predict disruption of sexual differentiation. Toxicol Sci 140(2):403–424. 10.1093/toxsci/kfu081.24798384
Ganning AE, Brunk U, Edlund C, 1987. Effects of prolonged administration of phthalate ester on the liver. Environ Health Perspect 73(0):251–258.3665868
Ganning AE, Olsson MJ, Peterson E, 1989. Fatty acid oxidation in hepatic peroxisomes and mitochondria after treatment of rats with di(2-ethylhexyl)phthalate. Pharmacol Toxicol 65(4):265–268. 10.1111/j.1600-0773.1989.tb01170.x.2587508
Ganning AE, Olsson MJ, Brunk U, 1991. Effects of prolonged treatment with phthalate ester on rat liver. Pharmacol Toxicol 68:392–401.
Gao X, Yang B, Tang Z, 2014. Determination of phthalates released from paper packaging materials by solid-phase extraction-high-performance liquid chromatography. J Chromatogr Sci 52(5):383–389. 10.1093/chromsci/bmt046.23661671
Gao HT, Xu R, Cao WX, 2016. Food emulsifier glycerin monostearate increases internal exposure levels of six priority controlled phthalate esters and exacerbates their male reproductive toxicities in rats. PLoS ONE 11(8):e0161253. 10.1371/journal.pone.0161253.27575856
Gao H, Xu YY, Huang K, 2017. Cumulative risk assessment of phthalates associated with birth outcomes in pregnant Chinese women: A prospective cohort study. Environ Pollut 222:549–556. 10.1016/j.envpol.2016.11.026.28024814
Gao H, YF Wang, Huang K, 2019. Prenatal phthalate exposure in relation to gestational age and preterm birth in a prospective cohort study. Environ Res 176:108530. 10.1016/j.envres.2019.108530.31220737
Gascon M, Casas M, Morales E, 2015a. Prenatal exposure to bisphenol A and phthalates and childhood respiratory tract infections and allergy. J Allergy Clin Immunol 135(2):370–378. 10.1016/j.jaci.2014.09.030.25445825
Gascon M, Valvi D, Forns J, 2015b. Prenatal exposure to phthalates and neuropsychological development during childhood. Int J Hyg Environ Health 218(6):550–558. 10.1016/j.ijheh.2015.05.006.26095249
Ge RS, Chen GR, Dong Q, 2007. Biphasic effects of postnatal exposure to diethylhexylphthalate on the timing of puberty in male rats. J Androl 28(4):513–520. 10.2164/jandrol.106.001909.17287459
Gejlsbjerg B, Klinge C, Madsen T. 2001. Mineralization of organic contaminants in sludge-soil mixtures. Environ Toxicol Chem 20(4):698–705.11345443
Genuis SJ, Beesoon S, Lobo RA, 2012. Human elimination of phthalate compounds: Blood, urine, and sweat (BUS) study. Sci World J 2012:615068. 10.1100/2012/615068.
Gerbracht U, Einig C, Oesterle D, 1990. Di(2-ethylhexyl)phthalate alters carbohydrate enzyme activities and foci incidence in rat liver. Carcinogenesis 11(12):2111–2115.1979936
Ghassemi M, Quinlivan S, Bachmaier J. 1984. Characteristics of leachates from hazardous waste landfills. J Environ Sci Health A Environ Sci Eng Toxic Hazard 19:579–620.
Giam CS, Wong MK. 1987. Plasticizers in food. J Food Prot 50(9):769–782.30978802
Giam CS, Chan HS, Neff GS. 1975. Sensitive method for determination of phthalate ester plasticizers in open-ocean biota samples. Anal Chem 47:2225–2228.1238033
Giam CS, Chan HS, Neff GS, 1978. Phthalate ester plasticizers: A new class of marine pollutant. Science 199:419–421.413194
Giam CS, Atlas E, Chan HS, 1980. Phthalate esters, PCB and DDT residues in the Gulf of Mexico atmosphere. Atmos Environ 14:65–69.
Gong M, Zhang Y, Weschler CJ. 2014. Measurement of phthalates in skin wipes: Estimating exposure from dermal absorption. Environ Sci Technol 48(13):7428–7435. 10.1021/es501700u.24911978
Goodman M, Lakind JS, Mattison DR. 2014. Do phthalates act as obesogens in humans? A systematic review of the epidemiological literature. Crit Rev Toxicol 44(2):151–175. 10.3109/10408444.2013.860076.24417397
Goodrich JM, Ingle ME, Domino SE, 2019. First trimester maternal exposures to endocrine disrupting chemicals and metals and fetal size in the Michigan Mother-Infant Pairs study. J Dev Orig Health Dis 10(4):447–458. 10.1017/S204017441800106X.30696509
Gramiccioni L, Milana MR, DiMarzio S, 1990. Experimental evaluation about the actual release of DEHP from caps to packaged foods. Rass Chim 42:3–7.
Grande SW, Andrade AJ, Talsness CE, 2006. A dose-response study following in utero and lactational exposure to di(2-ethylhexyl)phthalate: effects on female rat reproductive development. Toxicol Sci 91(1):247–254. 10.1093/toxsci/kfj128.16476687
Grande SW, Andrade AJ, Talsness CE, 2007. A dose-response study following in utero and lactational exposure to di-(2-ethylhexyl) phthalate (DEHP): reproductive effects on adult female offspring rats. Toxicology 229(1–2):114–122. 10.1016/j.tox.2006.10.005.17098345
Grasso P, Heindel JJ, Powell CJ, 1993. Effects of mono(2-ethylhexyl) phthalate, a testicular toxicant, on follicle-stimulating hormone binding to membranes from cultured rat Sertoli cells. Biol Reprod 48(3):454–459.8384005
Gray TJB, Beamand JA. 1984. Effect of some phthalate esters and other testicular toxins on primary cultures of testicular cells. Food Chem Toxicol 22(2):123–131. 10.1016/0278-6915(84)90092-9.6538161
Gray TJ, Gangolli SD. 1986. Aspects of the testicular toxicity of phthalate esters. Environ Health Perspect 65:229–235.3709446
Gray TJ, Butterworth KR, Gaunt IF, 1977. Short-term toxicity study of di-(2-ethylhexyl) phthalate in rats. Food Chem Toxicol 15(5):389–399. 10.1016/s0015-6264(77)80003-5.
Gray L, Barlow N, Howdeshell K, 2009. Transgenerational effects of di (2-ethylhexyl) phthalate in the male CRL:CD(SD) rat: added value of assessing multiple offspring per litter. Toxicol Sci 110(2):411–425. 10.1093/toxsci/kfp109.19482887
Greifenstein M, White DW, Stubner A, 2013. Impact of temperature and storage duration on the chemical and odor quality of military packaged water in polyethylene terephthalate bottles. Sci Total Environ 456–457:376–383. 10.1016/j.scitotenv.2013.03.092.
Grindler NM, Allsworth JE, Macones GA, . 2015. Persistent organic pollutants and early menopause in U.S. women. PLoS ONE 10(1):e0116057. 10.1371/journal.pone.0116057.25629726
Gu H, Liu Y, Wang W, 2016. In utero exposure to di-(2-ethylhexyl) phthalate induces metabolic disorder and increases fat accumulation in visceral depots of C57BL/6J mice offspring. Exp Ther Med 12(6):3806–3812. 10.3892/etm.2016.3820.28105114
Guo J, Han B, Qin L, 2012. Pulmonary toxicity and adjuvant effect of di-(2-exylhexyl) phthalate in ovalbumin-immunized BALB/c mice. PLoS ONE 7(6):e39008. 10.1371/journal.pone.0039008.22701742
Guo J, Li XW, Liang Y, 2013. The increased number of Leydig cells by di(2-ethylhexyl) phthalate comes from the differentiation of stem cells into Leydig cell lineage in the adult rat testis. Toxicology 306:9–15. 10.1016/j.tox.2013.01.021.23391632
Guo Y, Weck J, Sundaram R, 2014. Urinary concentrations of phthalates in couples planning pregnancy and its association with 8-hydroxy-2’-deoxyguanosine, a biomarker of oxidative stress: longitudinal investigation of fertility and the environment study. Environ Sci Technol 48(16):9804–9811. 10.1021/es5024898.25068827
Gupta RC, Goel SK, Earley K, 1985. 32P-Postlabeling analysis of peroxisome proliferator-DNA adduct formation in rat liver in vivo and hepatocytes in vitro. Carcinogenesis 6(6):933–936. 10.1093/carcin/6.6.933.4006083
Gupta C, Hattori A, Shinozuka H. 1988. Suppression of EGF binding in rat liver by the hypolipidemic peroxisome proliferators, 4-chloro-6-(2,3-xylidino)-2-pyrimidinylthio-(N-beta-hydroxyethyl)acetamide and di(2-ethylhexyl)phthalate. Carcinogenesis 9(1):167–169. 10.1093/carcin/9.1.167.3257172
Guyton KZ, Chiu WA, Bateson TF, 2009. A reexamination of the PPAR-alpha activation mode of action as a basis for assessing human cancer risks of environmental contaminants. Environ Health Perspect 117(11):1664–1672. 10.1289/ehp.0900758.20049115
Hall AP, Elcombe CR, Foster J, 2012. Liver hypertrophy: A review of the adaptive (adverse and non-adverse changes- conclusions from the 3rd International ESTP Expert Workshop. Toxicol Pathol 40(7):971–994.22723046
Han Y, Wang X, Chen G, 2014a. Di-(2-ethylhexyl) phthalate adjuvantly induces imbalanced humoral immunity in ovalbumin-sensitized BALB/c mice ascribing to T follicular helper cells hyperfunction. Toxicology 324:88–97. 10.1016/j.tox.2014.07.011.25093321
Han X, Cui Z, Zhou N, 2014b. Urinary phthalate metabolites and male reproductive function parameters in Chongqing general population, China. Int J Hyg Environ Health 217(2–3):271–278. 10.1016/j.ijheh.2013.06.006.23906849
Han H, Lee HA, Park B, 2019. Associations of phthalate exposure with lipid levels and insulin sensitivity index in children: A prospective cohort study. Sci Total Environ 662:714–721. 10.1016/j.scitotenv.2019.01.151.30703729
Hanioka N, Isobe T, Ohkawara S, 2019. Hydrolysis of di(2-ethylhexyl) phthalate in humans, monkeys, dogs, rats, and mice: An in vitro analysis using liver and intestinal microsomes. Toxicol in Vitro 54:237–242. 10.1016/j.tiv.2018.10.006.30315871
Hannas BR, Lambright CS, Furr J, 2011. Dose-response assessment of fetal testosterone production and gene expression levels in rat testes following in utero exposure to diethylhexyl phthalate, diisobutyl phthalate, diisoheptyl phthalate, and diisononyl phthalate. Toxicol Sci 123(1):206–216. 10.1093/toxsci/kfr146.21633115
Hannon PR, Peretz J, Flaws JA. 2014. Daily exposure to di(2-ethylhexyl) phthalate alters estrous cyclicity and accelerates primordial follicle recruitment potentially via dysregulation of the phosphatidylinositol 3-kinase signaling pathway in adult mice. Biol Reprod 90(6):136. 10.1095/biolreprod.114.119032.24804967
Hansen OG. 2019. Does it really make sense to develop PVC-free materials? Plastics Today. https://www.plasticstoday.com/medical/does-it-really-make-sense-develop-pvc-free-materials. July 9, 2021.
Hansen JF, Bendtzen K, Boas M, 2015. Influence of phthalates on cytokine production in monocytes and macrophages: a systematic review of experimental trials. PLoS ONE 10(3):e0120083. 10.1371/journal.pone.0120083.25811352
Hao C, Cheng X, Xia H, 2012. The endocrine disruptor mono-(2-ethylhexyl) phthalate promotes adipocyte differentiation and induces obesity in mice. Biosci Rep 32:619–629.22953781
Harley KG, Berger K, Rauch S, 2017. Association of prenatal urinary phthalate metabolite concentrations and childhood BMI and obesity. Pediatr Res 82(3):405–415.28426647
Hasegawa M, Kawai K, Mitsui T, 2011. The reconstituted ’humanized liver’ in TK-NOG mice is mature and functional. Biochem Biophys Res Commun 405(3):405–410. 10.1016/j.bbrc.2011.01.042.21238430
Hasmall SC, James NH, Macdonald N, 2000. Species differences in response to diethylhexylphthalate: suppression of apoptosis, induction of DNA synthesis and peroxisome proliferator activated receptor alpha-mediated gene expression. Arch Toxicol 74(2):85–91. 10.1007/s002040050657.10839475
Hatch EE, Nelson JW, Qureshi MM, 2008. Association of urinary phthalate metabolite concentrations with body mass index and waist circumference: a cross-sectional study of NHANES data, 1999–2002. Environ Health 7:27. 10.1186/1476-069x-7-27.18522739
Hauser TR, Bromberg SM. 1982. EPA’s monitoring program at Love Canal 1980. Environ Monit Assess 2(3):249–272. 10.1007/bf00394456.24264296
Hauser R, Williams P, Altshul L, 2005. Evidence of interaction between polychlorinated biphenyls and phthalates in relation to human sperm motility. Environ Health Perspect 113(4):425–430. 10.1289/ehp.7305.15811833
Hauser R, Meeker JD, Duty S, 2006. Altered semen quality in relation to urinary concentrations of phthalate monoester and oxidative metabolites. Epidemiology 17(6):682–691. 10.1097/01.ede.0000235996.89953.d7.17003688
Hauser R, Meeker JD, Singh NP, 2007. DNA damage in human sperm is related to urinary levels of phthalate monoester and oxidative metabolites. Hum Reprod 22(3):688–695. 10.1093/humrep/del428.17090632
Hauser R, Gaskins AJ, Souter I, 2016. Urinary phthalate metabolite concentrations and reproductive outcomes among women undergoing in vitro fertilization: Results from the EARTH study. Environ Health Perspect 124(6):831–839. 10.1289/ehp.1509760.26545148
Hayashi F, Tamura H, Yamada J, 1994. Characteristics of the hepatocarcinogenesis caused by dehydroepiandrosterone, a peroxisome proliferator, in male F-344 rats. Carcinogenesis 15(10):2215-2219. 10.1093/carcin/15.10.2215.7955056
Hayashi F, Motoki Y, Tamura H, 1998. Induction of hepatic poly(ADP-ribose) polymerase by peroxisome proliferators, non-genotoxic hepatocarcinogens. Cancer Lett 127(1–2):1–7.9619851
Hayashi Y, Ito Y, Yanagiba Y, 2012. Differences in metabolite burden of di(2-ethylhexyl)phthalate in pregnant and postpartum dams and their offspring in relation to drug-metabolizing enzymes in mice. Arch Toxicol 86(4):563–569. 10.1007/s00204-011-0790-2.22159897
Haynes WM. 2014. Physical constants of organic compounds. Bis(2-ethylhexyl) phthalate. In: CRC handbook of chemistry and physics. 95th ed. Boca Raton, FL: CRC Press, 3–54.
He L, Fan S, Müller K, 2018. Comparative analysis biochar and compost-induced degradation of di-(2-ethylhexyl) phthalate in soils. Sci Total Environ 625:987–993. 10.1016/j.scitotenv.2018.01.002.29996465
He Y, Wang Q, He W, 2019. Phthalate esters (PAEs) in atmospheric particles around a large shallow natural lake (Lake Chaohu, China). Sci Total Environ 687:297–308. 10.1016/j.scitotenv.2019.06.034.31207519
Health Canada. 1998. Risk assessment on diisononyl phthalate in vinyl children’s products. Ottawa, ON: Health Canada.
Heggeseth BC, Holland N, Eskenazi B, 2019a. Heterogeneity in childhood body mass trajectories in relation to prenatal phthalate exposure. Environ Res 175:22–33. 10.1016/j.envres.2019.04.036.31102947
Heggeseth BC, Holland N, Eskenazi B, 2019b. Supplementary data: Heterogeneity in childhood body mass trajectories in relation to prenatal phthalate exposure. Environ Res 175. 10.1016/j.envres.2019.04.036.
Heindel JJ, Powell CJ. 1992. Phthalate ester effects on rat Sertoli cell function in vitro: Effects of phthalate side chain and age of animal. Toxicol Appl Pharmacol 115(1):116–123. 10.1016/0041-008x(92)90374-2.1321518
Hellwig J, Freudenberger H, Jäckh R. 1997. Differential prenatal toxicity of branched phthalate esters in rats. Food Chem Toxicol 35(5):501–512. 10.1016/s0278-6915(97)00008-2.9216749
Helmig D, Bauer A, Mueller J, 1990. Analysis of particulate organics in a forest atmosphere by thermodesorption GC/MS. Atmos Environ 24(1):179–184. 10.1016/0960-1686(90)90454-u.
Herr C, zur A Nieden, Koch HM, 2009. Urinary di(2-ethylhexyl)phthalate (DEHP)--metabolites and male human markers of reproductive function. Int J Hyg Environ Health 212(6):648–653. 10.1016/j.ijheh.2009.08.001.19733116
Hill SS, Shaw BR, Wu AH. 2001. The clinical effects of plasticizers, antioxidants, and other contaminants in medical polyvinylchloride tubing during respiratory and non-respiratory exposure. Clin Chim Acta 304:1–8.11165193
Hines EP, Calafat AM, Silva MJ, 2009a. Concentrations of phthalate metabolites in milk, urine, saliva, and serum of lactating North Carolina women. Environ Health Perspect 117(1):86–92. 10.1289/ehp.11610.19165392
Hines CJ, Nilsen Hopf, Deddens JA, 2009b. Urinary phthalate metabolite concentrations among workers in selected industries: a pilot biomonitoring study. Ann Occup Hyg 53(1):1–17. 10.1093/annhyg/men066.18948546
Hines C, Hopf N, Deddens J, 2011. Estimated daily intake of phthalates in occupationally exposed groups. J Expo Sci Environ Epidemiol 21(2):133–141. 10.1038/jes.2009.62.20010977
Hinton RH, Mitchell FE, Mann A, 1986. Effects of phthalic acid esters on the liver and thyroid. Environ Health Perspect 70:195–210.3830106
Hites RA. 1973. Analysis of trace organic compounds in New England rivers. J Chromatogr Sci 11(11):570–574.4760599
Hodgson JR. 1987. Results of peroxisome induction studies on tri(2-ethylhexyl)trimellitate and 2-ethylhexanol. Toxicol Ind Health 3(2):49–61. 10.1177/074823378700300205.3617069
Hodgson JR, Myhr BC, McKeon M, 1982. Evaluation of di-(2-ethylhexyl)phthalate and its major metabolites in the primary rat hepatocyte unscheduled DNA synthesis assay. Environ Mutagen 4(3):388.
Hoff RM, Chan KW. 1987. Measurement of polycyclic aromatic hydrocarbons in the air along the Niagara River. Environ Sci Technol 21:556–561.19994975
Holmes AK, Koller KR, Kieszak SM, 2014. Case-control study of breast cancer and exposure to synthetic environmental chemicals among Alaska Native women. Int J Circumpolar Health 73:25760.25442219
Hopf NB, Berthet A, Vernez D, 2014. Skin permeation and metabolism of di(2-ethylhexyl) phthalate (DEHP). Toxicol Lett 224(1):47–53. 10.1016/j.toxlet.2013.10.004.24140552
Hoppin JA, Ulmer R, London SJ. 2004. Phthalate exposure and pulmonary function. Environ Health Perspect 112(5):571–574.15064163
Hoppin JA, Jaramillo R, London SJ, 2013. Phthalate exposure and allergy in the U.S. population: Results from NHANES 2005–2006. Environ Health Perspect 121(10):1129–1134. 10.1289/ehp.1206211.23799650
Hou JW, Lin CL, Tsai YA, 2015a. The effects of phthalate and nonylphenol exposure on body size and secondary sexual characteristics during puberty. Int J Hyg Environ Health 218(7):603–615. 10.1016/j.ijheh.2015.06.004.26163779
Hou JW, Lin CL, Tsai YA, 2015b. Supplemental data: The effects of phthalate and nonylphenol exposure on body size and secondary sexual characteristics during puberty. Int J Hyg Environ Health 218.
Howard PH. 1989. Large production and priority pollutants. In: Handbook of environmental fate and exposure data of environmental chemicals. Vol. 1. Chelsea, MA: Lewis Publishers Inc., 279–285.
Howard PH, Meylan WM. 1997. Di(2-ethylhexyl)phthalate. In: Handbook of physical properties of organic chemicals. Boca Raton, FL: CRC Press, Inc., 226.
Howard PH, Banerjee S, Robillard KH. 1985. Measurement of water solubilities, octanol/water partition coefficients and vapor pressures of commercial phthalate esters. Environ Toxicol Chem 4:653–661.
Howarth JA, Price SC, Dobrota M, 2001. Effects on male rats of di-(2-ethylhexyl) phthalate and di-n-hexylphthalate administered alone or in combination. Toxicol Lett 121(1):35–43.11312035
Howdeshell KL, Furr J, Lambright CR, 2007. Cumulative effects of dibutyl phthalate and diethylhexyl phthalate on male rat reproductive tract development: Altered fetal steroid hormones and genes. Toxicol Sci 99(1):190–202. 10.1093/toxsci/kfm069.17400582
Howdeshell KL, Wilson VS, Furr J, 2008. A mixture of five phthalate esters inhibits fetal testicular testosterone production in the Sprague-Dawley rat in a cumulative, dose-additive manner. Toxicol Sci 105(1):153–165. 10.1093/toxsci/kfn077.18411233
Hoyer BB, Lenters V, Giwercman A, 2018. Impact of di-2-ethylhexyl phthalate metabolites on male reproductive function: A systematic review of human evidence. Current Environmental Health Reports 5(1):20–33. 10.1007/s40572-018-0174-3.29468520
Hsu NY, Lee CC, Wang JY, 2012. Predicted risk of childhood allergy, asthma and reported symptoms using measured phthalate exposure in dust and urine. Indoor Air 22(3):186–199. 10.1111/j.1600-0668.2011.00753.x.21995786
Hsu PC, Kuo YT, Leon Y Guo, 2016. The adverse effects of low-dose exposure to di(2-ethylhexyl) phthalate during adolescence on sperm function in adult rats. Environ Toxicol 31(6):706–712. 10.1002/tox.22083.25410017
Hsu JW, Yeh SC, Tsai FY, 2019. Fibroblast growth factor 21 secretion enhances glucose uptake in mono(2-ethylhexyl)phthalate-treated adipocytes. Toxicol in Vitro 59:246–254. 10.1016/j.tiv.2019.04.021.31009676
Hsu JW, Nien CY, Yeh SC, 2020. Phthalate exposure causes browning-like effects on adipocytes in vitro and in vivo. Food Chem Toxicol 142:111487. 10.1016/j.fct.2020.111487.32522588
Hu JMY, Arbuckle TE, Janssen P, 2020. Associations of prenatal urinary phthalate exposure with preterm birth: the Maternal-Infant Research on Environmental Chemicals (MIREC) Study. Can J Public Health 111(3):333–341. 10.17269/s41997-020-00322-5.32441020
Huang PC, Kuo PL, Guo YL, 2007. Associations between urinary phthalate monoesters and thyroid hormones in pregnant women. Hum Reprod 22(10):2715–2722. 10.1093/humrep/dem205.17704099
Huang PC, Tsai EM, Li WF, 2010. Association between phthalate exposure and glutathione S-transferase M1 polymorphism in adenomyosis, leiomyoma and endometriosis. Hum Reprod 25(4):986–994. 10.1093/humrep/deq015.20147336
Huang LP, Lee CC, Fan JP, 2014a. Urinary metabolites of di(2-ethylhexyl) phthalate relation to sperm motility, reactive oxygen species generation, and apoptosis in polyvinyl chloride workers. Int Arch Occup Environ Health 87(6):635–646. 10.1007/s00420-013-0905-6.23995610
Huang T, Saxena AR, Isganaitis E, 2014b. Gender and racial/ethnic differences in the associations of urinary phthalate metabolites with markers of diabetes risk: National Health and Nutrition Examination Survey 2001–2008. Environ Health 13(1):6. 10.1186/1476-069x-13-6.24499162
Huang HB, Chen HY, Su PH, 2015. Fetal and childhood exposure to phthalate diesters and cognitive function in children up to 12 years of age: Taiwanese maternal and infant cohort study. PLoS ONE 10(6):e0131910. 10.1371/journal.pone.0131910.26121592
Huang HB, Pan WH, Chang JW, 2017. Does exposure to phthalates influence thyroid function and growth hormone homeostasis? The Taiwan Environmental Survey for Toxicants (TEST) 2013. Environ Res 153:63–72. 10.1016/j.envres.2016.11.014.27907809
Huang HB, Kuo PL, Chang JW, 2018. Longitudinal assessment of prenatal phthalate exposure on serum and cord thyroid hormones homeostasis during pregnancy- Tainan birth cohort study (TBCS). Sci Total Environ 619–620:1058–1065.
Huang HB, Kuo PH, Su PH, 2019. Prenatal and childhood exposure to phthalate diesters and neurobehavioral development in a 15-year follow-up birth cohort study. Environ Res 172:569–577. 10.1016/j.envres.2019.02.029.30875510
Huang PC, Waits A, Chen HC, 2020a. Mediating role of oxidative/nitrosative stress biomarkers in the associations between phthalate exposure and thyroid function in Taiwanese adults. Environ Int 140:105751. 10.1016/j.envint.2020.105751.32353668
Huang PC, Chang WH, Wu MT, 2020b. Characterization of phthalate exposure in relation to serum thyroid and growth hormones, and estimated daily intake levels in children exposed to phthalate-tainted products: A longitudinal cohort study. Environ Pollut 264:114648. 10.1016/j.envpol.2020.114648.32380394
Huber W, Grasl-Kraupp B, Schulte-Hermann R. 1996. Hepatocarcinogenic potential of di(2-ethylhexyl)phthalate in rodents and its implications on human risk. Crit Rev Toxicol 26(4):365–481. 10.3109/10408449609048302.8817083
Hunt BG, Wang Y, Chen M, 2017. Maternal diethylhexyl phthalate exposure affects adiposity and insulin tolerance in offspring in a PCNA-dependent manner. Environ Res 159:588–594.28915506
Hutchins SR, Tomson MB, Ward CH. 1983. Trace organic contamination of ground water from a rapid infiltration site: A laboratory-field coordinated study. Environ Toxicol Chem 2(2):195–216.
Iannuzzi TJ, Huntley SL, Schmidt CW, 1997. Combined sewer overflows (CSOs) as sources of sediment contamination in the lower Passaic River, New Jersey. I. Priority pollutants and inorganic chemicals. Chemosphere 34(2):213–231.
IARC. 1982. Di(2-ethylhexyl)phthalate. IARC Monographs on the evaluation of the carcinogenic risk of chemicals to humans: Some industrial chemicals and dyestuffs. Lyon, France: International Agency for Research on Cancer. Vol. 29, 269–294.
IARC. 2012. Di(2-ethylhexyl)phthalate. IARC Monographs. Some chemicals present in industrial and consumer products, food and drinking-water. International Agency for Research on Cancer.
IARC. 2013. Di(2-ethylhexyl)phthalate. IARC Monographs on the Evaluation of Carcinogenic Risks to Humans. Volume 101: Some chemicals present in industrial and consumer products, food and drinking-water. Lyon, France: International Agency for Research on Cancer.
IARC. 2013. Di(2-ethylhexyl)phthalate. IARC Monographs on the evaluation of carcinogenic risks to humans. Volume 101: Some chemicals present in industrial and consumer products, food and drinking-water. Lyon, France: International Agency for Research on Cancer. 149–284. https://publications.iarc.fr/125. April 27, 2017.
IARC. 2017. Agents classified by the IARC Monographs, Volumes 1–118. Lyon, France: International Agency for Research on Cancer.
ICI Americas Inc. 1982. Bis(2-ethylhexyl)phthalate: A comparative subacute toxicity study in the rat and marmoset with cover letter dated 032283. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS215194. 878220040. TSCATS/020230.
Ikeda GJ, Sapienza PP, Couvillion JL, 1980. Comparative distribution, excretion and metabolism of di-(2-ethylhexyl) phthalate in rats, dogs and miniature pigs. Food Cosmet Toxicol 18(6):637–642. 10.1016/s0015-6264(80)80012-5.7203310
Inoue K, Kawaguchi M, Yamanaka R, 2005. Evaluation and analysis of exposure levels of di(2-ethylhexyl) phthalate from blood bags. Clin Chim Acta 358(1–2):159–166. 10.1016/j.cccn.2005.02.019.15893743
Ipapo KN, Factor-Litvak P, Whyatt RM, 2017. Maternal prenatal urinary phthalate metabolite concentrations and visual recognition memory among infants at 27 weeks. Environ Res 155:7–14. 10.1016/j.envres.2017.01.019.28171772
IRIS. 1988. Di(2-ethylhexyl)phthalate (DEHP); CASRN 117–81-7. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0014_summary.pdf. April 27, 2017.
Isenberg JS, Kamendulis LM, Smith JH, 2000. Effects of di-2-ethlhexyl phthalate (DEHP) on gap-junctional intercellular communication (GJIC), DNA synthesis, and peroxisomal beta oxidation (PBOX) in rat, mouse, and hamster liver. Toxicol Sci 56:73–85.10869455
Isenberg JS, Kamendulis L, Ackley D, 2001. Reversibility and persistence of di-2-ethylhexyl phthalate (DEHP)- and phenobarbital-induced hepatocellular changes in rodents. Toxicol Sci 64(2):192–199. 10.1093/toxsci/64.2.192.11719701
Ito Y, Yokota H, Wang R, 2005. Species differences in the metabolism of di(2-ethylhexyl) phthalate (DEHP) in several organs of mice, rats, and marmosets. Arch Toxicol 79(3):147–154. 10.1007/s00204-004-0615-7.15798888
Ito Y, Kamijima M, Hasegawa C, 2014. Species and inter-individual differences in metabolic capacity of di(2-ethylhexyl)phthalate (DEHP) between human and mouse livers. Environ Health Prev Med 19(2):117–125. 10.1007/s12199-013-0362-6.24078404
Ito Y, Kamijima M, Nakajima T. 2019. Di(2-ethylhexyl) phthalate-induced toxicity and peroxisome proliferator-activated receptor alpha: a review. Environ Health Prev Med 24(1):47. 10.1186/s12199-019-0802-z.31279339
Itoh H, Iwasaki M, Hanaoka T, 2009. Urinary phthalate monoesters and endometriosis in infertile Japanese women. Sci Total Environ 408(1):37–42. 10.1016/j.scitotenv.2009.09.012.19811803
Jaeger RJ, Rubin RJ. 1972. Migration of a phthalate ester plasticizer from polyvinyl chloride blood bags into stored human blood and its localization in human tissues. N Engl J Med 287:1114–1118.5082191
Jaimes R, McCullough D, Siegel B, 2019. Plasticizer interaction with the heart: Chemicals used in plastic medical devices can interfere with cardiac electrophysiology. Circ Arrhythm Electrophysiol 12(7):e007294. 10.1161/circep.119.007294.31248280
James-Todd T, Stahlhut R, Meeker JD, 2012. Urinary phthalate metabolite concentrations and diabetes among women in the National Health and Nutrition Examination Survey (NHANES) 2001–2008. Environ Health Perspect 120(9):1307–1313. 10.1289/ehp.1104717.22796563
James-Todd TM, Huang T, Seely EW, 2016a. The association between phthalates and metabolic syndrome: the National Health and Nutrition Examination Survey 2001–2010. Environ Health 15:52. 10.1186/s12940-016-0136-x.27079661
James-Todd TM, Meeker JD, Huang T, 2016b. Pregnancy urinary phthalate metabolite concentrations and gestational diabetes risk factors. Environ Int 96:118–126. 10.1016/j.envint.2016.09.009.27649471
James-Todd TM, Chiu YH, Messerlian C, 2018. Trimester-specific phthalate concentrations and glucose levels among women from a fertility clinic. Environ Health 17(1):55. 10.1186/s12940-018-0399-5.29898728
Jarfelt K, Dalgaard M, Hass U, 2005. Antiandrogenic effects in male rats perinatally exposed to a mixture of di(2-ethylhexyl) phthalate and di(2-ethylhexyl) adipate. Reprod Toxicol 19(4):505–515. 10.1016/j.reprotox.2004.11.005.15749265
Jensen TK, Frederiksen H, Kyhl HB, 2016. Prenatal exposure to phthalates and anogenital distance in male infants from a low-exposed Danish cohort (2010–2012). Environ Health Perspect 124(7):1107–1113. 10.1289/ehp.1509870.26672060
Joensen UN, Frederiksen H, Blomberg M Jensen, 2012. Phthalate excretion pattern and testicular function: a study of 881 healthy Danish men. Environ Health Perspect 120(10):1397–1403. 10.1289/ehp.1205113.22832070
Joensen UN, Jorgensen N, Meldgaard M, 2014. Associations of filaggrin gene loss-of-function variants with urinary phthalate metabolites and testicular function in young Danish Men. Environ Health Perspect 122(4):345–350. 10.1289/ehp.1306720.24380925
Jøhnk C, Høst A, Husby S, 2020. Maternal phthalate exposure and asthma, rhinitis and eczema in 552 children aged 5 years; a prospective cohort study. Environ Health 19(1):32. 10.1186/s12940-020-00586-x.32169083
Johns LE, Ferguson KK, Soldin OP, 2015. Urinary phthalate metabolites in relation to maternal serum thyroid and sex hormone levels during pregnancy: a longitudinal analysis. Reprod Biol Endocrinol 13:4. 10.1186/1477-7827-13-4.25596636
Johns LE, Ferguson KK, McElrath TF, 2016. Associations between repeated measures of maternal urinary phthalate metabolites and thyroid hormone parameters during pregnancy. Environ Health Perspect 124(11):1808–1815. 10.1289/ehp170.27152641
Johns LE, Ferguson KK, Cantonwine DE, 2017. Urinary BPA and phthalate metabolite concentrations and plasma vitamin D levels in pregnant women: A repeated measures analysis. Environ Health Perspect 125(8):087026. 10.1289/EHP1178.28934718
Johnson BT, Heitkamp MA, Jones JR. 1977. Dynamics of phthalic acid esters in aquatic organisms. Fate of pollutants in the air and water environments: Part 2. Chemical and biological fate of pollutants in the environment. New York, NY: John Wiley & Sons. 283–300
Johnson BT, Heitkamp MA, Jones JR. 1984. Environmental and chemical factors influencing the biodegradation of phthalic-acid esters in freshwater sediments. Environ Pollut 8(2):101–118. 10.1016/0143-148x(84)90021-1.
Jones HB, Garside DA, Liu R, 1993. The influence of phthalate esters on Leydig cell structure and function in vitro and in vivo. Exp Mol Pathol 58(3):179–193. 10.1006/exmp.1993.1016.8519345
Jones DL, Burklin CE, Seaman JC, 1996. Models to estimate volatile organic hazardous air pollutant emissions from municipal sewer systems. J Air Waste Manage Assoc 46:657–666.
Jones S, Boisvert A, Duong TB, 2014. Disruption of rat testis development following combined in utero exposure to the phytoestrogen genistein and antiandrogenic plasticizer di-(2-ethylhexyl) phthalate. Biol Reprod 91(3):64. 10.1095/biolreprod.114.120907.25031359
Jones S, Boisvert A, Francois S, 2015. In utero exposure to di-(2-ethylhexyl) phthalate induces testicular effects in neonatal rats that are antagonized by genistein cotreatment. Biol Reprod 93(4):92. 10.1095/biolreprod.115.129098.26316063
Jones S, Boisvert A, Naghi A, 2016. Stimulatory effects of combined endocrine disruptors on MA-10 Leydig cell steroid production and lipid homeostasis. Toxicology 355–356:21–30. 10.1016/j.tox.2016.05.008.
Jonsson BAG, Richthoff J, Rylander L, 2005. Urinary phthalate metabolites and biomarkers of reproductive function in young men. Epidemiology 16(4):487–493. 10.1097/01.ede.0000164555.19041.01.15951666
Juberg DR, Alfano K, Coughlin RJ, 2001. An observational study of object mouthing behavior by young children. Pediatrics 107:135–142.11134447
Jukic AM, Calafat AM, McConnaughey DR, 2016. Urinary concentrations of phthalate metabolites and bisphenol A and associations with follicular-phase length, luteal-phase length, fecundability, and early pregnancy loss. Environ Health Perspect 124(3):321–328. 10.1289/ehp.1408164.26161573
Jurewicz J, Radwan M, Sobala W, 2013. Human urinary phthalate metabolites level and main semen parameters, sperm chromatin structure, sperm aneuploidy and reproductive hormones. Reprod Toxicol 42:232–241. 10.1016/j.reprotox.2013.10.001.24140385
Just AC, Whyatt RM, RL Miller, 2012. Children’s urinary phthalate metabolites and fractional exhaled nitric oxide in an urban cohort. Am J Respir Crit Care Med 186(9):830–837. 10.1164/rccm.201203-0398OC.22923660
Kaestner F, Seiler F, Rapp D, 2020. Exposure of patients to di(2-ethylhexy)phthalate (DEHP) and its metabolite MEHP during extracorporeal membrane oxygenation (ECMO) therapy. PLoS ONE 15(1):e0224931. 10.1371/journal.pone.0224931.31999712
Kambia K, Dine T, Gressier B, 2001. High-performance liquid chromatographic method for the determination of di(2-ethylhexyl) phthalate in total parenteral nutrition and in plasma. J Chromatogr 755(1–2):297–303. 10.1016/s0378-4347(01)00125-6.
Kamijo Y, Hora K, Nakajima T, 2007. Peroxisome proliferator-activated receptor alpha protects against glomerulonephritis induced by long-term exposure to the plasticizer di-(2-ethylhexyl)phthalate. J Am Soc Nephrol 18(1):176–188. 10.1681/asn.2006060597.17135395
Kang Y, Park J, Youn K. 2019. Association between urinary phthalate metabolites and obesity in adult Korean population: Korean National Environmental Health Survey (KoNEHS), 2012–2014. Ann Occup Environ Med 31:e23. 10.35371/aoem.2019.31.e23.31620300
Kanki K, Nishikawa A, Masumura K, 2005. In vivo mutational analysis of liver DNA in gpt delta transgenic rats treated with the hepatocarcinogens N-nitrosopyrrolidine, 2-amino-3-methylimidazo[4,5-f]quinoline, and di(2-ethylhexyl)phthalate. Mol Carcinog 42(1):9–17. 10.1002/mc.20061.15486947
Kanode R, Chandra S, Sharma S. 2017. Application of bacterial reverse mutation assay for detection of non-genotoxic carcinogens. Toxicol Mech Methods 27(5):376–381. 10.1080/15376516.2017.1300616.28325086
Karabulut G, Barlas N. 2018. Genotoxic, histologic, immunohistochemical, morphometric and hormonal effects of di-(2-ethylhexyl)-phthalate (DEHP) on reproductive systems in pre-pubertal male rats. Toxicology Research 7(5):859–873. 10.1039/c8tx00045j.30310663
Kardas F, Bayram AK, Demirci E, 2016. Increased serum phthalates (MEHP, DEHP) and bisphenol A concentrations in children with autism spectrum disorder: The role of endocrine disruptors in autism etiopathogenesis. J Child Neurol 31(5):629–635. 10.1177/0883073815609150.26450281
Karle VA, Short BL, Martin GR, 1997. Extracorporeal membrane oxygenation exposes infants to the plasticizer, di(2-ethylhexyl)phthalate. Crit Care Med 25:696–703.9142038
Kato K, Silva MJ, Reidy JA, 2004. Mono(2-ethyl-5-hydroxyhexyl) phthalate and mono-(2-ethyl-5-oxohexyl) phthalate as biomarkers for human exposure assessment to di-(2-ethylhexyl) phthalate. Environ Health Perspect 112(3):327–330. 10.1289/ehp.6663.14998748
Kaun-Yu L, Tseng FW, Wu CJ, 2004. Suppression by phthalates of the calcium signaling of human nicotinic acetylcholine receptors in human neuroblastoma SH-SY5Y cells. Toxicology 200(2–3):113–121. 10.1016/j.tox.2004.03.018.15212808
Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficient of pesticides and other chemicals. Ecotoxicol Environ Saf 4:26–38.7379718
Kessler W, Numtip W, Grote K, 2004. Blood burden of di(2-ethylhexyl) phthalate and its primary metabolite mono(2-ethylhexyl) phthalate in pregnant and nonpregnant rats and marmosets. Toxicol Appl Pharmacol 195(2):142–153. 10.1016/j.taap.2003.11.014.14998681
Kessler W, Numtip W, Völkel W, 2012. Kinetics of di(2-ethylhexyl) phthalate (DEHP) and mono(2-ethylhexyl) phthalate in blood and of DEHP metabolites in urine of male volunteers after single ingestion of ring-deuterated DEHP. Toxicol Appl Pharmacol 264(2):284–291. 10.1016/j.taap.2012.08.009.22963843
Keys DA, Wallace DG, Kepler TB, 1999. Quantitative evaluation of alternative mechanisms of blood and testes disposition of di(2-ethylhexyl) phthalate and mono(2-ethylhexyl) phthalate in rats. Toxicol Sci 49(2):172–185.10416263
Khedr A. 2013. Optimized extraction method for LC-MS determination of bisphenol A, melamine and di(2-ethylhexyl) phthalate in selected soft drinks, syringes, and milk powder. J Chromatogr 930:98–103. 10.1016/j.jchromb.2013.04.040.
Kickham P, Otton SV, Moore MM, 2012. Relationship between biodegradation and sorption of phthalate esters and their metabolites in natural sediments. Environ Toxicol Chem 31(8):1730–1737. 10.1002/etc.1903.22648531
Kim JH, Hong YC. 2014. HSP70-hom gene polymorphisms modify the association of diethylhexyl phthalates with insulin resistance. Environ Mol Mutagen 55(9):727–734. 10.1002/em.21884.25044062
Kim SH, Park MJ. 2014. Phthalate exposure and childhood obesity. Ann Pediatr Endocrinol Metab 19(2):69–75. 10.6065/apem.2014.19.2.69.25077088
Kim Y, Ha EH, Kim EJ, 2011. Prenatal exposure to phthalates and infant development at 6 months: prospective Mothers and Children’s Environmental Health (MOCEH) study. Environ Health Perspect 119(10):1495–1500. 10.1289/ehp.1003178.21737372
Kim JH, Park HY, Bae S, 2013. Diethylhexyl phthalates is associated with insulin resistance via oxidative stress in the elderly: a panel study. PLoS ONE 8(8):e71392. 10.1371/journal.pone.0071392.23977034
Kim SH, Cho S, Ihm HJ, 2015. Possible role of phthalate in the pathogenesis of endometriosis: in vitro, animal, and human data. J Clin Endocrinol Metab 100(12):E1502–E1511. 10.1210/jc.2015-2478.26439087
Kim JH, Park H, Lee J, 2016a. Association of diethylhexyl phthalate with obesity-related markers and body mass change from birth to 3 months of age. J Epidemiol Community Health 70(5):466–472. 10.1136/jech-2015-206315.26834143
Kim KN, Choi YH, Lim YH, 2016b. Urinary phthalate metabolites and depression in an elderly population: National Health and Nutrition Examination Survey 2005–2012. Environ Res 145:61–67. 10.1016/j.envres.2015.11.021.26624239
Kim S, Kim S, Won S, 2017a. Considering common sources of exposure in association studies - Urinary benzophenone-3 and DEHP metabolites are associated with altered thyroid hormone balance in the NHANES 2007–2008. Environ Int 107:25–32. 10.1016/j.envint.2017.06.013.28651165
Kim S, Kim S, Won S, 2017b. Supplemental material: Considering common sources of exposure in association studies - Urinary benzophenone-3 and DEHP metabolites are associated with altered thyroid hormone balance in the NHANES 2007–2008. Environ Int 107. 10.1016/j.envint.2017.06.013.
Kim SH, On JW, Pyo H, 2018a. Percentage fractions of urinary di(2-ethylhexyl) phthalate metabolites: Association with obesity and insulin resistance in Korean girls. PLoS ONE 13(11):e0208081. 10.1371/journal.pone.0208081.30481198
Kim HS, Cheon YP, Lee SH. 2018b. Hershberger assays for di-2-ethylhexyl phthalate and its substitute candidates. Dev Reprod 22(1):19–27. 10.12717/dr.2018.22.1.019.29707681
Kim M, Jeong JS, Kim H, 2018c. Low dose exposure to di-2-ethylhexylphthalate in juvenile rats alters the expression of genes related with thyroid hormone regulation. Biomol Ther (Seoul) 26(5):512–519. 10.4062/biomolther.2018.076.30078309
Kim M, Jeong JS, Kim H, 2018d. Supplemental material: Low dose exposure to di-2-ethylhexylphthalate in juvenile rats alters the expression of genes related with thyroid hormone regulation. Biomol Ther (Seoul) 26. 10.4062/biomolther.2018.076.
Kim YM, Kim J, Cheong HK, 2018e. Exposure to phthalates aggravates pulmonary function and airway inflammation in asthmatic children. PLoS ONE 13(12):e0208553. 10.1371/journal.pone.0208553.30557318
Kim S, Eom S, Kim HJ, 2018f. Association between maternal exposure to major phthalates, heavy metals, and persistent organic pollutants, and the neurodevelopmental performances of their children at 1 to 2years of age- CHECK cohort study. Sci Total Environ 624:377–384. 10.1016/j.scitotenv.2017.12.058.29258038
Kim J, Cha S, Lee MY, 2018g. Chronic low-dose nonylphenol or di-(2-ethylhexyl) phthalate has a different estrogen-like response in mouse uterus. Dev Reprod 22(4):379–391. 10.12717/dr.2018.22.4.379.30680337
Kim S, Park GY, Yoo YJ, 2019a. Di-2-ethylhexylphthalate promotes thyroid cell proliferation and DNA damage through activating thyrotropin-receptor-mediated pathways in vitro and in vivo. Food Chem Toxicol 124:265–272. 10.1016/j.fct.2018.12.010.30543897
Kim J, Cha S, Lee MY, 2019b. Chronic and low dose exposure to nonlyphenol or di(2-ethylhexyl) phthalate alters cell proliferation and the localization of steroid hormone receptors in uterine endometria in mice. Dev Reprod 23(3):263–275. 10.12717/dr.2019.23.3.263.31660453
Kirby PE, Pizzarello RF, Lawlor TE, 1983. Evaluation of di-(2-ethylhexyl)phthalate and its major metabolites in the Ames test and L5178Y mouse lymphoma mutagenicity assay. Environ Mutagen 5(5):657–663. 10.1002/em.2860050504.6352251
Kitaoka M, Hirai S, Terayama H, 2013. Effects on the local immunity in the testis by exposure to di-(2-ethylhexyl) phthalate (DEHP) in mice. J Reprod Dev 59(5):485–490. 10.1262/jrd.2012-180.23892333
Klaunig JE, Babich MA, Baetcke KP, 2003. PPARalpha agonist-induced rodent tumors: Modes of action and human relevance. Crit Rev Toxicol 33(6):655–780. 10.1080/713608372.14727734
Kleinsasser NH, Harreus UA, Kastenbauer ER, 2004. Mono(2-ethylhexyl)phthalate exhibits genotoxic effects in human lymphocytes and mucosal cells of the upper aerodigestive tract in the comet assay. Toxicol Lett 148(1–2):83–90. 10.1016/j.toxlet.2003.12.013.15019091
Klimisch HJ, Hellwig J, Kauffmann W, 1991. Di-(2-ethylhexyl)phthalate (DEHP): Investigation of inhalation toxicity in rats after repeated exposure (28 d). Hum Exp Toxicol 10:68.
Klimisch HJ, Gamer AO, Hellwig J, 1992. Di-(2-ethylhexyl) phthalate: A short-term repeated inhalation toxicity study including fertility assessment. Food Chem Toxicol 30(11):915–919. 10.1016/0278-6915(92)90175-k.1473784
Klinefelter GR, Laskey JW, Winnik WM, 2012. Novel molecular targets associated with testicular dysgenesis induced by gestational exposure to diethylhexyl phthalate in the rat: a role for estradiol. Reproduction 144(6):747–761. 10.1530/rep-12-0266.23041508
Klopcic I, Kolsek K, Dolenc MS. 2015. Glucocorticoid-like activity of propylparaben, butylparaben, diethylhexyl phthalate and tetramethrin mixtures studied in the MDA-kb2 cell line. Toxicol Lett 232(2):376–383. 10.1016/j.toxlet.2014.11.019.25448277
Kluwe WM, Haseman JK, Douglas JF, 1982a. The carcinogenicity of dietary di(2-ethylhexyl) phthalate (DEHP) in Fischer 344 rats and B6C3F1 mice. J Toxicol Environ Health 10(4–5):797–815. 10.1080/15287398209530296.7161829
Kluwe WM, McConnell EE, Huff JE, 1982b. Carcinogenicity testing of phthalate esters and related compounds by the National Toxicology Program and the National Cancer Institute. Environ Health Perspect 45:129–133. 10.2307/3429396.7140685
Kluwe WM, Huff JE, Matthews HB, 1985. Comparative chronic toxicities and carcinogenic potentials of 2-ethylhexyl-containing compounds in rats and mice. Carcinogenesis 6(11):1577–1583. 10.1093/carcin/6.11.1577.4053278
Ko NY, Lo YC, Huang PC, 2019. Changes in insulin resistance mediate the associations between phthalate exposure and metabolic syndrome. Environ Res 175:434–441. 10.1016/j.envres.2019.04.022.31158561
Ko C, Benedict RT. 2020. Personal communication: Animal numbers used in Barakat 2017 "Prenatal exposure to DEHP induces premature reproductive senescence in male” Toxicol Sci 156(1):96–108. University of Illinois at Urbana-Champaign. Agency for Toxic Substances and Disease Registry. December 2020.
Kobayashi K, Miyagawa M, Wang RS, 2006. Effects of in utero and lactational exposure to di(2-ethylhexyl)phthalate on somatic and physical development in rat offspring. Ind Health 44(4):652–660.17085928
Kobrosly RW, Evans S, Miodovnik A, 2014. Prenatal phthalate exposures and neurobehavioral development scores in boys and girls at 6–10 years of age. Environ Health Perspect 122(5):521–528. 10.1289/ehp.1307063.24577876
Koch HM, Bolt HM, Angerer J. 2004. Di(2-ethylhexyl)phthalate (DEHP) metabolites in human urine and serum after a single oral dose of deuterium-labelled DEHP. Arch Toxicol 78(3):123–130. 10.1007/s00204-003-0522-3.14576974
Koch HM, Bolt HM, Preuss R, 2005a. New metabolites of di(2-ethylhexyl)phthalate (DEHP) in human urine and serum after single oral doses of deuterium-labelled DEHP. Arch Toxicol 79(7):367–376. 10.1007/s00204-004-0642-4.15700144
Koch HM, Bolt HM, Preuss R, 2005b. Intravenous exposure to di(2-ethylhexyl)phthalate (DEHP): metabolites of DEHP in urine after a voluntary platelet donation. Arch Toxicol 79(12):689–693. 10.1007/s00204-005-0004-x.16059725
Koch HM, Lorber M, Christensen KL Y, 2013. Identifying sources of phthalate exposure with human biomonitoring: Results of a 48h fasting study with urine collection and personal activity patterns. Int J Hyg Environ Health 216(6):672–681. 10.1016/j.ijheh.2012.12.002.23333758
Kolena B, Petrovicova I, Pilka T, 2014. Phthalate exposure and health-related outcomes in specific types of work environment. Int J Environ Res Public Health 11(6):5628–5639. 10.3390/ijerph110605628.24865398
Kolena B, Petrovicova I, Sidlovska M, 2020. Occupational hazards and risks associated with phthalates among Slovakian firefighters. Int J Environ Res Public Health 17(7) 10.3390/ijerph17072483.
Koo HJ, Lee BM. 2007. Toxicokinetic relationship between di(2-ethylhexyl) phthalate (DEHP) and mono(2-ethylhexyl) phthalate in rats. J Toxicol Environ Health 70(5):383–387. 10.1080/15287390600882150.
Kornbrust DJ, Barfknecht TR, Ingram P, 1984. Effect of di(2-ethylhexyl) phthalate on DNA repair and lipid peroxidation in rat hepatocytes and on metabolic cooperation in Chinese hamster V-79 cells. J Toxicol Environ Health 13(1):99–116. 10.1080/15287398409530484.6716514
Kozumbo WJ, Kroll R, Rubin RJ. 1982. Assessment of the mutagenicity of phthalate esters. Environ Health Perspect 45:103–109. 10.2307/3429391.6754359
Krais AM, Andersen C, Eriksson AC, 2018. Excretion of urinary metabolites of the phthalate esters DEP and DEHP in 16 volunteers after inhalation and dermal exposure. Int J Environ Res Public Health 15(11) 10.3390/ijerph15112514.
Krishnan K, Anderson ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Ku HY, Su PH, Wen HJ, 2015. Prenatal and postnatal exposure to phthalate esters and asthma: a 9-year follow-up study of a Taiwanese birth cohort. PLoS ONE 10(4):e0123309. 10.1371/journal.pone.0123309.25875379
Ku HY, Tsai TL, Wang PL, 2020. Prenatal and childhood phthalate exposure and attention deficit hyperactivity disorder traits in child temperament: A 12-year follow-up birth cohort study. Sci Total Environ 699:134053. 10.1016/j.scitotenv.2019.134053.31678884
Kuo FC, Su SW, Wu CF, 2015. Relationship of urinary phthalate metabolites with serum thyroid hormones in pregnant women and their newborns: a prospective birth cohort in Taiwan. PLoS ONE 10(6):e0123884. 10.1371/journal.pone.0123884.26042594
Kurahashi N, Kondo T, Omura M, 2005. The effects of subacute inhalation of di (2-ethylhexyl) phthalate (DEHP) on the testes of prepubertal Wistar rats. J Occup Health 47(5):437–444.16230838
Kurane R. 1986. Microbial degradation of phthalate esters. Microbiol Sci 3(3):92–95.3153148
Kurata Y, Kidachi F, Yokoyama M, 1998. Subchronic toxicity of di(2-ethylhexyl)phthalate in common marmosets: lack of hepatic peroxisome proliferation, testicular atrophy, or pancreatic acinar cell hyperplasia. Toxicol Sci 42(1):49–56. 10.1006/toxs.1997.2414.9538047
Kurata Y, Makinodan F, Shimamura N, 2012a. Metabolism of di (2-ethylhexyl) phthalate (DEHP): comparative study in juvenile and fetal marmosets and rats. J Toxicol Sci 37(1):33–49. 10.2131/jts.37.33.22293410
Kurata Y, Shimamura N, Katoh M. 2012b. Metabolite profiling and identification in human urine after single oral administration of DEHP. J Toxicol Sci 37(2):401–414.22467031
Kushman ME, Kraft AD, Guyton KZ, 2013. A systematic approach for identifying and presenting mechanistic evidence in human health assessments. Regul Toxicol Pharmacol 67(2):266–277. 10.1016/j.yrtph.2013.08.005.23959061
La Rocca C, Tait S, Guerranti C, 2014. Exposure to endocrine disrupters and nuclear receptor gene expression in infertile and fertile women from different Italian areas. Int J Environ Res Public Health 11(10):10146–10164. 10.3390/ijerph111010146.25268510
Lacey S, Alexander BM, Baxter CS. 2014. Plasticizer contamination of firefighter personal protective clothing--a potential factor in increased health risks in firefighters. J Occup Environ Hyg 11(5):D43–48. 10.1080/15459624.2013.877142.24467725
Lagos-Cabré R, Moreno RD. 2012. Contribution of environmental pollutants to male infertility: a working model of germ cell apoptosis induced by plasticizers. Biol Res 45(1):5–14. 10.1590/s0716-97602012000100001.22688978
Lake BG, Brantom PG, Gangolli SD, 1976. Studies on the effects of orally administered di-(2-ethylhexyl) phthalate in the ferret. Toxicology 6(3):341–356.996879
Lake BG, Gray TJ, Foster JR, 1984. Comparative studies on di-(2-ethylhexyl) phthalate-induced hepatic peroxisome proliferation in the rat and hamster. Toxicol Appl Pharmacol 72(1):46–60. 10.1016/0041-008x(84)90248-5.6710484
Lake B, Kozlen S, Evans J, 1987. Effect of prolonged administration of clofibric acid and di-(2-ethylhexyl)phthalate on hepatic enzyme activities and lipid peroxidation in the rat. Toxicology 44(2):213–228.3564055
Lamb J, Chapin R, Teague J, 1987. Reproductive effects of four phthalic acid esters in the mouse. Toxicol Appl Pharmacol 88(2):255–269. 10.1016/0041-008x(87)90011-1.3564043
Larranaga MD, Lewis RJ, Lewis RA. 2016. Di(2-ethylhexyl) phthalate. In: Hawley’s condensed chemical dictionary. 16th ed. Hoboken, NJ: John Wiley & Sons, Inc., 470–471.
Larsen ST, Hansen JS, Hansen EW, 2007. Airway inflammation and adjuvant effect after repeated airborne exposures to di-(2-ethylhexyl)phthalate and ovalbumin in BALB/c mice. Toxicology 235(1–2):119–129. 10.1016/j.tox.2007.03.010.17462807
Latini G. 2000. Potential hazards of exposure to di-(2-ethylhexyl)-phthalate in babies. Biol Neonate 78:269–276.11093005
Latini G, Avery GB. 1999. Materials degradation in endotracheal tubes: a potential contributor to bronchopulmonary dysplasia. Acta Paediatr 88(10):1174–1175. 10.1111/j.1651-2227.1999.tb01011.x.10565474
Laurenzana EM, Coslo DM, Vigilar MV, 2016. Activation of the constitutive androstane receptor by monophthalates. Chem Res Toxicol 29(10):1651–1661. 10.1021/acs.chemrestox.6b00186.27551952
Lay JO, Miller BJ. 1987. Plasticizers in pacifiers: Direct determination by FAB-MS. Anal Chem 59(22):1323–1325.
Le Hegarat L, Mourot A, Huet S, 2014. Performance of comet and micronucleus assays in metabolic competent HepaRG cells to predict in vivo genotoxicity. Toxicol Sci 138(2):300–309. 10.1093/toxsci/kfu004.24431211
Leboeuf RA, Kerckaert GA, Aardema MJ, 1996. The pH 6.7 Syrian hamster embryo cell transformation assay for assessing the carcinogenic potential of chemicals. Mutat Res 356(1):85–127. 10.1016/0027-5107(95)00199-9.8841476
Lee BM, Koo HJ. 2007. Hershberger assay for antiandrogenic effects of phthalates. J Toxicol Environ Health 70(15–16):1365–1370. 10.1080/15287390701432285.
Lee PC, Borysewicz R, Raab K, 1993. Development of lipolytic activity in gastric aspirates from premature infants. J Pediatr Gastroenterol Nutr 17:291–297.8271129
Lee S, Martinez-Arguelles DB, Campioli E, 2017. Fetal exposure to low levels of the plasticizer DEHP predisposes the adult male adrenal gland to endocrine disruption. Endocrinology 158(2):304–318. 10.1210/en.2016-1604.27849367
Lee KS, Lim YH, Kim KN, 2018. Urinary phthalate metabolites concentrations and symptoms of depression in an elderly population. Sci Total Environ 625:1191–1197. 10.1016/j.scitotenv.2017.12.219.29996415
Lee DG, Kim KM, Lee HS, 2019a. Peroxiredoxin 5 prevents diethylhexyl phthalate-induced neuronal cell death by inhibiting mitochondrial fission in mouse hippocampal HT-22 cells. Neurotoxicology 74:242–251. 10.1016/j.neuro.2019.08.003.31408635
Lee JW, Lee SJ, Gye MC, 2019b. Genotoxicity and glucose tolerance induction by acetyltriethylcitrate, substitute plasticizer compared to di(2-ethylhexyl)phthalate. Sci Rep 9(1):12237. 10.1038/s41598-019-48599-y.31439862
Lee YS, Lee S, Lim JE, 2019c. Occurrence and emission of phthalates and non-phthalate plasticizers in sludge from wastewater treatment plants in Korea. Sci Total Environ 692:354–360. 10.1016/j.scitotenv.2019.07.301.31351279
Lee DW, Lim YH, Shin CH, 2020. Prenatal exposure to di-(2-ethylhexyl) phthalate and decreased skeletal muscle mass in 6-year-old children: A prospective birth cohort study. Environ Res 182:109020. 10.1016/j.envres.2019.109020.31863942
Letinski DJ, Connelly MJ, Peterson DR, 2002. Slow-stir water solubility measurements of selected alcohols and diesters. Chemosphere 48(3):257–265.12146613
Leyder F, Boulanger P. 1983. Ultraviolet absorption, aqueous solubility, and octanol-water partition for several phthalates. Bull Environ Contam Toxicol 30:152–157.6839039
Lhuguenot JC, Mitchell AM, Elcombe CR. 1988. The metabolism of mono-(2-ethylhexyl) phthalate (MEHP) and liver peroxisome proliferation in the hamster. Toxicol Ind Health 4(4):431–441. 10.1177/074823378800400402.3188042
Lhuguenot JC, Mitchell AM, Milner G, 1985. The metabolism of di(2-ethylhexyl) phthalate (DEHP) and mono-(2-ethylhexyl) phthalate (MEHP) in rats: in vivo and in vitro dose and time dependency of metabolism. Toxicol Appl Pharmacol 80(1):11–22. 10.1016/0041-008x(85)90096-1.4024100
Li H, Kim KH. 2003. Effects of mono-(2-ethylhexyl) phthalate on fetal and neonatal rat testis organ cultures. Biol Reprod 69(6):1964–1972. 10.1095/biolreprod.103.018895.12904314
Li LH, Jester WF, Orth JM. 1998. Effects of relatively low levels of mono-(2-ethylhexyl) phthalate on cocultured Sertoli cells and gonocytes from neonatal rats. Toxicol Appl Pharmacol 153(2):258–265. 10.1006/taap.1998.8550.9878596
Li LH, Jester WF, Laslett AL, 2000. A single dose of di-(2-ethylhexyl) phthalate in neonatal rats alters gonocytes, reduces Sertoli cell proliferation, and decreases cyclin D2 expression. Toxicol Appl Pharmacol 166(3):222–229. 10.1006/taap.2000.8972.10906286
Li XW, Liang Y, Su Y, 2012a. Adverse effects of di-(2-ethylhexyl) phthalate on Leydig cell regeneration in the adult rat testis. Toxicol Lett 215(2):84–91. 10.1016/j.toxlet.2012.10.001.23064086
Li N, Liu T, Zhou L, 2012b. Di-(2-ethylhcxyl) phthalate reduces progesterone levels and induces apoptosis of ovarian granulosa cell in adult female ICR mice. Environ Toxicol Pharmacol 34(3):869–875. 10.1016/j.etap.2012.08.013.22986106
Li R, Yu C, Gao R, 2012c. Effects of DEHP on endometrial receptivity and embryo implantation in pregnant mice. J Hazard Mater 241–242:231–240. 10.1016/j.jhazmat.2012.09.038.
Li L, Zhang T, Qin XS, 2014. Exposure to diethylhexyl phthalate (DEHP) results in a heritable modification of imprint genes DNA methylation in mouse oocytes. Mol Biol Rep 41(3):1227–1235. 10.1007/s11033-013-2967-7.24390239
Li L, Liu JC, Lai FN, 2016. Di (2-ethylhexyl) phthalate exposure impairs growth of antral follicle in mice. PLoS ONE 11(2):e0148350. 10.1371/journal.pone.0148350.26845775
Li W, Zhang W, Chang M, 2018. Quadrupole orbitrap mass spectrometer-based metabonomic elucidation of influences of short-term di(2-ethylhexyl) phthalate exposure on cardiac metabolism in male mice. Chem Res Toxicol 31(11):1185–1194. 10.1021/acs.chemrestox.8b00184.30284816
Li MC, Mínguez-Alarcón L, Bellavia A, 2019a. Serum beta-carotene modifies the association between phthalate mixtures and insulin resistance: The National Health and Nutrition Examination Survey 2003–2006. Environ Res 178:108729. 10.1016/j.envres.2019.108729.31521963
Li MC, Mínguez-Alarcón L, Bellavia A, 2019b. Supplemental material: Serum beta-carotene modifies the association between phthalate mixtures and insulin resistance: The National Health and Nutrition Examination Survey 2003–2006. Environ Res 178. 10.1016/j.envres.2019.108729.
Li YL, Lv J, Du ZP, 2020. The levels of phthalate exposure and associations with obesity in an elderly population in China. Ecotoxicol Environ Saf 201:110749. 10.1016/j.ecoenv.2020.110749.32505048
Liang Y, Bi C, Wang X, 2019. A general mechanistic model for predicting the fate and transport of phthalates in indoor environments. Indoor Air 29(1):55–69. 10.1111/ina.12514.30339320
Lien YJ, Ku HY, Su PH, 2015. Prenatal exposure to phthalate esters and behavioral syndromes in children at 8 years of age: Taiwan Maternal and Infant Cohort Study. Environ Health Perspect 123(1):95–100. 10.1289/ehp.1307154.25280125
Ligocki MP, Leuenberger C, Pankow JF. 1985a. Trace organic compounds in rain-II. Gas scavenging of neutral organic compounds. Atmos Environ 19(10):1609–1617.
Ligocki MP, Leuenberger C, Pankow JF. 1985b. Trace organic compounds in rain-III. Particle scavenging of neutral organic compounds. Atmos Environ 19(10):1619–1626.
Lin H, Ge R, Chen G, 2008. Involvement of testicular growth factors in fetal Leydig cell aggregation after exposure to phthalate in utero. Proc Natl Acad Sci U S A 105(20):7218–7222. 10.1073/pnas.0709260105.18469139
Lin H, Lian Q, Hu G, 2009. In utero and lactational exposures to diethylhexyl-phthalate affect two populations of Leydig cells in male Long-Evans rats. Biol Reprod 80(5):882–888. 10.1095/biolreprod.108.072975.19144960
Lin Y, Wei J, Li Y, 2011. Developmental exposure to di(2-ethylhexyl) phthalate impairs endocrine pancreas and leads to long-term adverse effects on glucose homeostasis in the rat. Am J Physiol Endocrinol Metab 301(3):E527–538. 10.1152/ajpendo.00233.2011.21673306
Lin CY, Hsieh CJ, Lo SC, 2016. Positive association between concentration of phthalate metabolites in urine and microparticles in adolescents and young adults. Environ Int 92-93:157–164. 10.1016/j.envint.2016.04.006.
Lin LY, Tsai MS, Chen MH, 2018. Childhood exposure to phthalates and pulmonary function. Sci Total Environ 615:1282–1289. 10.1016/j.scitotenv.2017.08.318.29751433
Lin CY, Lee HL, Hwang YT, 2020. The association between urine di-(2-ethylhexyl) phthalate metabolites, global DNA methylation, and subclinical atherosclerosis in a young Taiwanese population. Environ Pollut 265(Pt B):114912. 10.1016/j.envpol.2020.114912.
Lioy PJ, Hauser R, Gennings C, 2015. Assessment of phthalates/phthalate alternatives in children’s toys and childcare articles: Review of the report including conclusions and recommendations of Chronic Hazard Advisory Panel of the Consumer Product Safety Commission. J Expo Sci Environ Epidemiol 25:343–353.25944701
Liss GM, Albro PW, Hartle RW, 1985. Urine phthalate determinations as an index of occupational exposure to phthalic anhydride and di(2-ethylhexyl)phthalate. Scand J Work Environ Health 11(5):381–387.4071004
Liu X, He D, Zhang D, 2008. Di(2-ethylhexyl) phthalate (DEHP) increases transforming growth factor-beta1 expression in fetal mouse genital tubercles. J Toxicol Environ Health 71(19):1289–1294. 10.1080/15287390802114915.
Liu L, Bao H, Liu F, 2012. Phthalates exposure of Chinese reproductive age couples and its effect on male semen quality, a primary study. Environ Int 42:78–83. 10.1016/j.envint.2011.04.005.21524797
Liu L, Wang H, Tian M, 2017. Phthalate metabolites related to infertile biomarkers and infertility in Chinese men. Environ Pollut 231(Pt 1):291-300. 10.1016/j.envpol.2017.08.018.
Liu T, Wang Y, Yang M, 2018a. Di-(2-ethylhexyl) phthalate induces precocious puberty in adolescent female rats. Iran J Basic Med Sci 21(8):848–855. 10.22038/ijbms.2018.28489.6905.30186573
Liu H, Guo Y, Yang T, 2018b. Intervention effect of gamma aminobutyric acid on anxiety behavior induced by phthalate (2-ethylhexyl ester) in rats. Int J Neurosci 128(10):928–934. 10.1080/00207454.2017.1405952.29191066
Liu C, Deng YL, Zheng TZ, 2020. Urinary biomarkers of phthalates exposure and risks of thyroid cancer and benign nodule. J Hazard Mater 383:121189. 10.1016/j.jhazmat.2019.121189.31541958
Ljungvall K, Tienpont B, David F, 2004. Kinetics of orally administered di(2-ethylhexyl) phthalate and its metabolite, mono(2-ethylhexyl) phthalate, in male pigs. Arch Toxicol 78(7):384–389. 10.1007/s00204-004-0558-z.15022035
Loff S, Kabs F, Witt J, 2000. Polyvinylchloride infusion lines expose infants to large amounts of toxic plasticizers. J Pediatr Surg 35(12):1775–1781.11101735
Lopes TJ, Furlong ET. 2001. Occurrence and potential adverse effects of semivolatile organic compounds in streambed sediment, United States, 1992–1995. Environ Toxicol Chem 20(4):727–737.11345447
Lopes TJ, Furlong ET, Pritt JW. 1997. Occurrence and distribution of semivolatile organic compounds in stream bed sediments, United States, 1992–95. In: Little EE, Greenberg BM, DeLonay AJ, eds. Environmental toxicology and risk assessment. Vol. 7. West Conshohocken, PA: American Society for Testing and Materials, 105–119. 10.1520/STP12158S.
Lopez-Carrillo L, Hernandez-Ramirez RU, Calafat AM, 2010. Exposure to phthalates and breast cancer risk in northern Mexico. Environ Health Perspect 118(4):539–544. 10.1289/ehp.0901091.20368132
Lorber M, Calafat AM. 2012. Dose reconstruction of di(2-ethylhexyl) phthalate using a simple pharmacokinetic model. Environ Health Perspect 120(12):1705–1710. 10.1289/ehp.1205182.23010619
Lorber M, Angerer J, Koch H. 2010. A simple pharmacokinetic model to characterize exposure of Americans to di-2-ethylhexyl phthalate. J Expo Sci Environ Epidemiol 20(1):38–53. 10.1038/jes.2008.74.19127283
Lovekamp-Swan T, Davis BJ. 2003. Mechanisms of phthalate ester toxicity in the female reproductive system. Environ Health Perspect 111(2):139–145.12573895
Lu Z, Zhang C, Han C, 2019. Plasticizer bis(2-ethylhexyl) phthalate causes meiosis defects and decreases fertilization ability of mouse oocytes in vivo. J Agric Food Chem 67(12):3459–3468. 10.1021/acs.jafc.9b00121.30813722
Lunderberg DM, Kristensen K, Liu Y, 2019. Characterizing airborne phthalate concentrations and dynamics in a normally occupied residence. Environ Sci Technol 53(13):7337–7346. 10.1021/acs.est.9b02123.31180211
Luo Q, Liu ZH, Yin H, 2018. Migration and potential risk of trace phthalates in bottled water: A global situation. Water Res 147:362–372. 10.1016/j.watres.2018.10.002.30326398
Lutz WK. 1986. Investigation of the potential for binding of di(2-ethylhexyl) phthalate (DEHP) to rat liver DNA in vivo. Environ Health Perspect 65:267–269.3709452
Ma M, Kondo T, Ban S, 2006. Exposure of prepubertal female rats to inhaled di(2-ethylhexyl)phthalate affects the onset of puberty and postpubertal reproductive functions. Toxicol Sci 93(1):164–171. 10.1093/toxsci/kfl036.16763069
Machtinger R, Gaskins AJ, Racowsky C, 2018. Urinary concentrations of biomarkers of phthalates and phthalate alternatives and IVF outcomes. Environ Int 111:23–31. 10.1016/j.envint.2017.11.011.29161633
Mackintosh CE, Maldonado J, Hongwu J, 2004. Distribution of phthalate esters in a marine aquatic food web: Comparison to polychlorinated biphenyls. Environ Sci Technol 38(7):2011–2020.15112801
Maloney EK, Waxman DJ. 1999. trans-Activation of PPARα and PPARγ by structurally diverse environmental chemicals. Toxicol Appl Pharmacol 161(2):209–218. 10.1006/taap.1999.8809.10581215
Mangala Priya V, Mayilvanan C, Akilavalli N, 2014. Lactational exposure of phthalate impairs insulin signaling in the cardiac muscle of F1 female albino rats. Cardiovasc Toxicol 14(1):10–20. 10.1007/s12012-013-9233-z.24297258
Mannsville Chemical Products Corporation. 1990. Chemical products synopsis: Dioctyl phthalate. Asbury Park, NY: Mannsville Chemical Products Corp.
Maranghi F, Lorenzetti S, Tassinari R, 2010. In utero exposure to di-(2-ethylhexyl) phthalate affects liver morphology and metabolism in post-natal CD-1 mice. Reprod Toxicol 29(4):427–432. 10.1016/j.reprotox.2010.03.002.20307648
Maresca MM, Hoepner LA, Hassoun A, 2016. Prenatal exposure to phthalates and childhood body size in an urban cohort. Environ Health Perspect 124(4):514–520. 10.1289/ehp.1408750.26069025
Marie C, Vendittelli F, Sauvant-Rochat MP. 2015. Obstetrical outcomes and biomarkers to assess exposure to phthalates: A review. Environ Int 83:116–136. 10.1016/j.envint.2015.06.003.26118330
Marotta V, Russo G, Gambardella C, 2019. Human exposure to bisphenol AF and diethylhexylphthalate increases susceptibility to develop differentiated thyroid cancer in patients with thyroid nodules. Chemosphere 218:885–894. 10.1016/j.chemosphere.2018.11.084.30609493
Marsman DS, Cattley RC, Conway JG, 1988. Relationship of hepatic peroxisome proliferation and replicative DNA synthesis to the hepatocarcinogenicity of the peroxisome proliferators di(2-ethylhexyl)phthalate and [4-chloro-6-(2,3-xylidino)-2-pyrimidinylthio]acetic acid (Wy-14,643) in rats. Cancer Res 48(23):6739–6744.3180084
Martínez MA, Rovira J, Sharma RP, 2017. Prenatal exposure estimation of BPA and DEHP using integrated external and internal dosimetry: A case study. Environ Res 158:566–575. 10.1016/j.envres.2017.07.016.28715785
Martínez MA, Rovira J, Prasad Sharma R, 2018. Comparing dietary and non-dietary source contribution of BPA and DEHP to prenatal exposure: A Catalonia (Spain) case study. Environ Res 166:25–34. 10.1016/j.envres.2018.05.008.29859370
Martínez MA, Rovira J, Sharma RP, 2020. Reconstruction of phthalate exposure and DINCH metabolites from biomonitoring data from the EXHES cohort of Tarragona, Spain: A case study on estimated vs reconstructed DEHP using the PBPK model. Environ Res 186:109534. 10.1016/j.envres.2020.109534.32361526
Martinez-Arguelles DB, Papadopoulos V. 2015. Mechanisms mediating environmental chemical-induced endocrine disruption in the adrenal gland. Front Endocrinol (Lausanne) 6:29. 10.3389/fendo.2015.00029.25788893
Martinez-Arguelles DB, Guichard T, Culty M, 2011. In utero exposure to the antiandrogen di-(2-ethylhexyl) phthalate decreases adrenal aldosterone production in the adult rat. Biol Reprod 85(1):51–61. 10.1095/biolreprod.110.089920.21389346
Martinez-Arguelles DB, Mcintosh M, Rohlicek CV, 2013. Maternal in utero exposure to the endocrine disruptor di-(2-ethylhexyl) phthalate affects the blood pressure of adult male offspring. Toxicol Appl Pharmacol 266(1):95–100. 10.1016/j.taap.2012.10.027.23142467
Martinez-Nava GA, Burguete-Garcia AI, Lopez-Carrillo L, 2013. PPARgamma and PPARGC1B polymorphisms modify the association between phthalate metabolites and breast cancer risk. Biomarkers 18(6):493–501. 10.3109/1354750x.2013.816776.23866026
Martino-Andrade AJ, Morais RN, Botelho GG K, 2009. Coadministration of active phthalates results in disruption of foetal testicular function in rats. Int J Androl 32(6):704–712. 10.1111/j.1365-2605.2008.00939.x.19207615
Martino-Andrade AJ, Liu F, Sathyanarayana S, 2016. Timing of prenatal phthalate exposure in relation to genital endpoints in male newborns. Andrology 4(4):585–593. 10.1111/andr.12180.27062102
Marx J. 1990. Animal carcinogen testing challenged. Science 250:743–745.2237420
Mauthe RJ, Gibson DP, Bunch RT, 2001. The Syrian hamster embryo (SHE) cell transformation assay: review of the methods and results. Toxicol Pathol 29 Suppl:138–146 11695550
McCombie G, Biedermann S, Suter G, 2017. Survey on plasticizers currently found in PVC toys on the Swiss market: Banned phthalates are only a minor concern. J Environ Sci Health A Environ Sci Eng Toxic Hazard 52(5):491–496. 10.1080/10934529.2016.1274176.
McFall JA, Antoine SR, DeLeon IR. 1985a. Organics in the water column of Lake Pontchartrain. Chemosphere 14:1253–1265.
McFall JA, Antoine SR, DeLeon IR. 1985b. Base-neutral extractable organic pollutants in biota and sediments from Lake Pontchartrain. Chemosphere 14:1561–1569.
McKee RH. 2000. The role of inhibition of gap junctional intercellular communication in rodent liver tumor induction by phthalates: review of data on selected phthalates and the potential relevance to man. Regul Toxicol Pharmacol 32(1):51–55. 10.1006/rtph.2000.1407.11029268
Meeker JD, Ferguson KK. 2011. Relationship between urinary phthalate and bisphenol A concentrations and serum thyroid measures in U.S. adults and adolescents from the National Health and Nutrition Examination Survey (NHANES) 2007–2008. Environ Health Perspect 119(10):1396–1402. 10.1289/ehp.1103582.21749963
Meeker JD, Calafat AM, Hauser R. 2007. Di(2-ethylhexyl) phthalate metabolites may alter thyroid hormone levels in men. Environ Health Perspect 115(7):1029–1034. 10.1289/ehp.9852.17637918
Meeker JD, Hu H, Cantonwine DE, 2009a. Urinary phthalate metabolites in relation to preterm birth in Mexico city. Environ Health Perspect 117(10):1587–1592. 10.1289/ehp.0800522.20019910
Meeker JD, Calafat AM, Hauser R. 2009b. Urinary metabolites of di(2-ethylhexyl) phthalate are associated with decreased steroid hormone levels in adult men. J Androl 30(3):287–297. 10.2164/jandrol.108.006403.19059903
Meeker JD, Ferguson KK. 2014. Urinary phthalate metabolites are associated with decreased serum testosterone in men, women, and children from NHANES 2011–2012. J Clin Endocrinol Metab 99(11):4346–4352. 10.1210/jc.2014-2555.25121464
Melnick RL. 2001. Is peroxisome proliferation an obligatory precursor step in the carcinogenicity of di(2-ethylhexyl) phthalate (DEHP)? Environ Health Perspect 109(5):437–442.11401753
Mendiola J, Jørgensen N, Andersson AM, 2011. Associations between urinary metabolites of di(2-ethylhexyl) phthalate and reproductive hormones in fertile men. Int J Androl 34(4 Pt. 1):369378. 10.1111/j.1365-2605.2010.01095.x.
Mendiola J, Meeker JD, Jørgensen N, 2012. Urinary concentrations of di(2-ethylhexyl) phthalate metabolites and serum reproductive hormones: Pooled analysis of fertile and infertile men. J Androl 33(3):488–198. 10.2164/jandrol.111.013557.21597090
Meng F, Yin X, Ma X, 2013. Assessment of the value of serum cholinesterase as a liver function test for cirrhotic patients. Biomed Rep 1:265–268. 10.3892/br.2013.60.24648933
Mérida-Ortega Á, Hernández-Alcaraz C, Hernández-Ramírez RU, 2016. Phthalate exposure, flavonoid consumption and breast cancer risk among Mexican women. Environ Int 96:167–172. 10.1016/j.envint.2016.08.023.27690147
Merkle J, Klimisch HJ, Jäckh R. 1988. Developmental toxicity in rats after inhalation exposure of di-2-ethylhexylphthalate (DEHP). Toxicol Lett 42(2):215–223. 10.1016/0378-4274(88)90080-x.3406961
Mes J, Coffin DE, Campbell DS. 1974. Di-n-butyl- and di-2-ethylhexyl phthalate in human adipose tissue. Bull Environ Contam Toxicol 12:721–725.4457184
Messerlian C, Souter I, Gaskins AJ, 2016a. Urinary phthalate metabolites and ovarian reserve among women seeking infertility care. Hum Reprod 31(1):75–83. 10.1093/humrep/dev292.26573529
Messerlian C, Wylie BJ, Minguez-Alarcon L, 2016b. Urinary concentrations of phthalate metabolites and pregnancy loss among women conceiving with medically assisted reproduction. Epidemiology 27(6):879–888. 10.1097/ede.0000000000000525.27299194
Messerlian C, Braun JM, Minguez-Alarcon L, 2017a. Paternal and maternal urinary phthalate metabolite concentrations and birth weight of singletons conceived by subfertile couples. Environ Int 107:55–64. 10.1016/j.envint.2017.06.015.28666241
Messerlian C, Mustieles V, Wylie BJ, 2017b. Ultrasound gel as an unrecognized source of exposure to phthalates and phenols among pregnant women undergoing routine scan. Int J Hyg Environ Health 220:1285–1294.28830670
Meylan WM, Howard PH. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26(12):2293–2299.
Miao H, Liu X, Li J, 2020. Associations of urinary phthalate metabolites with risk of papillary thyroid cancer. Chemosphere 241:125093. 10.1016/j.chemosphere.2019.125093.31629241
Mikalsen S- O, Holen I, Sanner T. 1990. Morphological transformation and catalase activity of Syrian hamster embryo cells treated with hepatic peroxisome proliferators, TPA and nickel sulphate. Cell Biol Toxicol 6(1):1–14.2334865
Minguez-Alarcon L, Williams PL, Chiu YH, 2018a. Secular trends in semen parameters among men attending a fertility center between 2000 and 2017: Identifying potential predictors. Environ Int 121(Pt 2):1297–1303. 10.1016/j.envint.2018.10.052.30389382
Minguez-Alarcon L, Williams PL, Chiu YH, 2018b. Supplementary data: Secular trends in semen parameters among men attending a fertility center between 2000 and 2017: Identifying potential predictors. Environ Int 121(Pt 2) 10.1016/j.envint.2018.10.052.
Miodovnik A, Engel SM, Zhu C, 2011. Endocrine disruptors and childhood social impairment. Neurotoxicology 32(2):261–267. 10.1016/j.neuro.2010.12.009.21182865
Miodovnik A, Edwards A, Bellinger DC, 2014. Developmental neurotoxicity of ortho-phthalate diesters: review of human and experimental evidence. Neurotoxicology 41:112–122. 10.1016/j.neuro.2014.01.007.24486776
Mitchell FE, Price SC, Hinton RH, 1985. Time and dose-response study of the effects on rats of the plasticizer di(2-ethylhexyl) phthalate. Toxicol Appl Pharmacol 81(3 Pt. 1):371–392.2867621
Mittermeier A, Volkel W, Fromme H. 2016. Kinetics of the phthalate metabolites mono-2-ethylhexyl phthalate (MEHP) and mono-n-butyl phthalate (MnBP) in male subjects after a single oral dose. Toxicol Lett 252:22–28. 10.1016/j.toxlet.2016.04.009.27091076
Morelli-Cardoso MH W, Lachter ER, Tabak D, 1999. Determination of the specific migration of DEHP into food stimulants using high performance liquid chromatography. J High Resolut Chromatogr 22(1):70–72.
Morgan M, Deoraj A, Felty Q, 2017. Environmental estrogen-like endocrine disrupting chemicals and breast cancer. Mol Cell Endocrinol 457:89–102. 10.1016/j.mce.2016.10.003.27717745
Morgenstern R, Whyatt RM, Insel BJ, 2017. Phthalates and thyroid function in preschool age children: Sex specific associations. Environ Int 106:11–18. 10.1016/j.envint.2017.05.007.28554096
Morrissey RE, CLJ, Schwetz BA, 1988. Association of sperm, vaginal cytology, and reproductive organ weight data with results of continuous breeding reproduction studies in swiss (CD-1) mice. Fundam Appl Toxicol 11(2):359–371.3220213
Moser VC, Cheek BM, Macphail RC. 1995. A multidisciplinary approach to toxicological screening: III. Neurobehavioral toxicity. J Toxicol Environ Health 45(2):173–210. 10.1080/15287399509531988.7783252
Moser VC, Macphail RC, Gennings C. 2003. Neurobehavioral evaluations of mixtures of trichloroethylene, heptachlor, and di(2-ethylhexyl)phthalate in a full-factorial design. Toxicology 188(2–3):125–137. 10.1016/s0300-483x(03)00083-0.12767685
Moss EJ, Cook MW, Thomas LV, 1988. The effect of mono-(2-ethylhexyl) phthalate and other phthalate esters on lactate production by Sertoli cells in vitro. Toxicol Lett 40(1):77–84. 10.1016/0378-4274(88)90185-3.3341051
Mu D, Gao F, Fan Z, 2015a. Levels of phthalate metabolites in urine of pregnant women and risk of clinical pregnancy loss. Environ Sci Technol 49(17):10651–10657. 10.1021/acs.est.5b02617.26251123
Mu X, Liao X, Chen X, 2015b. DEHP exposure impairs mouse oocyte cyst breakdown and primordial follicle assembly through estrogen receptor-dependent and independent mechanisms. J Hazard Mater 298:232–240. 10.1016/j.jhazmat.2015.05.052.26073378
Muhlenkamp CR, Gill SS. 1998. A glucose-regulated protein, GRP58, is down-regulated in C57B6 mouse liver after diethylhexyl phthalate exposure. Toxicol Appl Pharmacol 148(1):101–108. 10.1006/taap.1997.8323.9465269
Murphy CJ, Stermer AR, Richburg JH. 2014. Age- and species-dependent infiltration of macrophages into the testis of rats and mice exposed to mono-(2-Ethylhexyl) phthalate (MEHP). Biol Reprod 91(1):18. 10.1095/biolreprod.113.115527.24876407
Murray HE, Ray LE, Giam CS. 1981. Analysis of marine sediment, water and biota for selected organic pollutants. Chemosphere 10:1327–1334.
Mustieles V, Minguez-Alarcon L, Christou G, 2019. Placental weight in relation to maternal and paternal preconception and prenatal urinary phthalate metabolite concentrations among subfertile couples. Environ Res 169:272–279. 10.1016/j.envres.2018.11.022.30497002
Myers BA. 1992a. A subchronic (4-week) dietary oral toxicity study of di(2-ethylhexyl)phthalate in B6C3F1 mice (final report) with attachments and cover letter dated 040392. Eastman Kodak Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535432. EPA 86–920000874.
Myers BA. 1992b. Subchronic (13-week) dietary oral toxicity study of di(2-ethylhexyl)phthalate in Fischer 344 rats (final report) w-attachments and letter dated 040392 (missing pages 304 to 386). Eastman Kodak Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535433. 86–920000875.
Nair N, Kurup CK R. 1986. Investigations on the mechanism of the hypocholesterolemic action of diethylhexyl phthalate in rats. Biochem Pharmacol 35(20):3441–3447.3768033
Nair N, Kurup CK. 1987a. Effect of administration of diethylhexyl phthalate on the function and turnover of rat hepatic mitochondria. Biochim Biophys Acta 925(3):332–340. 10.1016/0304-4165(87)90199-1.3040113
Nair N, Kurup CK R. 1987b. Increase in hepatic ubiquinone on administration of diethylhexyl phthalate to the rat. J Biosci 11(1–4):391–397.
Nakamura Y, Yagi Y, Tomita I, 1979. Teratogenicity of di-(2-ethylhexyl)phthalate in mice. Toxicol Lett 4(2):113–117. 10.1016/0378-4274(79)90084-5.
Nardelli TC, Albert O, Lalancette C, 2017. In utero and lactational exposure study in rats to identify replacements for di(2-ethylhexyl) phthalate. Sci Rep 7(1):3862. 10.1038/s41598-017-03979-0.28634325
Narotsky MG, Kavlock RJ. 1995. A multidisciplinary approach to toxicological screening: II. Developmental toxicity. J Toxicol Environ Health 45(2):145–171. 10.1080/15287399509531987.7783251
NAS. 2008. Phthalates and cumulative risk assessment. The tasks ahead. National Academy of Sciences. http://dels.nas.edu/dels/rpt_briefs/phthalates_final.pdf. June 19, 2018.
NAS. 2017. NAS systematic review: Application of systematic review methods in overall strategy for evaluating low-dose toxicity from endocrine active chemicals. Washington, DC: National Academy of Sciences. http://nap.edu/24758. June 05, 2018.
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences. National Research Council. 15–35.
Nasu M, Goto M, Oshima Y, 2001. Study on endocrine disrupting chemicals in wastewater treatment plants. Water Sci Technol 43(2):101–208.
Ng KM E, Chu I, Bronaugh RL, 1992. Percutaneous absorption and metabolism of pyrene, benzo[a]pyrene, and di(2-ethylhexyl) phthalate: comparison of in vitro and in vivo results in the hairless guinea pig. Toxicol Appl Pharmacol 115(2):216–223. 10.1016/0041-008x(92)90326-n.1641855
Niino T, Ishibashi T, Itho T, 2001. Monoester formation by hydrolysis of dialkyl phthalate migrating from polyvinyl chloride products in human saliva. J Health Sci 47(3):318–322.
NIOSH. 2001. Di-sec octyl phthalate. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health.
NIOSH. 2016. Di-sec octyl phthalate. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health.
NIOSH. 2019. Di-sec octyl phthalate. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0236.html. August 26, 2020.
NOES. 1990. National occupational exposure survey. Cincinnati, OH: National Institute of Occupational Safety and Health.
Noriega NC, Howdeshell KL, Furr J, 2009. Pubertal administration of DEHP delays puberty, suppresses testosterone production, and inhibits reproductive tract development in male Sprague-Dawley and Long-Evans rats. Toxicol Sci 111(1):163–178. 10.1093/toxsci/kfp129.19528224
NPS. 2016. Screening for contaminants of emerging concern in waters of the northern Colorado plateau network. 2015 Surface water data. National Park Service. NPS 960/133371, June 2016.
NTP. 1982. Carcinogenesis bioassay of di(2-ethylhexyl)phthalate (CAS No. 117–81-7) in F344 rats and B6C3F1 mice (feed studies). Research Triangle Park, NC: National Toxicology Program. NTP-TR-217. NTP-80–37. NIH Publication No. 82–1773.
NTP. 1984. Diethylhexyl phthalate (DEHP). Reproduction and fertility assessment in CD-1 mice when administered in the feed. Research Triangle Park, NC: National Toxicology Program. PB84181734.
NTP. 1988. Reproduction and fertility evaluation of diethylhexyl phthalate (CAS no 117–81-7) in CD-1 mice exposed during gestation. NTP 88. Jefferson, AK: U.S. National Toxicology Program. PB88204300. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB88204300.xhtml. April 15, 2020.
NTP. 1989. Fifth annual report on carcinogens: Summary 1989. Research Triangle Park, NC: National Toxicology Program.
NTP. 2000. NTP-CERHR expert panel report on di(2-ethylhexyl)phthalate. National Toxicology Program. NTP-CERHR-DEHP-00. http://cerhr.niehs.nih.gov/news/index.html. May 11, 2000.
NTP. 2005. Diethylhexylphthalate: Multigenerational reproductive assessment by continuous breeding when administered to Sprague-Dawley rats in the diet. Research Triangle Park, NC: National Toxicology Program. PB2005107575. TRC Study No 7244–200. NTP-RACB-98–004.
NTP. 2006. NTP-CERHR monograph on the potential human reproductive and developmental effects of di(2-ethylhexyl) phthalate (DEHP). National Toxicology Program. NIH Publication No. 06–4476.
NTP. 2016. Di(2-ethylhexyl) phthalate. In: Report on carcinogens. 14th ed. Research Triangle Park, NC: National Toxicology Program, https://ntp.niehs.nih.gov/ntp/roc/content/profiles/diethylhexylphthalate.pdf. August 27, 2020.
NYDEC. 2014. Water quality monitoring data for pesticides on Long Island, NY. New York State Department of Environmental Conservation.
Nyssen GA, Miller EC, Glass TF, 1987. Solubilities of hydrophobic compounds in aqueous-organic solvent mixtures. Environ Monit Assess 9:1–11.24254096
Oberly T, Bewsey B, Probst G. 1985. Tests for the induction of forward mutation at the thymidine kinase locus of L5178Y mouse lymphoma cells in culture. Prog Mutat Res 5:569–582.
O’Connor GA. 1996. Organic compounds in sludge-amended soils and their potential for uptake by crop plants. Sci Total Environ 185(1–3):71–81. 10.1016/0048-9697(95)05043-4.8643961
O’Connor OA, Rivera MD, Young LY. 1989. Toxicity and biodegradation of phthalic acid esters under methanogenic conditions. Environ Toxicol Chem 8(7):569–576.
O’Grady DP, Howard PH, Werner AF. 1985. Activated sludge biodegradation of 12 commercial phthalate esters. Appl Environ Microbiol 49(2):443–445.16346734
Oie L, Hersoug LG, Madsen JO. 1997. Residential exposure to plasticizers and its possible role in the pathogenesis of asthma. Environ Health Perspect 105(9):972–978.9374082
Oishi S. 1989. Effects of co-administration of di(2-ethylhexyl)phthalate and testosterone on several parameters in the testis and pharmacokinetics of its mono-de-esterified metabolite. Arch Toxicol 63(4):289–295.2764717
Oishi S. 1990. Effects of phthalic acid esters on testicular mitochondrial functions in the rat. Arch Toxicol 64(2):143–147.2350233
Okai Y, Higashi-Okai K. 2000. Enhancing effect of a plastic plasticizer, di-2-ethylhexyl phthalate on umu C gene expression in Salmonella typhimurium (TA 1535/pSK 1002). J UOEH 22(4):305–315.11132519
Olesen TS, Bleses D, Andersen HR, 2018a. Prenatal phthalate exposure and language development in toddlers from the Odense Child Cohort. Neurotoxicol Teratol 65:34–41. 10.1016/j.ntt.2017.11.004.29198963
Olesen TS, Bleses D, Andersen HR, 2018b. Supplementary data: Prenatal phthalate exposure and language development in toddlers from the Odense Child Cohort. Neurotoxicol Teratol 65. 10.1016/j.ntt.2017.11.004.
OSHA. 1994. Method 104. Dimethyl Phthalate (DMP), diethyl phthalate (DEP), dibutyl phthalate (DBP), di-2-ethylhexyl phthalate (DEHP), di-n-octyl phthalate (DNOP). Sampling and analytical methods. Occupational Safety and Health Administration.
OSHA. 2019a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1. October 25, 2019.
OSHA. 2019b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000. October 25, 2019.
OSHA. 2019c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55 Appendix A. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55AppA. October 25, 2019.
Otake T, Yoshinaga J, Yanagisawa Y. 2001. Analysis of organic esters of plasticizer in indoor air by GC-MS and GC-FPD. Environ Sci Technol 2001(35):3099–3102.
Oudir M, Chader H, Bouzid B, 2018. Male rat exposure to low dose of di(2-ethylhexyl) phthalate during pre-pubertal, pubertal and post-pubertal periods: Impact on sperm count, gonad histology and testosterone secretion. Reprod Toxicol 75:33–39. 10.1016/j.reprotox.2017.11.004.29158199
Ozaki H, Sugihara K, Watanabe Y, 2017. Comparative study of hydrolytic metabolism of dimethyl phthalate, dibutyl phthalate and di(2-ethylhexyl) phthalate by microsomes of various rat tissues. Food Chem Toxicol 100:217–224. 10.1016/j.fct.2016.12.019.28007454
Pan G, Hanaoka T, Yoshimura M, 2006. Decreased serum free testosterone in workers exposed to high levels of di-n-butyl phthalate (DBP) and di-2-ethylhexyl phthalate (DEHP), a cross-sectional study in China. Environ Health Perspect 114(11):1643–1648. 10.1289/ehp.9016.17107847
Pan Y, Jing J, Dong F, 2015. Association between phthalate metabolites and biomarkers of reproductive function in 1066 Chinese men of reproductive age. J Hazard Mater 300:729–736. 10.1016/j.jhazmat.2015.08.011.26296076
Pant K, Sly J, Bruce S, 2010. Syrian Hamster Embryo (SHE) cell transformation assay with and without X-ray irradiation of feeder cells using di(2-ethylhexyl)phthalate (DEHP) and N-nitroso-N-methylnitroguanidine (MNNG). Mutat Res 698(1–2):6–10. 10.1016/j.mrgentox.2010.02.017.20226874
Park SY, Choi J. 2007. Cytotoxicity, genotoxicity and ecotoxicity assay using human cell and environmental species for the screening of the risk from pollutant exposure. Environ Int 33(6):817–822. 10.1016/j.envint.2007.03.014.17499852
Park HY, Kim JH, Lim YH, 2013. Influence of genetic polymorphisms on the association between phthalate exposure and pulmonary function in the elderly. Environ Res 122:18–24. 10.1016/j.envres.2012.11.004.23261794
Park S, Kim BN, Cho SC, 2014. Association between urine phthalate levels and poor attentional performance in children with attention-deficit hyperactivity disorder with evidence of dopamine gene-phthalate interaction. Int J Environ Res Public Health 11(7):6743–6756. 10.3390/ijerph110706743.24978879
Park C, Choi W, Hwang M, 2017. Associations between urinary phthalate metabolites and bisphenol A levels, and serum thyroid hormones among the Korean adult population - Korean National Environmental Health Survey (KoNEHS) 2012–2014. Sci Total Environ 584–585:950–957. 10.1016/j.scitotenv.2017.01.144.
Parks LG, Ostby JS, Lambright CR, 2000. The plasticizer diethylhexyl phthalate induces malformations by decreasing fetal testosterone synthesis during sexual differentiation in the male rat. Toxicol Sci 58:339–349.11099646
Parmar D, Srivastava SP, Srivastava SP, 1985. Hepatic mixed function oxidases and cytochrome P-450 contents in rat pups exposed to di-(2-ethylhexyl)phthalate through mother’s milk. Drug Metab Dispos 13(3):368–370.2861998
Parmar D, Srivastava SP, Singh GB, 1987. Effect of testosterone on the testicular atrophy caused by di(2-ethylhexyl)phthalate (DEHP). Toxicol Lett 36(3):297–308. 10.1016/0378-4274(87)90199-8.2884757
Parmar D, Srivastava SP, Seth PK. 1988. Effect of di(2-ethylhexyl)phthalate (DEHP) on hepatic mixed function oxidases in different animal species. Toxicol Lett 40(3):209–217.3354005
Parmar D, Srivastava SP, Seth PK. 1994. Age related effects of di(2-ethylhexyl)phthalate on hepatic cytochrome P450 monooxygenases in Wistar rats. Pharmacol Toxicol 75:177–180.7800660
Parmar D, Srivastava SP, Singh GB, 1995. Testicular toxicity of di(2-ethylhexyl)phthalate in developing rats. Vet Hum Toxicol 37(4):310–313.8540215
Parra-Forero LY, Veloz-Contreras A, Vargas-Marín S, 2019. Alterations in oocytes and early zygotes following oral exposure to di(2-ethylhexyl) phthalate in young adult female mice. Reprod Toxicol 90:53–61. 10.1016/j.reprotox.2019.08.012.31442482
Parry JM, Arni P, Brooks TM, 1985. Summary report on the performance of the yeast and Aspergillus assays. Prog Mutat Res 5:25–46.
Parsanathan R, Maria Joseph A, Karundevi B. 2019. Postnatal exposure to di-(2-ethylhexyl)phthalate alters cardiac insulin signaling molecules and GLUT4(Ser488) phosphorylation in male rat offspring. J Cell Biochem 120(4):5802–5812. 10.1002/jcb.27866.30362281
Peck J, Sweeney A, Symanski E, 2010. Intra- and inter-individual variability of urinary phthalate metabolite concentrations in Hmong women of reproductive age. J Expo Sci Environ Epidemiol 20(1):90–100. 10.1038/jes.2009.4.19223940
Pegg D. 1982. Disposition of di-2-ethylhexyl phthalate following inhalation and peroral exposure in rats. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA86910000683. OTS0530339.
Percy Z, Xu Y, Sucharew H, 2016. Gestational exposure to phthalates and gender-related play behaviors in 8-year-old children: An observational study. Environ Health 15:87. 10.1186/s12940-016-0171-7.27527835
Perera MIR, Katyal SL, Shinozuka H. 1986. Suppression of choline-deficient diet-induced hepatocyte membrane lipid peroxidation in rats by the peroxisome proliferators 4-chloro-6-(2,3-xylidino)-2-pyrimidinylthio(N-beta-hydroxyethyl)acetamide and di(2-ethylhexyl)phthalate. Cancer Res 46:3304–3308.3708564
Pérez PA, Toledo J, Sosa LDV, 2020. The phthalate DEHP modulates the estrogen receptors α and β increasing lactotroph cell population in female pituitary glands. Chemosphere 258:127304. 10.1016/j.chemosphere.2020.127304.32559490
Perng W, Watkins DJ, Cantoral A, 2017. Exposure to phthalates is associated with lipid profile in peripubertal Mexican youth. Environ Res 154:311–317. 10.1016/j.envres.2017.01.033.28152472
Perng W, Kasper NM, Watkins DJ, 2020. Exposure to endocrine-disrupting chemicals during pregnancy is associated with weight change through 1 year postpartum among women in the early-life exposure in Mexico to Environmental Toxicants Project. J Womens Health 29(11):1419–1426. 10.1089/jwh.2019.8078.
Peters JM, Cheung C, Gonzalez FJ. 2005. Peroxisome proliferator-activated receptor-a and liver cancer: where do we stand? J Mol Med 83:774–785. 10.1007/s00109-005-0678-9.15976920
Petersen JH, Breindahl T. 2000. Plasticizers in total diet samples, baby food and infant formulae. Food Addit Contam 17(2):133–141.10793844
Philippat C, Bennett DH, Krakowiak P, 2015. Phthalate concentrations in house dust in relation to autism spectrum disorder and developmental delay in the CHildhood Autism Risks from Genetics and the Environment (CHARGE) study. Environ Health 14:56. 10.1186/s12940-015-0024-9.26108271
Phillips BJ, James TE, Gangolli SD. 1982. Genotoxicity studies of di(2-ethylhexyl)phthalate and its metabolites in CHO cells. Mutat Res 102(3):297–304. 10.1016/0165-1218(82)90139-2.6890626
Phillips B, Anderson D, Gangolli SD. 1986. Studies on the genetic effects of phthalic acid esters on cells in culture. Environ Health Perspect 65:263–266. 10.2307/3430192.3709451
Piepenbrink M, Hussain I, Marsh J, 2005. Developmental immunotoxicology of di-(2-Ethylhexyl)phthalate (DEHP): Age-based assessment in the female rat. J Immunotoxicol 2(1):21–31. 10.1080/15363750490429435.18958656
Plichta V, Volkel W, Fembacher L, 2019. Bioavailability of phthalate and DINCH(R) plasticizers, after oral administration of dust to piglets. Toxicol Lett 314:82–88. 10.1016/j.toxlet.2019.07.018.31306742
Plonait SL, Nau H, Maier RF, 1993. Exposure of newborn infants to di-(2-ethylhexyl)-phthalate and 2-ethylhexanoic acid following exchange transfusion with polyvinylchloride catheters. Transfusion 33:598–605.8333024
Plumb RH. 1987. A comparison of ground water monitoring data from CERCLA and RCRA sites. Ground Water Monit Rev 7:94–100.
Pocar P, Fiandanese N, Secchi C, 2012. Exposure to di(2-ethyl-hexyl) phthalate (DEHP) in utero and during lactation causes long-term pituitary-gonadal axis disruption in male and female mouse offspring. Endocrinology 153(2):937–948. 10.1210/en.2011-1450.22147016
Pocar P, Fiandanese N, Berrini A, 2017. Maternal exposure to di(2-ethylhexyl)phthalate (DEHP) promotes the transgenerational inheritance of adult-onset reproductive dysfunctions through the female germline in mice. Toxicol Appl Pharmacol 322:113–121. 10.1016/j.taap.2017.03.008.28286118
Podlecka D, Gromadzińska J, Mikołajewska K, 2020. Longitudinal effect of phthalates exposure on allergic diseases in children. Ann Allergy Asthma Immunol 125(1):84–89. 10.1016/j.anai.2020.03.022.32244034
Pogribny I, Tryndyak V, Boureiko A, 2008. Mechanisms of peroxisome proliferator-induced DNA hypomethylation in rat liver. Mutat Res 644(1–2):17–23. 10.1016/j.mrfmmm.2008.06.009.18639561
Polanska K, Ligocka D, Sobala W, 2014. Phthalate exposure and child development: the Polish Mother and Child Cohort Study. Early Hum Dev 90(9):477–485. 10.1016/j.earlhumdev.2014.06.006.25038557
Pollack GM, Li RCK, Ermer JC, 1985a. Effects of route of administration and repetitive dosing on the disposition kinetics of di(2-ethylhexyl) phthalate and its mono-de-esterified metabolite in rats. Toxicol Appl Pharmacol 79:246–256.4002226
Pollack GM, Buchanan JF, Slaughter RL, 1985b. Circulating concentrations of di(2-ethylhexyl) phthalate and its de-esterified phthalic acid products following plasticizer exposure in patients receiving hemodialysis. Toxicol Appl Pharmacol 79(2):257–267. 10.1016/0041-008x(85)90347-3.4002227
Pollack AZ, Buck Louis GM, Chen Z, 2015. Bisphenol A, benzophenone-type ultraviolet filters, and phthalates in relation to uterine leiomyoma. Environ Res 137:101–107. 10.1016/j.envres.2014.06.028.25531814
Poon R, Lecavalier P, Mueller R, 1997. Subchronic oral toxicity of di-n-octyl phthalate and di(2-ethylhexyl) phthalate in the rat. Food Chem Toxicol 35(2):225–239. 10.1016/s0278-6915(96)00064-6.9146736
Poulin P, Theil FP. 2002. Prediction of pharmacokinetics prior to in vivo studies. 1. Mechanism-based prediction of volume of distribution. J Pharm Sci 91(1):129–156.11782904
Pradeep S, Josh MK, Binod P, 2015. Achromobacter denitrificans strain SP1 efficiently remediates di(2-ethylhexyl)phthalate. Ecotoxicol Environ Saf 112:114–121. 10.1016/j.ecoenv.2014.10.035.25463861
Preston MR, Al-Omran LA. 1989. Phthalate ester speciation in estuarine water, suspended particulates and sediments. Environ Pollut 62(2–3):183–193. 10.1016/0269-7491(89)90186-3.15092344
Price SC, Ochieng W, Weaver R, 1987. Studies on the mechanisms of changes produced in the liver, thyroid, pancreas, and kidney by hypolipidemic drugs and di(2-ethylhexyl)phthalate. In: Reid E, Cook GM, Luziio JP, eds. Cells membranes, and disease, including renal. New York, NY: Plenum Press, 67–78.
Price SC, Chescoe D, Grasso P, 1988. Alterations in the thyroids of rats treated for long periods with di-(2-ethylhexyl) phthalate or with hypolipidaemic agents. Toxicol Lett 40(1):37–46. 10.1016/0378-4274(88)90181-6.3341048
Priston RAJ, Dean BJ. 1985. Tests for the induction of chromosome aberrations, polyploidy and sister-chromatid exchanges in rat liver (RL4) cells. Prog Mutat Res 5:387–395.
Probst GS, Hill LE. 1985. Tests for the induction of DNA-repair synthesis in primary cultures of adult rat hepatocytes. Prog Mutat Res 5:381–386.
Pugh G, Isenberg J, Kamendulis L, 2000. Effects of di-isononyl phthalate, di-2-ethylhexyl phthalate, and clofibrate in cynomolgus monkeys. Toxicol Sci 56(1):181–188. 10.1093/toxsci/56.1.181.10869467
Putman DL, Moore WA, Schechtman LM, 1983. Cytogenic evaluation of di-(2-ethylhexyl)phthalate and its major metabolites in Fischer 344 rats. Environ Mutagen 5:227–231.6861726
Qi W, Zhou L, Zhao T, 2019. Effect of the TYK-2/STAT-3 pathway on lipid accumulation induced by mono-2-ethylhexyl phthalate. Mol Cell Endocrinol 484:52–58. 10.1016/j.mce.2019.01.012.30660700
Qian X, Li J, Xu S, 2019a. Prenatal exposure to phthalates and neurocognitive development in children at two years of age. Environ Int 131:105023. 10.1016/j.envint.2019.105023.31351385
Qian X, Li J, Xu S, 2019b. Supplementary data: Prenatal exposure to phthalates and neurocognitive development in children at two years of age. Environ Int 131. 10.1016/j.envint.2019.105023.
Quinnies KM, Doyle TJ, Kim KH, 2015. Transgenerational effects of di-(2-ethylhexyl) phthalate (DEHP) on stress hormones and behavior. Endocrinology 156(9):3077–3083. 10.1210/en.2015-1326.26168342
Quintana-Belmares RO, Krais AM, Esfahani BK, 2018. Phthalate esters on urban airborne particles: Levels in PM(10) and PM(2.5) from Mexico City and theoretical assessment of lung exposure. Environ Res 161:439–445. 10.1016/j.envres.2017.11.039.29216490
Rajagopal G, Bhaskaran RS, Karundevi B. 2019a. Maternal di-(2-ethylhexyl) phthalate exposure alters hepatic insulin signal transduction and glucoregulatory events in rat F(1) male offspring. J Appl Toxicol 39(5):751–763. 10.1002/jat.3764.30565266
Rajagopal G, Bhaskaran RS, Karundevi B. 2019b. Developmental exposure to DEHP alters hepatic glucose uptake and transcriptional regulation of GLUT2 in rat male offspring. Toxicology 413:56–64. 10.1016/j.tox.2018.12.004.30597186
Rajesh P, Balasubramanian K. 2014. Phthalate exposure in utero causes epigenetic changes and impairs insulin signalling. J Endocrinol 223(1):47–66. 10.1530/JOE-14-0111.25232145
Rajesh P, Sathish S, Srinivasan C, 2013. Phthalate is associated with insulin resistance in adipose tissue of male rat: Role of antioxidant vitamins (C & E). J Cell Biochem 114(3):558–569. 10.1002/jcb.24399.22991202
Ran D, Luo Y, Gan Z, 2019. Neural mechanisms underlying the deficit of learning and memory by exposure to di(2-ethylhexyl) phthalate in rats. Ecotoxicol Environ Saf 174:58–65. 10.1016/j.ecoenv.2019.02.043.30822668
Rao MS, Usuda N, Subbarao V, 1987. Absence of gamma-glutamyl transpeptidase activity in neoplastic lesions induced in the liver of male F-344 rats by di-(2-ethylhexyl)phthalate, a peroxisome proliferator. Carcinogenesis 8(9):1347–1350. 10.1093/carcin/8.9.1347.2887302
Rao MS, Yeldandi AV, Subbarao V. 1990. Quantitative analysis of hepatocellular lesions induced by di(2-ethylhexyl)phthalate in F-344 rats. J Toxicol Environ Health 30(2):85–89. 10.1080/15287399009531413.2355402
Rattan S, Brehm E, Gao L, 2017. Prenatal exposure to di(2-ethylhexyl) phthalate disrupts ovarian function in a transgenerational manner in female mice. Biol Reprod 98(1):130–145. 10.1093/biolre/iox154.
Rattan S, Brehm E, Gao L, 2018. Di(2-ethylhexyl) phthalate exposure during prenatal development causes adverse transgenerational effects on female fertility in mice. Toxicol Sci 163(2):420–429. 10.1093/toxsci/kfy042.29471507
Rattan S, Beers HK, Kannan A, 2019. Prenatal and ancestral exposure to di(2-ethylhexyl) phthalate alters gene expression and DNA methylation in mouse ovaries. Toxicol Appl Pharmacol 379:114629. 10.1016/j.taap.2019.114629.31211961
Ray LE, Murray HE, Giam CS. 1983. Organic pollutants in marine samples from Portland, Maine. Chemosphere 12(7–8):7–8.
Reddy JK, Moody DE, Azarnoff DL, 1976. Di-(2-ethylhexyl)phthalate: an industrial plasticizer induces hypolipidemia and enhances hepatic catalase and carnitine acetyltransferase activities in rat and mice. Life Sci 18(9):941–945. 10.1016/0024-3205(76)90412-4.1271963
Reddy B, Rozati R, Reddy BV, 2006. Association of phthalate esters with endometriosis in Indian women. BJOG 113(5):515–520. 10.1111/j.1471-0528.2006.00925.x.16637895
Reeves KW, Diaz Santana M, Manson JE, 2019. Urinary phthalate biomarker concentrations and postmenopausal breast cancer risk. J Natl Cancer Inst 111(10):1059–1067. 10.1093/jnci/djz002.30629220
RePORTER. 2021. Di(2-ethylhexyl)phthalate (DEHP). National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. March 16, 2021.
Rhodes C, Orton TC, Pratt IS, 1986. Comparative pharmacokinetics and subacute toxicity of di(2-ethylhexyl) phthalate (DEHP) in rats and marmosets: extrapolation of effects in rodents to man. Environ Health Perspect 65:299–307.3086078
Ritsema R, Cofino WP, Frintrop P CM, 1989. Trace-level analysis of phthalate esters in surface water and suspended particulate matter by means of capillary gas chromatography with electron-capture and mass-selective detection. Chemosphere 18(11–12):11–12.
Ritter EJ, Scott WJ, Randall JL, 1987. Teratogenicity of di(2-ethylhexyl) phthalate, 2-ethylhexanol 2-ethylhexanoic acid, and valproic acid, and potentiation by caffeine. Teratology 35(1):41–46. 10.1002/tera.1420350107.3105103
Roberts RA, Ganey PE, Ju C, 2007. Role of the Kupffer cell in mediating hepatic toxicity and carcinogenesis. Toxicol Sci 96(1):2–15.17122412
Robledo CA, Peck JD, Stoner J, 2015. Urinary phthalate metabolite concentrations and blood glucose levels during pregnancy. Int J Hyg Environ Health 218(3):324–330. 10.1016/j.ijheh.2015.01.005.25726127
Rock G, Secours VE, Franklin CA, 1978. The accumulation of mono-2-ethylhexylphthalate (MEHP) during storage of whole blood and plasma. Transfusion 18(5):553–558.705860
Romani F, Tropea A, Scarinci E, 2014. Endocrine disruptors and human reproductive failure: The invitro effect of phthalates on human luteal cells. Fertil Steril 102(3):831–837. 10.1016/j.fertnstert.2014.05.041.25016925
Roth B, Herkenrath P, Lehmann HJ, 1988. Di-(2-ethylhexyl)-phthalate as plasticizer in PVC respiratory tubing systems: indications of hazardous effects on pulmonary function in mechanically ventilated, preterm infants. Eur J Pediatr 147(1):41–46. 10.1007/bf00442609.3422189
Rowland IR. 1974. Metabolism of di-(2-ethylhexyl) phthalate by the contents of the alimentary tract of the rat. Food Cosmet Toxicol 12(3):293–303. 10.1016/0015-6264(74)90001-7.4442812
Rowland IR, Cottrell RC, Phillips JC. 1977. Hydrolysis of phthalate esters by the gastro-intestinal contents of the rat. Food Chem Toxicol 15(1):17–21. 10.1016/s0015-6264(77)80257-5.
Roy WR. 1994. Groundwater contamination from municipal landfills in the USA. In: Adriano DC, Iskandar AK, Murarka IP, eds. Contamination of groundwaters. Northwood, England: Science Reviews, 411–446.
RTECS. 2013. Phthalic acid, bis(2-ethylhexyl) ester. Registry of Toxic Effects on Chemical Substances. National Institute of Occupational Safety and Health. MDL Information Systems, Inc.
Ruddick JA, Villeneuve DC, Chu I, 1981. An assessment of the teratogenicity in the rat and mutagenicity in Salmonella of mono-2-ethylhexyl phthalate. Bull Environ Contam Toxicol 27(2):181–186. 10.1007/bf01611005.7296047
Rudel RA, Brody JG, Spengler JD, 2001. Identification of selected hormonally active agents and animal mammary carcinogens in commercial and residential air and dust samples. J Air Waste Manage Assoc 51:499–513.
Rushbrook CJ, Jorgenson TA, Hodgson JR. 1982. Dominant lethal study of di(2-ethylhexyl)phthalate and its major metabolites in ICR/SIM mice. Environ Mutagen 4:387.
Russell DJ, McDuffie B. 1983. Analysis for phthalate esters in environmental samples: Separation from polychlorinated biphenyls and pesticides using dual column liquid chromatography. Int J Environ Anal Chem 15(3):165–184.
Rusyn I, Corton JC. 2012. Mechanistic considerations for human relevance of cancer hazard of di(2-ethylhexyl) phthalate. Mutat Res 750(2):141–158. 10.1016/j.mrrev.2011.12.004.22198209
Rusyn I, Peters JM, Cunningham ML. 2006. Modes of action and species-specific effects of di-(2-ethylhexyl)phthalate in the liver. Crit Rev Toxicol 36(5):459–479. 10.1080/10408440600779065.16954067
Sadakane K, Ichinose T, Takano H, 2014. Effects of oral administration of di-(2-ethylhexyl) and diisononyl phthalates on atopic dermatitis in NC/Nga mice. Immunopharmacol Immunotoxicol 36(1):61–69. 10.3109/08923973.2013.866678.24328677
Saillenfait AM, Sabaté JP, Robert A, 2013. Dose-dependent alterations in gene expression and testosterone production in fetal rat testis after exposure to di-n-hexyl phthalate. J Appl Toxicol 33(9):1027–1035. 10.1002/jat.2896.23754470
Sanchez JH, Abernethy DJ, Boreiko CJ. 1987. Lack of di-(2-ethyhhexyl) phthalate activity in the C3H/10T1/2 cell transformation system. Toxicol in Vitro 1(1):49–53.20702379
Sanner T, Rivedal E. 1985. Tests with the Syrian hamster embryo (SHE) cell transformation assay. Prog Mutat Res 5:665–671.
Sarath MK Josh, Pradeep S, Vijayalekshmy KS Amma, 2016. Human ketosteroid receptors interact with hazardous phthalate plasticizers and their metabolites: an in silico study. J Appl Toxicol 36(6):836–843. 10.1002/jat.3221.26304264
Sasaki T, Yoshikawa K, Harada H, 2003. No immunotoxic effect on T cells with di (2-ethylhexyl) phthalate in male C57BL/6 mice. Environ Health Prev Med 8(2):59–63. 10.1007/bf02897928.21432090
Satake S, Nakamura C, Minamide Y, 2010. Effect of a large dose of di (2-ethylhexyl) phthalate (DEHP) on hepatic peroxisome in cynomolgus monkeys (Macaca fascicularis). J Toxicol Pathol 23(2):75–83. 10.1293/tox.23.75.22272015
Sathyanarayana S, Barrett E, Butts S, 2014. Phthalate exposure and reproductive hormone concentrations in pregnancy. Reproduction 147(4):401–409. 10.1530/rep-13-0415.24196015
Sathyanarayana S, Grady R, Barrett ES, 2016a. First trimester phthalate exposure and male newborn genital anomalies. Environ Res 151:777–782. 10.1016/j.envres.2016.07.043.27567446
Sathyanarayana S, Barrett E, Nguyen R, 2016b. First trimester phthalate exposure and infant birth weight in the infant development and environment study. Int J Environ Res Public Health 13(10):945. 10.3390/ijerph13100945.27669283
Sathyanarayana S, Butts S, Wang C, 2017. Early prenatal phthalate exposure, sex steroid hormones, and birth outcomes. J Clin Endocrinol Metab 102(6):1870–1878. 10.1210/jc.2016-3837.28324030
Sato T, Nagase H, Sato K, 1994. Enhancement of the mutagenicity of amino acid pyrolysates by phthalate esters. Environ Mol Mutagen 24:325–331.7851345
SCENIHR. 2016. Opinion on the safety of medical devices containing DEHP-plasticized PVC or other plasticizers on neonates and other groups possibly at risk (2015 update). Revision February 2016. Scientific Committee on Emerging and Newly-Identified Health Risks. European Commission. http://ec.europa.eu/health/scientific_committees/policy/index_en.htm. June 18, 2018.
Schaedlich K, Gebauer S, Hunger L, 2018. DEHP deregulates adipokine levels and impairs fatty acid storage in human SGBS-adipocytes. Sci Rep 8(1):3447. 10.1038/s41598-018-21800-4.29472605
Schecter A, Lorber M, Guo Y, 2013. Phthalate concentrations and dietary exposure from food purchased in New York State. Environ Health Perspect 121(4):473–494. 10.1289/ehp.1206367.23461894
Schilling K, Deckardt K, Gembardt C, 1999. Support: Di-2-ethylhexyl phthalate -two-generation reproduction toxicity range-finding study in Wistar rats - continuous dietary administration, with cover letter dated 09/16/1999. Eastman Chemical Co. Submitted under TSCA Section 8E. OTS0530371–6. 89990000316.
Schilling K, Deckardt K, Gembardt C, 2001. Support: Di-2-ethylhexyl phthalate -two-generation reproduction toxicity study in Wistar rats continuous dietary administration, with cover letter dated 04/2/2001. Eastman Chemical Co. Submitted under TSCA Section 8E. OTS0574025–1. 89010000147.
Schmezer P, Pool BL, Klein RG, 1988. Various short-term assays and two long-term studies with the plasticizer di(2-ethylhexyl)phthalate in the Syrian golden hamster. Carcinogenesis 9(1):37–43. 10.1093/carcin/9.1.37.3335045
Schmid P, Schlatter C. 1985. Excretion and metabolism of di(2-ethylhexyl)-phthalate in man. Xenobiotica 15(3):251–256.4024660
Schmidt JS, Schaedlich K, Fiandanese N, 2012. Effects of di(2-ethylhexyl) phthalate (DEHP) on female fertility and adipogenesis in C3H/N mice. Environ Health Perspect 120(8):1123–1129. 10.1289/ehp.1104016.22588786
Schwope AD, Reid RC. 1988. Migration to dry foods. Food Addit Contam 5(Suppl 1):445–454.
Scott RC, Dugard PH, Ramsey JD, 1987. In vitro absorption of some o-phthalate diesters through human and rat skin. Environ Health Perspect 74:223–227. 10.2307/3430452.3691429
Seed JL. 1982. Mutagenic activity of phthalate esters in bacterial liquid suspension assays. Environ Health Perspect 45:111–114.6754360
Serrano SE, Braun J, Trasande L, 2014. Phthalates and diet: a review of the food monitoring and epidemiology data. Environ Health 13(1):43. 10.1186/1476-069X-13-43.24894065
Shaffer CB, Carpenter CP, Smyth HF. 1945. Acute and subacute toxicity of di(2-ethylhexyl)phthalate with note upon its metabolism. J Ind Hyg Toxicol 27:130–135.
Shao P, Wang Y, Zhang M, 2019. The interference of DEHP in precocious puberty of females mediated by the hypothalamic IGF-1/PI3K/Akt/mTOR signaling pathway. Ecotoxicol Environ Saf 181:362–369. 10.1016/j.ecoenv.2019.06.017.31212184
Shapiro GD, Dodds L, Arbuckle TE, 2015. Exposure to phthalates, bisphenol A and metals in pregnancy and the association with impaired glucose tolerance and gestational diabetes mellitus: The MIREC study. Environ Int 83:63–71. 10.1016/j.envint.2015.05.016.26101084
Sharma R, Lake BG, Gibson GG. 1988. Co-induction of microsomal cytochrome P-452 and the peroxisomal fatty acid β-oxidation pathway in the rat by clofibrate and di-(2-ethylhexyl) phthalate. Biochem Pharmacol 37(7):1203–1206. 10.1016/0006-2952(88)90771-x.3355594
Sharma RK, Lake BG, Makowski R, 1989. Differential induction of peroxisomal and microsomal fatty-acid-oxidising enzymes by peroxisome proliferators in rat liver and kidney. Characterisation of a renal cytochrome P-450 and implications for peroxisome proliferation. Eur J Biochem 184(1):69–78. 10.1111/j.1432-1033.1989.tb14991.x.2776771
Sharma RP, Schuhmacher M, Kumar V. 2018. Development of a human physiologically based pharmacokinetic (PBPK) model for phthalate (DEHP) and its metabolites: A bottom up modeling approach. Toxicol Lett 296:152–162. 10.1016/j.toxlet.2018.06.1217.29958929
She Y, Jiang L, Zheng L, 2017. The role of oxidative stress in DNA damage in pancreatic β cells induced by di-(2-ethylhexyl) phthalate. Chem Biol Interact 265:8–15. 10.1016/j.cbi.2017.01.015.28115068
Sheikh IA, Turki RF, Abuzenadah AM, 2016. Endocrine disruption: Computational perspectives on human sex hormone-binding globulin and phthalate plasticizers. PLoS ONE 11(3):e0151444. 10.1371/journal.pone.0151444.26963243
Sheldon LS, Hites RA. 1979. Sources and movement of organic chemicals in the Delaware River. Environ Sci Technol 13(5):574–579.
Shen R, Zhao LL, Yu Z, 2017. Maternal di-(2-ethylhexyl) phthalate exposure during pregnancy causes fetal growth restriction in a stage-specific but gender-independent manner. Reprod Toxicol 67:117–124. 10.1016/j.reprotox.2016.12.003.27956250
Shen L, Tang X, Wei Y, 2018. Vitamin E and vitamin C attenuate di-(2-ethylhexyl) phthalate-induced blood-testis barrier disruption by p38 MAPK in immature SD rats. Reprod Toxicol 81:17–27. 10.1016/j.reprotox.2018.06.015.29940330
Shin M, Ohnishi M, Iguchi S, 1999. Peroxisome-proliferator regulates key enzymes of the tryptophan-NAD+ pathway. Toxicol Appl Pharmacol 158(1):71–80. 10.1006/taap.1999.8683.10387934
Shinohara N, Uchino K. 2020. Diethylhexyl phthalate (DEHP) emission to indoor air and transfer to house dust from a PVC sheet. Sci Total Environ 711:134573. 10.1016/j.scitotenv.2019.134573.32000312
Shinohara N, Mizukoshi A, Uchiyama M, 2019. Emission characteristics of diethylhexyl phthalate (DEHP) from building materials determined using a passive flux sampler and micro-chamber. PLoS ONE 14(9):e0222557. 10.1371/journal.pone.0222557.31539387
Shintani H. 2000. Pretreatment and chromatographic analysis of phthalate esters, and their biochemical behavior in blood products. Chromatographia 52(11/12):721–726.
Shiota K, Nishimura H. 1982. Teratogenicity of di(2-ethylhexyl) phthalate (DEHP) and di-n-butyl phthalate (DBP) in mice. Environ Health Perspect 45(0):65–70. 10.2307/3429385.7140698
Shiota K, Chou MJ, Nishimura H. 1980. Embryotoxic effects of di-2-ethylhexyl phthalate (DEHP) and di-n-butyl phthalate (DBP) in mice. Environ Res 22(1):245–253. 10.1016/0013-9351(80)90136-x.7418682
Shiue I. 2015a. Urinary heavy metals, phthalates, perchlorate, nitrate, thiocyanate, hydrocarbons, and polyfluorinated compounds are associated with adult hearing disturbance: USA NHANES, 2011–2012. Environ Sci Pollut Res Int 22(24):20306–20311. 10.1007/s11356-015-5546-8.26490897
Shiue I. 2015b. Arsenic, heavy metals, phthalates, pesticides, hydrocarbons and polyfluorinated compounds but not parabens or phenols are associated with adult remembering condition: US NHANES, 2011–2012. Environ Sci Pollut Res Int 22(8):6381–6386. 10.1007/s11356-015-4261-9.25744817
Shiue I. 2015c. Urinary heavy metals, phthalates and polyaromatic hydrocarbons independent of health events are associated with adult depression: USA NHANES, 2011–2012. Environ Sci Pollut Res Int 22(21):17095–17103. 10.1007/s11356-015-4944-2.26126689
Shiue I, Hristova K. 2014. Higher urinary heavy metal, phthalate and arsenic concentrations accounted for 3–19% of the population attributable risk for high blood pressure: US NHANES, 2009–2012. Hypertens Res 37(12):1075–1081. 10.1038/hr.2014.121.25077919
Shneider B, Cronin J, Van Marter L, 1991. A prospective analysis of cholestasis in infants supported with extracorporeal membrane oxygenation. J Pediatr Gastroenterol Nutr 13(3):285–289.1791505
Shoaff JR, Romano ME, Yolton K, 2016. Prenatal phthalate exposure and infant size at birth and gestational duration. Environ Res 150:52–58. 10.1016/j.envres.2016.05.033.27236572
Shoaff J, Papandonatos GD, Calafat AM. 2017a. Early-life phthalate exposure and adiposity at 8 years of age. Environ Health Perspect 215(9) 28935615.
Shoaff J, Papandonatos GD, Calafat AM, 2017b. Supplementary data: Early-life phthalate exposure and adiposity at 8 years of age. Environ Health Perspect 125. 10.1289/EHP1022.
Short RD, Robinson EC, Lington AW, 1987. Metabolic and peroxisome proliferation studies with di(2-ethylhexyl)phthalate in rats and monkeys. Toxicol Ind Health 3(2):185–195. 10.1177/074823378700300213.3617067
Silva MJ, Barr DB, Reidy JA, 2003. Glucuronidation patterns of common urinary and serum monoester phthalate metabolites. Arch Toxicol 77(10):561–567. 10.1007/s00204-003-0486-3.14574443
Silva MJ Reidy JA, Preau JL, 2006. Oxidative metabolites of diisononyl phthalate as biomarkers for human exposure assessment. Environ Health Perspect 114(8):1158–1161. 10.1289/ehp.8865.16882519
Simmon VF, Kauhanen K, Tardiff RG. 1977. Mutagenic activity of chemicals identified in drinking water. In: Progress in genetic toxicology: Proceedings of the Second International Conference on Environmental Mutagens. Edinburgh, London: Elsevier/North Holland Press, 249–258.
Simmons J, Yeatts S, Zhao J, 2005. Evaluation of systemic toxicity in mixtures of trichloroethylene (TCE), heptachlor (HEPT), and di(2-ethylhexyl)phthalate (DEHP) assessed in a 5x5x5 design. Toxicologist 84:395.
Singh S, Li SS. 2011. Phthalates: Toxicogenomics and inferred human diseases. Genomics 97(3):148–157. 10.1016/j.ygeno.2010.11.008.21156202
Singh AR, Lawrence WH, Autian J. 1974. Mutagenic and antifertility sensitivities of mice to di-2-ethylhexyl phthalate (DEHP) and dimethoxyethyl phthalate (DMEP). Toxicol Appl Pharmacol 29:35–46.4283679
Singh AR, Lawrence WH, Autian J. 1975. Maternal-fetal transfer of 14C-di-2-ethylhexyl phthalate and 14C-diethyl phthalate in rats. J Pharm Sci 64(8):1347–1350. 10.1002/jps.2600640819.1151708
Sjoberg P, Bondesson U, Hammarlund M. 1985a. Non-linearities in the pharmacokinetics of di-(2-ethylhexyl) phthalate and metabolites in male rats. Arch Toxicol 58(2):72–77.4091659
Sjoberg P, Bondesson U, Kjellen L, 1985b. Kinetics of di-(2-ethylhexyl) phthalate in immature and mature rats and effect on testis. Acta Pharmacol Toxicol (Copenh) 56:30–37.3976401
Sjoberg P, Bondesson U, Sedin G, 1985c. Dispositions of di- and mono-(2-ethylhexyl) phthalate in newborn infants subjected to exchange transfusions. Eur J Clin Invest 15(6):430–436. 10.1111/j.1365-2362.1985.tb00297.x.3938415
Sjoberg P, Lindqvist NG, Ploen L. 1986. Age-dependent response of the rat testes to di(2-ethylhexyl) phthalate. Environ Health Perspect 65:237–242.3709447
Sjoberg P, Egestad B, Klasson-Wehler E, 1991. Glucuronidation of mono(2-ethylhexyl)phthalate. Biochem Pharmacol 41(10):1493–1496.1902107
Smith CA, Holahan MR. 2014. Reduced hippocampal dendritic spine density and BDNF expression following acute postnatal exposure to di(2-ethylhexyl) phthalate in male Long Evans rats. PLoS ONE 9(10):e109522. 10.1371/journal.pone.0109522.25295592
Smith CA, MacDonald A, Holahan MR. 2011. Acute postnatal exposure to di(2-ethylhexyl) phthalate adversely impacts hippocampal development in the male rat. Neuroscience 193:100–108. 10.1016/j.neuroscience.2011.06.082.21782900
Smith-Oliver T, Butterworth BE. 1987. Correlation of the carcinogenic potential of di(2-ethylhexyl)phthalate (DEHP) with induced hyperplasia rather than with genotoxic activity. Mutat Res 188(1):21–28. 10.1016/0165-1218(87)90110-8.3574334
Sobol Z, Homiski ML, Dickinson DA, 2012. Development and validation of an in vitro micronucleus assay platform in TK6 cells. Mutat Res 746(1):29–34. 10.1016/j.mrgentox.2012.02.005.22445949
Sol CM, Santos S, Asimakopoulos AG, 2020. Associations of maternal phthalate and bisphenol urine concentrations during pregnancy with childhood blood pressure in a population-based prospective cohort study. Environ Int 138:105677. 10.1016/j.envint.2020.105677.32220816
Song Y, Hauser R, Hu FB, 2014. Urinary concentrations of bisphenol A and phthalate metabolites and weight change: A prospective investigation in US women. Int J Obes 38(12):1532–1537. 10.1038/ijo.2014.63.
Souter I, Bellavia A, Williams PL, 2020a. Urinary concentrations of phthalate metabolite mixtures in relation to serum biomarkers of thyroid function and autoimmunity among women from a fertility center. Environ Health Perspect 128(6):67007. 10.1289/ehp6740.32515996
Souter I, Bellavia A, Williams PL, 2020b. Supplemental material: Urinary concentrations of phthalate metabolite mixtures in relation to serum biomarkers of thyroid function and autoimmunity among women from a fertility center. Environ Health Perspect 128. 10.1289/ehp6740.
Specht IO, Bonde JP, Toft G, 2015. Serum phthalate levels and time to pregnancy in couples from Greenland, Poland and Ukraine. PLoS ONE 10(3):e0120070. 10.1371/journal.pone.0120070.25786246
Stahlhut RW, van Wijngaarden E, Dye TD, 2007. Concentrations of urinary phthalate metabolites are associated with increased waist circumference and insulin resistance in adult U.S. males. Environ Health Perspect 115(6):876–882. 10.1289/ehp.9882.17589594
Stalling DL, Hogan JW, Johnson J. 1973. Phthalate ester residues - their metabolism and analysis in fish. Environ Health Perspect 3(3):159–173.4145078
Staples CA, Werner AF, Hoogheem TJ. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4:131–142.
Staples CA, Peterson DR, Parkerton TF, 1997. The environmental fate of phthalate esters: A literature review. Chemosphere 35(4):667–749.
Stein TP, Schluter MD, Steer RA, 2013. Autism and phthalate metabolite glucuronidation. J Autism Dev Disord 43(11):2677–2685. 10.1007/s10803-013-1822-y.23575644
Steiner I, Scharf L, Fiala F, 1998. Migration of di-(2-ethylhexyl) phthalate from PVC child articles into saliva and saliva simulant. Food Addit Contam 15(7):812–817. 10.1080/02652039809374715.10211190
Stelmach I, Majak P, Jerzynska J, 2015. The effect of prenatal exposure to phthalates on food allergy and early eczema in inner-city children. Allergy Asthma Proc 36(4):72–78. 10.2500/aap.2015.36.3867.26108074
Stenchever MA, Allen MA, Jerominski L, 1976. Effects of bis(2-ethylhexyl) phthalate on chromosomes of human leukocytes and human fetal lung cells. J Pharm Sci 65:1648–1651.993999
Stermer AR, Murphy CJ, Ghaffari R, 2017. Mono-(2-ethylhexyl) phthalate-induced Sertoli cell injury stimulates the production of pro-inflammatory cytokines in Fischer 344 rats. Reprod Toxicol 69:150–158. 10.1016/j.reprotox.2017.02.013.28238932
Strassle PD, Smit LAM, Hoppin JA. 2018. Endotoxin enhances respiratory effects of phthalates in adults: Results from NHANES 2005–6. Environ Res 162:280–286. 10.1016/j.envres.2018.01.017.29407759
Stringer R, Labunska I, Santillo D, 2000. Concentrations of phthalate esters and identification of other additives in PVC children’s toys. Environ Sci Pollut Res Int 7(1):27–36. 10.1065/espr199910.00.19153836
Stroheker T, Cabaton N, Nourdin G, 2005. Evaluation of anti-androgenic activity of di-(2-ethylhexyl)phthalate. Toxicology 208(1):115–121. 10.1016/j.tox.2004.11.013.15664438
Stroheker T, Regnier JF, Lassurguere J, 2006. Effect of in utero exposure to di-(2-ethylhexyl)phthalate: distribution in the rat fetus and testosterone production by rat fetal testis in culture. Food Chem Toxicol 44(12):2064–2069. 10.1016/j.fct.2006.07.007.16979278
Stubin AI, Brosnan TM, Porter KD, 1996. Organic priority pollutants in New York City municipal wastewaters: 1989–1993. Water Environ Res 68(6):1037–1044.
Su PH, Chen JY, Lin CY, 2014. Sex steroid hormone levels and reproductive development of eight-year-old children following in utero and environmental exposure to phthalates. PLoS ONE 9(9):e102788. 10.1371/journal.pone.0102788.25207995
Su PH, Chang CK, Lin CY, 2015. Prenatal exposure to phthalate ester and pubertal development in a birth cohort in central Taiwan: a 12-year follow-up study. Environ Res 136:324–330. 10.1016/j.envres.2014.10.026.25460653
Suemizu H, Sota S, Kuronuma M, 2014. Pharmacokinetics and effects on serum cholinesterase activities of organophosphorus pesticides acephate and chlorpyrifos in chimeric mice transplanted with human hepatocytes. Regul Toxicol Pharmacol 70(2):468–473. 10.1016/j.yrtph.2014.08.010.25158275
Sugatt RH, O’Grady DP, Banerjee S, 1984. Shake flask biodegradation of 14 commercial phthalate esters. Appl Environ Microbiol 47(4):601–606.16346500
Sullivan KF, Atlas EL, Glam CS. 1982. Adsorption of phthalic esters from seawater. Environ Sci Technol 16:428–432.22276761
Sumner RN, Tomlinson M, Craigon J, 2019. Independent and combined effects of diethylhexyl phthalate and polychlorinated biphenyl 153 on sperm quality in the human and dog. Sci Rep 9(1):3409. 10.1038/s41598-019-39913-9.30833626
Sun W, Ban JB, Zhang N, 2014a. Perinatal exposure to di-(2-ethylhexyl)-phthalate leads to cognitive dysfunction and phospho-tau level increase in aged rats. Environ Toxicol 29(5):596–603. 10.1002/tox.21785.22610992
Sun Q, Cornelis MC, Townsend MK, 2014b. Association of urinary concentrations of bisphenol A and phthalate metabolites with risk of type 2 diabetes: a prospective investigation in the Nurses’ Health Study (NHS) and NHSII cohorts. Environ Health Perspect 122(6):616–623. 10.1289/ehp.1307201.24633239
Sun J, Chen B, Zhang L, 2016. Phthalate ester concentrations in blood serum, urine and endometrial tissues of Chinese endometriosis patients Int J Clin Exp Med 9(2):3808–3819.
Sun X, Li J, Jin S, 2018. Associations between repeated measures of maternal urinary phthalate metabolites during pregnancy and cord blood glucocorticoids. Environ Int 121(Pt 1):471–479. 10.1016/j.envint.2018.09.037.30278310
Sun X, Chen W, Weng S, 2020. Effects of the environmental endocrine disruptors di-2-ethylhexyl phthalate and mono-2-ethylhexyl phthalate on human sperm function in vitro. Reprod Fertil Dev 32(6):629–636. 10.1071/rd19164.32027815
Supornsilchai V, Soder O, Svechnikov K. 2007. Stimulation of the pituitary-adrenal axis and of adrenocortical steroidogenesis ex vivo by administration of di-2-ethylhexyl phthalate to prepubertal male rats. J Endocrinol 192(1):33–39. 10.1677/joe-06-0004.17210740
Suzuki Y, Yoshinaga J, Mizumoto Y, 2012. Foetal exposure to phthalate esters and anogenital distance in male newborns. Int J Androl 35(3):236–244. 10.1111/j.1365-2605.2011.01190.x.21696396
Swan SH. 2008. Environmental phthalate exposure in relation to reproductive outcomes and other health endpoints in humans. Environ Res 108(2):177–184. 10.1016/j.envres.2008.08.007.18949837
Swan SH, Main KM, Liu F, 2005. Decrease in anogenital distance among male infants with prenatal phthalate exposure. Environ Health Perspect 113(8):1056–1061.16079079
Swan SH, Liu F, Hines M, 2010. Prenatal phthalate exposure and reduced masculine play in boys. Int J Androl 33(2):259–269. 10.1111/j.1365-2605.2009.01019.x.19919614
Swan SH, Sathyanarayana S, Barrett ES, 2015. First trimester phthalate exposure and anogenital distance in newborns. Hum Reprod 30(4):963–972. 10.1093/humrep/deu363.25697839
Swartz RC, Schults DW, Ditsworth GR, et al. 1985. Sediment toxicity, contamination, and macrobenthic communities near a large sewage outfall. In: Boyle TP, ed. Validation and predictability of laboratory methods for assessing the fate and effects of contaminants in aquatic ecosystems. Philadelphia, PA: American Society for Testing and Materials, 152–175.
Szewczyńska M, Pośniak M, Dobrzyńska E. 2020. Determination of phthalates in particulate matter and gaseous phase emitted into the air of the working environment. Int J Environ Sci Technol 17(1):175–186. 10.1007/s13762-019-02435-y.
Tabak HH, Quave SA, Mashni CI, 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53:1503–1518.
Takagi A, Sai K, Umemura T, 1990. Significant increase of 8-hydroxydeoxyguanosine in liver DNA of rats following short-term exposure to the peroxisome proliferators di(2-ethylhexyl)phthalate and di(2-ethylhexyl)adipate. Jpn J Cancer Res 81(3):213–215.2112523
Tamura H, Iida T, Watanabe T, 1990. Long-term effects of hypolipidemic peroxisome proliferator administration on hepatic hydrogen peroxide metabolism in rats. Carcinogenesis 11(3):445–450. 10.1093/carcin/11.3.445.2311188
Tamura H, Iida T, Watanabe T, 1991. Lack of induction of hepatic DNA damage on long-term administration of peroxisome proliferators in male F-344 rats. Toxicology 69(1):55–62.1926155
Tanaka T. 2002. Reproductive and neurobehavioural toxicity study of bis(2-ethylhexyl) phthalate (DEHP) administered to mice in the diet. Food Chem Toxicol 40(10):1499–1506. 10.1016/s0278-6915(02)00073-x.12387315
Tanaka A, Adachi T, Takahashi T, 1975. Biochemical studies on phthalic esters I. Elimination, distribution and metabolism of di-(2-ethylhexyl)phthalate in rats. Toxicology 4(2):253–264. 10.1016/0300-483x(75)90105-5.1154425
Tanaka A, Matsumoto A, Yamaha T. 1978. Biochemical studies on phthalic esters. III. Metabolism of dibutyl phthalate (DBP) in animals. Toxicology 9(1–2):109–123.653732
Tang C, Luo C, Hua Y, 2019. Placental P-glycoprotein inhibition enhances susceptibility to di-(2-ethylhexyl)-phthalate induced cardiac malformations in mice: A possibly promising target for congenital heart defects prevention. PLoS ONE 14(5):e0214873. 10.1371/journal.pone.0214873.31086358
Tanida T, Warita K, Ishihara K, 2009. Fetal and neonatal exposure to three typical environmental chemicals with different mechanisms of action: mixed exposure to phenol, phthalate, and dioxin cancels the effects of sole exposure on mouse midbrain dopaminergic nuclei. Toxicol Lett 189(1):40–47. 10.1016/j.toxlet.2009.04.005.19481886
Teirlynck OA, Belpaire F. 1985. Disposition of orally administered di-(2-ethylhexyl) phthalate and mono-(2-ethylhexyl) phthalate in the rat. Arch Toxicol 57:226–230.4091646
Teirlynck O, Kaufman JM, Bogaert MG, 1988. Testicular toxicity induced by single dosing of di- and mono-(2-ethylhexyl) phthalate in the rat. Toxicol Lett 40(1):85–91. 10.1016/0378-4274(88)90186-5.3124304
Teitelbaum SL, Mervish N, Moshier EL, 2012. Associations between phthalate metabolite urinary concentrations and body size measures in New York City children. Environ Res 112:186–193. 10.1016/j.envres.2011.12.006.22222007
Téllez-Rojo MM, Cantoral A, Cantonwine DE, 2013. Prenatal urinary phthalate metabolites levels and neurodevelopment in children at two and three years of age. Sci Total Environ 461–462:386–390. 10.1016/j.scitotenv.2013.05.021.
Tennant RW, Margolin BH, Shelby MD, 1987. Prediction of chemical carcinogenicity in rodents from in vitro genetic toxicity assays. Science 236:933–941.3554512
Testa C, Nuti F, Hayek J, 2012. Di-(2-ethylhexyl) phthalate and autism spectrum disorders. ASN Neuro 4(4):223–229. 10.1042/an20120015.22537663
Thiess A, Fleig I. 1978. [Chromosomal studies in workers exposed to di-2-ethylhexylphthalate (DOP).]. Zentralbl Arbeitsmed 28:351–355. (German)
Thomas JM, Yordy JR, Amador JA, 1986. Rates of dissolution and biodegradation of water-insoluble organic compounds. Appl Environ Microbiol 52(2):290–296.3092736
Thomsen AML, Riis AH, Olsen J, 2017. Female exposure to phthalates and time to pregnancy: A first pregnancy planner study. Hum Reprod 32(1):232–238. 10.1093/humrep/dew291.27852689
Thuren A, Larsson P. 1990. Phthalate esters in the Swedish atmosphere. Environ Sci Technol 24(4):554–559.
Tian M, Liu L, Zhang J, 2019. Positive association of low-level environmental phthalate exposure with sperm motility was mediated by DNA methylation: A pilot study. Chemosphere 220:459–467. 10.1016/j.chemosphere.2018.12.155.30594797
Tickner J, Schettler T, Guidotti T, 2001. Health risks posed by use of di-2-ethylhexyl phthalate (DEHP) in PVC medical devices: A critical review. Am J Ind Med 39(1):100–111.11148020
Toft G, Jonsson BA, Lindh CH, 2012. Association between pregnancy loss and urinary phthalate levels around the time of conception. Environ Health Perspect 120(3):458–463. 10.1289/ehp.1103552.22113848
Tomaszewski KE, Montgomery CA, Melnick RL. 1988. Modulation of 2,3,7,8-tetrachlorodibenzo-p-dioxin toxicity in F344 rats by di(2-ethylhexyl)phthalate. Chem Biol Interact 65(3):205–222. 10.1016/0009-2797(88)90107-x.3378278
Tomita I, Nakamura Y, Yagi Y, 1982a. Teratogenicity/fetotoxicity of DEHP in mice. Environ Health Perspect 45:71–75.7140699
Tomita I, Nakamura Y, Aoki N, 1982b. Mutagenic/carcinogenic potential of DEHP and MEHP. Environ Health Perspect 45:119–125.6814903
Tomonari Y, Kurata Y, David RM, 2006. Effect of di(2-ethylhexyl) phthalate (DEHP) on genital organs from juvenile common marmosets: I. Morphological and biochemical investigation in 65-week toxicity study. J Toxicol Environ Health 69(17):1651–1672. 10.1080/15287390600630054.
Tonk EC, Verhoef A, Gremmer ER, 2012. Relative sensitivity of developmental and immune parameters in juvenile versus adult male rats after exposure to di(2-ethylhexyl) phthalate. Toxicol Appl Pharmacol 260(1):48–57. 10.1016/j.taap.2012.01.018.22310177
Toyosawa K, Okimoto K, Kobayashi I, 2001. Di(2-ethylhexyl)phthalate induces hepatocellular adenoma in transgenic mice carrying a human prototype c-Ha-ras gene in a 26-week carcinogenicity study. Toxicol Pathol 29(4):458–466.11560251
Trasande L, Attina TM. 2015. Association of exposure to di-2-ethylhexylphthalate replacements with increased blood pressure in children and adolescents. Hypertension 66(2):301–308. 10.1161/hypertensionaha.115.05603.26156503
Trasande L, Sathyanarayana S, Spanier AJ, 2013a. Urinary phthalates are associated with higher blood pressure in childhood. J Pediatr 163(3):747–753. 10.1016/j.jpeds.2013.03.072.23706605
Trasande L, Spanier AJ, Sathyanarayana S, 2013b. Urinary phthalates and increased insulin resistance in adolescents. Pediatrics 132(3):e646–e655. 10.1542/peds.2012-4022.23958772
Trasande L, Sathyanarayana S, Trachtman H. 2014. Dietary phthalates and low-grade albuminuria in US children and adolescents. Clin J Am Soc Nephrol 9(1):100–109. 10.2215/cjn.04570413.24178978
TRI18. 2020. TRI explorer: Providing access to EPA’s toxics release inventory data. U.S. Environmental Protection Agency. https://enviro.epa.gov/triexplorer/tri_release.chemical. May 5, 2020.
Tripathi A, Pandey V, Sahu AN, 2019. Di-(2-ethylhexyl) phthalate (DEHP) inhibits steroidogenesis and induces mitochondria-ROS mediated apoptosis in rat ovarian granulosa cells. Toxicology Research 8(3):381–394. 10.1039/c8tx00263k.31160972
Trosko JE. 1997. Challenge to the simple paradigm that ’carcinogens’ are ’mutagens’ and to the in vitro and in vivo assays used to test the paradigm. Mutat Res 373:245–249.9042406
Trosko JE. 2001. Commentary: Is the concept of “tumor promotion” a useful paradigm? Mol Carcinog 30:131–137.11301473
Tsai YA, Lin CL, Hou JW, 2016. Effects of high di(2-ethylhexyl) phthalate (DEHP) exposure due to tainted food intake on pre-pubertal growth characteristics in a Taiwanese population. Environ Res 149:197–205. 10.1016/j.envres.2016.05.005.27209343
Tsai YA, Tsai MS, Hou JW, 2018a. Evidence of high di(2-ethylhexyl) phthalate (DEHP) exposure due to tainted food intake in Taiwanese pregnant women and the health effects on birth outcomes. Sci Total Environ 618:635–644. 10.1016/j.scitotenv.2017.07.175.29055577
Tsai YA, Tsai MS, Hou JW, 2018b. Supplemental material: Evidence of high di(2-ethylhexyl) phthalate (DEHP) exposure due to tainted food intake in Taiwanese pregnant women and the health effects on birth outcomes. Sci Total Environ 618. 10.1016/j.scitotenv.2017.07.175.
Tsukada A, Suemizu H, Murayama N, 2013. Plasma concentrations of melengestrol acetate in humans extrapolated from the pharmacokinetics established in in vivo experiments with rats and chimeric mice with humanized liver and physiologically based pharmacokinetic modeling. Regul Toxicol Pharmacol 65(3):316–324. 10.1016/j.yrtph.2013.01.008.23395687
Tsumura Y, Ishimitsu S, Kaihara A, 2001. Di(2-ethylhexyl) phthalate contamination of retail packed lunches caused by PVC gloves in the preparation of foods. Food Addit Contam 18(6):569–579.11407756
Tsutsui T, Watanabe E, Barrett JC. 1993. Ability of peroxisome proliferators to induce cell transformation, chromosome aberrations and peroxisome proliferation in cultured Syrian hamster embryo cells. Carcinogenesis 14(4):611–618.8472324
Tully K, Kupfer D, Dopico AM, 2000. A plasticizer released from IV drip chambers elevates calcium levels in neurosecretary terminals. Toxicol Appl Pharmacol 168:183–188.11042090
TURI. 2006. Five chemicals alternatives assessment study. Toxics Use Reduction Institute. University of Massachusetts Lowell.
Turner JH, Petricciani JC, Crouch ML, 1974. An evaluation of the effects of diethylhexyl phthalate (DEHP) on mitotically capable cells in blood packs. Transfusion 14(6):560–566. 10.1111/j.1537-2995.1974.tb04577.x.4432261
Turunen M, Dallner G. 1998. Elevation of ubiquinone content by peroxisomal inducers in rat liver during aging. Chem Biol Interact 116:79–91.9877202
Tyl RW, Price CJ, Marr MC, 1988. Developmental toxicity evaluation of dietary di(2-ethylhexyl)phthalate in Fischer 344 rats and CD-1 mice. Fundam Appl Toxicol 10(3):395–412. 10.1016/0272-0590(88)90286-2.3371580
Uhde E, Bednarek M, Fuhrmann F, 2001. Phthalic esters in the indoor environment--test chamber studies on PVC-coated wallcoverings. Indoor Air 11(3):150–155.11521498
Ungewitter E, Rotgers E, Bantukul T, 2017. Teratogenic effects of in utero exposure to di-(2-ethylhexyl)-phthalate (DEHP) in B6:129S4 mice. Toxicol Sci 157(1):8–19. 10.1093/toxsci/kfx019.28123099
Upson K, Sathyanarayana S, De Roos AJ, 2013. Phthalates and risk of endometriosis. Environ Res 126:91–97. 10.1016/j.envres.2013.07.003.23890968
USGS. 2006. Determination of semivolatile organic compounds and polycyclic aromatic hydrocarbons in solids by gas chromatography/mass spectrometry. U.S. Geological Survey. Techniques and Methods 5–B3.
Vafeiadi M, Myridakis A, Roumeliotaki T, 2018a. Association of early life exposure to phthalates with obesity and cardiometabolic traits in childhood: Sex specific associations. Front Public Health 6:327. 10.3389/fpubh.2018.00327.30538977
Vafeiadi M, Myridakis A, Roumeliotaki T, 2018b. Supplementary data: Association of early life exposure to phthalates with obesity and cardiometabolic traits in childhood: Sex specific associations. Front Public Health 6. 10.3389/fpubh.2018.00327.
Valvi D, Casas M, Romaguera D, 2015. Prenatal phthalate exposure and childhood growth and blood pressure: Evidence from the Spanish INMA-Sabadell birth cohort study. Environ Health Perspect 123(10):1022–1029. 10.1289/ehp.1408887.25850106
Van Vliet ED, Reitano EM, Chhabra JS, 2011. A review of alternatives to di (2-ethylhexyl) phthalate-containing medical devices in the neonatal intensive care unit. J Perinatol 31(8):551–560. 10.1038/jp.2010.208.21311501
Velez MP, Arbuckle TE, Fraser WD. 2015. Female exposure to phenols and phthalates and time to pregnancy: the Maternal-Infant Research on Environmental Chemicals (MIREC) Study. Fertil Steril 103(4):1011–1020. 10.1016/j.fertnstert.2015.01.005.25681860
Velinsky DJ, Riedel G, Ashley JTF, 2011. Historical contamination of the Anacostia River, Washington, D.C. Environ Monit Assess 183:307–328.21404015
Venturelli AC, Fischer SV, Nogueira de R Morais, 2015. Effects of exposure to di-(2-ethylhexyl) phthalate (DEHP) during lactation and puberty on sexual maturation and glycemic homeostasis in males rats. Clin Nutr ESPEN 10(1):e5–e12. 10.1016/j.clnme.2014.10.002.28531447
Venturelli AC, Meyer KB, Fischer SV, 2019. Effects of in utero and lactational exposure to phthalates on reproductive development and glycemic homeostasis in rats. Toxicology 421:30–40. 10.1016/j.tox.2019.03.008.30940548
Vessman J, Rietz G. 1974. Determination of di(ethylhexyl) phthalate in human plasma and plasma proteins by electron capture gas chromatography. J Chromatogr 100(1):153–163.4436401
Villanger GD, Drover SSM, Nethery RC, 2020a. Associations between urine phthalate metabolites and thyroid function in pregnant women and the influence of iodine status. Environ Int 137:105509. 10.1016/j.envint.2020.105509.32044443
Villanger GD, Drover SSM, Nethery RC, 2020b. Supplemental material: Associations between urine phthalate metabolites and thyroid function in pregnant women and the influence of iodine status. Environ Int 137. 10.1016/j.envint.2020.105509.
Vo T, Jung E, Dang V, 2009a. Differential effects of flutamide and di-(2-ethylhexyl) phthalate on male reproductive organs in a rat model. J Reprod Dev 55(4):400–411.19367084
Vo TT, Jung EM, Dang VH, 2009b. Di-(2 ethylhexyl) phthalate and flutamide alter gene expression in the testis of immature male rats. Reprod Biol Endocrinol 7:104. 10.1186/1477-7827-7-104.19781091
Vogel EW, Nivard MJ. 1993. Performance of 181 chemicals in a Drosophila assay predominantly monitoring interchromosomal mitotic recombination. Mutagenesis 8(1):57–81. 10.1093/mutage/8.1.57.8450769
Von Daniken A, Lutz WK, Jackh R, 1984. Investigation of the potential for binding of di(2-ethylhexyl) phthalate (DEHP) and di(2-ethylhexyl)adipate (DEHA) to liver DNA in vivo. Toxicol Appl Pharmacol 73:373–387.6719458
Voss C, Zerban H, Bannasch P, 2005. Lifelong exposure to di-(2-ethylhexyl)-phthalate induces tumors in liver and testes of Sprague-Dawley rats. Toxicology 206(3):359–371. 10.1016/j.tox.2004.07.016.15588926
Voss J, Stermer AR, Ghaffari R, 2018. MEHP-induced rat testicular inflammation does not exacerbate germ cell apoptosis. Reproduction 156(1):35–46. 10.1530/rep-18-0093.29743262
Walker C, Ghazisaeidi S, Collet B, 2020. In utero exposure to low doses of genistein and di-(2-ethylhexyl) phthalate (DEHP) alters innate immune cells in neonatal and adult rat testes. Andrology 8(4):943–964. 10.1111/andr.12840.32533902
Wallin RF, Klamer B, Nicora RW, 1974. Di (2-ethylhexyl) phthalate (DEHP) metabolism in animals and post-transfusion tissue levels in man. Bull Parenter Drug Assoc 28(6):278–287.4455324
Wams TJ. 1987. Diethylhexylphthalate as an environmental contaminant - A review. Sci Total Environ 66:1–16.3317819
Wang IJ, Karmaus WJ. 2015. The effect of phthalate exposure and filaggrin gene variants on atopic dermatitis. Environ Res 136:213–218. 10.1016/j.envres.2014.09.032.25460639
Wang H, Zhou Y, Tang C, 2013. Urinary phthalate metabolites are associated with body mass index and waist circumference in Chinese school children. PLoS ONE 8(2):e56800. 10.1371/journal.pone.0056800.23437242
Wang IJ, Lin CC, Lin YJ, 2014. Early life phthalate exposure and atopic disorders in children: a prospective birth cohort study. Environ Int 62:48–54. 10.1016/j.envint.2013.09.002.24161446
Wang W, Xu X, Fan CQ. 2015. Health hazard assessment of occupationally di-(2-ethylhexyl)-phthalate-exposed workers in China. Chemosphere 120:37–44. 10.1016/j.chemosphere.2014.05.053.24974312
Wang YX, Zeng Q, Sun Y, 2016. Phthalate exposure in association with serum hormone levels, sperm DNA damage and spermatozoa apoptosis: A cross-sectional study in China. Environ Res 150:557–565. 10.1016/j.envres.2015.11.023.26654563
Wang X, Wang Y, Song Q, 2017a. In utero and lactational exposure to di(2-ethylhexyl) phthalate increased the susceptibility of prostate carcinogenesis in male offspring. Reprod Toxicol 69:60–67. 10.1016/j.reprotox.2017.01.008.28115265
Wang S, Zhang P, Liu R, 2017b. A DEHP plasticizer alters synaptic proteins via peroxidation. Toxicology Research 6(1):89–97. 10.1039/c6tx00361c.30090480
Wang B, Liu F, Dong J, 2018. Maternal exposure to environmental DEHP exacerbated OVA-induced asthmatic responses in rat offspring. Sci Total Environ 615:253–261. 10.1016/j.scitotenv.2017.09.276.28972901
Wang G, Chen Q, Tian P, 2020. Gut microbiota dysbiosis might be responsible to different toxicity caused by di-(2-ethylhexyl) phthalate exposure in murine rodents. Environ Pollut 261:114164. 10.1016/j.envpol.2020.114164.32088434
Ward JM, Hagiwara A, Anderson LM, 1988. The chronic hepatic or renal toxicity of di(2-ethylhexyl) phthalate, acetaminophen, sodium barbital, and phenobarbital in male B6C3F1 mice: Autoradiographic, immunohistochemical, and biochemical evidence for levels of DNA synthesis not associated with carcinogenesis or tumor promotion. Toxicol Appl Pharmacol 96(3):494–506. 10.1016/0041-008x(88)90009-9.3206528
Watkins DJ, Tellez-Rojo MM, Ferguson KK, 2014. In utero and peripubertal exposure to phthalates and BPA in relation to female sexual maturation. Environ Res 134:233–241. 10.1016/j.envres.2014.08.010.25173057
Watkins DJ, Peterson KE, Ferguson KK, 2016. Relating phthalate and BPA exposure to metabolism in peripubescence: The role of exposure timing, sex, and puberty. J Clin Endocrinol Metab 101(1):79–88. 10.1210/jc.2015-2706.26529628
Wei Z, Song L, Wei J, 2012. Maternal exposure to di-(2-ethylhexyl)phthalate alters kidney development through the renin-angiotensin system in offspring. Toxicol Lett 212(2):212–221. 10.1016/j.toxlet.2012.05.023.22677342
Wei N, Feng X, Xie Z, 2017. Long-term di (2-ethylhexyl)-phthalate exposure promotes proliferation and survival of HepG2 cells via activation of NFκB. Toxicol in Vitro 42:86–92. 10.1016/j.tiv.2017.04.015.28412506
Wen HJ, Chen CC, Wu MT, 2017. Phthalate exposure and reproductive hormones and sex-hormone binding globulin before puberty - Phthalate contaminated-foodstuff episode in Taiwan. PLoS ONE 12(4):e0175536. 10.1371/journal.pone.0175536.28410414
Weng TI, Chen MH, Lien GW, 2017. Effects of gender on the association of urinary phthalate metabolites with thyroid hormones in children: A prospective cohort study in Taiwan. Int J Environ Res Public Health 14(2):123. 10.3390/ijerph14020123.28146055
Wenzel AG, Bloom MS, Butts CD, 2018. Influence of race on prenatal phthalate exposure and anogenital measurements among boys and girls. Environ Int 110:61–70.29097052
Werner EF, Braun JM, Yolton K, 2015. The association between maternal urinary phthalate concentrations and blood pressure in pregnancy: The HOME Study. Environ Health 14:75. 10.1186/s12940-015-0062-3.26380974
Wester RC, Melendres J, Sedik L, 1998. Percutaneous absorption of salicylic acid, theophylline, 2,4-dimethylamine, diethyl hexyl phthalic acid, and p-aminobenzoic acid in the isolated perfused porcine skin flap compared to man in vivo. Toxicol Appl Pharmacol 151:159–165.9705899
Weuve J, Hauser R, Calafat AM, 2010. Association of exposure to phthalates with endometriosis and uterine leiomyomata: findings from NHANES, 1999–2004. Environ Health Perspect 118(6):825–832. 10.1289/ehp.0901543.20185384
White PD, Carter DE, Earnest D, 1980. Absorption and metabolism of 3 phthalate diesters by the rat small intestine. Food Cosmet Toxicol 18(4):383–386.7461517
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
Whyatt RM, Adibi JJ, Calafat AM, 2009. Prenatal di(2-ethylhexyl)phthalate exposure and length of gestation among an inner-city cohort. Pediatrics 124(6):e1213–e1220. 10.1542/peds.2009-0325.19948620
Whyatt RM, Liu X, Rauh VA, 2012. Maternal prenatal urinary phthalate metabolite concentrations and child mental, psychomotor, and behavioral development at 3 years of age. Environ Health Perspect 120(2):290–295. 10.1289/ehp.1103705.21893441
Whyatt RM, Perzanowski MS, Just AC, 2014. Asthma in inner-city children at 5–11 years of age and prenatal exposure to phthalates: the Columbia Center for Children’s Environmental Health Cohort. Environ Health Perspect 122(10):1141–1146. 10.1289/ehp.1307670.25230320
Wilkinson CF, Lamb JC. 1999. The potential health effects of phthalate esters in children’s toys: a review and risk assessment. Regul Toxicol Pharmacol 30(2 Pt 1):140–155. 10.1006/rtph.1999.133.
Williams D. 1973. Dibutyl- and di-2(ethylhexyl)phthalate in fish. J Agric Food Chem 21:1128–1129.4755838
Williams D, Blanchfield B. 1974. Retention, excretion and metabolism of phthalic acid administered orally to the rat. Bull Environ Contam Toxicol 12(1):109–112.4433845
Wirth J, Rossano M, Potter R, 2008. A pilot study associating urinary concentrations of phthalate metabolites and semen quality. Syst Biol Reprod Med 54(3):143–154. 10.1080/19396360802055921.18570050
Wofford HW, Wilsey CD, Neff GS. 1981. Bioaccumulation and metabolism of phthalate esters of oysters, brown shrimp, and sheepshead minnows. Ecotoxicol Environ Saf 5:202–210.7250005
Wolfe NL, Burns LA, Steen WC. 1980. Use of linear free energy relationships and an evaluative model to assess the fate and transport of phthalate esters in the aquatic environment. Chemosphere 9:393–402.
Wolff MS, Engel SM, Berkowitz GS, 2008. Prenatal phenol and phthalate exposures and birth outcomes. Environ Health Perspect 116(8):1092–1097. 10.1289/ehp.11007.18709157
Wolff MS, Teitelbaum SL, McGovern K, 2014. Phthalate exposure and pubertal development in a longitudinal study of US girls. Hum Reprod 29(7):1558–1566. 10.1093/humrep/deu081.24781428
Woodward MJ, Obsekov V, Jacobson MH, 2020. Phthalates and sex steroid hormones among men from NHANES, 2013–2016. J Clin Endocrinol Metab 105(4):e1225–1234. 10.1210/clinem/dgaa039.31996892
Wormuth M, Scheringer M, Vollenweider M, 2006. What are the sources of exposure to eight frequently used phthalic acid esters in Europeans? Risk Anal 26(3):803–824. 10.1111/j.1539-6924.2006.00770.16834635
Wu MT, Wu CF, Chen BH, 2013. Intake of phthalate-tainted foods alters thyroid functions in Taiwanese children. PLoS ONE 8(1):e55005. 10.1371/journal.pone.0055005.23383031
Wu H, Olmsted A, Cantonwine DE, 2017. Urinary phthalate and phthalate alternative metabolites and isoprostane among couples undergoing fertility treatment. Environ Res 153:1–7. 10.1016/j.envres.2016.11.003.27875712
Wu CF, Hsiung CA, Tsai HJ, 2018. Interaction of melamine and di-(2-ethylhexyl) phthalate exposure on markers of early renal damage in children: The 2011 Taiwan food scandal. Environ Pollut 235:453–461. 10.1016/j.envpol.2017.12.107.29310089
Wu M, Xu L, Teng C, 2019. Involvement of oxidative stress in di-2-ethylhexyl phthalate (DEHP)-induced apoptosis of mouse NE-4C neural stem cells. Neurotoxicology 70:41–47. 10.1016/j.neuro.2018.10.013.30395871
Xie C, Jin R, Zhao Y, 2015. Paraoxonase 2 gene polymorphisms and prenatal phthalates’ exposure in Chinese newborns. Environ Res 140:354–359. 10.1016/j.envres.2015.03.028.25913154
Xie X, Deng T, Duan J, 2019. Comparing the effects of diethylhexyl phthalate and dibutyl phthalate exposure on hypertension in mice. Ecotoxicol Environ Saf 174:75–82. 10.1016/j.ecoenv.2019.02.067.30822670
Xu Y, Agrawal S, Cook TJ, 2007. Di-(2-ethylhexyl)-phthalate affects lipid profiling in fetal rat brain upon maternal exposure. Arch Toxicol 81(1):57–62. 10.1007/s00204-006-0143-8.16951938
Xu Y, Agrawal S, Cook T, 2008. Maternal di-(2-ethylhexyl)-phthalate exposure influences essential fatty acid homeostasis in rat placenta. Placenta 29(11):962–969. 10.1016/j.placenta.2008.08.011.18829104
Xu C, Chen J, Qiu Z, 2010. Ovotoxicity and PPAR-mediated aromatase downregulation in female Sprague-Dawley rats following combined oral exposure to benzo[a]pyrene and di-(2-ethylhexyl) phthalate. Toxicol Lett 199(3):323–332. 10.1016/j.toxlet.2010.09.015.20920559
Xu X, Yang Y, Wang R, 2015. Perinatal exposure to di-(2-ethylhexyl) phthalate affects anxiety- and depression-like behaviors in mice. Chemosphere 124:22–31. 10.1016/j.chemosphere.2014.10.056.25441928
Xu J, Zhou L, Wang S, 2018. Di-(2-ethylhexyl)-phthalate induces glucose metabolic disorder in adolescent rats. Environ Sci Pollut Res Int 25(4):3596–3607. 10.1007/s11356-017-0738-z.29164460
Xu Y, Park SH, Yoon KN, 2019. Effects of citrate ester plasticizers and bis (2-ethylhexyl) phthalate in the OECD 28-day repeated-dose toxicity test (OECD TG 407). Environ Res 172:675–683. 10.1016/j.envres.2019.03.004.30878739
Yaghjyan L, Sites S, Ruan Y, 2015a. Associations of urinary phthalates with body mass index, waist circumference and serum lipids among females: National Health and Nutrition Examination Survey 1999–2004. Int J Obes 39(2):994–1000. 10.1038/ijo.2015.8.
Yaghjyan L, Sites S, Ruan Y, 2015b. Supplemental data: Associations of urinary phthalates with body mass index, waist circumference and serum lipids among females: National Health and Nutrition Examination Survey 1999–2004. Int J Obes 39.
Yaghjyan L, Ghita GL, Dumont-Driscoll M, 2016. Maternal exposure to di-2-ethylhexylphthalate and adverse delivery outcomes: A systematic review. Reprod Toxicol 65:76–86. 10.1016/j.reprotox.2016.07.002.27412369
Yagi Y, Nakamura Y, Tomita I, 1980. Teratogenic potential of di- and mono-(2-ethylhexyl)phthalate in mice. J Environ Pathol Toxicol 4(2–3):533–544.7462917
Yamashita M, Suemizu H, Murayama N, 2014. Human plasma concentrations of herbicidal carbamate molinate extrapolated from the pharmacokinetics established in in vivo experiments with chimeric mice with humanized liver and physiologically based pharmacokinetic modeling. Regul Toxicol Pharmacol 70(1):214–221. 10.1016/j.yrtph.2014.06.028.25016177
Yang G, Qiao Y, Li B, 2008. Adjuvant effect of di-(2-ethylhexyl) phthalate on asthma-like pathological changes in ovalbumin-immunised rats. Food Agric Immunol 19(4):351–362. 10.1080/09540100802545869.
Yang G, Zhou X, Wang J, 2012. MEHP-induced oxidative DNA damage and apoptosis in HepG2 cells correlates with p53-mediated mitochondria-dependent signaling pathway. Food Chem Toxicol 50(7):2424–2431. 10.1016/j.fct.2012.04.023.22542555
Yao HY, Han Y, Gao H, 2016. Maternal phthalate exposure during the first trimester and serum thyroid hormones in pregnant women and their newborns. Chemosphere 157:42–48. 10.1016/j.chemosphere.2016.05.023.27208644
Ye H, Ha M, Yang M, 2017. Di2-ethylhexyl phthalate disrupts thyroid hormone homeostasis through activating the Ras/Akt/TRHr pathway and inducing hepatic enzymes. Sci Rep 7:40153. 10.1038/srep40153.28065941
Yolton K, Xu Y, Strauss D, 2011. Prenatal exposure to bisphenol A and phthalates and infant neurobehavior. Neurotoxicol Teratol 33(5):558–566. 10.1016/j.ntt.2011.08.003.21854843
Yoon JS, Mason JM, Nalencia R, 1985. Chemical mutagenesis testing in drosophila. IV. Results of 45 coded compounds tested for the National Toxicology Program. Environ Mutagen 7:349–367.3930235
Yoshikawa K, Tanaka A, Yamaha T, 1983. Mutagenicity study of nine monoalkyl phthalates and a dialkyl phthalate using Salmonella typhimurium and Escherichia coli. Food Chem Toxicol 21(2):221–223.6339336
You M, Dong J, Fu Y, 2018. Exposure to di-(2-ethylhexyl) phthalate during perinatal period gender-specifically impairs the dendritic growth of pyramidal neurons in rat offspring. Front Neurosci 12:444. 10.3389/fnins.2018.00444.30087586
Yu C, Chu K. 2009. Occurrence of pharmaceuticals and personal care products along the West Prong Little Pigeon River in east Tennessee, USA. Chemosphere 75(10):1281–1286. 10.1016/j.chemosphere.2009.03.043.19395062
Yu Z, Han Y, Shen R, 2018. Gestational di-(2-ethylhexyl) phthalate exposure causes fetal intrauterine growth restriction through disturbing placental thyroid hormone receptor signaling. Toxicol Lett 294:1–10. 10.1016/j.toxlet.2018.05.013.29753845
Yu Q, Xiong X, He J, 2019. Photolysis of bis(2-ethylhexyl) phthalate in aqueous solutions at the presence of natural water photoreactive constituents under simulated sunlight irradiation. Environ Sci Pollut Res Int 26(26):26797–26806. 10.1007/s11356-019-05913-5.31300990
Yu Z, Wang F, Han J, 2020. Opposite effects of high- and low-dose di-(2-ethylhexyl) phthalate (DEHP) exposure on puberty onset, oestrous cycle regularity and hypothalamic kisspeptin expression in female rats. Reprod Fertil Dev 32(6):610–618. 10.1071/rd19024.32209209
Yuwatini E, Hata N, Kuramitz H, 2013. Effect of salting-out on distribution behavior of di(2-ethylhexyl) phthalate and its analogues between water and sediment. SpringerPlus 2:422. 10.1186/2193-1801-2-422.24024106
Zacharewski TR, Meek MD, Clemons JH, 1998. Examination of the in vitro and in vivo estrogenic activities of eight commercial phthalate esters. Toxicol Sci 46(2):282–293. 10.1093/toxsci/46.2.282.10048131
Zeiger E, Haworth S, Mortelmans K, 1985. Mutagenicity testing of di(2-ethylhexyl)phthalate and related chemicals in Salmonella. Environ Mol Mutagen 7(2):213–232. 10.1002/em.2860070209.
Zhang YH, Zheng LX, Chen BH. 2006. Phthalate exposure and human semen quality in Shanghai: a cross-sectional study. Biomed Environ Sci 19(3):205–209.16944777
Zhang Y, Lin L, Liu Z, 2008. Disruption effects of monophthalate exposures on inter-Sertoli tight junction in a two-compartment culture model. Environ Toxicol 23(3):302–308. 10.1002/tox.20343.18214902
Zhang X-F, Zhang T, Wang L, 2013. Effects of diethylhexyl phthalate (DEHP) given neonatally on spermatogenesis of mice. Mol Biol Rep 40(11):6509–6517. 10.1007/s11033-013-2769-y.24057186
Zhang Y, Meng X, Chen L, 2014. Age and sex-specific relationships between phthalate exposures and obesity in Chinese children at puberty. PLoS ONE 9(8):e104852. 10.1371/journal.pone.0104852.25121758
Zhang XF, Zhang T, Han Z, 2015. Transgenerational inheritance of ovarian development deficiency induced by maternal diethylhexyl phthalate exposure. Reprod Fertil Dev 27(8):1213–1221. 10.1071/rd14113.24919469
Zhang J, Liu L, Wang X, 2016. Low-level environmental phthalate exposure associates with urine metabolome alteration in a Chinese male cohort. Environ Sci Technol 50(11):5953–5960. 10.1021/acs.est.6b00034.27138838
Zhang W, Shen XY, Zhang WW, 2017. Di-(2-ethylhexyl) phthalate could disrupt the insulin signaling pathway in liver of SD rats and L02 cells via PPARγ. Toxicol Appl Pharmacol 316:17–26. 10.1016/j.taap.2016.12.010.28025108
Zhang L, Li H, Gao M, 2018a. Genistein attenuates di-(2-ethylhexyl) phthalate-induced testicular injuries via activation of Nrf2/HO-1 following prepubertal exposure. Int J Mol Med 41(3):1437–1446. 10.3892/ijmm.2018.3371.29328408
Zhang P, Guan X, Yang M, 2018b. Roles and potential mechanisms of selenium in countering thyrotoxicity of DEHP. Sci Total Environ 619–620:732–739. 10.1016/j.scitotenv.2017.11.169.
Zhang Y, Mu X, Gao R, 2018c. Foetal-neonatal exposure of di (2-ethylhexyl) phthalate disrupts ovarian development in mice by inducing autophagy. J Hazard Mater 358:101–112. 10.1016/j.jhazmat.2018.06.042.29990796
Zhang Y, Gao H, Mao L, 2018d. Effects of the phthalate exposure during three gestation periods on birth weight and their gender differences: A birth cohort study in China. Sci Total Environ 613–614:1573–1578. 10.1016/j.scitotenv.2017.08.319.
Zhang YZ, Zhang ZM, Zhou LT, 2019. Di (2-ethylhexyl) phthalate disorders lipid metabolism via TYK2/STAT1 and autophagy in rats. Biomed Environ Sci 32(6):406–418. 10.3967/bes2019.055.31262386
Zhang Y, Mustieles V, Yland J, 2020a. Association of parental preconception exposure to phthalates and phthalate substitutes with preterm birth. JAMA Netw Open 3(4):e202159. 10.1001/jamanetworkopen.2020.2159.32259265
Zhang S, Sun C, Zhao S, 2020b. Exposure to DEHP or its metabolite MEHP promotes progesterone secretion and inhibits proliferation in mouse placenta or JEG-3 cells. Environ Pollut 257:113593. 10.1016/j.envpol.2019.113593.31771930
Zhang Y, Zhou L, Zhang Z, 2020c. Effects of di (2-ethylhexyl) phthalate and high-fat diet on lipid metabolism in rats by JAK2/STAT5. Environ Sci Pollut Res Int 27(4):3837–3848. 10.1007/s11356-019-06599-5.31732953
Zhang Y, Mustieles V, Yland J, 2020d. Supplementary material: Association of parental preconception exposure to phthalates and phthalate substitutes with preterm birth. JAMA Netw Open 3. 10.1001/jamanetworkopen.2020.2159.
Zhang T, Ma YB, Li HC, 2020e. Low dose of genistein alleviates mono-(2-ethylhexyl) phthalate-induced fetal testis disorder based on organ culture model. Oxid Med Cell Longev 2020:4569268. 10.1155/2020/4569268.32566080
Zhao Y, Chen L, Li LX, 2014. Gender-specific relationship between prenatal exposure to phthalates and intrauterine growth restriction. Pediatr Res 76(4):401–408. 10.1038/pr.2014.103.25003910
Zhao H, Li J, Zhou Y, 2018. Investigation on metabolism of di(2-ethylhexyl) phthalate in different trimesters of pregnant women. Environ Sci Technol 52(21):12851–12858. 10.1021/acs.est.8b04519.30257557
Zhou JL, Liu YP. 2000. Kinetics and equilibria of the interactions between diethylhexyl phthalate and sediment particles in simulated estuarine systems. Mar Chem 71:165–176.
Zhou L, Chen H, Xu Q, 2019. The effect of di-2-ethylhexyl phthalate on inflammation and lipid metabolic disorder in rats. Ecotoxicol Environ Saf 170:391–398. 10.1016/j.ecoenv.2018.12.009.30550969
Zhu Y, Wan Y, Zhang B, 2018. Relationship between maternal phthalate exposure and offspring size at birth. Sci Total Environ 612:1072–1078. 10.1016/j.scitotenv.2017.08.207.28892847
Zolfaghari M, Drogui P, Seyhi B, 2014. Occurrence, fate and effects of di (2-ethylhexyl) phthalate in wastewater treatment plants: A review. Environ Pollut 194C:281–293. 10.1016/j.envpol.2014.07.014.