# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Rae T. Benedict, Ph.D. (Lead)
  Sam Keith, M.S., C.H.P.
  Hana Pohl, M.D., Ph.D.
  Mike Fay, Ph.D.
- ATSDR, Office of Innovation and Analytics, Toxicology Section, Atlanta, GA
- Kimberly Zaccaria, Ph.D., D.A.B.T.
  Heather Carlson-Lynch, M.S., D.A.B.T.
  Julie Melia, Ph.D., D.A.B.T.
  Deborah Herber, Ph.D.
  Parker Honey, M.P.H.
  Courtney Hard, B.A.
  Mario Citra, Ph.D.
- SRC, Inc., North Syracuse, NY

## REVIEWERS

Interagency Minimal Risk Level Workgroup:

Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Safety and Health (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).

Additional reviews for science and/or policy:

ATSDR, Office of Community Health and Hazard Assessment; ATSDR, Office of Capacity Development and Applied Prevention Science; ATSDR, Office of Science; NCEH, Division of Laboratory Science; NCEH, Division of Environmental Health Science and Practice; EPA, Center for Public Health and Environmental Assessment.

## PEER REVIEWERS

1. Tee L. Guidotti, M.D., MPH; Retired Chair of the Department of Environmental and Occupational Health and Director of the Division of Occupational Medicine and Toxicology at George Washington University; Affiliate with Risk Sciences International Inc., Silver Spring, Maryland
2. J. E. Klaunig, Ph.D., Fellow ATS, Fellow IATP; Professor, Environmental Health; Professor, School of Public and Environmental Affairs; Indiana University Bloomington; Bloomington, Indiana
3. Emily S. Barrett, Ph.D.; Associate Professor, Department of Epidemiology; Environmental and Occupational Health Sciences Institute; Rutgers School of Public Health; Piscataway, New Jersey

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(i)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.