# VERSION HISTORY

Date | Description
January 2022 | Final toxicological profile released
December 2019 | Draft for public comment toxicological profile released
September 2002 | Final toxicological profile released
April 1993 | Final toxicological profile released
June 1989 | Final toxicological profile released