# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR DEHP

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to DEHP.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen was conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for DEHP. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of DEHP have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of DEHP are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Health Effects
Species
Human
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
Health outcome
Death
Systemic effects
Body weight effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects
Renal effects
Dermal effects
Ocular effects
Endocrine effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Other noncancer effects
Cancer
Toxicokinetics
Absorption
Distribution
Metabolism
Excretion
PBPK models
Biomarkers
Biomarkers of exposure
Biomarkers of effect
Interactions with other chemicals
Potential for human exposure
Releases to the environment
Air
Water
Soil
Environmental fate
Transport and partitioning
Transformation and degradation
Environmental monitoring
Air
Water
Sediment and soil
Other media
Biomonitoring
General populations
Occupation populations

### B.1.1 Literature Search

The current literature search was intended to update the draft toxicological profile for DEHP released for public comment in DEHP; thus, the literature search was restricted to studies published between September 2015 and June 2020. The following main databases were searched in June 2020:

- PubMed
- National Library of Medicine’s TOXLINE
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for DEHP. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to DEHP were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
9/2016 | (“Diethylhexyl Phthalate”[mh] AND 2014/08/01:3000[mhda]) OR (((“1,2-Benzenedicarboxylic acid, 1,2-bis(2-ethylhexyl) ester”[tw] OR “1,2-Benzenedicarboxylic acid, bis(2-ethylhexyl) ester”[tw] OR “2-Ethylhexyl phthalate”[tw] OR “Bis(2-ethylhexyl) 1,2-benzenedicarboxylate”[tw] OR “Bis(2-ethylhexyl) o-phthalate”[tw] OR “Bis(2-ethylhexyl) phthalate”[tw] OR “Bis(2-ethylhexyl)phthalate”[tw] OR “DEHP”[tw] OR “Di(2-ethylhexyl) orthophthalate”[tw] OR “Di(2-ethylhexyl) phthalate”[tw] OR “Di-(2-ethylhexyl) phthalate”[tw] OR “Di(2-ethylhexyl)orthophthalate”[tw] OR “Di(2-ethylhexyl)phthalate”[tw] OR “Di(isooctyl) phthalate”[tw] OR “Di-2-ethylhexyl phthalate”[tw] OR “Di-2-ethylhexylphthalate”[tw] OR “Diethylhexyl phthalate”[tw] OR “Dioctyl phthalate”[tw] OR “Di-sec-octyl phthalate”[tw] OR “Ethyl hexyl phthalate”[tw] OR “Ethylhexyl phthalate”[tw] OR “Octyl phthalate”[tw] OR “Phthalic acid di(2-ethylhexyl) ester”[tw] OR “Phthalic acid dioctyl ester”[tw] OR “Phthalic acid, bis(2-ethylhexyl) ester”[tw]) OR (“DOF plasticizer”[tw] OR “Bisoflex DOP”[tw] OR “Celluflex DOP”[tw] OR “Diacizer DOP”[tw] OR “Diplast O”[tw] OR “Ergoplast FDO”[tw] OR “Ergoplast FDO-S”[tw] OR “Fleximel”[tw] OR “Flexol DOD”[tw] OR “Flexol DOP”[tw] OR “Flexol Plasticizer DOP”[tw] OR “Hatco DOP”[tw] OR “Hatcol DOP”[tw] OR “Jayflex DOP”[tw] OR “Kodaflex DEHP”[tw] OR “Kodaflex DOP”[tw] OR “Mollan O”[tw] OR “Monocizer DOP”[tw] OR “Nuoplaz DOP”[tw] OR “Octoil”[tw] OR “Palatinol AH”[tw] OR “Palatinol AH-L”[tw] OR “Palatinol DOP”[tw] OR “Plasthall DOP”[tw] OR “Platinol AH”[tw] OR “Platinol DOP”[tw] OR “RC Plasticizer DOP”[tw] OR “Reomol DOP”[tw] OR “Sansocizer DOP”[tw] OR “Sconamoll DOP”[tw] OR “Staflex DOP”[tw] OR “Truflex DOP”[tw] OR “Vestinol AH”[tw] OR “ZS plasticizer”[tw] OR “PX-138”[tw] OR “Garbeflex DOP-D 40”[tw] OR “Reomol D 79P”[tw] OR “Eviplast 80”[tw] OR “Vinicizer 80”[tw] OR “Vinycizer 80”[tw] OR “Vinycizer 80K”[tw] OR “Bisoflex 81”[tw] OR “Eviplast 81”[tw] OR “ESBO-D 82”[tw] OR “Codan Set L 86P”[tw] OR “Pittsburgh PX 138”[tw] OR “Sicol 150”[tw] OR “Hercoflex 260”[tw] OR “Good-rite GP 264”[tw] OR “Witcizer 312”[tw] OR “Corflex 400”[tw] OR “Compound 889”[tw] OR “Scandinol SC 1000”[tw] OR “3315AF2”[tw] OR “Sansocizer R 8000”[tw]) AND (2014/08/01:3000[crdat] OR 2014/08/01:3000[edat])) NOT medline[sb])
Toxline
9/2016 | (117-81-7 [rn] OR “2-ethylhexyl phthalate” OR “3315af2” OR “bis ( 2-ethylhexyl ) 1 2-“ethyl hexyl phthalate” OR “ethylhexyl phthalate” OR “eviplast 80” OR “eviplast 81” OR “fleximel” OR “flexol dod” OR “flexol dop” OR “flexol plasticizer dop” OR “garbeflex dop-d 40” OR “good-rite gp 264” OR “hatco dop” OR “hatcol dop” OR “hercoflex 260” OR “jayflex dop” OR “kodaflex dop” OR “mollan o” OR “monocizer dop” OR “nuoplaz dop” OR “octoil” OR “octyl phthalate” OR “px-138” OR “palatinol ah” OR “palatinol ah-l” OR “palatinol dop” OR “phthalic acid di ( 2-ethylhexyl ) ester” OR “phthalic acid dioctyl ester” OR “pittsburgh px 138” OR “plasthall dop” OR “platinol ah” OR “platinol dop” OR “rc plasticizer dop” OR “reomol d 79p” OR “reomol dop” OR “sansocizer dop” OR “sansocizer r 8000” OR “scandinol sc 1000” OR “sconamoll dop” OR “sicol 150” OR “staflex dop” OR “truflex dop” OR “vestinol ah” OR “vinicizer 80” OR “vinycizer 80” OR “vinycizer 80k” OR “witcizer 312” OR “zs plasticizer” OR “dof plasticizer” ) AND 2014:2016 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]
Toxcenter
9/2016 | FILE ‘TOXCENTER’ ENTERED AT 12:14:23 ON 26 SEP 2016 CHARGED TO COST=EH011.11.LB.01.01; L1 12228 SEA 117-81-7; L2 11971 SEA L1 NOT TSCATS/FS L3 10697 SEA L2 NOT PATENT/DT L4 1507 SEA L3 AND ED>=20140101; ACT TOXQUERY/Q; ---------; L5 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L6 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L7 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L8 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L9 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L10 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L11 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS; OR; DIETARY OR DRINKING(W)WATER?); L12 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L13 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L14 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM?; OR; OVUM?); L15 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L16 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L17 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR; SPERMATOC? OR SPERMATOG?); L18 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR; SPERMATU? OR SPERMI? OR SPERMO?); L19 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L20 QUE (ENDOCRIN? AND DISRUPT?); L21 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L22 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L23 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L24 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER?; OR; NEOPLAS?); L25 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L26 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L27 QUE (NEPHROTOX? OR HEPATOTOX?); L28 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L29 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L30 QUE L5 OR L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29; L31 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE; OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR; SWINE; OR PORCINE OR MONKEY? OR MACAQUE?); L32 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA; OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L33 QUE L30 OR L31 OR L32; L34 QUE (NONHUMAN MAMMALS)/ORGN; L35 QUE L33 OR L34; L36 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL?; OR; PRIMATES OR PRIMATE?); L37 QUE L35 OR L36; ---------; L38 1092 SEA L4 AND L30; L39 976 SEA L38 AND PY>=2014; L40 218 SEA L38 AND MEDLINE/FS; L41 277 SEA L38 AND BIOSIS/FS; L42 597 SEA L38 AND CAPLUS/FS; L43 0 SEA L38 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L44 803 DUP REM L40 L41 L43 L42 (289 DUPLICATES REMOVED); L*** DEL 218 S L38 AND MEDLINE/FS; L*** DEL 218 S L38 AND MEDLINE/FS L45 218 SEA L44; L*** DEL 277 S L38 AND BIOSIS/FS; L*** DEL 277 S L38 AND BIOSIS/FS L46 181 SEA L44; L*** DEL 597 S L38 AND CAPLUS/FS; L*** DEL 597 S L38 AND CAPLUS/FS L47 404 SEA L44; L48 585 SEA (L45 OR L46 OR L47) NOT MEDLINE/FS; SAVE TEMP L48 DEHP/A; D SCAN L48

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS ^a^
9/2016 | Compounds searched: 117-81-7
NTP
9/2016 | “117-81-7” OR “2-ethylhexyl phthalate” OR “bis(2-ethylhexyl)1,2-benzenedicarboxylate” OR “bis(2-ethylhexyl)o-phthalate” OR “bis(2-ethylhexyl)phthalate” OR “bis(2-ethylhexyl)phthalate” OR ”dehp” OR “di(2-ethylhexyl)orthophthalate” OR “di(2-ethylhexyl) phthalate” OR “di(2-ethylhexyl)orthophthalate” OR “di(2-ethylhexyl) phthalate” OR “di(isooctyl)phthalate” OR “di-(2-ethylhexyl)phthalate” OR “di-2-ethylhexyl phthalate” OR “di-2-ethylhexylphthalate” OR “di-sec-octyl phthalate” OR “diethylhexyl phthalate” OR “dioctyl phthalate” OR “ethyl hexyl phthalate” OR “ethylhexyl phthalate” OR “octyl phthalate” OR “phthalic acid di(2-ethylhexyl) ester” OR “phthalic acid dioctyl ester” (limited to 2010–2016 and NOT dated)
NIH RePORTER
2/2017 | “1,2-Benzenedicarboxylic acid, 1,2-bis(2-ethylhexyl) ester” OR “1,2-Benzenedicarboxylic acid, bis(2-ethylhexyl) ester” OR “2-Ethylhexyl phthalate” OR “Bis(2-ethylhexyl) 1,2-benzenedicarboxylate” OR “Bis(2-ethylhexyl) o-phthalate” OR “Bis(2-ethylhexyl) phthalate” OR “Bis(2-ethylhexyl)phthalate” OR “DEHP” OR “Di(2-ethylhexyl) orthophthalate” OR “Di(2-ethylhexyl) phthalate” OR “Di-(2-ethylhexyl) phthalate” OR “Di(2-ethylhexyl)orthophthalate” OR “Di(2-ethylhexyl)phthalate” OR “Di(isooctyl) phthalate” OR “Di-2-ethylhexyl phthalate” OR “Di-2-ethylhexylphthalate” OR “Diethylhexyl phthalate” OR “Dioctyl phthalate” OR “Di-sec-octyl phthalate” OR “Ethyl hexyl phthalate” OR “Ethylhexyl phthalate” OR “Octyl phthalate” OR “Phthalic acid di(2-ethylhexyl) ester” OR “Phthalic acid dioctyl ester” OR “Phthalic acid, bis(2-ethylhexyl) ester”) OR (“DOF plasticizer” OR “Bisoflex DOP” OR “Celluflex DOP” OR “Diacizer DOP” OR “Diplast O” OR “Ergoplast FDO” OR “Ergoplast FDO-S” OR “Fleximel” OR “Flexol DOD” OR “Flexol DOP” OR “Flexol Plasticizer DOP” OR “Hatco DOP” OR “Hatcol DOP” OR “Jayflex DOP” OR “Kodaflex DEHP” OR “Kodaflex DOP” OR “Mollan O” OR “Monocizer DOP” OR “Nuoplaz DOP” OR “Octoil” OR “Palatinol AH” OR “Palatinol AH-L” OR “Palatinol DOP” OR “Plasthall DOP” OR “Platinol AH” OR “Platinol DOP” OR “RC Plasticizer DOP” OR “Reomol DOP” OR “Sansocizer DOP” OR “Sconamoll DOP” OR “Staflex DOP” OR “Truflex DOP” OR “Vestinol AH” OR “ZS plasticizer” OR “PX-138” OR “Garbeflex DOP-D 40” OR “Reomol D 79P” OR “Eviplast 80” OR “Vinicizer 80” OR “Vinycizer 80” OR “Vinycizer 80K” OR “Bisoflex 81” OR “Eviplast 81” OR “ESBO-D 82” OR “Codan Set L 86P” OR “Pittsburgh PX 138” OR “Sicol 150” OR “Hercoflex 260” OR “Good-rite GP 264” OR “Witcizer 312” OR “Corflex 400” OR “Compound 889” OR “Scandinol SC 1000” OR “3315AF2” OR “Sansocizer R 8000” (Advanced), Search in: Projects Admin IC: All, Fiscal Year: Active Projects, 2017, 2016, 2015, 2014, 2013, 2012
Other | Identified throughout the assessment process

a Several versions of the TSCATS database were searched, as needed, by CASRN including TSCATS1 via Toxline (no date limit), TSCATS2 via https://yosemite.epa.gov/oppts/epatscat8.nsf/ReportSearch?OpenForm (date restricted by EPA receipt date), and TSCATS via CDAT (date restricted by ‘Mail Received Date Range’), as well as google for recent TSCA submissions.

The 2020 results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 1,578
- Number of records identified from other strategies: 80
- Total number of records to undergo literature screening: 1,658

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on DEHP:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 1,648
- Number of studies considered relevant and moved to the next step: 618

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 618
- Number of studies cited in the pre-public draft of the toxicological profile: 786
- Total number of studies cited in the profile: 1,064

Prioritization of Human Data. The epidemiological database for DEHP is extensive, but is largely focused on a small number of endpoints: body weight (BMI and waist circumference), cardiovascular (blood pressure), hepatic (serum lipids), endocrine (diabetes), immunological (allergy and asthma), and reproductive and developmental endpoints. For endpoints with few epidemiological studies (e.g., respiratory, hepatic effects other than serum lipids, hematological, neurological, and cancer), all relevant human data were considered. For the data-rich endpoints, a series of inclusion criteria were defined to facilitate the selection of human studies of greater utility in assessing the hazards of DEHP, and only studies meeting the criteria were included in the Toxicological Profile. The criteria are shown below, and Table B-4 summarizes how the criteria were applied to the available epidemiological data by health outcome.

- Exposure was assessed by analysis of a biomarker, and the levels of exposure were reported in the study; studies using indirect exposure assessment such as job-exposure matrix or proximity to sources of phthalate exposure such as flooring were not included, nor were those in which exposure levels were not reported.
- The biomarker used to assess exposure was the concentration(s) of one, or all, of the following metabolites in urine: MEHP, MEHHP, MEOHP, MECPP^1^ (the metabolites included in the CDC’s National Biomonitoring Program [see Section 3.1.3] and those most commonly reported in the available studies), or the summed concentrations of these metabolites. Studies using concentrations of DEHP or its metabolites in blood/serum, amniotic fluid, cord blood, breast milk, semen, or other biological fluids were not included. As discussed in detail in Section 3.3.1 (Biomarkers of Exposure), urinary metabolite levels are considered the optimal biomarkers of exposure to DEHP, for several important reasons (Calafat et al. 2015; Johns et al. 2016):
  ○ urine samples are the least invasive samples to obtain, improving participation in efforts to assess exposure;
  ○ urine samples are typically of larger volume than those of other biological fluids, facilitating detection of metabolites;
  ○ the concentration of DEHP metabolites in urine is higher than that of DEHP or its metabolites in other biological fluids, leading to fewer samples below the limit of detection;
  ○ enzymes present in blood, milk, amniotic fluid, etc., but not in urine, are known to hydrolyze DEHP to its monoester during sample storage, leading to underestimates of DEHP levels; and,
  ○ the potential for sample contamination by the parent diester and subsequent formation of metabolites is reduced in urine due to lack of metabolic enzymes.
  1 Two recent studies (Bloom et al. 2015a, 2015b and Valvi et al. 2015) included another metabolite of DEHP (MCMHP), but there were too few studies of this metabolite to warrant its inclusion.
- In addition, studies that analyzed exposure as the sum of high molecular weight phthalates that included DEHP as well as others such as butyl benzyl phthalate were not considered, as the effects attributable to DEHP itself could not be determined from such analyses.
- The statistical analysis of the association was multivariate, with consideration of at least one potential covariate. Studies limited to bivariate analyses (i.e., Pearson or Spearman correlation coefficients) were not included, nor were studies in which the analysis was limited to a comparison between urinary metabolite concentrations in cases and controls.
- The health outcomes evaluated in the study were not mechanistic in nature (e.g., oxidative stress) or nonspecific (e.g., nonspecific markers of inflammation).

Table B-4 Application of Selection Criteria to Epidemiological Data by Health Outcome

Outcome | Selection process
Death | All studies included
Body weight | Systematic review used for studies up through 2012; criteria applied to studies published from 2012 to 2020.
Respiratory | All studies included
Cardiovascular | Blood pressure: criteria applied
| Endpoints other than blood pressure: all studies included
Gastrointestinal | All studies included
Hematological | All studies included
Musculoskeletal | No studies identified
Hepatic | Serum triglycerides and cholesterol: criteria applied; Other endpoints: all studies included
Renal | All studies included
Dermal | All studies included
Ocular | No studies identified
Endocrine | Thyroid: criteria applied
| Endpoints other than thyroid: all studies included
Immunological | Allergy and asthma endpoints: criteria applied
| Nonspecific inflammatory markers: not included
Neurological | All studies included
Reproductive | Criteria applied
Developmental | Criteria applied
Other noncancer | Criteria applied (diabetes/altered glucose homeostasis)
Cancer | All studies included

In addition, for health outcomes with robust databases that included cohort as well as case-control or cross-sectional studies, only those studies in which exposure was measured prior to outcome determination (cohort studies) were included. For endpoints with fewer studies, all study designs were considered.

Prioritization of Animal Data. All inhalation studies were retained (small database); however, the full text review process returned a large database of oral animal studies. Therefore, the oral animal data were prioritized for efficient review. Studies were excluded from Chapter 2 if the design and/or reporting were inadequate to inform hazard identification, dose-response assessment, or derivation of MRLs. Studies were excluded from Chapter 2 based on the following criteria:

- Acute- and intermediate-duration single-dose studies were excluded when there was adequate information from multi-dose studies for the examined endpoints. All chronic studies, primate studies, and studies that filled data gaps were retained regardless of number of dose groups. Lethality data were retained from all studies.
- Only studies that evaluated at least one dose <100 mg/kg/day were included for acute- and intermediate-duration reproductive/developmental studies (reproductive/developmental effects have been consistently observed in numerous studies at doses <100 mg/kg/day). All chronic studies, primate studies, and studies that filled data gaps in developmental health effect categories (e.g., developmental cardiovascular effects) were retained regardless of dose. Lethality data were retained from all studies.
- Only acute- and intermediate-duration studies evaluating at least one dose <1,000 mg/kg/day were included for endpoints other than reproductive/developmental effects. All chronic studies, studies in primates, and studies that provide information for data poor health effect categories (e.g., lethality, cardiovascular, neurological) were retained regardless of dose. Lethality data were retained from all studies.
- Any oral studies with major design and/or reporting deficiencies were excluded.

Summary of Literature Search and Screening. A summary of the results of the literature search and screening for the DEHP profile is presented in Figure B-1.

Figure B-1 June 2020 Literature Search Results and Screen for DEHP

*Some cited studies fall into multiple categories (e.g., chemistry and toxicology).

Figure B-1 description