# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | DEHP
CAS Numbers: | 117-81-7
Date: | January 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL. The intermediate-duration MRL should be protective of acute inhalation exposures.

Rationale for Not Deriving an MRL: Only two acute inhalation studies were identified. Larsen et al. (2007) reported decreased tidal volume and increased respiratory rate in mice exposed to 19 ppm for 60 minutes; respiratory function was the only endpoint examined. The other available study was a developmental study by Merkle et al. (1988) that reported an increase in the percent of litters with visceral retardations following maternal exposure to 21 ppm on GDs 6–15; observed retardations were characterized as delays in development (not variations or anomalies). Incidence data were not provided for any specific lesions described as visceral retardations; however, the study authors indicated that effects were “mostly” renal pelvis dilation. These data are considered inadequate for MRL derivation due to limited reporting of lesion incidence, lack of fetus data for each litter (benchmark dose [BMD] modeling not advisable), and the fact that reported retardations may be developmental effects from multiple body systems (e.g., renal, reproductive, cardiovascular, etc.). In addition, no acute studies evaluated the most sensitive effects observed in intermediate-duration inhalation studies (immune effects, reproductive toxicity). These key data gaps preclude derivation of an acute-duration inhalation MRL; however, the intermediate-duration inhalation MRL should be protective of acute exposures.

Agency Contacts (Chemical Managers): Rae T. Benedict

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | DEHP
CAS Numbers: | 117-81-7
Date: | January 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL: | 0.0002 ppm
Critical Effect: | Altered reproductive system in developing males and females
Reference: | Kurahashi et al. 2005; Ma et al. 2006
Point of Departure: | LOAEL_HEC_ of 0.05 ppm
Uncertainty Factor: | 300
LSE Graph Key: | 4, 5, 6, 7
Species: | Rat

MRL Summary: An intermediate-duration inhalation MRL of 0.0002 ppm was derived for DEHP based on evidence of reproductive effects in developing male and female rats exposed to 0.3 ppm for 3–9 weeks (6 hours/day, 5 days/week) after weaning. Observed effects included increased plasma testosterone in young males prior to sexual development, increased plasma testosterone and seminal vesicle weight in sexually mature males, and accelerated vaginal opening and first estrous in females (Kurahashi et al. 2005; Ma et al. 2006). The MRL is based on the LOAELHEC (adjusted for continuous exposure) of 0.05 ppm and a total uncertainty factor of 300 (3 for extrapolation from animals to humans after dosimetric adjustment, 10 for human variability, and 10 for use of a LOAEL).

Selection of the Critical Effect and Principal Study: Available data indicate that the immunological and developing reproductive systems are the most sensitive following intermediate-duration inhalation exposure to DEHP (Table A-1). While inhalation data are limited, these endpoints have been identified as sensitive targets of oral DEHP exposure (see oral MRL worksheets). BMD modeling was attempted for developmental endpoints reported by Ma et al. (2006) and Kurahashi et al. (2005); however, data were not amenable to modeling (no adequate models identified). Data from Larsen et al. (2007) were not modeled because exact animal numbers/group were not reported. After review of the available data, the developmental effects on the male and female reproductive system were selected as the critical effect because: (1) the study design for the immunological study is a poor model of intermediate-duration exposure since animals were only exposed once per week after the initial 2 weeks (and only 20 minutes/day, 5 days/week for the first 2 weeks, and (2) it is unclear whether an MRL based on the NOAEL of 0.11 ppm for immune effects in sensitized animals would be protective of developmental effects since a developmental NOAEL was not identified (i.e., developmental effects could potentially occur at 0.11 ppm). The developmental studies by Kurahashi et al. (2005) and Ma et al. (2006) were selected as co-principal studies.

Table A-1 Summary of Candidate POD Values for Intermediate Inhalation MRL for DEHP

Species | Duration | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference
Immune effects
BALB/c mouse | 14 weeks (20 minutes/day, 5 days/week for 2 weeks plus 1 day/week for 12 weeks) | 0.11 | 0.81 | Enhanced immune response to OVA challenge in sensitized animals | Larsen et al. 2007
Developmental effects
Wistar rat | PNWs 3–6 or 3–12 (6 hours/day, 5 days/week) | ND | 0.3a | Accelerated vaginal opening and first estrous | Ma et al. 2006
Wistar rat | PNWs 4–8 or 4–12 (6 hours/day, 5 days/week) | ND | 0.3a | Increased plasma testosterone (both time points); increased seminal vesicle weight (PNW 12 only) | Kurahashi et al. 2005

a Selected POD.

DEHP = di(2-ethylhexyl)phthalate; LOAEL = lowest-observed-adverse-effect level; MRL = Minimal Risk Level; NOAEL = no-observed-adverse-effect level; ND = not determined; OVA = ovalbumin; PNW = postnatal week; POD = point of departure

Summary of the Principal Studies:

Kurahashi N, Kondo T, Omura M, 2005. The effects of subacute inhalation of di(2-ethylhexyl)phthalate (DEHP) on the testes of prepubertal Wistar rats. J Occup Health 47(5):437–444.16230838

Ma M, Kondo T, Ban S, 2006. Exposure of prepubertal female rats to inhaled di(2-ethylhexyl)phthalate affects the onset of puberty and postpubertal reproductive functions. Toxicol Sci 93(1):164–171.16763069

Kurahashi et al. (2005) exposed groups of PND 28 prepubertal male rats to DEHP vapor for 4 or 8 weeks (6 hours/day, 5 days/week) at concentrations of 0, 5, or 25 mg/m^3^ (0, 0.3, or 1.6 ppm). At sacrifice on PND 56 (around the time of sexual maturation) or PND 84 (sexually mature), body weight was recorded, and blood was collected for determination of plasma testosterone, LH, and FSH. Testes, epididymides, seminal vesicles, and ventral prostate were removed and weighed. One testis was examined for histopathologic changes, and the other testis was evaluated for mRNA expression of androgen biosynthesis enzyme, cytochrome P450scc, 3βHSD, CYP17, and CYP19.

No statistically significant, exposure-related changes in body weight were observed. The only statistically significant reproductive organ weight change was a 30–31% increase in relative seminal vesicle weights in exposed groups at 8 weeks. Plasma testosterone was increased by approximately 2- to 4-fold in the low- and high-exposure groups at both timepoints, compared with respective controls. The increase was significant at both exposure levels after 8 weeks, but only at the low exposure level after 4 weeks. No exposure-related changes were observed in plasma LH or FSH or mRNA expression levels at 4 or 8 weeks. No exposure-related histopathological changes in the testes were observed at either time point.

Ma et al. (2006) exposed groups of PND 21 prepubertal female rats to DEHP vapor for 3 or 9 weeks (6 hours/day, 5 days/week) at concentrations of 0, 5, or 25 mg/m^3^ (0, 0.3, or 1.6 ppm). Food and water intake were measured. Body weight and vaginal opening were monitored daily. Beginning on the day of vaginal opening, vaginal smears were examined until the first estrous cycle was completed; the age at first estrus was recorded. For the group exposed for 3 weeks, vaginal smears were collected again just prior to necropsy on PND 42. For the group exposed for 9 weeks, estrous cyclicity was evaluated from PND 49 to 84, and animals were sacrificed on PNDs 84–85. Blood was collected at necropsy for determination of FSH, LH, estradiol, testosterone, and cholesterol levels. Lungs, liver, kidneys, ovaries, and uterus were removed and weighed. The vagina, right ovary, and uterus were prepared for histology. Left ovaries were removed, and RNA was extracted for reverse transcription polymerase chain reaction (RT-PCR) analysis of the genes encoding enzymes responsible for estradiol biosynthesis.

No clinical signs of toxicity were observed. Body weights were significantly decreased by ∼10–15% by the end of the 9-week exposure period in the high-exposure group; however, body weights at vaginal opening and first estrus were comparable to controls in all exposed groups. Mean age at vaginal opening and first estrus were significantly earlier in both exposed groups by 2.3–2.8 days in the 3-week experiment and 1.7–2.9 days in the 9-week experiment, compared with respective controls. In the 9-week experiment, the number of irregular estrous cycles was significantly elevated in the high-exposure group (25/61) compared with the control group (12/72). Serum LH and estradiol were significantly elevated by ∼1.5–3-fold at the high exposure level following 3-week exposure, compared with controls; however, no exposure-related changes were observed in serum hormone levels following exposure for 9 weeks. Serum cholesterol was significantly elevated by 18–25% in both exposure groups at both time points, compared with controls. No exposure-related changes in organ weights were observed; histology data were not reported. The only exposure-related change in estradiol biosynthesis genes was a 145% increase in the mRNA level of CYP19 in the high-exposure group after 9 weeks, compared with controls.

Selection of the Point of Departure: The LOAEL of 5 mg/m^3^ (0.3 ppm) for male and female developmental reproductive effects was selected as the POD for the intermediate-duration inhalation MRL.

Calculations: Exposure levels of 0, 5, and 25 mg/m^3^ were converted to concentrations of 0, 0.3, and 1.6 ppm using a molecular weight of 390.57 g/mol, assuming 25 °C and 1 atmosphere (1 ppm=15.94 mg/m^3^).

Adjustment for Intermittent Exposure: The LOAEL of 0.3 ppm was adjusted from intermittent exposure to account for a continuous exposure scenario:

- LOAEL_ADJ_ = LOAEL of 0.3 ppm × (6 hours/24 hours) × (5 days/7 days) = 0.05 ppm

Human Equivalent Concentration: A PBPK modeling approach was initially considered to calculate a human equivalent to the rat BMCL_ADJ_. However, a PBPK modeling approach was rejected due to a lack of experimental data regarding the proper dose metric (proximate toxicant) for DEHP-induced developmental toxicity. A human equivalent concentration (HEC) was calculated by multiplying the duration-adjusted LOAEL by the regional gas dose ratio (RGDR). The RGDR for extrarespiratory tract effects is the ratio of animal to human blood:gas partition coefficients.

- LOAEL_HEC_ = LOAEL_ADJ_ × RGDR_ER_
- LOAEL_HEC_ = LOAEL_ADJ_ × ([H_b/g_]_A_/[H_b/g_]_H_)

[H_b/g_]_A_ = animal blood/air partition coefficient

[H_b/g_]_H_ = human blood/air partition coefficient

A default value of 1 is used for the ratio of blood/air partition coefficients because the DEHP values are unknown.

- LOAEL_HEC_ = 0.05 ppm × 1 = 0.05 ppm

Uncertainty Factor: The LOAEL_HEC_ is divided by a total uncertainty factor of 300:

- 10 for use of a LOAEL
- 10 for human variability
- 3 for extrapolation from animals to humans after dosimetric adjustment
  - MRL = LOAEL_HEC_ ÷ UFs
  - MRL = 0.05 ppm ÷ (3 × 10 × 10) = 0.0002 ppm (0.003 mg/m^3^)

Other Additional Studies or Pertinent Information: No other inhalation studies evaluated these developmental reproductive endpoints following exposure to DEHP; however, Klimisch et al. (1991, 1992) did not observe impaired male fertility or testicular lesions in Wistar rats following exposure to concentrations up to 63 ppm for 4 weeks during adulthood. Evidence from oral studies indicates that both the developing and adult reproductive systems are a sensitive target of DEHP toxicity in rodents. In sexually immature males, the lowest identified LOAEL was associated with potentially transient changes in reproductive organ weight and sperm parameters in mouse offspring at maternal doses of 0.05 mg/kg/day (Pocar et al. 2012), with evidence for severe and permanent reproductive tract malformations and lesions in rat offspring at maternal doses of 3–10 mg/kg/day (Arcadi et al. 1998; Christiansen et al. 2010; Klinefelter et al. 2012; Lin et al. 2008, 2009; Vo et al. 2009b). In sexually mature male rodents, the lowest identified LOAELs include various effects on the male reproductive system at oral doses of 10 mg/kg/day, including altered serum hormones, decreased Leydig cell hormone production, and Leydig cell proliferation (Akingbemi et al. 2004; Guo et al. 2013; Li et al. 2012a). In females, the lowest identified LOAELs include delayed meiotic progression of germ cells and accelerated folliculogenesis in mouse offspring at maternal doses of 0.04 mg/kg/day (Zhang et al. 2015) and evidence for decreased quality and fertilization rate of mouse oocytes following pre-mating exposure to ≥0.2 mg/kg/day (Parra-Forero et al. 2019).

Epidemiological studies show potential associations between altered male reproductive development (cryptorchidism, hypospadias, hydrocele, and/or AGD) and maternal DEHP exposure (Barrett et al. 2016; Sathyanarayana et al. 2016b; Suzuki et al. 2012; Swan 2008; Wenzel et al. 2018). Epidemiological studies also suggest that DEHP exposure may be associated with alterations in adult male reproductive endpoints, including decreased serum testosterone (Chang et al. 2015; Joensen et al. 2012; Jurewicz et al. 2013; Meeker et al. 2009b; Pan et al. 2006; Wang et al. 2016) and reduced sperm motility and/or concentration (Axelsson et al. 2015; Bloom et al. 2015a, 2015b; Huang et al. 2014b; Jurewicz et al. 2013).

In a systematic review, NAS (2017) concluded that DEHP is presumed to be a reproductive hazard to humans based on evidence integration of the animal and the human evidence on DEHP and effects on AGD and fetal testosterone. DEHP is also suspected to be a reproductive hazard to humans based on evidence integration of the animal evidence and the human evidence on DEHP and fetal hypospadias (NAS 2017).

Agency Contacts (Chemical Managers): Rae T. Benedict

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | DEHP
CAS Numbers: | 117-81-7
Date: | January 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: No chronic-duration studies examining noncarcinogenic effects following inhalation exposure were identified.

Agency Contacts (Chemical Managers): Rae T. Benedict

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | DEHP
CAS Numbers: | 117-81-7
Date: | January 2022
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL: | 0.003 mg/kg/day
Critical Effect: | Altered glucose homeostasis in adult offspring following fetal exposure
Reference: | Rajesh and Balasubramanian 2014a
Point of Departure: | LOAEL of 1 mg/kg/day
Uncertainty Factor: | 300
LSE Graph Key: | 38
Species: | Rat

MRL Summary: An acute-duration oral MRL of 0.003 mg/kg/day was derived for DEHP based on evidence of altered glucose homeostasis in adult rat offspring following maternal exposure to DEHP via gavage on GDs 9–21, including elevated serum glucose, decreased serum insulin, altered glucose and insulin tolerance, reduced insulin receptors, and reduced glucose uptake and oxidation in skeletal muscle (Rajesh and Balasubramanian 2014). These effects were observed at all tested doses (≥1 mg/kg/day). The MRL is based on the LOAEL of 1 mg/kg/day for altered glucose homeostasis following developmental exposure and a total uncertainty factor of 300 (10 for use of a LOAEL, 3 for human variability, and 10 for extrapolation from animals to humans).

Selection of the Critical Effect: Numerous studies have evaluated the toxicity of DEHP following acute oral exposure. The most sensitive effects identified in acute oral studies included neurodevelopmental effects and altered glucose homeostasis in offspring following developmental exposure (Table A-2). Other effects, including alterations in the developing and adult male reproductive system, were not observed until much higher doses (Table A-2). Although neurodevelopmental effects were observed at the lowest identified LOAEL (0.2 mg/kg/day), support for neurodevelopmental effects following acute oral exposure is inconsistent. In particular, findings regarding anxiety following oral exposure to DEHP in rodents are mixed, with some studies reporting increased anxiety (Barakat et al. 2018; Carbone et al. 2013; Liu et al. 2018b) and others reporting decreased anxiety (Feng et al. 2020). Additionally, Barakat et al. (2018) reported increased anxiety in an open field test at ≥0.2 mg/kg/day (based on decreased time spent in the center of the open field), but they did not observe elevated anxiety in the elevated plus maze until maternal doses of 750 mg/kg/day. Due to the discrepancies in the anxiety endpoint, ATSDR did not further consider this as a critical effect. Therefore, the next most sensitive effect (altered glucose homeostasis in offspring at 1 mg/kg/day) was selected as the critical effect.

Table A-2 Summary of Candidate Lowest LOAELs for Acute-Duration Oral Exposure to DEHP

Species | Duration (route) | NOAEL/LOAEL (mg/kg/day) | | System: effect | Reference
Species | Duration (route) | NOAEL | LOAEL | System: effect | Reference
CD-1 mouse | 10 days [GD 11–PND 0] (IN) | ND | 0.2 | Developmental: increased anxiety in adult offspring | Barakat et al. 2018
Wistar rat | 13 days [GDs 9–21] (GO) | ND | 1^a^ | Developmental: altered glucose homeostasis in adult offspring | Rajesh and Balasu-bramanian 2014
Long-Evans rat | 14 days [PNDs 35–48] (GO) | 1 | 10 | Developmental: reduced testosterone production in Leydig cells | Akingbemi et al. 2001
Sprague-Dawley rat | 7 days [GDs 13–19] (GO) | ND | 10 | Developmental: Leydig cell clustering in fetal testes | Klinefelter et al. 2012
Sprague-Dawley rat | 11 days [GDs 11–21] (GO) | ND | 10 | Developmental: sperm effects at PND 63 | Vo et al. 2009a
Long-Evans rat | 14 days (GO) | ND | 10 | Reproductive: increased Leydig cell number and proliferation | Li et al. 2012a
Long-Evans rat | 7–11 days (GO) | ND | 10 | Reproductive: increased Leydig cell proliferation | Guo et al. 2013

a Selected POD.

DEHP = di(2-ethylhexyl)phthalate; GD = gestation day; (GO) = gavage in oil vehicle; (IN) = ingestion; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; NA = not applicable (data unsuitable for modeling); ND = not determined; PND = postnatal day; POD = point of departure

Selection of the Principal Study: The acute oral study with the lowest identified POD for the critical effect of altered glucose homeostasis in offspring (Rajesh and Balasubramanian 2014) was selected as the principal study for the acute oral MRL.

Summary of the Principal Study:

Rajesh P, Balasubramanian K. 2014. Phthalate exposure in utero causes epigenetic changes and impairs insulin signalling. J Endocrinol 223(1):47–66.25232145

Groups of pregnant Wistar rats (6/group) were administered DEHP at doses of 0, 1, 10, or 100 mg/kg/day via gavage in olive oil from GD 9 to 21 or until parturition. Litters were culled to 4/sex (day of culling not reported). Oral glucose tolerance and insulin tolerance tests were conducted in adult PND 60 offspring. Offspring were sacrificed around PND 60 (females were in diestrus phase). Body and visceral adipose weights were recorded. Blood was collected for analysis of serum glucose and insulin. Skeletal muscle was collected for analysis of genes and proteins involved in insulin signaling (RT-PCR, Western blot), DNA methylation, and evaluation of insulin receptors and glucose uptake and oxidation.

F1 male body weight was significantly reduced on PND 60 by 4, 12, and 19% at 1, 10, and 100 mg/kg/day, respectively, compared with control. F1 female body weight was similarly reduced by 8, 17, and 21%, respectively. In contrast, fat weight was significantly elevated in all dose groups, compared with control, by 2–7%. Fasting blood glucose was significantly elevated in both F1 males and females in all dose groups by 16–49%, compared with control. Both insulin and insulin binding protein levels were significantly decreased in all dose groups by 21–70 and 13–36%, respectively. Elevated serum glucose levels were observed in both the glucose and insulin challenges. Additional significant findings observed in all dose groups included decreased glycogen content and decreased insulin binding, glucose uptake, and glucose oxidation in skeletal muscle. Several genes/proteins involved in insulin signaling were dysregulated. Key findings included decreased glucose transporter 4 (GLU4) gene expression, increased GLU4 phosphorylation (posttranslational modification that decreases activity), and epigenetic silencing of GLU4.

Selection of the Point of Departure: In order to identify the most sensitive POD, BMD modeling was attempted for the 11 measures of glucose homeostasis that were altered in offspring following exposure to ≥1 mg/kg/day (Rajesh and Balasubramanian 2014). The data were fit to all available continuous models in EPA’s Benchmark Dose Software (BMDS, version 2.6.0) using a BMR of 1 SD. Adequate model fit was judged by three criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined BMR. Adequate fit was achieved based on goodness-of-fit statistics for some of the available data sets from the Rajesh and Balasubramanian (2014) study; however, upon visual inspection, the models were highly influenced by the last dose, forcing model fit when there normally would be none (graphs available upon request). Dropping the highest dose from the female glucose oxidation data (the most sensitive endpoint) resulted in questionable or unusable models. Because the data were not amenable to modeling, the LOAEL of 1 mg/kg/day for altered glucose homeostasis in adult rat offspring was selected as the basis of the MRL.

Adjustment for Intermittent Exposure: Not applicable.

Uncertainty Factor: The LOAEL is divided by a total uncertainty factor of 300:

- 10 for use of a LOAEL
- 3 for human variability; a full factor of 10 was not warranted because the study population (F1 offspring exposed in utero) is considered a susceptible subpopulation since offspring are not fully developed until after puberty (or later)
- 10 for extrapolation from animals to humans
  - MRL = LOAEL ÷ UFs
  - MRL = 1 mg/kg/day ÷ (10 × 3 × 10) = 0.003 mg/kg/day

Other Additional Studies or Pertinent Information: Altered glucose homeostasis was observed in several developmental rat studies following gestation plus lactation, lactation-only, or early post-weaning exposure to DEHP (Lin et al. 2011; Mangala Priya et al. 2014; Parsanathan et al. 2019; Rajagopal et al. 2019a; Venturelli et al. 2015, 2019). Consistent with the gestation-only study by Rajesh and Balasubramanian (2014), the lowest identified LOAEL for these other studies was also 1 mg/kg/day (Mangala Priya et al. 2014; Venturelli et al. 2015). In the gestation plus lactation study, no changes in maternal rat serum insulin or blood glucose levels were observed at doses up to 6.25 mg/kg/day, indicating that developing offspring may be more susceptible to pancreatic toxicity (Lin et al. 2011). In intermediate-duration mouse studies, metabolic syndrome (including abnormal glucose metabolism) was observed in offspring following maternal exposure to ≥0.2 mg/kg/day from 7 days premating through PND 0 (Fan et al. 2020) or ≥0.05 mg/kg/day from GD 1 to 19 (Gu et al. 2016).

In adult rats, altered glucose homeostasis was also observed following intermediate-duration exposure to doses ≥5 mg/kg/day (Aydemir et al. 2018; Rajesh et al. 2013; Xu et al. 2018; Zhang et al. 2017). In adult mice, altered glucose homeostasis was only observed at much higher doses of 2,000 mg/kg/day for acute exposure and ≥180 mg/kg/day for intermediate-duration exposure (Ding et al. 2019; Lee et al. 2019a; Li et al. 2018).

Epidemiological studies suggest a potential association between impaired glucose homeostasis and DEHP exposure in adult humans, with reported associations between increased fasting serum glucose and/or insulin resistance and higher levels of DEHP metabolites in urine in eleven of thirteen studies (see Section 2.18 for references). In children and adolescents, findings are inconsistent, with reported associations between increased fasting serum glucose and/or insulin resistance and higher levels of DEHP metabolites in urine in some studies (Han et al. 2019; Kim et al. 2018a), but not others (Chen et al. 2017; Watkins et al. 2016).

Agency Contacts (Chemical Managers): Rae T. Benedict

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | DEHP
CAS Numbers: | 117-81-7
Date: | January 2022
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.0001 mg/kg/day
Critical Effect: | Delayed meiotic progression of germ cells in GD 17.5 F1 fetuss; accelerated folliculogenesis in F1 and F2 PND 21 offspring
Reference: | Zhang et al. 2015
Point of Departure: | LOAEL of 0.04 mg/kg/day
Uncertainty Factor: | 300
LSE Graph Key: | 181
Species: | Mouse

MRL Summary: An intermediate-duration oral MRL of 0.0001 mg/kg/day was derived for DEHP based on evidence of altered female reproductive development in F1 and F2 mouse offspring following F0 maternal exposure to 0.04 mg/kg/day from GD 0.5 to 18.5, compared with controls. The MRL is based on the LOAEL of 0.04 mg/kg/day and a total uncertainty factor of 300 (10 for use of a LOAEL, 3 for human variability, and 10 for extrapolation from animals to humans).

Selection of the Critical Effect: Numerous studies have evaluated the toxicity of DEHP following intermediate-duration oral exposure. The most sensitive effects identified in intermediate oral studies were observed at 0.03–0.05 mg/kg/day (Table A-3). Observed effects included immune adjuvant effects, developmental effects (ovarian developmental deficiency, alterations in offspring body weight, metabolic syndrome, male reproductive effects), hepatic effects, and increased body weight and adiposity. While the immune alterations in sensitized animals were observed at the lowest dose, the human health relevance of findings from sensitized animals is uncertain in the absence of clear evidence that the immune system is a target of DEHP toxicity in humans or unsensitized animals. Therefore, immune effects reported by Guo et al. (2012) and Han et al. (2014a) were not further considered as the basis for the intermediate-duration oral MRL. The next most sensitive effect was altered female reproductive development at 0.04 mg/kg/day (Zhang et al. 2015). Several additional developmental effects were observed at 0.05 mg/kg/day (Gu et al. 2016; Pocar et al. 2012; Schmidt et al. 2012). Therefore, developmental effects were selected as the critical effect for the derivation of the intermediate-duration oral MRL.

Table A-3 Summary of Lowest LOAELs for Intermediate-Duration Oral Exposure to DEHP

Species | Duration (route) | NOAEL/LOAEL (mg/kg/day) | | System: effect | Reference
Species | Duration (route) | NOAEL | LOAEL | System: effect | Reference
BALB/c mouse | 28 days (GO) | ND | 0.03 | Immunological: enhanced immune response to OVA challenge in sensitized animals | Han et al. 2014a
BALB/c mouse | 52 days (GS) | ND | 0.03 | Immunological: enhanced immune response to OVA challenge in sensitized animals | Guo et al. 2012
CD-1 mouse | 20 days [GDs 0.5–18.5] (NS) | ND | 0.04^a^ | Developmental: delayed meiotic progression of germ cells in ovaries of GD 17.5 F1 fetuses; accelerated folliculogenesis in F1 and F2 PND 21 offspring; Reproductive: 25% decrease in maternal serum estradiol | Zhang et al. 2015
C57bbl/6AJ mice | 19 days [GDs 1–19] (GO) | ND | 0.05 | Developmental: metabolic syndrome in PNW 9 offspring | Gu et al. 2016
Sprague-Dawley rat | 15 weeks (GO) | ND | 0.05 | Hepatic: vacuolar degeneration and inflammatory infiltration | Zhang et al. 2017
C3H/N mouse | 8 weeks [1 week premating– PND 21] (F) | ND | 0.05 | Body weight: ~18% increase in maternal body weight; Other noncancer: increased visceral adipose tissue and adipocyte hypertrophy | Schmidt et al. 2012
CD-1 mouse | 42 days [GD 0–PND 21] (F) | ND | 0.05 (serious LOAEL) | Developmental: >20% decrease in offspring body weight at PNDs 21 and 42; decrease in sperm count and viability; decrease in offspring seminal vesicle weight | Pocar et al. 2012
C3H/N mouse | 8 weeks [1 week premating– PND 21] (F) | ND | 0.05 (serious LOAEL) | Developmental: >20% increase in offspring body weight at PND 21, increased visceral adipose tissue | Schmidt et al. 2012

a Selected POD.

DEHP = di(2-ethylhexyl)phthalate; (F) = feed; (G) = gavage (Tween-80 and sterile water vehicle); GD = gestation day; (GO) = gavage (oil vehicle); (GS) = gavage (TWEEN 80 plus saline vehicle); LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level; NS = not specified (reported as “oral administration”); OVA = ovalbumin; PND = postnatal day; PNW = postnatal week; POD = point of departure

Selection of the Principal Study: The intermediate-duration oral study with the lowest identified developmental LOAEL (Zhang et al. 2015) was selected as the principal study for the intermediate oral MRL (Table A-3).

Summary of the Principal Study:

Zhang XF, Zhang T, Han Z, 2015. Transgenerational inheritance of ovarian development deficiency induced by maternal diethylhexyl phthalate exposure. Reprod Fertil Dev 27(8):1213–1221. 10.1071/rd14113.24919469

Groups of plug positive female CD-1 mice (5/group) were administered DEHP at 0 or 0.04 mg/kg/day from GD 0.5 to 18.5 in saline containing 0.1% dimethylsulfoxide (DMSO); exact method of oral administration was not reported. Serum estradiol levels in F0 dams were measured on GD 12.5. F0 dams were allowed to deliver naturally and rear their young. Select female F1 offspring were mated with unexposed males. Folliculogenesis was assessed in F1 and F2 female offspring at PND 21. In a second set of experiments following the same exposure protocol, pregnant F0 and F1 mice were sacrificed on GD 13.5 for sodium bisulfite sequencing of female germ cells or GD 17.5 for analysis of oocyte meiosis in female fetuses. Total mRNA was extracted from female fetal genital ridges, ovary, and oocytes for RT-PCR.

Estradiol levels in exposed F0 mice were significantly decreased by 25%, compared with controls. Fetal meiotic progression of female germs cells in the fetal mouse ovary was significantly delayed, with increased percentage of immature leptotene and zygotene and decreased percentage of more mature pachytene and diplotene oocytes in exposed fetuses, compared with controls. At GD 13.5, the meiosis-specific gene, Stra8, and its protein product were significantly reduced in exposed mice, and the gene was significantly more methylated. In PND 21 F1 offspring, altered folliculogenesis was observed, with rare follicles and large regions of germ-cell cysts; ovaries in control mice showed primarily primordial follicles. Further analysis showed accelerated folliculogenesis and premature ovary failure. The number of primordial follicles was significantly decreased, and the number of secondary follicles was significantly increased, in exposed PND 21 F1 and F2 females, compared with controls. Decreased expression of folliculogenesis-related genes (Cx43, Egr3, Tff1, and Ptgs2) was observed.

The only dose, 0.04 mg/kg/day, was identified as a developmental LOAEL for altered reproductive system development in F1 and F2 female mouse offspring. The decreased estradiol levels in F0 dams was not identified as a reproductive LOAEL because the biological significance is unknown in the absence of additional reproductive endpoint evaluation in F0 animals.

Selection of the Point of Departure: The LOAEL of 0.04 mg/kg/day for altered reproductive system development in F1 and F2 female mouse offspring was selected as the basis of the MRL. BMD modeling was not attempted for this dataset due to use of a single dose group.

Adjustment for Intermittent Exposure: Not applicable.

Uncertainty Factor: The LOAEL is divided by a total uncertainty factor of 300:

- 10 for use of a LOAEL
- 3 for human variability; a full factor of 10 was not warranted because the study population (offspring) is considered a susceptible subpopulation since offspring are not fully developed until after puberty (or later)
- 10 for extrapolation from animals to humans
  - MRL = LOAEL÷ UFs
  - MRL = 0.04 mg/kg/day ÷ (10 × 3 × 10) = 0.0001 mg/kg/day

Other Additional Studies or Pertinent Information: As shown in Table A-3, studies reported various developmental effects following exposure to oral doses of 0.04–0.05 mg/kg/day in intermediate-duration gestational and/or early postnatal studies, with some studies reporting serious effects at 0.05 mg/kg/day. None of these studies identified a NOAEL for developmental effects following intermediate-duration oral exposure. Additional higher-dose developmental studies also reported altered female reproductive system development following early-life exposure, including delayed puberty (vaginal opening) and increased number of tertiary atretic ovarian follicles at doses ≥70 mg/kg/day (Blystone et al. 2010; Grande et al. 2006, 2007; Nardelli et al. 2017; NTP 2005; Schilling et al. 1999, 2001; Venturelli et al. 2019). Other studies have reported delayed vaginal opening following developmental exposure to 5 mg/kg/day (Shao et al. 2019) or 250 mg/kg/day (lowest dose tested; Liu et al. 2018a). In males, evidence for severe and permanent reproductive tract malformations and lesions in rat offspring have been observed at maternal oral doses of 3–10 mg/kg/day (Arcadi et al. 1998; Christiansen et al. 2010; Klinefelter et al. 2012; Lin et al. 2008, 2009; Vo et al. 2009b). The sexually mature male and female reproductive systems are also targets of DEHP toxicity following intermediate exposure, with lowest identified LOAELs of 0.1 and 0.2 mg/kg/day, respectively (Hsu et al. 2016; Parra-Forero et al. 2019).

Epidemiological data on the potential association between early-life exposure and female reproductive system development are limited, and results are mixed. Early onset of puberty was associated with increased maternal urinary MEHP levels in one study (Watkins et al. 2014); however, delayed pubertal onset was associated with increased childhood urinary metabolite levels in another study (Wolff et al. 2014). Some human epidemiological studies suggest potential associations between maternal DEHP exposure and increased risk of male genital anomalies (Sathyanarayana et al. 2016b; Swan 2008), reduced AGD (Barrett et al. 2016; Suzuki et al. 2012; Swan 2008; Wenzel et al. 2018), and delayed puberty (Ferguson et al. 2014b) in male offspring; however, results were mixed.

In a systematic review, NAS (2017) concluded that DEHP is presumed to be a reproductive hazard to humans based on evidence integration of the animal and the human evidence on DEHP and effects on AGD and fetal testosterone. Based on evidence integration for hypospadias, NAS (2017) concluded that DEHP is suspected to be a reproductive hazard to humans based on moderate level of evidence in rats and inadequate evidence in humans for hypospadias following prenatal exposure to DEHP.

The MRL value is further supported by evidence of immune effects in OVA-sensitized rats at oral doses ≥0.03 mg/kg/day (Guo et al. 2012; Han et al. 2014a). An MRL based on these studies would be identical to the MRL derived using developmental data: the LOAEL of 0.03 mg/kg/day divided by an uncertainty factor of 300 (10 for use of a LOAEL, 3 for human variability [OVA-sensitized mice are susceptible population because they are considered a murine model of hypersensitivity diseases in humans], and 10 for extrapolation from animals to humans) yields an MRL of 0.0001 mg/kg/day.

Agency Contacts (Chemical Managers): Rae T. Benedict

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | DEHP
CAS Numbers: | 117-81-7
Date: | January 2022
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL.

Rationale for Not Deriving an MRL: Several chronic-duration studies were identified (Table A-4), but the lowest identified candidate POD values were several orders of magnitude greater than the POD used to derive the intermediate-duration MRL. Therefore, any MRL derived based on available chronic data would be higher than the derived intermediate MRL and may not be protective of developmental effects.

Table A-4 Summary of Lowest LOAELs for Chronic-Duration Oral Exposure to DEHP

Species | Duration (route) | NOAEL/LOAEL (mg/kg/day) | | System: effect | Reference
Species | Duration (route) | NOAEL | LOAEL | System: effect | Reference
SV/129 mouse | 22 months (F) | ND | 9.5 | Renal: mild glomerulonephritis, cell proliferation, proteinuria | Kamijo et al. 2007
Sprague-Dawley rat | 104 weeks (F) | ND | 14 | Reproductive: inhibition of spermatogenesis and general tubule atrophy (magnitude not reported) | Ganning et al. 1991
F344 rat | 104 weeks (F) | 5.8 | 29 | Reproductive: testicular toxicity (aspermatogenesis) | David et al. 2000a

DEHP = di(2-ethylhexyl)phthalate; (F) = feed; LOAEL 9= lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; ND = not determined

Agency Contacts (Chemical Managers): Rae T. Benedict