# 9 REFERENCES

* Not cited in text

AAP. 2015. Prevention of mosquitoborne infections. In: Kimberlin DW, Brady MT, Jackson MA, ., eds. Red Book. 2015 Report of the Committee on Infectious Diseases. 30th ed. Elk Grove Village, IL: American Academy of Pediatrics, 213–215.
AAPCC. 2013. 2012 Annual report of the American Association of Poison Control Centers’ National Poison Data System (NPDS): 30th Annual Report. Clin Toxicol 51:949–1229.
Abadin HG, Chou C, Llados FT. 2007. Health effects classification and its role in the derivation of minimal risk levels: Immunological effects. Regul Toxicol Pharmacol 47:249–256.17194513
Abdel-Rahman A, Dechkovskaia AM, Goldstein LB, . 2004. Neurological deficits induced by malathion, DEET, and permethrin, alone or in combination in adult rats. J Toxicol Environ Health A 67(4):331–356.14713564
Abdel-Rahman A, Shetty AK, Abou-Donia MB. 2001. Subchronic dermal application of N,N-diethyl m-toluamide (DEET) and permethrin to adult rats, alone or in combination, causes diffuse neuronal cell death and cytoskeletal abnormalities in the cerebral cortex and the hippocampus, and Purkinje neuron loss in the cerebellum. Exp Neurol 172(1):153–171.11681848
Abou-Donia MB, Goldstein LB, Dechovskaia A, . 2001a. Effects of daily dermal application of DEET and permethrin, alone and in combination, on sensorimotor performance, blood-brain barrier, and blood-testis barrier in rats. J Toxicol Environ Health A 62(7):523–541.11289702
Abou-Donia MB, Goldstein LB, Jones KH, . 2001b. Locomotor and sensorimotor performance deficit in rats following exposure to pyridostigmine bromide, DEET, and permethrin, alone and in combination. Toxicol Sci 60(2):305–314.11248143
Abou-Donia MB, Jensen KF, Oehme FW, . 1996. Neurotoxicity resulting from coexposure to pyridostigmine bromide, DEET, and permethrin: implications of Gulf War chemical exposures. J Toxicol Environ Health 48: 35–56.8637057
Abu-Qare A, Abou-Donia M. 2000. Increased 8-hydroxy-2’-deoxyguanosine, a biomarker of oxidative DNA damage in rat urine following a single dermal dose of DEET (N, N-diethyl-m-toluamide), and permethrin, alone and in combination. Toxicol Lett 117(3):151–160.11087981
Abu-Qare AW, Abou-Donia MB. 2001a. In vitro metabolism of pyridostigmine bromide (PB), DEET and permethrin, alone and in combination by human plasma and liver microsomes. Toxicologist 60(1):89–90.
Abu-Qare AW, Abou-Donia MB. 2001c. Development of a high-performance liquid chromatographic method for the quantification of chlorpyrifos, pyridostigmine bromide, N,N-diethyl-m-toluamide and their metabolites in rat plasma and urine. J Chromatogr B Biomed Sci Appl 754(2):533–538.11339298
Abu-Qare AW, Abou-Donia MB. 2001b. High performance liquid chromatographic determination of diazinon, permethrin, DEET (N, N-diethyl-m-toluamide), and their metabolites in rat plasma and urine. Fresenius J Anal Chem 370(4):403–407.11495064
Abu-Qare AW, Abou-Donia MB. 2001d. Simultaneous determination of malathion, permethrin, DEET (N,N-diethyl-m-toluamide), and their metabolites in rat plasma and urine using high performance liquid chromatography. J Pharm Biomed Anal 26(2):291–299.11470206
Abu-Qare AW, Suliman HB, Abou-Donia MB. 2001. Induction of urinary excretion of 3-nitrotyrosine, a marker of oxidative stress, following administration of pyridostigmine bromide, DEET (N,N-diethyl-m-toluamide) and permethrin, alone and in combination in rats. Toxicol Lett 121(2):127–134.11325563
Abu-Qare AW, Abou-Donia MB. 2002. Binding of pyridostigmine bromide, N,N-diethyl-m-toluamide and permethrin, alone and in combinations, to human serum albumin. Arch Toxicol 76(4):203–208.12029383
Abu-Qare AW, Abou-Donia MB. 2008. In vitro metabolism and interactions of pyridostigmine bromide, N,N-diethyl-m-toluamide, and permethrin in human plasma and liver microsomal enzymes. Xenobiotica 38(3):294–313.18274958
ACGIH. 2013. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
AIHA. 2013. Emergency response planning guidelines (ERPG). Fairfax, VA: American Industrial Hygiene Association. https://www.aiha.org/get-involved/AIHAGuidelineFoundation/EmergencyResponsePlanningGuidelines/Pages/default.aspx. January 08, 2014.
Alden CL. 1986. A review of unique male rat hydrocarbon nephropathy. Toxicol Pathol 14(1):109–111.2424069
Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies of Experimental Biology, 1987–2008, 2041
Alvarez DA, Stackelberg PE, Petty JD, . 2005. Comparison of novel passive sampler to standard water-column sampling for organic contaminants associated with wastewater effluents entering a New Jersey stream. Chemosphere 61:610–622.16219498
Ambrose AM. 1959. Pharmacologic and toxicologic studies on N,N-diethyltoluamide. I. N,N-diethyl-m-toluamide. Toxicol Appl Pharmacol 1:97–115.13625321
Amichai B, Lazarov A, Halevy S. 1994. Contact dermatitis from diethyltoluamide. Contact Dermatitis 30(3):188.8187533
Andersen ME, Clewell HJ, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87(2):185–205.3824380
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, and replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Antwi FB, Shama LM, Peterson RK. 2008. Risk assessments for the insect repellents DEET and picaridin. Regul Toxicol Pharmacol 51(1):31–36.18406029
Arcury TA, Grzywacz JG, Barr DB, . 2007. Pesticide urinary metabolite levels of children in eastern North Carolina farmworker households. Environ Health Perspect 115(8):1254–1260.17687456
Army. 1979. Behavioral effects of acute aerosol exposure to N,N-diethyl-meta-toluamide (M-DET). January - February 1979. Toxicological Assessment Program Study No. 75-51-0034-80. Fort Sam, Houston, TX: U.S. Army. ADA076939
Army. 1980a. Inhalation toxicities of N,N-diethyl-meta-toluamide (M-DET) Study No. 75-51-0034-80, January - May 1979. Fort Sam Houston, TX: U.S. Army.
Army. 1980b. Phase 5, Subchronic oral toxicity of the insect repellent N,N-diethyl-M-toluamide (M-DET) Study No. 75-51-0034-80, September 1978-May 1979. Fort Sam, Houston, TX: U.S. Army.
Army. 1995. Acute oral toxicity study of pyridostigmine bromide, permethrin and DEET in the laboratory rat. Fort Detrick, MD: U.S. Army Medical Research and Materiel Command. Toxicological Study 75-48-2665. http://www.defense.gov/news/fact_sheets/f950616_ratsheet.html. December 1, 2014.
Aronson D, Weeks J, Meylan B, . 2012. Environmental release, environmental concentrations, and ecological risk of N,N-diethyl-m-toluamide (DEET). Integr Environ Assess Manag 8(1):135–166.21913321
Atalay MK, Kochilas LK. Familial pseudocoarctation of the aorta. 2011. Pediatr Cardiol 32:692–695.21347833
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 2015. Deet. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention. http://www.atsdr.cdc.gov/SPL/resources/index.html. August 2, 2016.
Balducci C, Perilli M, Romagnoli P, . 2012. New developments on emerging organic pollutants in the atmosphere. Environ Sci Pollut Res Int 19(6):1875–1884.22767285
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Barnes KK, Christenson SC, Kolpin DW, . 2004. Pharmaceuticals and other organic waste water contaminants within a leachate plume downgradient of a municipal landfill. Ground Water Monit Remed 24:119–126.
Barr DB, Ananth CV, Yan X, . 2010. Pesticide concentrations in maternal and umbilical cord sera and their relation to birth outcomes in a population of pregnant women and newborns in New Jersey. Sci Total Environ 408(4):790–795.19900697
Barr DB, Barr JR, Maggio VL, . 2002. A multi-analyte method for the quantification of contemporary pesticides in human serum and plasma using high-resolution mass spectrometry. J Chromatogr B Analyt Technol Biomed Life Sci 778(1–2):99–111.
Bell JW, Veltri JC, Page BC. 2002. Human exposures to N,N-diethyl-m-toluamide insect repellents reported to the American Association of Poison Control Centers 1993-1997. Int J Toxicol 21(5):341–352.12396679
Benotti MJ, Trenholm RA, Vanderford BJ, . 2009. Pharmaceuticals and endocrine disrupting compounds in U.S. drinking water. Environ Sci Technol 43:597–603.19244989
Berger GS, ed. 1994. Epidemiology of endometriosis. In: Endometriosis: Modern surgical management of endometriosis. New York, NY: Springer-Verlag, 3–7.
Blomquist L, Thorsell W. 1977. Distribution and fate of the insect repellent ^14^C-N,N-diethyl-m-toluamide in the animal body. II. Distribution and excretion after cutaneous application. Acta Pharmacol Toxicol (Copenh) 41(3):235–243.578652
Blomquist L, Stroeman L, Thorsell W. 1975. Distribution and fate of the insect repellent ^14^C-N,N-diethyl-m-toluamide in the animal body: I. Distribution and excretion after injection into mice. Acta Pharmacol Toxicol 37(2):121–133.
Borron SW. 2007. Pyrethrins, repellants, and other pesticides. In: Shannon MW, Borron SW, Burns MJ, eds. Haddad and Winchester’s clinical management of poisoning and drug overdose. 4th ed. Philadelphia, PA: Saunders Elsevier, 1185–1194.
Bradman A, Barr DB, Claus Henn BG, . 2003. Measurement of pesticides and other toxicants in amniotic fluid as a potential biomarker of prenatal exposure: A validation study. Environ Health Perspect 111(14):1779–1782.14594631
Brand RM, Jendrzejewski JL, Henery EM, . 2006. A single oral dose of ethanol can alter transdermal absorption of topically applied chemicals in rats. Toxicol Sci 92(2):349–355. 10.1093/toxsci/kfl010.16679347
Brausch JM, Rand GM. 2011. A review of personal care products in the aquatic environment: Environmental concentrations and toxicity. Chemosphere 82:1518–1532.21185057
Briassoulis G, Narlioglou M, Hatzis T. 2001. Toxic encephalopathy associated with use of DEET insect repellents: A case analysis of its toxicity in children. Hum Exp Toxicol 20(1):8–14.11339626
Calafat AM, Baker SE, Wong L-Y, . 2016. Novel exposure biomarkers of N,N-diethyl-m-toluamide (DEET): Data from the 2007–2010 National Health and Nutrition Examination Survey. Environ Int 92–93:398–404. 10.1016/j.envint.2016.04.021.
Calza P, Medana C, Raso E, . 2011. N,N-diethyl-m-toluamide transformation in river water. Sci Total Environ 409:3894–3901.21708398
Carlson DA. 2000. Repellants. In: Kirk-Othmer encyclopedia of chemical technology. http://onlinelibrary.wiley.com/doi/10.1002/0471238961.1805160503011812.a01/abstract. March 10, 2014.
Carpenter CP, Weil CS, Smyth HF. 1974. Range-finding toxicity data: List VIII. Toxicol Appl Pharmacol 28:313–319.4854023
Castorina R, Bradman A, Fenster L, . 2010. Comparison of current-use pesticide and other toxicant urinary metabolite levels among pregnant women in the CHAMACOS cohort and NHANES. Environ Health Perspect 118(6):856–863.20129873
CDC. 2009. Fourth national report on human exposure to environmental chemicals. Atlanta, GA: Centers for Disease Control and Prevention, Department of Health and Human Services. http://www.cdc.gov/exposurereport. April 20, 2014.
CDC. 2015. Chapter 2. Protection against mosquitoes, ticks, & other arthropods. In: CDC health information for international travel 2016. Centers for Disease Control and Prevention. http://wwwnc.cdc.gov/travel/yellowbook/2016/the-pre-travel-consultation/protection-against-mosquitoes-ticks-other-arthropods. August 1, 2016.
CDC. 2017. Fourth national report on human exposure to environmental chemicals. Updated tables, January 2017, volume one. Atlanta, GA: Centers for Disease Control and Prevention, Department of Health and Human Services. https://www.cdc.gov/biomonitoring/pdf/FourthReport_UpdatedTables_Volume1_Jan2017.pdf. February 23, 2017.
Chandramouli B, Harvan D, Brittain S, . 2004. A gas/liquid chromatographic-mass spectrometric method for the rapid screening of 250 pesticides in aqueous matrices. Organohalogen Compounds 66:246–252.
Chaney LA, Rockhold RW, Hume AS. 2002. Cardiorespiratory effects following acute exposure to pyridostigmine bromide and/or N,N-diethyl-m-toluamide (DEET) in rats. Int J Toxicol 21(4):287–300.12171630
Chaney LA, Rockhold RW, Wineman RW, . 1999. Anticonvulsant-resistant seizures following pyridostigmine bromide (PB) and N,N-diethyl-m-toluamide (DEET). Toxicol Sci 49(2):306–311.10416276
Chaney LA, Wineman RW, Rockhold RW, . 2000. Acute effects of an insect repellent, N,N-diethyl-m-toluamide, on cholinesterase inhibition induced by pyridostigmine bromide in rats. Toxicol Appl Pharmacol 165(2):107–114.10828206
Chaudhary AM, Harrison LR, Khan SI, . 2005. Estrogen equivalents and corresponding chemical analyses of marine water samples collected along a coral reef. Toxicol Sci 84(1-S):324.
ChemIDplus. 2013. Diethyltoluamide. ChemIDplus. Bethesda, MD: U.S. National Library of Medicine. http://sis.nlm.nih.gov/chemical.html. March 7, 2014.
Chen T, Burczynski FJ, Miller DW, . 2010. Percutaneous permeation comparison of repellents picaridin and DEET in concurrent use with sunscreen oxybenzone from commercially available preparations. Pharmazie 65(11):835–839.21155391
Cheng Y, Li S, Leithead A. 2006. Chemical characteristics and origins of nitrogen-containing organic compounds in PM2.5 aerosols in the Lower Fraser Valley. Environ Sci Technol 40:5846–5852.17051769
Cherstniakova SA, Garcia GE, Strong J, . 2006. Rapid determination of N,N-diethyl-m-toluamide and permethrin in human plasma by gas chromatography-mass spectrometry and pyridostigmine bromide by high-performance liquid chromatography. J Anal Toxicol 30(1):21–26.16620527
CITI. 1992. N,N-Diethyl-m-toluamide. In: Biodegradation and bioaccumulation data of existing chemicals based on the CSCL Japan. Japan: Chemical Inspection & Testing Institute. Japan Chemical Industry Ecology-Toxicology & Information Center, 3–93.
Clem JR, Havemann DF, Raebel MA. 1993. Insect repellent (N,N-diethyl-m-toluamide) cardiovascular toxicity in an adult. Ann Pharmacother 27(3):289–293.8453162
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Constantino L, Iley J. 1999. Microsomal metabolism of N,N-diethyl-m-toluamide (DEET, DET): The extended network of metabolites. Xenobiotica 29(4):409–416.10375009
Cordy GE, Duran NL, Bouwer H, . 2004. Do pharmaceuticals, pathogens, and other organic waste water compounds persist when waste water is used for recharge? Ground Water Monit Remed 24:58–69.
Costa LG, Aschner M, Vitalone A, . 2004. Developmental neuropathology of environmental agents. Annu Rev Pharmacol Toxicol 44:87–110.14744240
Costanzo SD, Watkinson AJ, Murby EJ, . 2007. Is there a risk associated with the insect repellent DEET (N,N-diethyl-m-toluamide) commonly found in aquatic environments? Sci Total Environ 384(1–3):214–220.17659764
Crowley RJ, Geyer R, Muir SG. 1986. Analysis of N,N-diethyl-m-toluamide (DEET) in human postmortem specimens. J Forensic Sci 31(1):280–282.3944567
Davies B, Morris T. 1993. Physiological parameters in laboratory animals and humans. Pharm Res 10(7):1093–1095.8378254
Deb U, Ahmed F, Singh S, . 2010. Comparative effects of insect repellent N,N-diethylbenzamide, N,N-diethylphenylacetamide, and N,N-diethyl-3-methylbenzamide aerosols on the breathing pattern and respiratory variables in mice. Inhal Toxicol 22(6):469–478.20384542
DOE. 2012. Protective action criteria (PAC). Oak Ridge, TN: U.S. Department of Energy and Subcommittee on Consequence Assessment and Protective Actions (SCAPA). http://orise.orau.gov/emi/scapa/chem-pacs-teels/default.htm. January 08, 2014.
Dougherty JA, Swarzenski PW, Dinicola R, . 2010. Occurrence of herbicides and pharmaceutical and personal products in surface water and groundwater around Liberty Bay, Puget Sound, Washington. J Environ Qual 39:1173–1180.20830904
DVA. 2011. Determinations concerning illnesses discussed in National Academy of Sciences Reports on Gulf War and health, volumes 4 and 8. Department of Veterans Affairs. Fed Regist 76(72):21099–21107. http://www.gpo.gov/fdsys/pkg/FR-2011-04-14/pdf/2011-8937.pdf. September 11, 2014.
ECHA. 2010. N,N-diethyl-meta-toluamide (DEET). Product-type 19 (repellents and attractants). Directive 98/8/EC concerning the placing biocidal products on the market. Assessment report. Sweden: European Chemicals Agency http://esis.jrc.ec.europa.eu/doc/biocides/annex_I/assessment_reports/AnnexI_AR_134-62-3_PT19_en.pdf. April 23, 2014.
Eckel WP, Ross B, Isensee RK. 1993. Pentobarbital found in ground water. Ground Water 31:801–804.
Edwards DL, Johnson CE. 1987. Insect-repellent-induced toxic encephalopathy in a child. Clin Pharm 6(6):496–498.3690996
Eggen T, Moeder M, Arukwe A. 2010. Municipal landfill leachates: A significant source for new and emerging pollutants. Sci Total Environ 408(21):5147–5157.20696466
Ek CJ, Dziegielewska KM, Habgood MD, . 2012. Barriers in the developing brain and neurotoxicology. Neurotoxicology 33(3):586–604.22198708
EPA. 1983. Methods for nonconventional pesticide analysis of industrial and municipal wastewater. U.S. Environmental Protection Agency. EPA440183079C. http://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000K02U.txt. June 18, 2014.
EPA. 1988. Memorandum: DEET: Review of three 90-day toxicity studies data. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances.
EPA. 1989. [EPA memorandum 007645 from Whang Phang, Subject: Review of a two-generation reproduction on DEET, dated 13 December 1989]. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/pesticides/chem_search/cleared_reviews/csr_PC-080301_13-Dec-89_032.pdf. April 24, 2014.
EPA. 1990a. DEET: Review of a 90-day dermal toxicity study in castrated male rats. MRID No. 41199301, EPA ID No. TF-CSMA, HED Project No. 9-2036, EPA Record No. 250417. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/pesticides/chem_search/cleared_reviews/csr_PC-080301_6-Feb-90_034.pdf. April 24, 2014.
EPA. 1990b. DEET: Review of a two-generation reproduction in rats and a 90-day dose-range finding study in hamsters. Washington, DC: U.S. Environmental Protection Agency. MRID No. 413441-01, 409790-01; HED Project No. 0-0837.
EPA. 1990c. DEET: Review of three mutagenicity studies. MRID No. 413448-01, 413444-01, 413443001, HED Project No. 0-0836, EPA Record No. 260702. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/opp00001/chem_search/cleared_reviews/csr_PC-080301_26-Sep-90_039.pdf. April 24, 2014.
EPA. 1990d. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development. PB90238890.
*EPA. 1992b. DEET: Reviews of 2 neurotoxicity studies. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1992a. Review of a 90-day dermal toxicity study in micropigs^®^. Washington, DC: U.S. Environmental Protection Agency. MRID No. 419874-01; HED Project No. I-2462.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. EPA630R96012.
EPA. 1998a. RCRA waste minimization PBT priority chemical list. U.S. Environmental Protection Agency. Fed Regist 63 FR 60332. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 1998b. Reregistration eligibility decision (RED): DEET. Washington, DC: U.S. Environmental Protection Agency, Office of Prevention, Pesticides and Toxic Substances. http://www.epa.gov/oppsrrd1/REDs/0002red.pdf. April 20, 2014.
EPA. 1998c. R.E.D. Facts: DEET. Washington, DC: U.S. Environmental Protection Agency, Office of Prevention, Pesticides and Toxic Substances. http://www.epa.gov/oppsrrd1/REDs/factsheets/0002fact.pdf. April 20, 2014.
EPA. 2002. Secondary review of studies on the insect repellent oil of lemon eucalyptus and revisions to the human health risk assessment (PC011550: WPC Brands; Case No. (62646) EPA file symbol 305-LI.) DP Barcode D279876. U.S. Environmental Protection Agency. http://www.epa.gov/opp00001/chem_search/cleared_reviews/csr_PC-011550_18-Apr-02_a.pdf. April 24, 2014.
EPA. 2004. Pesticides industry sales and usage. 2000 and 2001 market estimates. Washington, DC: U.S. Environmental Protection Agency, Office of Prevention, Pesticides, and Toxic Substances, Office of Pesticide Programs, Biological and Economic Analysis Division. EPA733R04001. http://www.epa.gov/opp00001/pestsales/01pestsales/market_estimates2001.pdf. June 18, 2014.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency, Office of Environmental Information. EPA260B05001.
EPA. 2007. Diethyltoluamide (DEET). Chemical summary. U.S. Environmental Protection Agency. http://www.epa.gov/teach/chem_summ/DEET_summary.pdf. June 18, 2014.
EPA. 2009a. Drinking water contaminant candidate list. U.S. Environmental Protection Agency. Fed Regist 74 FR 51850:51850–51862. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2009b. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA816F090004. http://water.epa.gov/drink/contaminants/. January 08, 2014.
EPA. 2012a. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822S12001. http://water.epa.gov/drink/standards/hascience.cfm. January 08, 2014.
EPA. 2012b. Method 525.3. Determination of semivolatile organic chemicals in drinking water by solid phase extraction and capillary column gas chromatography/mass spectrometry (GC/MS). Version 1.0. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. EPA 600R12010. http://www.epa.gov/nerlcwww/documents/method%20525_3_feb21_2012%20final.pdf. August 6, 2014.
EPA. 2012c. Registration review. Ecological risk, environmental fate, and endangered species assessment for DEET. U.S. Environmental Protection Agency. https://www.regulations.gov/docketBrowser?rpp=25&so=DESC&sb=commentDueDate&po=0&D=EPA-HQ-OPP-2012-0162. March 23, 2017.
EPA. 2013a. Acute exposure guideline levels (AEGLs). Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/oppt/aegl/. January 08, 2014.
EPA. 2013b. Designated as hazardous substances in accordance with section 311(b)(2)(a) of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 116.4. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013c. Identification and listing of hazardous waste. Hazardous constituents. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 261, Appendix VIII. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013d. Reportable quantities of hazardous substances designated pursuant to section 311 of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 117.3. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013e. Standards for owners and operators of hazardous waste TSD facilities. Groundwater monitoring list. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 264, Appendix IX. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013f. Superfund, emergency planning, and community right-to-know programs. Designation, reportable quantities, and notifications. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 302.4. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013g. Superfund, emergency planning, and community right-to-know programs. Extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 355, Appendix A. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013h. Superfund, emergency planning, and community right-to-know programs. Toxic chemical release reporting. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 372.65. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013i. Toxic Substances Control Act. Chemical lists and reporting periods. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 712.30. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013j. Toxic Substances Control Act. Health and safety data reporting. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 716.120. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2014a. Acute exposure guideline levels (AEGLs). Second AEGL chemical priority list. Washington, DC: U. S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/opptintr/aegl/pubs/priority_2.htm. January 08, 2014.
EPA. 2014b. Hazardous air pollutants. Clean Air Act. U.S. Environmental Protection Agency. United States Code 42 USC 7412. http://www.epa.gov/ttn/atw/orig189.html. January 08, 2014.
EPA. 2014c. Inert ingredients permitted for use in nonfood pesticide products. Washington, DC: U.S. Environmental Protection Agency. http://iaspub.epa.gov/apex/pesticides/f?p=124:1. January 08, 2014.
EPA. 2014d. Master testing list. Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/opptintr/chemtest/pubs/mtl.html. January 08, 2014.
EPA. 2014e. National ambient air quality standards (NAAQS). Washington, DC: U.S. Environmental Protection Agency, Office of Air and Radiation. http://www.epa.gov/air/criteria.html. January 08, 2014.
EPA. 2014f. National recommended water quality criteria. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Office of Science and Technology. http://water.epa.gov/scitech/swguidance/standards/criteria/current/index.cfm. January 08, 2014.
EPA. 2014g. Final National Priorities List (NPL) sites - by state. Texas. U.S. Environmental Protection Agency. http://www.epa.gov/superfund/sites/query/queryhtm/nplfin.htm#TX. December 4, 2014.
EPA. 2014h. National Priorities List (NPL). NPL site narrative for Bennington Municipal Sanitary Landfill. U.S. Environmental Protection Agency. http://www.epa.gov/superfund/sites/npl/nar1215.htm. December 4, 2014.
EPA. 2014i. DEET. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticide Programs. http://www2.epa.gov/insect-repellents/deet. December 03, 2014.
EPA. 2014j. Envirofacts. TRI Search. U.S. Environmental Protection Agency. http://www.epa.gov/superfund/sites/npl/. December 4, 2014.
EPA. 2014k. National Priorities List (NPL). U.S. Environmental Protection Agency. http://www.epa.gov/superfund/sites/npl/. December 4, 2014.
EPA. 2014l. DEET (N,N-diethyl-m-toluamide). Intermin registration review decision. Case number 002. U.S. Environmental Protection Agency. EPAHQOPP20120162. https://archive.epa.gov/pesticides/reregistration/web/pdf/0002red.pdf. April 5, 2017.
EPA. 2014m. DEET (N,N-diethyl-m-toluamide). Revised human health risk assessment in support of registration review. U.S. Environmental Protection Agency. https://archive.epa.gov/pesticides/reregistration/web/pdf/0002red.pdf. April 5, 2017.
EPA. 2017a. Superfund: National Priorities List (NPL). U.S. Environmental Protection Agency. https://www.epa.gov/superfund/superfund-national-priorities-list-npl. June 14, 2017.
EPA. 2017b. Superfund. Search Superfund site information, contaminants. DEET. U.S. Environmental Protection Agency. https://cumulis.epa.gov/supercpad/CurSites/srchsites.cfm. June 14, 2017.
EPIWIN. 2012. CAS 000134-62-3. Estimation Program Interface (EPI Suite) version 4.11. U.S. Environmental Protection Agency. http://www.epa.gov/oppt/exposure/pubs/episuitedl.htm. April 20, 2014.
Etzel RA. 2012. Pesticides. In: Pediatric environmental health. 3rd Edition; Elk Grove Village, IL: American Academy of Pediatrics Council on Environmental Health, 538–540.
FDA. 2014. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnnavigation.cfm?rpt=eafuslisting. January 08, 2014.
Fediuk DJ, Wang T, Chen Y, . 2011. Tissue disposition of the insect repellent DEET and the sunscreen oxybenzone following intravenous and topical administration in rats. Biopharm Drug Dispos 32(7):369–379.21812003
Fediuk DJ, Wang T, Chen Y, . 2012. Metabolic disposition of the insect repellent DEET and the sunscreen oxybenzone following intravenous and skin administration in rats. Int J Toxicol 31(5):467–476.23064701
Fediuk DJ, Wang T, Raizman JE, . 2010. Tissue deposition of the insect repellent DEET and the sunscreen oxybenzone from repeated topical skin applications in rats. Int J Toxicol 29(6):594–603.20959613
Feldman RJ, Maibach HI. 1970. Absorption of some organic compounds through the skin in man. J Invest Dermatol 54(5):399–404.4245370
Fomon SJ. 1966. Body composition of the infant: Part 1: The male reference infant. In: Faulkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35(Suppl 5):1169–1175.7081099
Foster AL. 2007. Occurrence and fate of endocrine disruptors through the San Marcos wastewater treatment plant. [MS thesis]. San Marcos, TX: Texas State University. http://ecommons.txstate.edu/bchemtad/2. April 24, 2014.
Fraser AD, MacNeil A, Theriault M, . 1995. Analysis of diethyltoluamide (DEET) following intentional oral ingestion of Muscol. J Anal Toxicol 19(3):197–199.7564300
Gerecke AC, Scharer M, Singer HP, . 2002. Sources of pesticides in surface waters in Switzerland: Pesticide load through waste water treatment plants-current situation and reduction potential. Chemosphere 48:307–315.12146619
Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect 101(Supp 2):65–71.7902273
Glassmeyer ST, Furlong ET, Kolpin DW, . 2005. Transport of chemical and microbial compounds from known wastewater discharges: Potential for use as indicators of human fecal contamination. Environ Sci Technol 39:5157–5169.16082943
Goolsby DA, Pereira WE. 1996. Pesticides in the Mississippi River. In: Meade RH, ed. Contaminants in the Mississippi River, 1987-1992, No. 1133. Denver, CO: U.S. Geological Survey, 86–101.
Gryboski J, Weinstein D, Ordway NK. 1961. Toxic encephalopathy apparently related to the use of an insect repellent. N Engl J Med 264(6):289–291.13709286
Gu X, Wang T, Collins DM, . 2005. In vitro evaluation of concurrent use of commercially available insect repellent and sunscreen preparations. Br J Dermatol 152(6):1263–1267.15948991
Guardiola J, Ventura F, Rivera J. 1989. Occurrence of industrial organic pollution of groundwater supply: Screening, monitoring and evaluation of treatment processes. Water Supply 7:11–16.
Guzelian PS, Henry CJ, Olin SS. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences and Press Institute Press.
Haggard BE, Galloway JM, Green WR, . 2006. Pharmaceuticals and other chemicals in selected North-Central and Northwestern Arkansas streams. J Environ Qual 35:1078–1087.16738393
Haley RW, Kurt TL. 1997. Self-reported exposure to neurotoxic chemical combinations in the Gulf War: Cross-sectional epidemiologic study. JAMA 277(Jan):231–237.9005273
Hall JG, McLaughlin JF, Stamm S. 1975. Coarctation of the aorta in male cousins with similar maternal environmental exposure to insect repellent and insecticides. Pediatrics 55(3):425–427.1143982
Hampers LC, Oker E, Leikin JB. 1999. Topical use of DEET insect repellent as a cause of severe encephalopathy in a healthy adult male. Acad Emerg Med 6(12):1295–1297.10609933
Hardell L, Nasman A, Ohlson CG, . 1998. Case-control study on risk factors for testicular cancer. Int J Oncol 13(6):1299–1303.9824648
He Y, Lee HK. 1997. Combination of solid-phase extraction and field-amplified concentration of trace analysis of organonitrogen pesticides by micellar electrokinetic chromatography. Electrophoresis 18(11):2036–2041.9420165
Heick HM, Shipman RT, Norman MG, . 1980. Reye-like syndrome associated with use of insect repellent in a presumed heterozygote for ornithine carbamoyl transferase deficiency. J Pediatr 97(3):471–473.7411313
Hendriks AJ, Maas-Diepeveen JL, Noordsij A, . 1994. Monitoring response of XAD-concentrated water in the Rhine Delta: A major part of the toxic compounds remains unidentified. Water Res 28:581–598.
Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
Holland MG. 2015. Insecticides: Organochlorines, pyrethrins/pyrethroids, and insect repellents. In: Hoffman RS, Howland MA, Lewin NA, eds. Goldfrank’s toxicologic emergencies. 10^th^ ed. New York, NY: McGraw-Hill Education, 1435–1448.
Hoy JB, Cornell JA, Karlix JL, . 2000a. Interactions of pyridostigmine bromide, DEET and permethrin alter locomotor behavior of rats. Vet Hum Toxicol 42(2):65–71.10750168
Hoy JB, Cornell JA, Karlix JL, . 2000b. Repeated coadministrations of pyridostigmine bromide, DEET, and permethrin alter locomotor behavior of rats. Vet Hum Toxicol 42(2):72–76.10750169
HSDB. 2001. DEET. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. April 22, 2014.
IARC. 2013. Agents classified by the IARC monographs. Volumes 1–109. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/index.php. January 08, 2014.
ILS. 1999. N,N-Diethyl-m-toluamide (DEET). Review of toxicological literature. Research Triangle Park, NC: Integrated Laboratory Systems. http://ntp.niehs.nih.gov/ntp/htdocs/chem_background/exsumpdf/deet_508.pdf. June 19, 2014.
IRIS. 2014. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/. January 08, 2014.
Iscan Y, Hekimoglu S, Sargon MF, . 2006. DEET-loaded solid lipid particles for skin delivery: In vitro release and skin permeation characteristics in different vehicles. J Microencapsul 23(3):315–327.16801243
Jortner BS. 2006. The return of the dark neuron. A histological artifact complicating contemporary neurotoxicologic evaluation. Neurotoxicology 27:628–634.16650476
Karr JI, Speaker TJ, Kasting GB. 2012. A novel encapsulation of N,N-diethyl-3-methylbenzamide (DEET) favorably modifies skin absorption while maintaining effective evaporation rates. J Control Release 160(3):502–508.22546679
Kasichayanula S, House JD, Wang T, . 2005. Simultaneous analysis of insect repellent DEET, sunscreen oxybenzone and five relevant metabolites by reversed-phase HPLC with UV detection: Application to an in vivo study in a piglet model. J Chromatogr B Analyt Technol Biomed Life Sci 822(1–2):271–277.
Kasichayanula S, House JD, Wang T, . 2007. Percutaneous characterization of the insect repellent DEET and the sunscreen oxybenzone from topical skin application. Toxicol Appl Pharmacol 223(2):187–194.17602720
Kasting GB, Bhatt VD, Speaker TJ. 2008. Microencapsulation decreases the skin absorption of N,N-diethyl-m-toluamide (DEET). Toxicol in Vitro 22(2):548–552.18093794
Kaushik D, Costache A, Michniak-Kohn B. 2010. Percutaneous penetration modifiers and formulation effects. Int J Pharm 386(1–2):42–51.19900521
Kearns GL, Abdel-Rahman SM, Alander SW, . 2003. Developmental pharmacology-drug disposition, action, and therapy in infants and children. N Engl J Med 349(12):1157–1167.13679531
Kenefick RW, Cheuvront SN, Ely BR, . 2011. DEET insect repellent: Effects on thermoregulatory sweating and physiological strain. Eur J Appl Physiol 111:3061–3068.21455616
Kim SD, Cho JH, Kim IS, . 2007. Occurrence and removal of pharmaceuticals and endocrine disruptors in South Korean surface, drinking, and waste waters. Water Res 41:1013–1021.16934312
Knepper TP. 2004. Analysis and fate of insect repellents. Water Sci Technol 50(5):301–308.
Kolpin DW, Furlong ET, Meyer MT, . 2002. Pharmaceuticals, hormones, and other organic wastewater contaminants in U.S. streams, 1999-2000: A national reconnaissance. Environ Sci Technol 36:1202–1211.11944670
Kolpin DW, Skopec M, Meyer MT, . 2004. Urban contribution of pharmaceuticals and other organic wastewater contaminants to streams during differing flow conditions. Sci Total Environ 348:119–130.
Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29(18):4430–4433.2350547
Koren G, Matsui D, Bailey B. 2003. DEET-based insect repellents: safety implications for children and pregnant and lactating women. CMAJ 169(3):209–212.12900480
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kuhn EP, Suflita JM. 1989. Anaerobic biodegradation of nitrogen-substituted and sulfonated benzene aquifer contaminants. Hazard Waste Hazard Mater 6(2):121–134.
Kuklenyik P, Baker SE, Bishop AM, . 2013. On-line solid phase extraction-high performance liquid chromatography-isotope dilution-tandem mass spectrometry approach to quantify N,N-diethyl-m-toluamide and oxidative metabolites in urine. Anal Chim Acta 787:267–273.23830449
Kuroda K, Murakami M, Oguma K, . 2012. Assessment of groundwater pollution in Tokyo using PPCPs as sewage markers. Environ Sci Technol 46(3):1455–1464.22191375
Langford KH, Thomas KV. 2008. Inputs of chemicals from recreational activities into the Norwegian coastal zone. J Environ Monit 10:894–898.18688459
Lebowitz H, Young R, Kidwell J, . 1983. DEET (N,N-diethyltoluamide) does not affect sperm number, viability and head morphology in male rats treated dermally. Drug Chem Toxicol 6(4):379–395.6617532
Lee CJ, Rasmussen TJ. 2006. Occurrence of organic wastewater compounds in effluent-dominated streams in northeastern Kansas. Sci Total Environ 37:258–269.
Lee KE, Barber LB, Furlong ET, . 2004. Presence and distribution of organic wastewater compounds in wastewater, surface, ground, and drinking waters, Minnesota, 2000-02. U.S. Geological Survey Scientific Investigation Report 2004-5138. Reston, Virginia: U.S. Department of the Interior, U.S. Geological Survey. http://pubs.usgs.gov/sir/2004/5138/20045138.pdf. April 22, 2014.
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Leung H. 1993. Physiologically-based pharmacokinetic modelling. In: Ballantyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Lietz AC, Meyer MT. 2006. Evaluation of emerging contaminants of concern at the South District Wastewater Treatment plant based on seasonal sampling events, Miami-Dade County, Florida, 2004. U.S. Geological Survey Scientific Investigations Report 2006-5240. Reston, Virginia: U.S. Department of the Interior, U.S. Geological Survey.
Lipscomb JW, Kramer JE, Leikin JB. 1992. Seizure following brief exposure to the insect repellent N,N-diethyl-m-toluamide. Ann Emerg Med 21(3):315–317.1536495
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4(2–3):301–324.351201
Loos R, Carvalho R, Antonio DC, . 2013a. EU-wide monitoring survey on emerging polar organic contaminants in wastewater treatment plant effluents. Water Res 47(17):6475–6487.24091184
Loos R, Locoro G, Comero S, . 2010. Pan-European survey on the occurrence of selected polar organic persistent pollutants in ground water. Water Res 44(14):4115–4126.20554303
Loos R, Tavazzi S, Paracchini B, . 2013b. Analysis of polar organic contaminants in surface water of the northern Adriatic Sea by solid-phase extraction followed by ultrahigh-pressure liquid chromatography-QTRAP(R) MS using a hybrid triple-quadrupole linear ion trap instrument. Anal Bioanal Chem 405(18):5875–5885.23657443
Loraine GA, Pettigrove ME. 2006. Seasonal variations in concentrations of pharmaceuticals and personal care products in drinking water and reclaimed wastewater in Southern California. Environ Sci Technol 40:687–695.16509304
Mac Rae SM, Brown BA, Ubels JL, . 1984. Ocular toxicity of diethyltoluamide. J Toxicol Cutaneous Ocul Toxicol 3(1):17–30.
Maibach HI, Johnson HL. 1975. Contact urticaria syndrome. Contact urticaria to diethyltoluamide (immediate-type hypersensitivity). Arch Dermatol 111(6):726–730.1137416
Markovic G, Agbaba D, Stakic DZ, . 1999. Determination of some insect repellents in cosmetic products by high-performance thin-layer chromatography. J Chromatogr A 847(1–2):365–368.10431366
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74(2–3):135–149.1387742
McCain WC, Lee R, Johnson MS, . 1997. Acute oral toxicity study of pyridostigmine bromide, permethrin, and DEET in the laboratory rat. J Toxicol Environ Health 50(2):113–124.9048956
McDuffie HH, Pahwa P, Robson D, . 2005. Insect repellents, phenoxyherbicide exposure, and non-Hodgkin’s lymphoma. J Occup Environ Med 47(8):806–816.16093930
McGready R, Hamilton KA, Simpson JA, . 2001. Safety of the insect repellent N,N-diethyl-M-toluamide (DEET) in pregnancy. Am J Trop Med Hyg 65(4):285–289.11693870
Menon KS, Brown AE. 2005. Exposure of children to DEET and other topically applied insect repellents. Am J Ind Med 47(1):91–97.15597352
MMWR. 1989. Epidemiologic notes and reports seizures temporally associated with use of DEET insect repellent- New York and Connecticut. MMWR 38(39):679–680.
Moody RP, Nadeau B. 1993. An automated in vitro dermal absorption procedure: III. In vivo and in vitro comparison with the insect repellent N,N-diethyl-m-toluamide in mouse, rat, guinea pig, pig, human and tissue-cultured skin. Toxicol in Vitro 7(2):167–176.20732186
Moody RP, Carroll JM, Kresta AME. 1987. Automated high performance liquid chromatography and liquid scintillation counting determination of pesticide mixture octanol/water partition rates. Toxicol Ind Health 3(4):479–490.3433285
Moody RP, Nadeau B, Chu I. 1995. In vitro dermal absorption of N,N-diethyl-m-toluamide (DEET) in rat, guinea pig, and human skin. In Vitro Toxicology 8(3):263–275.
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokinet 5(6):485–527.7002417
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press. 15–35.
NIOSH. 1986. Health Hazard Evaluation Report. Cincinnati, OH: U.S. Department of Health and Human Services, Hazard Evaluations and Technical Assistance Branch. HETA830851757. PB87189270.
NIOSH. 2014. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/. January 08, 2014.
NLM. 2014. TOXMAP:® Environmental health maps. Superfund NPL. DEET. U.S. National Library of Medicine, National Institutes of Health. http://toxmap-classic.nlm.nih.gov/toxmap/main/quickSearch.do. December 4, 2014.
NPIRS. 2017. Diethyl toluamide. Search Federal Pesticide Products. West Lafeayette, IN: National Pesticide Information Retrieval System. http://npirspublic.ceris.purdue.edu/ppis/. April 5, 2017.
NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Research Council. National Academy Press. PB93216091.
NTP. 2016. Report on carcinogens, fourteenth edition.; Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/listed_substances_508.pdf. February 16, 2017.
Olsson AO, Baker SE, Nguyen JV, . 2004. A liquid chromatography-tandem mass spectrometry multiresidue method for quantification of specific metabolites of organophosphorus pesticides, synthetic pyrethroids, selected herbicides, and DEET in human urine. Anal Chem 76(9):2453–2461.15117183
Oman C, Hynning P. 1993. Identification of organic compounds in municipal landfill leachates. Environ Pollut 80:265–271.15091846
O’Neil MJ, Heckelman PE, Dobbelaar PH, . 2013. DEET. The Merck index. Cambridge, UK: The Royal Society of Chemistry, 515.
OSHA. 2013a. List of highly hazardous chemicals, toxics, and reactives. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations 29 CFR 1910.119, Appendix A. http://www.osha.gov/law-regs.html. January 08, 2014.
OSHA. 2013b. Toxic and hazardous substances. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations 29 CFR 1910.1000, Table Z-1. http://www.osha.gov/law-regs.html. January 08, 2014.
Osimitz TG, Murphy JV. 1997. Neurological effects associated with use of the insect repellent N,N-diethyl-m-toluamide (DEET). J Toxicol Clin Toxicol 35(5):435–441.9279298
Osimitz TG, Murphy JV, Fell LA, . 2010. Adverse events associated with the use of insect repellents containing N,N-diethyl-m-toluamide (DEET). Regul Toxicol Pharmacol 56(1):93–99.19751786
Osmundson M. 1998. Insecticides and pesticides. In: Viccellio P, ed. Emergency toxicology. 2nd ed. Philadelphia, PA: Lippincott-Raven Publishers, 401–413.
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Paxeus N. 1996. Organic pollutants in the effluents of large wastewater treatment plants in Sweden. Water Res 5:1115–1122.
Perera JL, Johnson NM, Judge DP, . 2014. Novel and highly lethal NKX2.5 missense mutation in a family with sudden death and ventricular arrhythmia. Pediatr Cardiol http://rd.springer.com/article/10.1007%2Fs00246-014-0917-3. September 11, 2014.
Petrucci N, Sardini S. 2000. Severe neurotoxic reaction associated with oral ingestion of low-dose diethyltoluamide-containing insect repellent in a child. Pediatr Emerg Care 16(5):341–342.11063364
Phillips P, Furlong ET, Stinson B, . 2005. (PHI-1117-635166) Concentrations and removal of pharmaceutical compounds at four wastewater plants in New York State, 2003-2005. Baltimore (MD). Environmental Science in a Global Society: SETAC’s Role in the Next 25 Years. http://abstracts.co.allenpress.com/pweb/setac2005/document/55859. April 24, 2014.
PhysProp. 2014. DEET. Physical Properties Database. http://www.syrres.com/what-we-do/databaseforms.aspx?id=386. April 22, 2014.
Pronczuk de Garbino J, Laborde A, Fogel de Korc E. 1983. Toxicity of an insect repellent: N,N-diethyltoluamide. Vet Hum Toxicol 25(Dec):422–423.6659308
Qiu H, Jun HW. 1996. Solid-phase extraction and liquid chromatographic quantitation of insect repellent N,N-diethyl-m-toluamide in plasma. J Pharm Biomed Anal 15(2):241–250.8933426
Qiu H, Jun HW, Dzimianski M, . 1997a. Reduced transdermal absorption of N,N-diethyl-m-toluamide from a new topical insect repellent formulation. Pharm Dev Technol 2(1):33–42.9552429
Qiu H, Jun HW, Tao J. 1997b. Pharmacokinetics of insect repellent N,N-diethyl-m-toluamide in beagle dogs following intravenous and topical routes of administration. J Pharm Sci 86(4):514–516.9109058
Qiu H, McCall JW, Jun HW. 1998. Formulation of topical insect repellent N,N-diethyl-m-toluamide (DEET): Vehicle effects on DEET in vitro skin permeation. Int J Pharm 163(1–2):167–176.
Quednow K, Puttmann W. 2009. Temporal concentration changes of DEET, TCEP, terbutryn, and nonylphenols in freshwater streams of Hesse, Germany: Possible influence of mandatory regulations and voluntary environmental agreements. Environ Sci Pollut Res Int 16(6):630–640.19462192
Reifenrath WG, Hawkins GS, Kurtz MS. 1991. Percutaneous penetration and skin retention of topically applied compounds: an in vitro-in vivo study. J Pharm Sci 80(6):526–532.1941541
RePORTER. 2017. DEET. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. May 25, 2017.
Reuveni H, Yagupsky P. 1982. Diethyltoluamide-containing insect repellent: Adverse effects in worldwide use. Arch Dermatol 118(8):582–583.7049092
Rivera-Cancel G, Bocioaga D, Hay AG. 2007. Bacterial degradation of N,N-diethyl-m-toluamide (DEET): Cloning and heterologous expression of DEET hydrolase. Appl Environ Microbiol 73(9):3105–3108.17337538
Roland EH, Jan JE, Rigg JM. 1985. Toxic encephalopathy in a child after brief exposure to insect repellents. Can Med Assoc J 132(2):155–156.3965068
Ross EA, Savage KA, Utley LJ, . 2004. Insect repellent [correction of repellant] interactions: Sunscreens enhance DEET (N,N-diethyl-m-toluamide) absorption. Drug Metab Dispos 32(8):783–785.15258101
Roy MJ, Kraus PL, Seegers CA, . 2006. Pyridostigmine, diethyltoluamide, permethrin, and stress: a double-blind, randomized, placebo-controlled trial to assess safety. Mayo Clin Proc 81(10):1303–1310.17036555
Sandstrom MW, Kolpin DW, Thurman EM, . 2005. Widespread detection of N,N-diethyl-m-toluamide in U.S. streams: Comparison with concentrations of pesticides, personal care products, and other organic wastewater compounds. Environ Toxicol Chem 24(5):1029–1034.16110978
Santhanam A, Miller MA, Kasting GB. 2005. Absorption and evaporation of N,N-diethyl-m-toluamide from human skin in vitro. Toxicol Appl Pharmacol 204(1):81–90.15781296
Saunders NR, Ek CJ, Habgood MD, . 2008. Barriers in the brain: A renaissance? Trends Neurosci 31(6):279–286.18471905
Saunders NR, Liddelow SA, Dziegielewska KM. 2012. Barrier mechanisms in the developing brain. Front Pharmacol 3(Article 46):1–18.22291651
Sawyer ML. 2010. Sawyer insect repellent ultra 30, 30% DEET liposome base. Material Safety Data Sheet. Safety Harbor, FL.
Schaefer C, Peters PW. 1992. Intrauterine diethyltoluamide exposure and fetal outcome. Reprod Toxicol 6(2):175–176.1591475
Scheuplein R, Charnley G, Dourson M. 2002. Differential sensitivity of children and adults to chemical toxicity. I. Biological basis. Regul Toxicol Pharmacol 35(3):429–447.12202057
Schoenig GP. 2002. Letters to the editor in response to “Locomotor and sensorimotor performance deficit in rats following exposure to pyridostigmine bromide, DEET, and permethrin, alone and in combination, by Abou-Donia et al. (2001) Toxicological Sciences 60, 305-314”. Toxicol Sci 68:526–519.
Schoenig GP, Osimitz TG. 2001. DEET. In: Handbook of Pesticide Toxicology. Vol. 2. Academic Press, 1439–1459.
Schoenig GP, Hartnagel RE, Jr., Osimitz TG, . 1996. Absorption, distribution, metabolism, and excretion of N,N-diethyl-M-toluamide in the rat. Drug Metab Dispos 24(2):156–163.8742226
Schoenig GP, Hartnage RE, Jr., Schardein JL, . 1993. Neurotoxicity evaluation of N,N-diethyl-m-toluamide (DEET) in rats. Fundam Appl Toxicol 21(3):355–365.8258389
Schoenig GP, Neeper-Bradley TL, Fisher LC, . 1994. Teratologic evaluations of N,N-diethyl-m-toluamide (DEET) in rats and rabbits. Fundam Appl Toxicol 23(1):63–69.7958564
Schoenig GP, Osimitz TG, Gabriel KL, . 1999. Evaluation of the chronic toxicity and oncogenicity of N,N-diethyl-m-toluamide (DEET). Toxicol Sci 47(1):99–109.10048158
Selim S, Hartnagel RE, Jr., Osimitz TG, . 1995. Absorption, metabolism, and excretion of N,N-diethyl-m-toluamide following dermal application to human volunteers. Fundam Appl Toxicol 25(1):95–100.7601331
Seo J, Lee YG, Kim SD, . 2005. Biodegradation of the insecticide N,N-diethyl-m-toluamide by fungi: Identification and toxicity of metabolites. Arch Environ Contam Toxicol 48(3):323–328.15750774
Shutty B, Swender D, Chernin L, . 2013. Insect repellents and contact urticaria: Differential response to DEET and picaridin. Cutis 91(6):280–282.23837149
Smallwood AW, DeBord KE, Lowry LK. 1992. N,N’-diethyl-m-toluamide (m-DET): Analysis of an insect repellent in human urine and serum by high-performance liquid chromatography. J Anal Toxicol 16(1):10–13.1640692
Snodgrass HL, Nelson DC, Weeks MH. 1982. Dermal penetration and potential for placental transfer of the insect repellent, N,N-diethyl-m-toluamide. Am Ind Hyg Assoc J 43(10):747–753.7148680
Snyder JW, Poe RO, Stubbins JF, . 1986. Acute manic psychosis following the dermal application of N,N-diethyl-m-toluamide (DEET) in an adult. J Toxicol Clin Toxicol 24(5):429–439.3783806
Snyder SA. 2005. PowerPoint Presentation: Endocrine disruptors and pharmaceuticals: Implications for the water industry. Las Vegas (NV): Southern Nevada Water Authority, Las Vegas Valley Water District. http://dtsc.ca.gov/AssessingRisk/PPCP/upload/05_Snyder.pdf. April 24, 2014.
Spencer TS, Hill JA, Feldman RJ, . 1979. Evaporation of diethyltoluamide from human skin in vivo and in vitro.1. J Invest Dermatol 72(6):317–319.448165
Stackelberg PE, Furlong ET, Meyer MT, . 2004. Persistence of pharmaceutical compounds and other organic wastewater contaminants in a conventional drinking-water-treatment plant. Sci Total Environ 329:99–113.15262161
Stenback F. 1977. Local and systemic effects of commonly used cutaneous agents: Lifetime studies of 16 compounds in mice and rabbits. Acta Pharmacol Toxicol 41(5):417–431.
Stinecipher J, Shah J. 1997. Percutaneous permeation of N,N-diethyl-m-toluamide (DEET) from commercial mosquito repellents and the effect of solvent. J Toxicol Environ Health 52(2):119–135.9310145
Sudakin DL, Trevathan WR. 2003. DEET: A review and update of safety and risk in the general population. J Toxicol Clin Toxicol 41(6):831–839.14677793
Swengberg JA. 1993. Cell proliferation and chemical carcinogenesis: Conference summary and future directions. Environ Health Perspect Suppl 101(5):153–158.
Tateishi T, Nakura H, Asoh M, . 1997. A comparison of hepatic cytochrome P450 protein expression between infancy and postinfancy. Life Sci 61(26):2567–2574.9416779
Taylor WG. 1986. Metabolism of N,N-diethyl-meta-toluamide by rat liver microsomes. Drug Metab Dispos 14(5):532–539.2876858
Taylor WG, Spooner RW. 1990. Identification and gas chromatographic determination of some carboxylic acid metabolites of N,N-diethyl-m-toluamide in rat urine. J Agric Food Chem 38(6):1422–1427.
Tenenbein M. 1987. Severe toxic reactions and death following the ingestion of diethyltoluamide-containing insect repellents. JAMA 258(11):1509–1511.3625951
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
Tian JN, Yiin TM. 2014. Urinary metabolites of DEET after dermal application on child and adult subjects. J Environ Health 76(6):162–169.24645428
Tisch M, Schmezer P, Faulde M, . 2002. Genotoxicity studies on permethrin, DEET and diazinon in primary human nasal mucosal cells. Eur Arch Otorhinolaryngol 259(3):150–153.12003267
Trenholm RA, Vanderford BJ, Drewes JE, . 2008. Determination of household chemicals using gas chromatography and liquid chromatography with tandem mass spectrometry. J Chromatogr A 1190:253–262.18374930
USGS. 2006. Determination of wastewater compounds in whole water by continuous liquid- liquid extraction and capillary-column gas chromatography/mass spectrometry. U.S. Geological Survey Office of Water Quality, National Water Quality Laboratory.
Usmani KA, Rose RL, Goldstein JA, . 2002. In vitro human metabolism and interactions of repellent N,N-diethyl-m-toluamide. Drug Metab Dispos 30(3):289–294.11854147
Veltri JC, Osimitz TG, Bradford DC, . 1994. Retrospective analysis of calls to poison control centers resulting from exposure to the insect repellent N,N-diethyl-m-toluamide (DEET) from 1985-1989. J Toxicol Clin Toxicol 32(1):1–16.8308945
Verschoyle RD, Brown AW, Nolan C, . 1992. A comparison of the acute toxicity, neuropathology, and electrophysiology of N,N-diethyl-m-toluamide and N,N-dimethyl-2,2-diphenylacetamide in rats. Fundam Appl Toxicol 18(1):79–88.1601213
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238(2):476–483.8681961
Vozmediano JM, Armario J, Gonzalez-Cabrerizo A. 2000. Immunologic contact urticaria from diethyltoluamide. Int J Dermatol 39(11):876–877.11123458
Waiser MJ, Humphries D, Tumber V, . 2011. Effluent-dominated streams. Part 2: Presence and possible effects of pharmaceuticals and personal care products in Wascana Creek, Saskatchewan, Canada. Environ Toxicol Chem 30(2):508–519.21072845
Wang C, Gardinali PR. 2013. Detection and occurrence of microconstituents in reclaimed water used for irrigation--a potentially overlooked source. Anal Bioanal Chem 405(18):5925–5935.23436167
Wang T, Gu X. 2007. In vitro percutaneous permeation of the repellent DEET and the sunscreen oxybenzone across human skin. J Pharm Pharm Sci 10(1):17–25.17498390
Wang C, Lu L, Zhang A, . 2013. Repellency of selected chemicals against the bed bug (Hemiptera: Cimicidae). J Econ Entomol 106(6):2522–2529.24498754
Wang T, Miller D, Burczynski F, . 2014. Evaluation of percutaneous permeation of repellent DEET and sunscreen oxybenzone from emulsion-based formulations in artificial membrane and human skin. Acta pharmaceutica Sinica. B 4(1):43–51. 10.1016/j.apsb.2013.11.002.26579363
Wantke F, Focke M, Hemmer W, . 1996. Generalized urticaria induced by a diethyltoluamide-containing insect repellent in a child. Contact Dermatitis 35(3):186–187.8930491
Weeks JA, Guiney PD, Nikiforov AI. 2012. Assessment of the environmental fate and ecotoxicity of N,N-diethyl-m-toluamide (DEET). Integr Environ Assess Manag 8(1):120–134.22006575
Weigel S, Berger U, Jensen E, . 2004. Determination of selected pharmaceuticals and caffeine in sewage and seawater from Tromso/Norway with emphasis on ibuprofen and its metabolites. Chemosphere 56:583–592.15212901
Weigel S, Kuhlmann J, Huhnerfuss H. 2002. Drugs and personal care products as ubiquitous pollutants: Occurrence and distribution of clofibric acid, caffeine and DEET in the North Sea. Sci Total Environ 295(1–3):131–141.12186282
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
WHO. 1987. Data sheet on pesticides No. 80: DEET. World Health Organization.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. January 08, 2014.
WHO. 2011. Guidelines for drinking-water quality. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/publications/2011/dwq_guidelines/en/index.html. January 08, 2014.
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advance treatise. Volume II: The elements Part A. New York, NY: Academic Press, 1–247.
Wiles D, Yee J, Castillo U, . 2014. A lethal case of DEET toxicity due to intentional ingestion. J Anal Toxicol [Epub ahead of print]
Windheuser JJ, Haslam JL, Caldwell L, . 1982. The use of N,N-diethyl-m-toluamide to enhance dermal and transdermal delivery of drugs. J Pharm Sci 71(11):1211–1213.7175710
Wu A, Pearson ML, Shekoski DL, . 1979. High resolution gas chromatography/ mass spectrometric characterization of urinary metabolites of N,N-diethyl-m-toluamide (DEET) in man. J High Resolut Chromatogr Commun 2(9):558–562.
Yan X, Lashley S, Smulian JC, . 2009. Pesticide concentrations in matrices collected in the perinatal period in a population of pregnant women and newborns in New Jersey, USA. Hum Ecol Risk Assess 15(5):948–967.
Yang X, Chen F, Meng F, . 2013. Occurrence and fate of PPCPs and correlations with water quality parameters in urban riverine waters of the Pearl River Delta, South China. Environ Sci Pollut Res Int 20(8):5864–5875.23608973
Yeung JM, Taylor WG. 1988. Metabolism of N,N-diethyl-m-toluamide (DEET) by liver microsomes from male and female rats. Simultaneous quantitation of DEET and its metabolites by high performance liquid chromatography. Drug Metab Dispos 16(4):600–604.2903029
Zadikoff CM. 1979. Toxic encephalopathy associated with use of insect repellent. J Pediatr 95(1):140–142.479998
Zaugg SD, Smith SG, Schroeder MP, . 2002. Method of analysis of the U.S. Geological Survey National Water Quality Laboratory--Determination of wastewater compounds by polystyrene-divinylbenzene solid-phase extraction and capillary-column gas chromatography/mass spectrometry: U.S. Geological Survey Water-Resources Investigations Report 01-4186. Method Number 0-1433-01.
Zeiger E, Anderson B, Haworth S, . 1992. Salmonella mutagenicity tests: V. Results from the testing of 311 chemicals. Environ Mol Mutagen 21:2–141.
Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12(1):29–34.643372