# 8 REGULATIONS, ADVISORIES, AND GUIDELINES

MRLs are substance-specific estimates that are intended to serve as screening levels. They are used by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites.

ATSDR derived an intermediate-duration oral MRL of 1.0 mg/kg/day for DEET based on a NOAEL of 100 mg DEET/kg/day for developmental effects in rats (EPA 1989). The MRL was derived by dividing the NOAEL by an uncertainty factor of 100 (10 for animal to human extrapolation and 10 for human variability).

The International Agency for Research on Cancer (IARC) has not classified DEET as to its carcinogenicity (IARC 2013). The World Health Organization (WHO) has not established any air quality or drinking water guidelines for DEET (WHO 2010, 2011).

The Occupational Safety and Health Administration (OSHA) has not established any enforceable standards for DEET (OSHA 2013b) nor has the National Institute for Occupational Safety and Health (NIOSH) or the American Conference of Governmental Industrial Hygienists (ACGIH) recommended a threshold limit value for DEET (ACGIH 2013; NIOSH 2012).

The American Industrial Hygiene Association (AIHA) and the Department of Energy (DOE) have not established any values for responding to potential releases of airborne DEET for use in community emergency planning (AIHA 2013, DOE 2012).

The Department of Health and Human Services (NTP 2016) has not classified DEET as a carcinogen. The EPA’s OPP (EPA 2007) classified DEET as a Group D substance, not classifiable as a human carcinogen, based on no evidence of mutagenicity in multiple tests, or of carcinogenicity in long-term oral ingestion studies in adult rats or mice. EPA’s OPP (EPA2007) has not derived inhalation or oral toxicity values for DEET.

EPA has classified DEET as an inert pesticide ingredient in pesticide products that are approved for nonfood human and veterinary use only (EPA 2014c).

The international and national regulations, advisories, and guidelines regarding DEET in air, water, and other media are summarized in Table 8-1.

Table 8-1 Regulations, Advisories, and Guidelines Applicable to DEET

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | No data | IARC 2013
WHO | Air quality guidelines | No data | WHO 2010
WHO | Drinking water quality guidelines | No data | WHO 2011
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV-TWA | No data | ACGIH 2013
AIHA | ERPGs | No data | AIHA 2013
DOE | PACs | No data | DOE 2012
EPA | AEGLs | No data | EPA 2013a
EPA | Second AEGL chemical priority list | No data | EPA 2014a
EPA | Hazardous air pollutant | No data | EPA 2014b; 42 USC 7412
EPA | NAAQS | No data | EPA 2014e
NIOSH | REL | No data | NIOSH 2014
NIOSH | IDLH | No data
OSHA | PEL (8-hour TWA) for general industry | No data | OSHA 2013b; 29 CFR 1910.1000, Table Z-1
OSHA | Highly hazardous chemicals | No data | OSHA 2013a; 29 CFR 1910.119, Appendix A
b. Water
EPA | Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act | No data | EPA 2013b; 40 CFR 116.4
EPA | Drinking water contaminant candidate list | No data | EPA 2009a; 74 FR 51850
EPA | Drinking water standards and health advisories | No data | EPA 2012a
EPA | National primary drinking water standards | No data | EPA 2009b
EPA | National recommended water quality criteria | No data | EPA 2014f
EPA | Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | No data | EPA 2013d; 40 CFR 117.3
c. Food
FDA | EAFUS^a^ | No data | FDA 2014
d. Other
ACGIH | Carcinogenicity classification | No data | ACGIH 2013
EPA | Carcinogenicity classification | Group D^b^ | EPA 2007
EPA | RfC | Not available
EPA | RfD | Not available
EPA | Identification and listing of hazardous waste | No data | EPA 2013c; 40 CFR 261, Appendix VIII
EPA | Inert pesticide ingredients in pesticide products approved for nonfood use only | Yes | EPA 2014c
EPA | Master Testing List | No data | EPA 2014d
EPA | RCRA waste minimization PBT priority chemical list | No data | EPA 1998a; 63 FR 60332
EPA | Standards for owners and operators of hazardous waste TSD facilities; groundwater monitoring list | No data | EPA 2013e; 40 CFR 264; Appendix IX
EPA | Superfund, emergency planning, and community right-to-know
EPA | Designated CERCLA hazardous substance and reportable quantity | No data | EPA 2013f, 40 CFR 302.4
EPA | Effective date of toxic chemical release reporting | No data | EPA 2013h, 40 CFR 372.65
EPA | Extremely hazardous substances and its threshold planning quantity | No data | EPA 2013g, 40 CFR 355, Appendix A
EPA | TSCA chemical lists and reporting periods | No data | EPA 2013i, 40 CFR 712.30
EPA | TSCA health and safety data reporting | No data | EPA 2013j, 40 CFR 716.120
NTP | Carcinogenicity classification | No data | NTP 2016

a The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

b Not classifiable as a human carcinogen.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; AIHA = American Industrial Hygiene Association; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; ERPG = emergency response planning guidelines; FDA = Food and Drug Administration; FR = Federal Register; GRAS = generally recognized as safe; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; NAAQS = National Ambient Air Quality Standards; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PBT = persistent, bioaccumulative, and toxic; PEL = permissible exposure limit; RCRA = Resource Conservation and Recovery Act; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; TSCA = Toxic Substances Control Act; TSD = treatment, storage, and disposal; TWA = time-weighted average; USC = United States Code; WHO = World Health Organization