# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of DEET is located in Table 4-1.

DEET is the chemical, N,N-diethyl-meta-toluamide, ortho and para isomers are present at low concentrations. DEET is an N,N-disubstituted aromatic carbonamide, which is used as an active ingredient in insect repellents. DEET was registered for commercial use by the general public in 1957. In December 1980, DEET was issued a Registration Standard (PB81-207722) followed by a Data Call-In in September 1988 requiring additional mammalian and avian toxicity data (EPA 1998c). Technical-grade DEET is typically formulated with carriers and solvents (such as ethanol, isopropanol, or water) for use in commercial products. Commercial product formulations include microencapsulated, pressurized sprays or aerosols, impregnated materials such as towelettes and roll-ons, and ready-to-use solutions such as non-aerosol pump sprays, liquids, creams, lotions, and foams. Some DEET products are also formulated with sunscreen. (EPA 2014l, 2014m; HSDB 2001). The DEET concentration in commercial products varies according to country and can range from 4 to 100% (by weight) in the United States. Technical-grade DEET typically contains 95% meta-isomer, the most effective form of the chemical (EPA 1998b, 1998c; O’Neil et al. 2013). The EPA does not require expiration dates to be included on the label of DEET products manufactured in the United States (EPA 1998b).

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of DEET is located in Table 4-2.

Table 4-1 Chemical Identity of DEET (N,N-Diethyl-meta-Toluamide)

Characteristic | Information
Chemical name | N,N-Diethyl-meta-toluamide
Synonym(s) | Benzamide, N,N-diethyl-3-methyl; N,N-diethyl-3-methylbenzamide; diethyltoluamide; diethyl toluamide; N,N-diethyl-m-toluamide; 3-methylN,N-diethylbenzamide; m-toluamide, N,N-diethyl; m-toluic acid diethylamide; m-delphene | ChemIDplus 2013; HSDB 2001
Registered trade name(s) | DEET; Delphene^®^; MGK diethyltoluamide; Detamide_®_; Detamine; Metadelphene^®^; Skeeter Skat^®^; Autan^®^ (some formulations); Amincene C 140^®^; Amincene C-EM^®^; Bepper-DET^®^; DET^®^; DETA_®_; DET-20^®^; DETA-20^®^; Flypel^®^; Muscol^®^; Muskol^®^; Off!^®^; Repel^®^; Repper-DET^®^; Repudin-Special^®^; Chemform^®^; Cutter^®^; Old Time Woodsman^®^ | ChemIDplus 2013; EPA 1998b, 1998c; HSDB 2001
Chemical formula | C_12_H_17_NO | HSDB 2001
Chemical structure | [image]
Identification numbers:
CAS registry | 134-62-3 | HSDB 2001
NIOSH RTECS | No data
EPA hazardous waste | No data
DOT/UN/NA/IMDG shipping | UN; IMO
HSDB | 1582 | HSDB 2001
NCI | No data
EPA Pesticide Chemical Code | 080301 | ChemIDplus 2013; HSDB 2001

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of DEET

Property | Information | Reference
Molecular weight | 191.27 | HSDB 2001
Color | Nearly colorless liquid | EPA 1998b, 2012c
Physical state | Liquid | HSDB 2001
Melting point | -45°C | PhysProp 2014
Melting point | -44.3°C | Weeks et al. 2012
Boiling point | 284-285°C | Weeks et al. 2012
Boiling point | 284.2°C | ECHA 2010
Boiling point | 160°C at 19 mm Hg | HSDB 2001
Boiling point | 111°C at 1.0 mm Hg | O’Neil 2013
Boiling point | 290°C 760 mm Hg | PhysProp 2014
Density:
at 20°C/4°C | 0.996 g/cm^3^ | HSDB 2001
at 20°C/4°C | 1.01 g/cm^3^ | Weeks et al. 2012
at 20°C/4°C | 0.998 g/cm^3^ | Weeks et al. 2012
Odor | Faint, characteristic odor | EPA 1998b, 2012c
Odor threshold:
Water | No data
Air | No data
Taste threshold | No data
Solubility:
Water at 25°C | 11,200 mg/L | Weeks et al. 2012
Water at 25°C | >1,000 mg/L at room temperature; | CITI 1992; HSDB 2001
Water at 25°C | 9,900 mg/L at 25°C | O’Neil et al. 2013
Organic solvent(s) | Miscible in benzene, carbon disulfide, chloroform, ethanol, ether, and isopropanol; soluble in hexane, acetonitrile, toluene, methylene chloride, and methanol; practically insoluble in glycerin | HSDB 2001; O’Neil et al. 2013; Weeks et al. 2012
Partition coefficients:
Log K_ow_ | 2.02 | Moody 1987; HSDB 2001
Log K_ow_ | 2.18 | PhysProp 2014
Log K_ow_ | 2.4 at 22°C and pH 6 | ECHA 2010
Log K_ow_ | 2.66 | CITI 1992; Weeks et al. 2012
K_oc_ | 300 | HSDB 2001
K_oc_ | 47–126 | ECHA 2010; Weeks et al. 2012
Vapor pressure
at 20°C | 0.0056 mm Hg | HSDB 2001
at 20°C | 0.00167 mm Hg at 25°C | O’Neil et al. 2013
at 20°C | 0.00013 mm Hg at 25°C | Weeks et al. 2012
Henry’s law constant | 5.1 x10^-8^ atm-m^3^/mol at 25°C | EPIWIN 2012
Autoignition temperature | No data
Flashpoint | 155°C | O’Neil et al. 2013
Flashpoint | 144°C | ECHA 2010
Flammability limits | No data
Explosive limits | No data