# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-57, Atlanta, Georgia 30329-4027.

## DEET Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | DEET
CAS Numbers: | 134-62-3
Date: | August 2017
Profile Status: | Final
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 35
Species: | Rats

[underlined: Minimal Risk Level]: 1.0 [X] mg/kg/day [ ] ppm

[underlined: Reference]: EPA. 1989. [EPA memorandum 007645 from Whang Phang, Subject: Review of a two-generation reproduction on DEET, dated 13 December 1989]. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/pesticides/chem_search/cleared_reviews/csr_PC-080301_13-Dec-89_032.pdf. April 24, 2014.

[underlined: Experimental design]: Groups of Sprague-Dawley rats (28/sex/group) were fed diets containing 0, 500, 2,000, or 5,000 ppm DEET for at least 80 days before mating (EPA 1989). Using the standard conversion, 20 ppm=1 mg/kg/day (EPA 1998b), the diet provided doses of approximately 0, 25, 100, or 250 mg DEET/kg/day. Parental F0 animals were allowed to produce only one litter. Animals remained on the test diets during mating, gestation, and lactation. After weaning of F1 rats, 28 males and 28 females were randomly chosen to serve as parents for the F2 generation. F1 rats were mated after at least 93 days on the test diet. After weaning, 10 pups/sex/groups were subjected to gross necropsy. F0 females were killed after the selection of F1 parents. F1 females were sacrificed after weaning of their litters. The following parameters were used to assess toxicity: twice daily observations for deaths and clinical signs, body weight, and food consumption (not measured during the mating periods). Additionally, gross necropsy and histological examination of the ovaries, prostate, seminal vesicles, testes with epididymides, uterus, vagina, and all gross lesions were conducted in all parental rats and 10 weanlings/sex/group in the control and high-dose groups. Parameters used to assess developmental toxicity in the F1 and F2 litters included number of live and stillborn pups, external anomalies, sex and body weight grouped by sex on lactation days 0, 4, 7, and 14, sex and individual body weights (only group weights reported) on lactation day 21, viability, and behavioral abnormalities at least twice daily during lactation.

[underlined: Effects noted in study and corresponding doses]: There were no chemical-related deaths during the study. Hair loss appeared to be more prominent in high-dose F0 and F1 females than in other groups. Body weights of parental rats were lower in some of the mid- and high-dose groups at some points in the study, but the difference with controls was generally <10%. Changes in food consumption tended to parallel the changes in body weight and were generally <10% different than controls. F1 males showed mottled kidneys with incidences of 0/23, 2/23 (9%), 6/23 (26%), and 8/23 (35%) of the males (control and increasing dose groups). Microscopy revealed inflammation, hyaline droplet and granular cast formation, and regeneration of tubules. No explicit information was provided in the review regarding the other organs examined. The only significant reproductive/developmental effects reported were decreased F2 pup viability in the low- and high-dose groups on postnatal day 4 and reduced male and female F1 and F2 pup weights in the high-dose group on lactation days 14 and 21 (Table A-1).

Table A-1 Body Weight (g) of Rats on Lactation Day 21 in a 2-Generation Reproductive Study

Doses (mg/kg/day) | 0 | 25 | 100 | 250
F1 males | 46.2±6.50^a^ | 46.8±5.06 | 45.7±4.53 | 40.1±4.22^b^
F1 females | 44.1±4.64 | 44.6±4.44 | 44.2±4.51 | 39.1±4.60^b^
F2 males | 50.4±4.31 | 49.4±6.07 | 47.9±4.02 | 44.5±3.93^b^
F2 females | 47.3±4.52 | 47.6±5.35 | 44.1±7.50 | 42.3±3.23^b^

a Mean±standard deviation.

b p<0.01.

Source: EPA (1989)

[underlined: Dose and end point used for MRL derivation]: NOAEL of 100 mg/kg/day (LOAEL of 250 mg/kg/day for reduced body weight in F1 and F2 male and female pups on lactation day 21).

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Yes, 20 ppm=1 mg/kg/day was used as done in EPA (1998b).

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? No.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: The intermediate-duration oral database showed relatively little toxicity for DEET. Most effects reported were of questionable toxicological significance except for the developmental effects that were used for MRL derivation. The fact that the reduction in body weight occurred in both male and female pups from both the F1 and F2 generations, provides strength to the MRL.

[underlined: Intermediate-duration oral MRL is protective for chronic-duration exposure]. The available chronic-duration oral database does not support derivation of a chronic-duration oral MRL for DEET. Long-term exposure, however, does not lead to more toxic effects than those reported for intermediate-duration exposure, so the intermediate-duration oral MRL of 1 mg/kg/day for DEET is protective for chronic-duration exposure.

[underlined: Agency Contacts (Chemical Managers)]: Sam Keith