# CHAPTER 8 REFERENCES

Abdelouahab N, Mergler D, Takser L, 2008. Gender differences in the effects of organochlorines, mercury, and lead on thyroid hormone levels in lakeside communities of Quebec (Canada). Environ Res 107(3):380–392. 10.1016/j.envres.2008.01.006.18313043
Abou-Arab AA. 1999. Behavior of pesticides in tomatoes during commercial and home preparation. Food Chem 65:509–514.
Adamson RH, Sieber SM. 1979. The use of nonhuman primates for chemical carcinogenesis studies. In: Regulatory aspects of carcinogenesis and food additives: The Delaney Clause. San Francisco: Academy Press, 257–296.
Adamson RH, Sieber SM. 1983. Chemical carcinogenesis studies in nonhuman primates. Basic Life Sci 24:129–156. 10.1007/978-1-4684-4400-1_7.6860262
Adamsson A, Salonen V, Paranko J, 2009. Effects of maternal exposure to di-isononylphthalate (DINP) and 1,1-dichloro-2,2-bis(p-chlorophenyl)ethylene (p,p’-DDE) on steroidogenesis in the fetal rat testis and adrenal gland. Reprod Toxicol 28(1):66–74. 10.1016/j.reprotox.2009.03.002.19490997
Addison RF, Stobo WT. 2001. Trends in organochlorine residue concentrations and burdens in grey seals (Halichoerus grypus) from Sable Is., NS, Canada, between 1974–1994. Environ Pollut 112(3):505–513.11291457
Adeshina F, Todd EL. 1990. Organochlorine compounds in human adipose tissue from north Texas. J Toxicol Environ Health 29(2):147–156. 10.1080/15287399009531379.1688952
Agarwal N, Sanyal S, Khuller GK, 1978. Effect of acute administration of dichlorodiphenyl trichloroethane on certain enzymes of Rhesus monkey. Indian J Med Res 68:1001–1006.220189
Agay-Shay K, Martinez D, Valvi D, 2015. Exposure to endocrine-disrupting chemicals during pregnancy and weight at 7 years of age: A multi-pollutant approach. Environ Health Perspect 123(10):1030–1037. 10.1289/ehp.1409049.25956007
Agthe C, Garcia H, Shubik P, 1970. Study of the potential carcinogenicity of DDT in the Syrian golden hamster. Proc Soc Exp Biol Med 134(1):113–116. 10.3181/00379727-134-34740.4316381
Aigner EJ, Leone AD, Falconer RL. 1998. Concentrations and enantiomeric ratios of organochlorine pesticides in soils from the U.S. Corn Belt. Environ Sci Technol 32(9):1162–1168. 10.1021/es970750h.
AIHW. 2009. A picture of Australia’s children 2009. Canberra, Australia: Australian Institute of Health and Welfare.
Airaksinen R, Rantakokko P, Eriksson JG, 2011. Association between type 2 diabetes and exposure to persistent organic pollutants. Diabetes Care 34(9):1972–1979. 10.2337/dc10-2303.21816981
Aislabie JM, Richards NK, Boul HL. 1997. Microbial degradation of DDT and its residues- a review. N Z J Agric Res 40:269–282.
Alegria-Torres JA, Diaz-Barriga F, Gandolfi AJ, 2009. Mechanisms of p,p’-DDE-induced apoptosis in human peripheral blood mononuclear cells. Toxicol in Vitro 23(6):1000–1006. 10.1016/j.tiv.2009.06.021.19545618
Alexander M. 1995. How toxic are toxic chemicals in soil? Environ Sci Technol 29(11):2713–2717. 10.1021/es00011a003.22206515
Alexander M. 1997. Environmentally acceptable endpoints in soil: Risk-based approach to contaminated site management based on availability of chemicals in soil. American Academy of Environmental Engineers. 48–56, 103–104, 110–111, 115–116, 127–136.
Allen-Gil SM, Gubala CP, Wilson R, 1997. Organochlorine pesticides and polychlorinated biphenyls (PCBs) in sediments and biota from four US Arctic lakes. Arch Environ Contam Toxicol 33(4):378–387. 10.1007/s002449900267.9419256
Al-Othman AA, Abd-Alrahman SH, Al-Daghri NM. 2015. DDT and its metabolites are linked to increased risk of type 2 diabetes among Saudi adults: a cross-sectional study. Environ Sci Pollut Res Int 22(1):379–386. 10.1007/s11356-014-3371-0.25077657
Al-Saleh I, Coskun S, El-Doush I, 2009. Outcome of in-vitro fertilization treatment and DDT levels in serum and follicular fluid. Med Sci Monit 15(11):BR320–333.19865049
Al-Saleh I, Al-Doush I, Alsabbaheen A, 2012. Levels of DDT and its metabolites in placenta, maternal and cord blood and their potential influence on neonatal anthropometric measures. Sci Total Environ 416:62–74. 10.1016/j.scitotenv.2011.11.020.22192892
Alvarado-Hernandez DL, Montero-Montoya R, Serrano-Garcia L, 2013. Assessment of exposure to organochlorine pesticides and levels of DNA damage in mother-infant pairs of an agrarian community. Environ Mol Mutagen 54(2):99–111. 10.1002/em.21753.23355095
Alvarez-Pedrerol M, Ribas-Fito N, Torrent M, 2008. Effects of PCBs, p,p’-DDT, p,p’-DDE, HCB and beta-HCH on thyroid function in preschool children. Occup Environ Med 65(7):452–457. 10.1136/oem.2007.032763.17933884
Alvarez-Pedrerol M, Guxens M, Ibarluzea J, 2009. Organochlorine compounds, iodine intake, and thyroid hormone levels during pregnancy. Environ Sci Technol 43(20):7909–7915. 10.1021/es9007273.19921913
Amacher DE, Zelljadt I. 1984. Mutagenic activity of some clastogenic chemicals at the hypoxanthine guanine phosphoribosyl transferase locus of Chinese hamster ovary cells. Mutat Res 136:137–145.6717480
Aminov Z, Haase R, Rej R, 2016. Diabetes prevalence in relation to serum concentrations of polychlorinated biphenyl (PCB) congener groups and three chlorinated pesticides in a Native American population. Environ Health Perspect 124(9):1376–1383. 10.1289/ehp.1509902.27035469
Anand M, Agarwal P, Singh L, 2015. Persistent organochlorine pesticides and oxidant/antioxidant status in the placental tissue of the women with full-term and pre-term deliveries. Toxicology Research 4(2):326–332. 10.1039/c4tx00094c.
Anderson HA. 1985. Utilization of adipose tissue biopsy in characterizing human halogenated hydrocarbon exposure. Environ Health Perspect 60:127–131. 10.1289/ehp.8560127.2992921
Anderson HA, Falk C, Hanrahan L, 1998. Profiles of Great Lakes critical pollutants: a sentinel analysis of human blood and urine. The Great Lakes Consortium. Environ Health Perspect 106(5):279–289. 10.1289/ehp.98106279.9560354
Anderson KA, Johnson E. 2001. Bioavailable organochlorine pesticides in a semi-arid region of eastern Oregon, USA, as determined by gas chromatography with electron-capture detection. J AOAC Int 84(5):1371–1382.11601456
Andrea MM, Tomita RY, Luchini LC, 1994. Laboratory studies on volatilization and mineralization of c14-p,p’-ddt in soil, release of bound residues and dissipation from solid surfaces. J Environ Sci Health B 29:133–139.
Aneck-Hahn NH, Schulenburg GW, Bornman MS, 2007. Impaired semen quality associated with environmental DDT exposure in young men living in a malaria area in the Limpopo Province, South Africa. J Androl 28(3):423–434. 10.2164/jandrol.106.001701.17192596
Anthony RG, Miles K, Estes JA, 1999. Productivity, diets, and environmental contaminants in nesting bald eagles from the Aleutian Archipelago. Environ Toxicol Chem 18(9):2054–2062.
Appenzeller BM R, Hardy EM, Grova N, 2017. Hair analysis for the biomonitoring of pesticide exposure: comparison with blood and urine in a rat model. Arch Toxicol 91(8):2813–2825. 10.1007/s00204-016-1910-9.28011991
Araki A, Miyashita C, Mitsui T, 2018. Prenatal organochlorine pesticide exposure and the disruption of steroids and reproductive hormones in cord blood: The Hokkaido study. Environ Int 110:1–13. 10.1016/j.envint.2017.10.006.29055783
Archibeque-Engle SL, Tessari JD, Winn DT, 1997. Comparison of organochlorine pesticide and polychlorinated biphenyl residues in human breast adipose tissue and serum. J Toxicol Environ Health 52(4):285–293. 10.1080/00984109708984065.9354175
Arisoy M. 1998. Biodegradation of chlorinated organic compounds by white-rot fungi. Bull Environ Contam Toxicol 60(6):872–876. 10.1007/s001289900708.9606263
Aronson KJ, Wilson JW, Hamel M, 2010. Plasma organochlorine levels and prostate cancer risk. J Expo Sci Environ Epidemiol 20(5):434–445. 10.1038/jes.2009.33.19513097
Arrebola JP, Pumarega J, Gasull M, 2013. Adipose tissue concentrations of persistent organic pollutants and prevalence of type 2 diabetes in adults from Southern Spain. Environ Res 122:31–37. 10.1016/j.envres.2012.12.001.23290489
Arrebola JP, Ocana-Riola R, Arrebola-Moreno AL, 2014. Associations of accumulated exposure to persistent organic pollutants with serum lipids and obesity in an adult cohort from Southern Spain. Environ Pollut 195:9–15. 10.1016/j.envpol.2014.08.003.25173983
Arrebola JP, Belhassen H, Artacho-Cordon F, 2015a. Risk of female breast cancer and serum concentrations of organochlorine pesticides and polychlorinated biphenyls: a case-control study in Tunisia. Sci Total Environ 520:106–113. 10.1016/j.scitotenv.2015.03.045.25804877
Arrebola JP, Fernandez MF, Martin-Olmedo P, 2015b. Historical exposure to persistent organic pollutants and risk of incident hypertension. Environ Res 138:217–223. 10.1016/j.envres.2015.02.018.25725302
Arrebola JP, Gonzalez-Jimenez A, Fornieles-Gonzalez C, 2015c. Relationship between serum concentrations of persistent organic pollutants and markers of insulin resistance in a cohort of women with a history of gestational diabetes mellitus. Environ Res 136:435–440. 10.1016/j.envres.2014.11.007.25460665
Arrebola JP, Fernandez-Rodriguez M, Artacho-Cordon F, 2016. Associations of persistent organic pollutants in serum and adipose tissue with breast cancer prognostic markers. Sci Total Environ 566–567:41–49. 10.1016/j.scitotenv.2016.04.188.
Arthur RD, Cain JD, Barrentine BF. 1977. DDT residues in air in the Mississippi delta, 1975. Pestic Monit J 10(4):168.857242
Ashley-Martin J, Levy AR, Arbuckle TE, 2015. Maternal exposure to metals and persistent pollutants and cord blood immune system biomarkers. Environ Health 14:52. 10.1186/s12940-015-0046-3.26084354
Asplund L, Svensson BG, Nilsson A, 1994. Polychlorinated biphenyls, 1,1,1-trichloro-2,2-bis(p-chlorophenyl)ethane (p,p’-DDT) and 1,1-dichloro-2,2-bis(p-chlorophenyl)-ethylene (p,p’-DDE) in human plasma related to fish consumption. Arch Environ Health 49(6):477–486. 10.1080/00039896.1994.9955004.7818291
Atlas E, Foster R, Giam CS. 1982. Air-sea exchange of high-molecular weight organic pollutants: laboratory studies. Environ Sci Technol 16(5):283–286. 10.1021/es00099a010.22257254
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 2019. DDT. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry.
Attaran A, Roberts DR, Curtis CF, 2000. Balancing risks on the backs of the poor. Nat Med 6(7):729–731. 10.1038/77438.10888909
Austin H, Keil JE, Cole P. 1989. A prospective follow-up study of cancer mortality in relation to serum DDT. Am J Public Health 79(1):43–46. 10.2105/ajph.79.1.43.2909181
Axmon A, Rignell-Hydbom A. 2006. Estimations of past male and female serum concentrations of biomarkers of persistent organochlorine pollutants and their impact on fecundability estimates. Environ Res 101(3):387–394. 10.1016/j.envres.2005.10.005.16352301
Axmon A, Thulstrup AM, Rignell-Hydbom A, 2006. Time to pregnancy as a function of male and female serum concentrations of 2,2’4,4’5,5’-hexachlorobiphenyl (CB-153) and 1,1-dichloro-2,2-bis (p-chlorophenyl)-ethylene (p,p’-DDE). Hum Reprod 21(3):657–665. 10.1093/humrep/dei397.16361295
Bachelet D, Verner MA, Neri M, 2019. Breast cancer and exposure to organochlorines in the CECILE Study: Associations with plasma levels measured at the time of diagnosis and estimated during adolescence. Int J Environ Res Public Health 16(2) 10.3390/ijerph16020271.
Bagga D, Anders KH, Wang HJ, 2000. Organochlorine pesticide content of breast adipose tissue from women with breast cancer and control subjects. J Natl Cancer Inst 92(9):750–753. 10.1093/jnci/92.9.750.10793112
Bahena-Medina LA, Torres-Sanchez L, Schnaas L, 2011. Neonatal neurodevelopment and prenatal exposure to dichlorodiphenyldichloroethylene (DDE): a cohort study in Mexico. J Expo Sci Environ Epidemiol 21(6):609–614. 10.1038/jes.2011.25.21750576
Baker RD, Applegate HG. 1970. Effect of temperature and ultraviolet radiation on the persistence of methyl parathion and DDT in soils. Agron J 62:509–512.
Bakke JE, Bergman AL, Larsen GL. 1982. Metabolism of 2,4’,5-trichlorobiphenyl by the mercapturic acid pathway. Science 217(4560):645–647. 10.1126/science.6806905.6806905
Balaguer P, Francois F, Comunale F, 1999. Reporter cell lines to study the estrogenic effects of xenoestrogens. Sci Total Environ 233(1–3):47–56. 10.1016/s0048-9697(99)00178-3.10492897
Balte PP, Kuhr J, Kruse H, 2017. Body burden of dichlorodiphenyl dichloroethene (DDE) and childhood pulmonary function. Int J Environ Res Public Health 14(11) 10.3390/ijerph14111376.
Banerjee BD. 1987a. Sub-chronic effect of DDT on humoral immune response to a thymus-independent antigen (bacterial lipopolysaccharide) in mice. Bull Environ Contam Toxicol 39:822–826.3318960
Banerjee BD. 1987b. Effects of sub-chronic DDT exposure on humoral and cell-mediated immune responses in albino rats. Bull Environ Contam Toxicol 39:827–834.3690008
Banerjee BD, Ramachandran M, Hussain QZ. 1986. Sub-chronic effect of DDT on humoral immune response in mice. Bull Environ Contam Toxicol 37(3):433–440. 10.1007/BF01607785.3527308
Banerjee BD, Saha S, Mohapatra TK, 1995. Influence of dietary protein on DDT-induced immune responsiveness in rats. Indian J Exp Biol 33(10):739–744.8575804
Banerjee BD, Ray A, Pasha ST. 1996. A comparative evaluation of immunotoxicity of DDT and its metabolites in rats. Indian J Exp Biol 34(6):517–522.8792639
Banerjee BD, Koner BC, Pasha ST. 1997a. Influence of DDT exposure on susceptibility to human leprosy bacilli in mice. Int J Lepr Other Mycobact Dis 65(1):97–99.9207760
Banerjee BD, Koner BC, Ray A. 1997b. Influence of stress on DDT-induced humoral immune responsiveness in mice. Environ Res 74:43–47.9339213
Bard SM. 1999. Global transport of anthropogenic contaminants and the consequences for the arctic marine ecosystem. Mar Pollut Bull 38(5):356–379.
Barmpas M, Vakonaki E, Tzatzarakis M, 2020. Organochlorine pollutants’ levels in hair, amniotic fluid and serum samples of pregnant women in Greece. A cohort study. Environ Toxicol Pharmacol 73:103279. 10.1016/j.etap.2019.103279.31704585
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Bassig BA, Engel LS, Langseth H, 2019. Pre-diagnostic serum concentrations of organochlorines and risk of acute myeloid leukemia: A nested case-control study in the Norwegian Janus Serum Bank Cohort. Environ Int 125:229–235. 10.1016/j.envint.2019.01.066.30721827
Bassig BA, Shu XO, Sjodin A, 2020. Prediagnostic blood levels of organochlorines and risk of non-Hodgkin lymphoma in three prospective cohorts in China and Singapore. Int J Cancer 146(3):839–849. 10.1002/ijc.32350.31001807
Bayarri S, Conchello P, Arino A, 1994. DDT, DDT metabolites, and other organochlorines as affected by thermal processing in three commercial cuts of lamb. Bull Environ Contam Toxicol 52:554–559.8167449
Beard J, Marshall S, Jong K, 2000. 1,1,1-Trichloro-2,2-bis (p-chlorophenyl)-ethane (DDT) and reduced bone mineral density. Arch Environ Health 55(3):177–180. 10.1080/00039890009603403.10908100
Beard J, Sladden T, Morgan G, 2003. Health impacts of pesticide exposure in a cohort of outdoor workers. Environ Health Perspect 111(5):724–730. 10.1289/ehp.5885.12727601
Becker PR, Mackey EA, Demiralp R, 1997. Concentrations of chlorinated hydrocarbons and trace elements in marine mammal tissues archives in the U.S. National Biomonitoring Specimen Bank. Chemosphere 34(9/10):2067–2098.9159906
Ben Maamar M, Sadler-Riggleman I, Beck D, 2018. Epigenetic transgenerational inheritance of altered sperm histone retention sites. Sci Rep 8(1):5308. 10.1038/s41598-018-23612-y.29593303
Ben Maamar M, Nilsson E, Sadler-Riggleman I, 2019. Developmental origins of transgenerational sperm DNA methylation epimutations following ancestral DDT exposure. Dev Biol 445(2):280–293. 10.1016/j.ydbio.2018.11.016.30500333
Ben Maamar M, King SE, Nilsson E, 2020. Epigenetic transgenerational inheritance of parent-of-origin allelic transmission of outcross pathology and sperm epimutations. Dev Biol 458(1):106–119. 10.1016/j.ydbio.2019.10.030.31682807
Ben-Dyke R, Sanderson DM, Noakes DN. 1970. Acute toxicity data for pesticides (1970). World Rev Pest Control 9:119–127.
Bennison BE, Mostofi FK. 1950. Observations on inbred mice exposed to DDT. J Natl Cancer Inst 10(4):989–992.15415737
Berg V, Nost TH, Sandanger TM, 2018. Predicting human plasma concentrations of persistent organic pollutants from dietary intake and socio-demographic information in the Norwegian Women and Cancer study. Environ Int 121(Pt 2):1311–1318. 10.1016/j.envint.2018.10.057.30415879
Berghuis SA, Van Braeckel K, Sauer PJ J, 2018. Prenatal exposure to persistent organic pollutants and cognition and motor performance in adolescence. Environ Int 121(Pt 1):13–22. 10.1016/j.envint.2018.08.030.30172231
Bergman A, Norstrom RJ, Haraguchi K, 1994. PCB and DDE methyl sulfones in mammals from Canada and Sweden. Environ Toxicol Chem 13:121–128.
Bergonzi R, Specchia C, Dinolfo M, 2009. Distribution of persistent organochlorine pollutants in maternal and foetal tissues: data from an Italian polluted urban area. Chemosphere 76(6):747–754. 10.1016/j.chemosphere.2009.05.026.19539348
Bergonzi R, De Palma G, Specchia C, 2011. Persistent organochlorine compounds in fetal and maternal tissues: evaluation of their potential influence on several indicators of fetal growth and health. Sci Total Environ 409(15):2888–2893. 10.1016/j.scitotenv.2011.04.031.21669324
Bernard RF, Gaertner RA. 1964. Some effects of DDT on reproduction in mice. J Mammal 45(2):272–276.
Bernard L, Martinat N, Lecureuil C, 2007. Dichlorodiphenyltrichloroethane impairs follicle-stimulating hormone receptor-mediated signaling in rat Sertoli cells. Reprod Toxicol 23(2):158–164. 10.1016/j.reprotox.2006.11.002.17157474
Bertrand KA, Spiegelman D, Aster JC, 2010. Plasma organochlorine levels and risk of non-Hodgkin lymphoma in a cohort of men. Epidemiology 21(2):172–180. 10.1097/EDE.0b013e3181cb610b.20087190
Bevenue A, Hylin JW, Kawano Y, 1972. Pesticides in water: Organochlorine pesticide residues in water, sediment, algae, and fish, Hawaii, 1970–71. Pestic Monit J 6:56–64.4115671
Bhatia R, Shiau R, Petreas M, 2005. Organochlorine pesticides and male genital anomalies in the child health and development studies. Environ Health Perspect 113(2):220–224. 10.1289/ehp.7382.15687061
Bidleman TF. 1988. Atmospheric processes. Wet and dry deposition of organic compounds are controlled by their vapor-particle partitioning. Environ Sci Technol 22:361–367.
Bidleman TF, Matthews J, Olney C, 1978. Pesticide residues: Separation of polychlorinated biphenyls, chlordane, and p,p’-DDD from toxaphene by silicic acid column chromatography. Journal - Association of Official Analytical Chemists 61:820–828.
Bidleman TF, Christensen EJ, Billings WN, 1981. Atmospheric transport of organochlorines in the North Atlantic gyre. J Mar Res 39:443–464.
Bidleman TF, Cotham WE, Addison RF, 1992. Organic contaminants in the northwest Atlantic atmosphere at Sable Island, Nova Scotia, 1988–1989. Chemosphere 24(9):1389–1412.
Bidleman TF, Walla MD, Roura R, 1993. Organochlorine pesticides in the atmosphere of the Southern Ocean and Antarctica, January-March, 1990. Mar Pollut Bull 26(5):258–262.
Biggs ML, Davis MD, Eaton DL, 2008. Serum organochlorine pesticide residues and risk of testicular germ cell carcinoma: a population-based case-control study. Cancer Epidemiol Biomarkers Prev 17(8):2012–2018. 10.1158/1055-9965.EPI-08-0032.18708392
Bilrha H, Roy R, Moreau B, 2003. In vitro activation of cord blood mononuclear cells and cytokine production in a remote coastal population exposed to organochlorines and methyl mercury. Environ Health Perspect 111(16):1952–1957. 10.1289/ehp.6433.14644672
Bitman J, Cecil HC. 1970. Estrogenic activity of DDT analogs and polychlorinated biphenyls. J Agric Food Chem 18(6):1108–1112. 10.1021/jf60172a019.5483049
Bjerregaard P, Hansen JC. 2000. Organochlorines and heavy metals in pregnant women from the Disko Bay area in Greenland. Sci Total Environ 245(1–3):195–202. 10.1016/s0048-9697(99)00444-1.10682367
Blanco-Munoz J, Lacasana M, Aguilar-Garduno C, 2012. Effect of exposure to p,p’-DDE on male hormone profile in Mexican flower growers. Occup Environ Med 69(1):5–11. 10.1136/oem.2010.059667.21558473
Blanco-Munoz J, Lacasana M, Lopez-Flores I, 2016. Association between organochlorine pesticide exposure and thyroid hormones in floriculture workers. Environ Res 150:357–363. 10.1016/j.envres.2016.05.054.27344267
Bloom MS, Jansing RL, Kannan K, 2014. Thyroid hormones are associated with exposure to persistent organic pollutants in aging residents of upper Hudson River communities. Int J Hyg Environ Health 217(4–5):473–482. 10.1016/j.ijheh.2013.09.003.24138783
Bloom MS, Fujimoto VY, Storm R, 2017. Persistent organic pollutants (POPs) in human follicular fluid and in vitro fertilization outcomes, a pilot study. Reprod Toxicol 67:165–173. 10.1016/j.reprotox.2017.01.004.28089717
Blus LJ, Henny CJ, Stafford CJ, 1987. Persistence of DDT and metabolites in wildlife from Washington State orchards. Arch Environ Contam Toxicol 16(4):467–476. 10.1007/BF01055269.3300572
Boada LD, Zumbado M, Henriquez-Hernandez LA, 2012. Complex organochlorine pesticide mixtures as determinant factor for breast cancer risk: a population-based case-control study in the Canary Islands (Spain). Environ Health 11:28. 10.1186/1476-069X-11-28.22534004
Boada LD, Henriquez-Hernandez LA, Zumbado M, 2016. Organochlorine pesticides exposure and bladder cancer: Evaluation from a gene-environment perspective in a hospital-based case-control study in the Canary Islands (Spain). J Agromedicine 21(1):34–42. 10.1080/1059924x.2015.1106374.26479327
Bohannon AD, Cooper GS, Wolff MS, 2000. Exposure to 1,1-dichloro-2,2-bis(p-chlorophenyl)ethylene (DDT) in relation to bone mineral density and rate of bone loss in menopausal women. Arch Environ Health 55(6):386–391. 10.1080/00039890009604035.11128875
Bonde JP, Flachs EM, Rimborg S, 2016. The epidemiologic evidence linking prenatal and postnatal exposure to endocrine disrupting chemicals with male reproductive disorders: a systematic review and meta-analysis. Hum Reprod Update 23(1):104–125. 10.1093/humupd/dmw036.27655588
Bornman M, Delport R, Farias P, 2018. Alterations in male reproductive hormones in relation to environmental DDT exposure. Environ Int 113:281–289. 10.1016/j.envint.2017.12.039.29373146
Boul H. 1996. Effect of soil moisture on the fate of radiolabelled DDT and DDE in vitro. Chemosphere 32(5):855–866.
Boul HL, Garnham ML, Hucker D, 1994. Influence of agricultural practices on the levels of DDT and its residues in soil. Environ Sci Technol 28(8):1397–1402. 10.1021/es00057a004.22165920
Bouwman H, Reinecke AJ, Cooppan RM, 1990. Factors affecting levels of DDT and metabolites in human breast milk from Kwazulu. J Toxicol Environ Health 31(2):93–115. 10.1080/15287399009531440.2213927
Bradt PT, Herrenkohl RC. 1976. DDT in human milk. What determines the levels? Sci Total Environ 6(2):161–163. 10.1016/0048-9697(76)90011-5.989182
Brauner EV, Sorensen M, Gaudreau E, 2012. A prospective study of organochlorines in adipose tissue and risk of non-Hodgkin lymphoma. Environ Health Perspect 120(1):105–111.22328999
Bravo N, Hansen S, Okland I, 2017. Influence of maternal and sociodemographic characteristics on the accumulation of organohalogen compounds in Argentinian women. The EMASAR study. Environ Res 158:759–767. 10.1016/j.envres.2017.07.033.28753526
Brevik EM, Grande M, Knutzen J, 1996. DDT contamination of fish and sediments from Lake Orsjoen, Southern Norway: Comparison of data from 1975 and 1994. Chemosphere 33(11):2189–2200.
Brock JW, Melnyk LJ, Caudill SP, 1998. Serum levels of several organochlorine pesticides in farmers correspond with dietary exposure and local use history. Toxicol Ind Health 14(1/2):275–289.9460180
Brown DP. 1992. Mortality of workers employed at organochlorine pesticide manufacturing plants -- an update. Scand J Work Environ Health 18:155–161.1615289
Brucker-Davis F, Wagner-Mahler K, Delattre I, 2008. Cryptorchidism at birth in Nice area (France) is associated with higher prenatal exposure to PCBs and DDE, as assessed by colostrum concentrations. Hum Reprod 23(8):1708–1718. 10.1093/humrep/den186.18503055
Buck NA, Estesen BJ, Ware GW. 1983. DDT moratorium in Arizona: residues in soil and alfalfa after 12 years. Bull Environ Contam Toxicol 31(1):66–72. 10.1007/BF01608768.6882942
Buck Louis GM. 2014. Persistent environmental pollutants and couple fecundity: an overview. Reproduction 147(4):R97–R104. 10.1530/REP-13-0472.24310101
Buck Louis GM, Sundaram R, Schisterman EF, 2013. Persistent environmental pollutants and couple fecundity: the LIFE study. Environ Health Perspect 121(2):231–236. 10.1289/ehp.1205301.23151773
Burns JS, Williams PL, Sergeyev O, 2012. Serum concentrations of organochlorine pesticides and growth among Russian boys. Environ Health Perspect 120(2):303–308. 10.1289/ehp.1103743.21984531
Burns JS, Williams PL, Korrick SA, 2014. Association between chlorinated pesticides in the serum of prepubertal Russian boys and longitudinal biomarkers of metabolic function. Am J Epidemiol 180(9):909–919. 10.1093/aje/kwu212.25255811
Buselmaier W, Rohrborn G, Propping P. 1973. Comparative investigations on the mutagenicity of pesticides in mammalian test systems. Mutat Res 21:25–26.
Büyüksönmez F, Rynk R, Hess TF. 2000. Occurrence, degradation and fate of pesticides during composting. Part II. Occurrence and fate of pesticides in compost and composting systems. Compost Sci Util 8:61–81.
Cabral JR P, Hall RK, Rossi L, 1982a. Lack of carcinogenicity of DDT in hamsters. Tumori 68:5–10.7071944
Cabral JR P, Hall RK, Rossi L, 1982b. Effects of long-term intake of DDT on rats. Tumori 68:11–17.6280347
Cabrera-Rodriguez R, Luzardo OP, Almeida-Gonzalez M, 2019. Association between prenatal exposure to multiple persistent organic pollutants (POPs) and growth indicators in newborns. Environ Res 171:285–292. 10.1016/j.envres.2018.12.064.30708232
Cahill TM, Cousins I, Mackay D. 2003. Development and application of a generalized physiologically based pharmacokinetic model for multiple environmental contaminants. Environ Toxicol Chem 22(1):26–34.12503743
Cameron GR, Burgess F. 1945. The toxicity of 2,2-bis (p-chlorophenyl) 1,1,1-trichloroethane (DDT). Br Med J 1(June 23):865–871.20786134
Canales-Aguirre A, Padilla-Camberos E, Gomez-Pinedo U, 2011. Genotoxic effect of chronic exposure to DDT on lymphocytes, oral mucosa and breast cells of female rats. Int J Environ Res Public Health 8(2):540–553. 10.3390/ijerph8020540.21556202
Cano-Sancho G, Salmon AG, La Merrill MA. 2017. Association between exposure to p,p’-DDT and its metabolite p,p’-DDE with obesity: Integrated systematic review and meta-analysis. Environ Health Perspect 125(9):096002. 10.1289/EHP527.28934091
Canter LW, Sabatini DA. 1994. Contamination of public ground water supplies by Superfund sites. Int J Environ Stud 46(1):35–57. 10.1080/00207239408710909.
Carey AE, Kutz FW. 1985. Trends in ambient concentrations of agrochemicals in humans and the environment of the United States. Environ Monit Assess 5(2):155–163. 10.1007/BF00395844.24257992
Carey AE, Douglas P, Tai H, 1979a. Pesticide residue concentrations in soils of five United States cities, 1971--urban soils monitoring program. Pestic Monit J 13(1):17–22.492926
Carey AE, Gowen J, Tai H, 1979b. Pesticide residue levels in soils and crops from 37 states, 1972– National Soils Monitoring Program (IV). Pestic Monit J 12:209–229.461116
Carmichael SL, Herring AH, Sjodin A, 2010. Hypospadias and halogenated organic pollutant levels in maternal mid-pregnancy serum samples. Chemosphere 80(6):641–646. 10.1016/j.chemosphere.2010.04.055.20494400
Carr RS, Montagna PA, Biedenbach JM, 2000. Impact of storm-water outfalls on sediment quality in Corpus Christi Bay, Texas, USA. Environ Toxicol Chem 19(3):561–574.
Cartier C, Muckle G, Jacobson SW, 2014. Prenatal and 5-year p,p’-DDE exposures are associated with altered sensory processing in school-aged children in Nunavik: a visual evoked potential study. Neurotoxicology 44:8–16. 10.1016/j.neuro.2014.04.009.24812027
Casas M, Nieuwenhuijsen M, Martinez D, 2015. Prenatal exposure to PCB-153, p,p’-DDE and birth outcomes in 9000 mother-child pairs: exposure-response relationship and effect modifiers. Environ Int 74:23–31. 10.1016/j.envint.2014.09.013.25314142
Castellanos CG, Sorvik IB, Tanum MB, 2013. Differential effects of the persistent DDT metabolite methylsulfonyl-DDE in nonstimulated and LH-stimulated neonatal porcine Leydig cells. Toxicol Appl Pharmacol 267(3):247–255. 10.1016/j.taap.2012.12.022.23333615
CDC. 2018. Fourth national report on human exposure to environmental chemicals. Updated tables, March 2018. Centers for Disease Control and Prevention, U.S. Department of Health and Human Services. http://www.cdc.gov/exposurereport/. April 17, 2018.
Cetkovic-Cvrlje M, Olson M, Schindler B, 2016. Exposure to DDT metabolite p,p’-DDE increases autoimmune type 1 diabetes incidence in NOD mouse model. J Immunotoxicol 13(1):108–118. 10.3109/1547691X.2015.1017060.25721050
Charles GD, Gennings C, Tornesi B, 2007. Analysis of the interaction of phytoestrogens and synthetic chemicals: an in vitro/in vivo comparison. Toxicol Appl Pharmacol 218(3):280–288. 10.1016/j.taap.2006.11.029.17222880
Charlier CJ, Foidart JM. 2005. Comparative study of dichlorodiphenyldichloroethylene in blood and semen of two young male populations: lack of relationship to infertility, but evidence of high exposure of the mothers. Reprod Toxicol 20(2):215–220. 10.1016/j.reprotox.2005.03.007.15907656
Charlier C, Foidart JM, Pitance F, 2004. Environmental dichlorodiphenyltrichlorethane or hexachlorobenzene exposure and breast cancer: is there a risk? Clin Chem Lab Med 42(2):222–227. 10.1515/CCLM.2004.040.15061365
Chedrese PJ, Feyles F. 2001. The diverse mechanism of action of dichlorodiphenyldichloroethylene (DDE) and methoxychlor in ovarian cells in vitro. Reprod Toxicol 15(6):693–698. 10.1016/s0890-6238(01)00172-1.11738522
Chen A, Zhang J, Zhou L, 2005. DDT serum concentration and menstruation among young Chinese women. Environ Res 99(3):397–402. 10.1016/j.envres.2004.12.015.16307982
Chen MW, Santos HM, Que DE, 2018. Association between organochlorine pesticide levels in breast milk and their effects on female reproduction in a Taiwanese population. Int J Environ Res Public Health 15(5):931. 10.3390/ijerph15050931.29735922
Chevrier J, Eskenazi B, Holland N, 2008. Effects of exposure to polychlorinated biphenyls and organochlorine pesticides on thyroid function during pregnancy. Am J Epidemiol 168(3):298–310. 10.1093/aje/kwn136.18550560
Chevrier C, Warembourg C, Gaudreau E, 2013. Organochlorine pesticides, polychlorinated biphenyls, seafood consumption, and time-to-pregnancy. Epidemiology 24(2):251–260. 10.1097/EDE.0b013e31827f53ec.23348067
Chowdhury AR, Gautam AK, Venkatakrishna-Bhatt H. 1990. DDT (2,2,bis(p-chlorophenyl) 1,1,1-trichloroethane) induced structural changes in adrenal glands of rats. Bull Environ Contam Toxicol 45(2):193–196. 10.1007/BF01700183.2400834
Clark JM. 1974. Mutagenicity of DDT in mice, Drosophila melanogaster and Neurospora crassa. Aust J Biol Sci 27(4):427–440. 10.1071/bi9740427.4279650
Clement JG, Okey AB. 1972. Estrogenic and anti-estrogenic effects of DDT administered in the diet to immature female rats. Can J Physiol Pharmacol 50(10):971–975. 10.1139/y72-141.4637185
Clement JG, Okey AB. 1974. Reproduction in female rats born to DDT-treated parents. Bull Environ Contam Toxicol 12(3):373–377. 10.1007/BF01709135.4433883
Clewell HJ 3rd, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131. 10.1177/074823378500100408.3843496
Cocco P, Kazerouni N, Zahm SH. 2000. Cancer mortality and environmental exposure to DDE in the United States. Environ Health Perspect 108(1):1–4. 10.1289/ehp.001081.10620518
Cocco P, Fadda D, Billai B, 2005. Cancer mortality among men occupationally exposed to dichlorodiphenyltrichloroethane. Cancer Res 65(20):9588–9594. 10.1158/0008-5472.CAN-05-1487.16230425
Cocco P, Brennan P, Ibba A, 2008. Plasma polychlorobiphenyl and organochlorine pesticide level and risk of major lymphoma subtypes. Occup Environ Med 65(2):132–140. 10.1136/oem.2007.033548.17699548
Codru N, Schymura MJ, Negoita S, 2007. Diabetes in relation to serum levels of polychlorinated biphenyls and chlorinated pesticides in adult Native Americans. Environ Health Perspect 115(10):1442–1447. 10.1289/ehp.10315.17938733
Cohn BA. 2011. Developmental and environmental origins of breast cancer: DDT as a case study. Reprod Toxicol 31(3):302–311. 10.1016/j.reprotox.2010.10.004.20965245
Cohn BA, Cirillo PM, Wolff MS, 2003. DDT and DDE exposure in mothers and time to pregnancy in daughters. Lancet 361(9376):2205–2206. 10.1016/S0140-6736(03)13776-2.12842376
Cohn BA, Wolff MS, Cirillo PM, 2007. DDT and breast cancer in young women: new data on the significance of age at exposure. Environ Health Perspect 115(10):1406–1414. 10.1289/ehp.10260.17938728
Cohn BA, La Merrill M, Krigbaum NY, 2015. DDT Exposure in Utero and Breast Cancer. J Clin Endocrinol Metab 100(8):2865–2872. 10.1210/jc.2015-1841.26079774
Coker E, Chevrier J, Rauch S, 2018. Association between prenatal exposure to multiple insecticides and child body weight and body composition in the VHEMBE South African birth cohort. Environ Int 113:122–132. 10.1016/j.envint.2018.01.016.29421401
Consales C, Toft G, Leter G, 2016. Exposure to persistent organic pollutants and sperm DNA methylation changes in Arctic and European populations. Environ Mol Mutagen 57(3):200–209. 10.1002/em.21994.26801515
Cooney MA, Buck Louis GM, Hediger ML, 2010. Organochlorine pesticides and endometriosis. Reprod Toxicol 30(3):365–369. 10.1016/j.reprotox.2010.05.011.
Cooper GS, Savitz DA, Millikan R, 2002. Organochlorine exposure and age at natural menopause. Epidemiology 13(6):729–733. 10.1097/00001648-200211000-00021.
Cooper GS, Martin SA, Longnecker MP, 2004. Associations between plasma DDE levels and immunologic measures in African-American farmers in North Carolina. Environ Health Perspect 112(10):1080–1084. 10.1289/ehp.6892.
Cooper GS, Klebanoff MA, Promislow J, 2005. Polychlorinated biphenyls and menstrual cycle characteristics. Epidemiology 16(2):191–200. 10.1097/01.ede.0000152913.12393.86.
Coulston F. 1985. Reconsideration of the dilemma of DDT for the establishment of an acceptable daily intake. Regul Toxicol Pharmacol 5(4):332–383. 10.1016/0273-2300(85)90002-9.3912850
Coupe RH, Manning MA, Foreman WT, 2000. Occurrence of pesticides in rain and air in urban and agricultural areas of Mississippi, April-September 1995. Sci Total Environ 248(2–3):227–240. 10.1016/s0048-9697(99)00545-8.
Cox S, Niskar AS, Narayan KM, 2007. Prevalence of self-reported diabetes and exposure to organochlorine pesticides among Mexican Americans: Hispanic health and nutrition examination survey, 1982–1984. Environ Health Perspect 115(12):1747–1752. 10.1289/ehp.10258.
Craig GR, Ogilvie DM. 1974. Alteration of T-maze performance in mice exposed to DDT during pregnancy and lactation. Environ Physiol Biochem 4:189–199.4461271
Cranmer MF, Carroll JJ, Copeland MF. 1972. Determinations of DDT and metabolites including DDA in human urine by gas chromatography. In: Davies JE, Edmundson WF, eds. Epidemiology of DDT, appendix A. State of Florida, Bureau of Research, Division of Health, 147–152.
Crockett AB, Wiersma GB, Tai H, 1974. Pesticides in soils: Pesticide residue levels in soils and crops, FY-70–National Soils Monitoring Program. Pestic Monit J 8:69–97.4216877
Croes K, Den Hond E, Bruckers L, 2015. Endocrine actions of pesticides measured in the Flemish environment and health studies (FLEHS I and II). Environ Sci Pollut Res Int 22(19):14589–14599. 10.1007/s11356-014-3437-z.
Cueto C. 1970. Cardiovascular effects of o,p’-DDD. IMS Ind Med Surg 39(1):55–56.5263055
Cupul-Uicab LA, Hernandez-Avila M, Terrazas-Medina EA, 2010. Prenatal exposure to the major DDT metabolite 1,1-dichloro-2,2-bis(p-chlorophenyl)ethylene (DDE) and growth in boys from Mexico. Environ Res 110(6):595–603. 10.1016/j.envres.2010.06.001.
Cupul-Uicab LA, Klebanoff MA, Brock JW, 2013. Prenatal exposure to persistent organochlorines and childhood obesity in the U.S. collaborative perinatal project. Environ Health Perspect 121(9):1103–1109. 10.1289/ehp.1205901.23799652
Cupul-Uicab LA, Terrazas-Medina EA, Hernandez-Avila M, 2014. Prenatal exposure to p,p’-DDE and p,p’-DDT in relation to lower respiratory tract infections in boys from a highly exposed area of Mexico. Environ Res 132:19–23. 10.1016/j.envres.2014.03.017.
Cupul-Uicab LA, Terrazas-Medina EA, Hernandez-Avila M, 2017. In utero exposure to DDT and incidence of diarrhea among boys from tropical Mexico. Environ Res 159:331–337. 10.1016/j.envres.2017.08.027.28841520
Custer TW, Hines RK, Stewart PM, 1998. Organochlorines, mercury, and selenium in great blue heron eggs from Indiana Dunes National Lakeshore, Indiana. J Great Lakes Res 24(1):3–11.
Dallaire F, Dewailly E, Muckle G, 2004. Acute infections and environmental exposure to organochlorines in Inuit infants from Nunavik. Environ Health Perspect 112(14):1359–1365. 10.1289/ehp.7255.15471725
Dallaire R, Dewailly E, Pereg D, 2009. Thyroid function and plasma concentrations of polyhalogenated compounds in Inuit adults. Environ Health Perspect 117(9):1380–1386. 10.1289/ehp.0900633.19750101
Dallinga JW, Moonen EJ, Dumoulin JC, 2002. Decreased human semen quality and organochlorine compounds in blood. Hum Reprod 17(8):1973–1979. 10.1093/humrep/17.8.1973.12151423
Damgaard IN, Skakkebaek NE, Toppari J, 2006. Persistent pesticides in human breast milk and cryptorchidism. Environ Health Perspect 114(7):1133–1138. 10.1289/ehp.8741.16835070
Daniels SI, Chambers JC, Sanchez SS, 2018. Elevated levels of organochlorine pesticides in South Asian immigrants are associated with an increased risk of diabetes. J Endocr Soc 2(8):832–841. 10.1210/js.2017-00480.30019022
Danzo BJ. 1997. Environmental xenobiotics may disrupt normal endocrine function by interfering with the binding of physiological ligands to steroid receptors and binding proteins. Environ Health Perspect 105(3):294–301.9171990
Darnerud PO, Lignell S, Glynn A, 2010. POP levels in breast milk and maternal serum and thyroid hormone levels in mother-child pairs from Uppsala, Sweden. Environ Int 36(2):180–187. 10.1016/j.envint.2009.11.001.19954849
Davies RP, Dobbs AJ. 1984. The prediction of bioconcentration in fish. Water Res 18:1253–1262.
de Cock M, de Boer MR, Lamoree M, 2014. Prenatal exposure to endocrine disrupting chemicals in relation to thyroid hormone levels in infants - a Dutch prospective cohort study. Environ Health 13:106. 10.1186/1476-069X-13-106.25495114
de Cock M, De Boer MR, Lamoree M, 2016. Prenatal exposure to endocrine disrupting chemicals and birth weight-A prospective cohort study. J Environ Sci Health A Tox Hazard Subst Environ Eng 51(2):178–185. 10.1080/10934529.2015.1087753.26605905
de Cock M, de Boer MR, Govarts E, 2017. Thyroid-stimulating hormone levels in newborns and early life exposure to endocrine-disrupting chemicals: analysis of three European mother-child cohorts. Pediatr Res 82(3):429–437. 10.1038/pr.2017.50.28288144
de Jager C, Farias P, Barraza-Villarreal A, 2006. Reduced seminal parameters associated with environmental DDT exposure and p,p’-DDE concentrations in men in Chiapas, Mexico: A cross-sectional study. J Androl 27(1):16–27. 10.2164/jandrol.05121.16400073
de Jager C, Aneck-Hahn NH, Bornman MS, 2009. Sperm chromatin integrity in DDT-exposed young men living in a malaria area in the Limpopo Province, South Africa. Hum Reprod 24(10):2429–2438. 10.1093/humrep/dep249.19608568
De Roos AJ, Hartge P, Lubin JH, 2005. Persistent organochlorine chemicals in plasma and risk of non-Hodgkin’s lymphoma. Cancer Res 65(23):11214–11226. 10.1158/0008-5472.CAN-05-1755.16322272
De Roos AJ, Ulrich CM, Sjodin A, 2012. Adiposity, body composition, and weight change in relation to organochlorine pollutant plasma concentrations. J Expo Sci Environ Epidemiol 22(6):617–624. 10.1038/jes.2012.43.22588213
de Waziers I, Azais V. 1987. Drug-metabolizing enzyme activities in the liver and intestine of rats exposed to DDT: effects of vitamin A status. Arch Environ Contam Toxicol 16(3):343–348. 10.1007/BF01054952.3592760
Debost-Legrand A, Warembourg C, Massart C, 2016a. Prenatal exposure to persistent organic pollutants and organophosphate pesticides, and markers of glucose metabolism at birth. Environ Res 146:207–217. 10.1016/j.envres.2016.01.005.26775002
Debost-Legrand A, Warembourg C, Massart C, 2016b. Supplemental file to "Prenatal exposure to persistent organic pollutants and organophosphate pesticides, and markers of glucose metabolism at birth". Environ Res 10.1016/j.envres.2016.01.005.
Deichmann WB, Keplinger M, Sala F, 1967. Synergism among oral carcinogens. IV. The simultaneous feeding of four tumorigens to rats. Toxicol Appl Pharmacol 11:88–103.6056159
Del Pup JA, Pasternack BS, Harley NH, 1978. Effects of DDT on stable laboratory mouse populations. J Toxicol Environ Health 4(4):671–687. 10.1080/15287397809529689.682216
Delvaux I, Van Cauwenberghe J, Den Hond E, 2014. Prenatal exposure to environmental contaminants and body composition at age 7–9 years. Environ Res 132:24–32. 10.1016/j.envres.2014.03.019.24742724
Demers A, Ayotte P, Brisson J, 2000. Risk and aggressiveness of breast cancer in relation to plasma organochlorine concentrations. Cancer Epidemiol Biomarkers Prev 9(2):161–166.10698476
Den Hond E, Dhooge W, Bruckers L, 2011. Internal exposure to pollutants and sexual maturation in Flemish adolescents. J Expo Sci Environ Epidemiol 21(3):224–233. 10.1038/jes.2010.2.20197795
Denham M, Schell LM, Deane G, 2005. Relationship of lead, mercury, mirex, dichlorodiphenyldichloroethylene, hexachlorobenzene, and polychlorinated biphenyls to timing of menarche among Akwesasne Mohawk girls. Pediatrics 115(2):e127–134. 10.1542/peds.2004-1161.15653789
Dewailly E, Ayotte P, Laliberte C, 1996. Polychlorinated biphenyl (PCB) and dichlorodiphenyl dichloroethylene (DDE) concentrations in the breast milk of women in Quebec. Am J Public Health 86(9):1241–1246. 10.2105/ajph.86.9.1241.8806375
Dewailly E, Ayotte P, Bruneau S, 2000. Susceptibility to infections and immune status in Inuit infants exposed to organochlorines. Environ Health Perspect 108(3):205–211. 10.1289/ehp.00108205.10706525
Dhooge W, Den Hond E, Koppen G, 2010. Internal exposure to pollutants and body size in Flemish adolescents and adults: associations and dose-response relationships. Environ Int 36(4):330–337. 10.1016/j.envint.2010.01.005.20181395
Dhooge W, den Hond E, Koppen G, 2011. Internal exposure to pollutants and sex hormone levels in Flemish male adolescents in a cross-sectional study: associations and dose-response relationships. J Expo Sci Environ Epidemiol 21(1):106–113. 10.1038/jes.2009.63.20010975
Diel P, Schulz T, Smolnikar K, 2000. Ability of xeno- and phytoestrogens to modulate expression of estrogen-sensitive genes in rat uterus: estrogenicity profiles and uterotropic activity. J Steroid Biochem Mol Biol 73(1–2):1–10. 10.1016/s0960-0760(00)00051-0.10822019
Dimond JB, Owen RB. 1996. Long-term residue of DDT compounds in forest soils in Maine. Environ Pollut 92(2):227–230. 10.1016/0269-7491(95)00059-3.15091403
Ding J, Wu S. 1997. Transport of organocholorine pesticides in soil columns enhanced by dissolved organic carbon. Water Sci Technol 35:139–145.
Dirinck EL, Dirtu AC, Govindan M, 2014. Exposure to persistent organic pollutants: relationship with abnormal glucose metabolism and visceral adiposity. Diabetes Care 37(7):1951–1958. 10.2337/dc13-2329.24963112
Diwan BA, Ward JM, Kurata Y, 1994. Dissimilar frequency of hepatoblastomas and hepatic cystadenomas and adenocarcinomas arising in hepatocellular neoplasms of D2B6F1 mice initiated with N-nitrosodiethylamine and subsequently given Aroclor-1254, dichlorodiphenyltrichloroethane, or phenobarbital. Toxicol Pathol 22(4):430–439. 10.1177/019262339402200409.7817132
Djordjevic MV, Fan J, Hoffmann D. 1995. Assessment of chlorinated pesticide residues in cigarette tobacco based on supercritical fluid extraction and GC-ECD. Carcinogenesis 16(11):2627–2632. 10.1093/carcin/16.11.2627.7586177
DOE. 2018a. Protective action criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. U.S. Department of Energy. https://edms.energy.gov/pac/. April 12, 2020.
DOE. 2018b. Table 3: Protective action criteria (PAC) rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. U.S. Department of Energy. https://edms.energy.gov/pac/docs/Revision_29A_Table3.pdf. April 12, 2020.
Donaldson GM, Shutt JL, Hunter P. 1999. Organochlorine contamination in bald eagle eggs and nestlings from the Canadian Great Lakes. Arch Environ Contam Toxicol 36(1):70–80. 10.1007/s002449900444.9828264
Donat-Vargas C, Akesson A, Tornevi A, 2018. Persistent organochlorine pollutants in plasma, blood pressure, and hypertension in a longitudinal study. Hypertension 71(6):1258–1268. 10.1161/hypertensionaha.117.10691.29712742
Dorea JG, Cruz-Granja AC, Lacayo-Romero ML, 2001. Perinatal metabolism of dichlorodiphenyldichloroethylene in Nicaraguan mothers. Environ Res 86(3):229–237. 10.1006/enrs.2001.4277.11453673
Dorgan JF, Brock JW, Rothman N, 1999. Serum organochloride pesticides and PCBs and breast cancer risk: results from a prospective analysis (USA). Cancer Causes Control 10:1–11.10334636
Dua VK, Kumari R, Sharma VP, 2001. Organochlorine residues in human blood from Nainital (U.P.), India. Bull Environ Contam Toxicol 67(1):42–45. 10.1007/s001280088.11381310
Duby RT, Travis HF, Terrill CE. 1971. Uterotropic activity of DDT in rats and mink and its influence on reproduction in the rat. Toxicol Appl Pharmacol 18(2):348–355. 10.1016/0041-008x(71)90127-x.5569378
Duggan RE, Corneliussen PE, Duggan MB, 1983. Pesticide residue levels in foods in the United States from July 1, 1969, to June 30, 1976: Summary. J Assoc Off Anal Chem 66(6):1534–1535.6643370
Dunstan RH, Roberts TK, Donohoe M, 1996. Bioaccumulated chlorinated hydrocarbons and red/white blood cell parameters. Biochem Mol Med 58(1):77–84. 10.1006/bmme.1996.0035.8809349
Durham WF, Ortega P, Hayes WJ. 1963. The effect of various dietary levels of DDT on liver function, cell morphology, and DDT storage in the Rhesus monkey. Arch Int Pharmacodyn Ther 141:111–129.
Dutta R, Mondal AM, Arora V, 2008. Immunomodulatory effect of DDT (bis[4-chlorophenyl]-1,1,1-trichloroethane) on complement system and macrophages. Toxicology 252(1–3):78–85. 10.1016/j.tox.2008.07.063.18755234
Eden PR, Meek EC, Wills RW, 2016. Association of type 2 diabetes mellitus with plasma organochlorine compound concentrations. J Expo Sci Environ Epidemiol 26(2):207–213. 10.1038/jes.2014.69.25335866
Elobeid MA, Padilla MA, Brock DW, 2010. Endocrine disruptors and obesity: an examination of selected persistent organic pollutants in the NHANES 1999–2002 data. Int J Environ Res Public Health 7(7):2988–3005. 10.3390/ijerph7072988.20717554
Elvia LF, Sioban HD, Bernardo HP, 2000. Organochlorine pesticide exposure in rural and urban areas in Mexico. J Expo Anal Environ Epidemiol 10(4):394–399. 10.1038/sj.jea.7500103.10981733
Emeville E, Giton F, Giusti A, 2013. Persistent organochlorine pollutants with endocrine activity and blood steroid hormone levels in middle-aged men. PLoS ONE 8(6):e66460. 10.1371/journal.pone.0066460.23785499
Emeville E, Giusti A, Coumoul X, 2015. Associations of plasma concentrations of dichlorodiphenyldichloroethylene and polychlorinated biphenyls with prostate cancer: a case-control study in Guadeloupe (French West Indies). Environ Health Perspect 123(4):317–323. 10.1289/ehp.1408407.25493337
Engel LS, Laden F, Andersen A, 2007. Polychlorinated biphenyl levels in peripheral blood and non-Hodgkin’s lymphoma: a report from three cohorts. Cancer Res 67(11):5545–5552. 10.1158/0008-5472.CAN-06-3906.17545638
Engel LS, Zabor EC, Satagopan J, 2019. Prediagnostic serum organochlorine insecticide concentrations and primary liver cancer: A case-control study nested within two prospective cohorts. Int J Cancer 145(9):2360–2371. 10.1002/ijc.32175.30701531
Ennaceur S, Ridha D, Marcos R. 2008. Genotoxicity of the organochlorine pesticides 1,1-dichloro-2,2-bis(p-chlorophenyl)ethylene (DDE) and hexachlorobenzene (HCB) in cultured human lymphocytes. Chemosphere 71(7):1335–1339. 10.1016/j.chemosphere.2007.11.040.18164367
EPA. 1979. Water-related environmental fate of 129 priority pollutants: Volume II: Halogenated aliphatic hydrocarbons, halogenated ethers, monocyclic aromatics, phthalate esters, polycyclic aromatic hydrocarbons, nitrosamines, and miscellaneous compounds. Washington, DC: U.S. Environmental Protection Agency. EPA440479026b. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000K6JL.txt. August 10, 2021.
EPA. 1980. Ambient water quality criteria for DDT. U.S. Environmental Protection Agency. EPA440580038. PB81117491.
EPA. 1986a. Superfund public health evaluation manual. Washington, DC: U.S. Environmental Protection Agency. EPA540186060.
EPA. 1992. U.S. pesticide use trends: 1966–1989. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1998. Method 8081B. Organochlorine pesticides by gas chromatography. U.S. Environmental Protection Agency.
EPA. 1999. National recommended water quality criteria-correction. U.S. Environmental Protection Agency. EPA822Z99001.
EPA. 2005. Toxic Chemical Release Inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001.
EPA. 2008. The analysis of occurrence data from the first unregulated contaminant monitoring regulation (UCMR 1) in support of regulatory determinations for the second drinking water contaminant candidate list (CCL 2). U.S. Environmental Protection Agency. EPA815R08013.
EPA. 2009. National primary drinking water regulations. U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
EPA. 2011. Exposure factors handbook: 2011 edition. Washington, DC: U.S. Environmental Protection Agency. EPA600R09052F. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=236252. July 19, 2021.
EPA. 2014. United Heckathorn Superfund site, Richmond, California. DDT fate and transport study. U.S. Environmental Protection Agency. http://yosemite.epa.gov/r9/sfund/r9sfdocw.nsf/3dc283e6c5d6056f88257426007417a2/d9263fb3f9c7358e88257d18005d365d/$FILE/Final_Heckathorn_DDT_FateAndTransport.pdf January 18, 2018.
EPA. 2017a. Guidelines establishing test procedures for the analysis of pollutants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136. https://www.gpo.gov/fdsys/pkg/CFR-2017-title40-vol25/pdf/CFR-2017-title40-vol25-part136.pdf. January 9, 2017.
EPA. 2017b. Provisional peer-reviewed toxicity values for p,p′-dichlorodiphenyldichloroethane (p,p′-DDD). Cincinnati, OH: U.S. Environmental Protection Agency. EPA690R17006. https://cfpub.epa.gov/ncea/pprtv/chemicalLanding.cfm?pprtv_sub_id=1663. July 26, 2021.
EPA. 2017c. Provisional peer-reviewed toxicity values for p,p′-dichlorodiphenyldichloroethylene (p,p′-DDE). Cincinnati, OH: U.S. Environmental Protection Agency. EPA690R17007. https://cfpub.epa.gov/ncea/pprtv/chemicalLanding.cfm?pprtv_sub_id=1664. July 25, 2021.
EPA. 2018a. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2018b. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. July 25, 2018.
Eriksson P, Nordberg A. 1986. The effects of DDT, DDOH-palmitic acid, and a chlorinated paraffin on muscarinic receptors and the sodium-dependent choline uptake in the central nervous system of immature mice. Toxicol Appl Pharmacol 85(2):121–127. 10.1016/0041-008x(86)90105-5.3764899
Eriksson P, Archer T, Fredriksson A. 1990a. Altered behaviour in adult mice exposed to a single low dose of DDT and its fatty acid conjugate as neonates. Brain Res 514:141–142.2357521
Eriksson P, Nilsson-Hakansson L, Nordberg A, 1990b. Neonatal exposure to DDT and its fatty acid conjugate: effects on cholinergic and behavioural variables in the adult mouse. Neurotoxicology 11(2):345–354.2234550
Eriksson P, Ahlbom J, Fredriksson A. 1992. Exposure to DDT during a defined period in neonatal life induces permanent changes in brain muscarinic receptors and behaviour in adult mice. Brain Res 582(2):277–281. 10.1016/0006-8993(92)90144-x.1393550
Eriksson P, Johansson U, Ahlborn J, 1993. Neonatal exposure to DDT induces increased susceptibility to pyrethroid (bioallthrin) exposure at adult age. Changes in cholinergic muscarinic receptor and behavioural variables. Toxicology 77:21–30.8442015
Eskenazi B, Marks AR, Bradman A, 2006. In utero exposure to dichlorodiphenyltrichloroethane (DDT) and dichlorodiphenyldichloroethylene (DDE) and neurodevelopment among young Mexican American children. Pediatrics 118(1):233–241. 10.1542/peds.2005-3117.16818570
Eskenazi B, Rauch SA, Tenerelli R, 2017. In utero and childhood DDT, DDE, PBDE and PCBs exposure and sex hormones in adolescent boys: The CHAMACOS study. Int J Hyg Environ Health 220(2 Pt B):364–372. 10.1016/j.ijheh.2016.11.001.27876543
Eskenazi B, An S, Rauch SA, 2018. Prenatal exposure to DDT and pyrethroids for malaria control and child neurodevelopment: The VHEMBE cohort, South Africa. Environ Health Perspect 126(4):047004. 10.1289/ehp2129.29648420
Evangelou E, Ntritsos G, Chondrogiorgi M, 2016. Exposure to pesticides and diabetes: A systematic review and meta-analysis. Environ Int 91:60–68. 10.1016/j.envint.2016.02.013.26909814
Evans MS, Noguchi GE, Rice CP. 1991. The biomagnification of polychlorinated biphenyls, toxaphene, and DDT compounds in a Lake Michigan offshore food web. Arch Environ Contam Toxicol 20(1):87–93. 10.1007/BF01065333.1899993
Everett CJ, Frithsen IL, Diaz VA, 2007. Association of a polychlorinated dibenzo-p-dioxin, a polychlorinated biphenyl, and DDT with diabetes in the 1999–2002 National Health and Nutrition Examination Survey. Environ Res 103(3):413–418. 10.1016/j.envres.2006.11.002.17187776
Everett CJ, Matheson EM. 2010. Biomarkers of pesticide exposure and diabetes in the 1999–2004 national health and nutrition examination survey. Environ Int 36(4):398–401. 10.1016/j.envint.2010.02.010.20299099
Everett CJ, Thompson OM. 2015. Association of DDT and heptachlor epoxide in human blood with diabetic nephropathy. Rev Environ Health 30(2):93–97. 10.1515/reveh-2015-0003.25822320
Everett CJ, Thompson OM, Dismuke CE. 2017a. Exposure to DDT and diabetic nephropathy among Mexican Americans in the 1999–2004 National Health and Nutrition Examination Survey. Environ Pollut 222:132–137.28065571
Everett CJ, Thompson OM, Dismuke CE. 2017b. DDT and DDE concentrations in blood of Mexican Americans exposed to DDT in Mexico: The 1999–2004 National Health and Nutrition Examination Study. Int J Agric Environ Res 3(4):370–376.
Fabro S, McLachlan JA, Dames NM. 1984. Chemical exposure of embryos during the preimplantation stages of pregnancy: mortality rate and intrauterine development. Am J Obstet Gynecol 148(7):929–938. 10.1016/0002-9378(84)90535-0.
Fahrig R. 1974. Comparative mutagenicity studies with pesticides. IARC Sci Publ 10:161–181.
Fakhri Y, Sheikhmohammadi A, Bay A, 2017. Association between dichlorodiphenyldichloroethylene in the serum and adipose tissue with Type 2 Diabetes: A systematic review and meta-analysis. Glob J Health Sci 9(2):43.
Falck F, Ricci A, Wolff MS, 1992. Pesticides and polychlorinated biphenyl residues in human breast lipids and their relation to breast cancer. Arch Environ Health 47(2):143–146.1567239
Fang SC, Fallin E, Freed VH. 1977. Maternal transfer of 14C-p,p’-DDT via placenta and milk and its metabolism in infant rats. Arch Environ Contam Toxicol 5(4):427–436. 10.1007/BF02220922.883850
Farhang L, Weintraub JM, Petreas M, 2005. Association of DDT and DDE with birth weight and length of gestation in the Child Health and Development Studies, 1959–1967. Am J Epidemiol 162(8):717–725. 10.1093/aje/kwi276.16120698
Fawcett SC, King LJ, Bunyan PJ, 1987. The metabolism of ^14^C-DDT, ^14^C-DDD, ^14^C-DDE, and ^14^C-DDMU in rats and Japanese quail. Xenobiotica 17(5):525–538.3604258
FDA. 1995. Pesticide program residue monitoring. Washington, DC: U.S. Food and Drug Administration.
FDA. 1999. Food and Drug Administration Pesticide Program: Residue monitoring 1999. U.S. Food and Drug Administration. http://www.cfsan.fda.gov/~dms/pesrpts.html. March 27, 2017.
FDA. 2001. Drug products containing certain active ingredients offered over-the-counter. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 310.545.
FDA. 2006. U.S. Food and Drug Administration- total diet study market baskets 2004–1 through 2005–4. College Park, MD: U.S. Food and Drug Administration.
FDA. 2021. Substances added to food. U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/?set=FoodSubstances. February 3, 2021.
Fenster L, Eskenazi B, Anderson M, 2006. Association of in utero organochlorine pesticide exposure and fetal growth and length of gestation in an agricultural population. Environ Health Perspect 114(4):597–602. 10.1289/ehp.8423.16581552
Fenster L, Eskenazi B, Anderson M, 2007. In utero exposure to DDT and performance on the Brazelton neonatal behavioral assessment scale. Neurotoxicology 28(3):471–477. 10.1016/j.neuro.2006.12.009.17287022
Ferguson KK, Hauser R, Altshul L, 2012. Serum concentrations of p, p’-DDE, HCB, PCBs and reproductive hormones among men of reproductive age. Reprod Toxicol 34(3):429–435. 10.1016/j.reprotox.2012.04.006.22564984
Fernandez MF, Olmos B, Granada A, 2007. Human exposure to endocrine-disrupting chemicals and prenatal risk factors for cryptorchidism and hypospadias: a nested case-control study. Environ Health Perspect 115 Suppl 1:8–14. 10.1289/ehp.9351.18174944
Fiorini C, Tilloy-Ellul A, Chevalier S, 2004. Sertoli cell junctional proteins as early targets for different classes of reproductive toxicants. Reprod Toxicol 18(3):413–421. 10.1016/j.reprotox.2004.01.002.15082077
Fishbein L. 1973. Mutagens and potential mutagens in the biosphere. I. DDT and its metabolites, polychlorinated biphenyls, chlorodioxins, polycyclic aromatic hydrocarbons, haloethers. Sci Total Environ 4:305–340.
Fitzhugh OG, Nelson AA. 1947. The chronic oral toxicity of DDT (2,2-bis(p-chlorophenyl-1,1,1-trichloroethane). J Pharmacol Exp Ther 89(1):18–30.20281336
Fluck ER, Poirier LA, Ruelius HW. 1976. Evaluation of a DNA polymerase-deficient mutant of E. coli for the rapid detection of carcinogens. Chem Biol Interact 15(3):219–231. 10.1016/0009-2797(76)90148-4.793736
Ford WM, Hill EP. 1990. Organochlorine contaminants in eggs and tissue of wood ducks from Mississippi. Bull Environ Contam Toxicol 45(6):870–875. 10.1007/BF01701086.2279137
Ford WM, Hill EP. 1991. Organochlorine pesticides in soil sediments and aquatic animals in the upper Steele bayou watershed of Mississippi. Arch Environ Contam Toxicol 20:161–167.
Forns J, Torrent M, Garcia-Esteban R, 2012a. Longitudinal association between early life socio-environmental factors and attention function at the age 11 years. Environ Res 117:54–59. 10.1016/j.envres.2012.04.007.22608140
Forns J, Lertxundi N, Aranbarri A, 2012b. Prenatal exposure to organochlorine compounds and neuropsychological development up to two years of life. Environ Int 45:72–77. 10.1016/j.envint.2012.04.009.22575806
Forns J, Mandal S, Iszatt N, 2016. Novel application of statistical methods for analysis of multiple toxicants identifies DDT as a risk factor for early child behavioral problems. Environ Res 151:91–100. 10.1016/j.envres.2016.07.014.27466755
Forns J, Stigum H, Hoyer BB, 2018. Prenatal and postnatal exposure to persistent organic pollutants and attention-deficit and hyperactivity disorder: a pooled analysis of seven European birth cohort studies. Int J Epidemiol 47(4):1082–1097. 10.1093/ije/dyy052.29912347
Francone MP, Mariani FH, DeMare C. 1952. [Clinical signs of poisoning by DDT]. Rev Asoc Med Argent 66:56–59. (Spanish)12994116
Frank R, Braun HE. 1989. PCB and DDE residues in milk supplies of Ontario, Canada 1985–1986. Bull Environ Contam Toxicol 42(5):666–669. 10.1007/BF01700385.2500993
Franken C, Koppen G, Lambrechts N, 2017. Environmental exposure to human carcinogens in teenagers and the association with DNA damage. Environ Res 152:165–174. 10.1016/j.envres.2016.10.012.27771571
Freire C, Lopez-Espinosa MJ, Fernandez M, 2011. Prenatal exposure to organochlorine pesticides and TSH status in newborns from Southern Spain. Sci Total Environ 409(18):3281–3287. 10.1016/j.scitotenv.2011.05.037.21683986
Freire C, Koifman RJ, Sarcinelli P, 2012. Long term exposure to organochlorine pesticides and thyroid function in children from Cidade dos Meninos, Rio de Janeiro, Brazil. Environ Res 117:68–74. 10.1016/j.envres.2012.06.009.22776325
Freire C, Koifman RJ, Sarcinelli PN, 2013. Long-term exposure to organochlorine pesticides and thyroid status in adults in a heavily contaminated area in Brazil. Environ Res 127:7–15. 10.1016/j.envres.2013.09.001.24183346
Freire C, Koifman RJ, Sarcinelli PN, 2014. Association between serum levels of organochlorine pesticides and sex hormones in adults living in a heavily contaminated area in Brazil. Int J Hyg Environ Health 217(2–3):370–378. 10.1016/j.ijheh.2013.07.012.23972672
Freire C, Koifman RJ, Koifman S. 2015a. Hematological and hepatic alterations in Brazilian population heavily exposed to organochlorine pesticides. J Toxicol Environ Health A 78(8):534–548. 10.1080/15287394.2014.999396.25849770
Freire C, Koifman RJ, Koifman S. 2015b. Supplemental data to "Hematological and hepatic alterations in Brazilian population heavily exposed to organochlorine pesticides". J Toxicol Environ Health A 10.1080/15287394.2014.999396.
Fry K, Power MC. 2017. Persistent organic pollutants and mortality in the United States, NHANES 1999–2011. Environ Health 16(1):105. 10.1186/s12940-017-0313-6.29017533
Fuhremann TW, Lichtenstein EP. 1980. A comparative study of the persistence, movement, and metabolism of six carbon-14 insecticides in soils and plants. J Agric Food Chem 28(2):446–452. 10.1021/jf60228a016.7391380
Gabliks J, Al-zubaidy T, Askari E. 1975. DDT and immunological responses. 3. Reduced anaphylaxis and mast cell populations in rats fed DDT. Arch Environ Health 30:81–84.234722
Gaido KW, Leonard LS, Lovell S, 1997. Evaluation of chemicals with endocrine modulating activity in a yeast-based steroid hormone receptor gene transcription assay. Toxicol Appl Pharmacol 143(1):205–212. 10.1006/taap.1996.8069.9073609
Gaines TB. 1969. Acute toxicity of pesticides. Toxicol Appl Pharmacol 14(3):515–534. 10.1016/0041-008x(69)90013-1.5787520
Gallo MV, Ravenscroft J, Carpenter DO, 2016. Endocrine disrupting chemicals and ovulation: Is there a relationship? Environ Res 151:410–418. 10.1016/j.envres.2016.08.007.27543788
Gammon MD, Wolff MS, Neugut AI, 1997. Temporal variation in chlorinated hydrocarbons in healthy women. Cancer Epidemiol Biomarkers Prev 6(5):327–332.9149892
Garabrant DH, Held J, Langholz B, 1992. DDT and related compounds and risk of pancreatic cancer. J Natl Cancer Inst 84(10):764–771. 10.1093/jnci/84.10.764.1573662
Garced S, Torres-Sanchez L, Cebrian ME, 2012. Prenatal dichlorodiphenyldichloroethylene (DDE) exposure and child growth during the first year of life. Environ Res 113:58–62. 10.1016/j.envres.2011.12.002.22244494
Garcia M, Mourelle M. 1984. Gamma-glutamyl transpeptidase: a sensitive marker in DDT and toxaphene exposure. J Appl Toxicol 4(5):246–248. 10.1002/jat.2550040506.6150953
Garcia-Villarino M, Riano-Galan I, Rodriguez-Dehli AC, 2018. Prenatal Exposure to Persistent Organic Pollutants and Anogenital Distance in Children at 18 Months. Horm Res Paediatr 90(2):116–122. 10.1159/000492236.30212819
Garrett RM. 1947. Toxicity of DDT for man. J Med Assoc State Ala 17(2):74–76.20257833
Gartrell MJ, Craun JC, Podrebarac DS, 1985. Pesticides, selected elements, and other chemicals in adult total diet samples, October 1979-September 1980. J Assoc Off Anal Chem 68(6):1184–1197.4086442
Gartrell MJ, Craun JC, Podrebarac DS, 1986a. Pesticides, selected elements, and other chemicals in adult total diet samples, October 1980-March 1982. J Assoc Off Anal Chem 69(1):146–159.3949687
Gartrell MJ, Craun JC, Podrebarac DS, 1986b. Pesticides, selected elements, and other chemicals in infant and toddler total diet samples, October 1980-March 1982. J Assoc Off Anal Chem 69(1):123–145.3949685
Gascon M, Vrijheid M, Martinez D, 2012. Pre-natal exposure to dichlorodiphenyldichloroethylene and infant lower respiratory tract infections and wheeze. Eur Respir J 39(5):1188–1196. 10.1183/09031936.00011711.22075485
Gascon M, Verner MA, Guxens M, 2013. Evaluating the neurotoxic effects of lactational exposure to persistent organic pollutants (POPs) in Spanish children. Neurotoxicology 34:9–15. 10.1016/j.neuro.2012.10.006.23085522
Gascon M, Sunyer J, Casas M, 2014. Prenatal exposure to DDE and PCB 153 and respiratory health in early childhood: a meta-analysis. Epidemiology 25(4):544–553. 10.1097/EDE.0000000000000097.24776790
Gaspar FW, Harley KG, Kogut K, 2015a. Prenatal DDT and DDE exposure and child IQ in the CHAMACOS cohort. Environ Int 85:206–212. 10.1016/j.envint.2015.09.004.26414943
Gaspar FW, Harley KG, Kogut K, 2015b. Supplemental material: Prenatal DDT and DDE exposure and child IQ in the CHAMACOS cohort. Environ Int 10.1016/j.envint.2015.09.004.
Gaspar-Ramirez O, Perez-Vazquez FJ, Salgado-Bustamante M, 2015. DDE and PCB 153 independently induce aryl hydrocarbon receptor (AhR) expression in peripheral blood mononuclear cells. J Immunotoxicol 12(3):266–272. 10.3109/1547691X.2014.960108.25316167
Gasull M, Porta M, Pumarega J, 2010. The relative influence of diet and serum concentrations of organochlorine compounds on K-ras mutations in exocrine pancreatic cancer. Chemosphere 79(7):686–697. 10.1016/j.chemosphere.2010.03.011.20350743
Gasull M, Pumarega J, Tellez-Plaza M, 2012. Blood concentrations of persistent organic pollutants and prediabetes and diabetes in the general population of Catalonia. Environ Sci Technol 46(14):7799–7810. 10.1021/es300712g.22681243
Gauthier JM, Pelletier E, Brochu C, 1998. Environmental contaminants in tissues of neonate St Lawrence Beluga whale (Delphinapterus leucas). Mar Pollut Bull 36(1):102–108.
Gellert RJ, Heinrichs WL. 1975. Effects of DDT homologs administered to female rats during the perinatal period. Biol Neonate 26(3–4):283–290. 10.1159/000240740.1169078
Gellert RJ, Heinrichs WL, Swerdloff RS. 1972. DDT homologues: estrogen-like effects on the vagina, uterus and pituitary of the rat. Endocrinology 91(4):1095–1100. 10.1210/endo-91-4-1095.5051333
Gellert RJ, Heinrichs WL, Swerdloff R. 1974. Effects of neonatally-administered DDT homologs on reproductive function in male and female rats. Neuroendocrinology 16(2):84–94. 10.1159/000122555.4473748
Genuis SJ, Lane K, Birkholz D. 2016. Human elimination of organochlorine pesticides: Blood, urine, and sweat study. Biomed Res Int 2016:1624643. 10.1155/2016/1624643.27800487
Geric M, Ceraj-Ceric N, Gajski G, 2012. Cytogenetic status of human lymphocytes after exposure to low concentrations of p,p’-DDT, and its metabolites (p,p’-DDE, and p,p’-DDD) in vitro. Chemosphere 87(11):1288–1294. 10.1016/j.chemosphere.2012.01.037.22354074
Geyer H, Sheehan P, Kotzias D, 1982. Prediction of ecotoxicological behaviour of chemicals: Relationship between physico-chemical properties and bioaccumulation of organic chemicals in the mussel Mytilus edulis. Chemosphere 11:1121–1134.
Gianessi LP, Puffer CA. 1992. Insecticide use in U.S. crop production: Resources for the future. Washington, DC: U.S. Food and Drug Administration and U.S. Environmental Protection Agency. U.S. EPA Cooperative Agreement CR 813719.
Giannandrea F, Gandini L, Paoli D, 2011. Pesticide exposure and serum organochlorine residuals among testicular cancer patients and healthy controls. J Environ Sci Health B 46(8):780–787. 10.1080/03601234.2012.597704.21902556
Giesy JP, Verbrugge DA, Othout RA, 1994. Contaminants in fishes from Great Lakes-influenced sections and above dams of three Michigan rivers. I: Concentrations of organo chlorine insecticides, polychlorinated biphenyls, dioxin equivalents, and mercury. Arch Environ Contam Toxicol 27(2):202–212. 10.1007/BF00214264.8060164
Gilliom RJ. 1984. Pesticides in rivers of the United States. National water summary 1984: Hydrologic events, selected water-quality trends, and ground-water resources. Water Supply Paper 2275. U.S. Geological Survey. 85–92. 10.3133/wsp2275.
Gillis CA, Bonnevie NL, Su SH, 1995. DDT, DDD, and DDE contamination of sediment in the Newark Bay Estuary, New Jersey. Arch Environ Contam Toxicol 28:85–92.
Gingell R. 1975. Enterohepatic circulation of bis(p-chlorophenyl)acetic acid in the rat. Drug Metab Dispos 3(1):42–46.234833
Giordano F, Abballe A, De Felip E, 2010. Maternal exposures to endocrine disrupting chemicals and hypospadias in offspring. Birth Defects Res A Clin Mol Teratol 88(4):241–250. 10.1002/bdra.20657.20196143
Giwercman AH, Rignell-Hydbom A, Toft G, 2006. Reproductive hormone levels in men exposed to persistent organohalogen pollutants: a study of Inuit and three European cohorts. Environ Health Perspect 114(9):1348–1353. 10.1289/ehp.8935.16966087
Gladen BC, Rogan WJ. 1995. DDE and shortened duration of lactation in a northern Mexican town. Am J Public Health 85(4):504–508. 10.2105/ajph.85.4.504.7702113
Gladen BC, Rogan WJ, Hardy P, 1988. Development after exposure to polychlorinated biphenyls and dichlorodiphenyl dichloroethene transplacentally and through human milk. J Pediatr 113(6):991–995. 10.1016/s0022-3476(88)80569-9. 2017/04/05.3142988
Gladen BC, Ragan NB, Rogan WJ. 2000. Pubertal growth and development and prenatal and lactational exposure to polychlorinated biphenyls and dichlorodiphenyl dichloroethene. J Pediatr 136(4):490–496. 10.1016/s0022-3476(00)90012-x.10753247
Gladen BC, Shkiryak-Nyzhnyk ZA, Chyslovska N, 2003. Persistent organochlorine compounds and birth weight. Ann Epidemiol 13(3):151–157. 10.1016/s1047-2797(02)00268-5.12604157
Gladen BC, Klebanoff MA, Hediger ML, 2004. Prenatal DDT exposure in relation to anthropometric and pubertal measures in adolescent males. Environ Health Perspect 112(17):1761–1767. 10.1289/ehp.7287.15579424
Glynn AW, Michaelsson K, Lind PM, 2000. Organochlorines and bone mineral density in Swedish men from the general population. Osteoporos Int 11(12):1036–1042. 10.1007/s001980070025.11256895
Glynn A, Thuvander A, Aune M, 2008. Immune cell counts and risks of respiratory infections among infants exposed pre- and postnatally to organochlorine compounds: a prospective study. Environ Health 7:62. 10.1186/1476-069X-7-62.19055819
Gold B, Brunk G. 1982. Metabolism of 1,1,1-trichloro-2,2-bis(p-chlorophenyl)-ethane and 1,1-dichloro-2,2-bis(p-chlorophenyl)ethane in the mouse. Chem Biol Interact 41(3):327–339. 10.1016/0009-2797(82)90109-0.7105253
Gold B, Brunk G. 1983. Metabolism of 1,1,1-trichloro-2,2-bis(p-chlorophenyl)ethane (DDT), 1,1-dichloro-2,2-bis(p-chlorophenyl)ethane, and 1-chloro-2,2-bis(p-chlorophenyl)ethene in the hamster. Cancer Res 43(6):2644–2647.6850581
Gold B, Brunk G. 1984. A mechanistic study of the metabolism of 1,1-dichloro-2,2-bis(p-chlorophenyl)ethane (DDD) to 2,2-bis(p-chlorophenyl)acetic acid (DDA). Biochem Pharmacol 33(7):979–982. 10.1016/0006-2952(84)90503-3.6712728
Goldberg ED. 1975. Synthetic organohalides in the sea. Proc R Soc Lond B Biol Sci 189(1096):277–289. 10.1098/rspb.1975.0057.238197
Goldman M. 1981. The effect of a single dose of DDT on thyroid function in male rats. Arch Int Pharmacodyn Ther 252(2):327–334.7305567
Goncharov A, Rej R, Negoita S, 2009. Lower serum testosterone associated with elevated polychlorinated biphenyl concentrations in Native American men. Environ Health Perspect 117(9):1454–1460. 10.1289/ehp.0800134.19750113
Goncharov A, Pavuk M, Foushee HR, 2011. Blood pressure in relation to concentrations of PCB congeners and chlorinated pesticides. Environ Health Perspect 119(3):319–325. 10.1289/ehp.1002830.21362590
Govarts E, Nieuwenhuijsen M, Schoeters G, 2012. Birth weight and prenatal exposure to polychlorinated biphenyls (PCBs) and dichlorodiphenyldichloroethylene (DDE): a meta-analysis within 12 European Birth Cohorts. Environ Health Perspect 120(2):162–170. 10.1289/ehp.1103767.21997443
Govarts E, Iszatt N, Trnovec T, 2018. Prenatal exposure to endocrine disrupting chemicals and risk of being born small for gestational age: Pooled analysis of seven European birth cohorts. Environ Int 115:267–278. 10.1016/j.envint.2018.03.017.29605679
Graillot C, Gak JC, Truhart CL R. 1975. Recherches sur les modalites et les mecanismes d’action toxique des insecticides organochlores. II. Etude chez le hamster des effets de toxicite a long terme du DDT. Eur J Toxicol 8(6):353–359. (French)
Grandjean P, Henriksen JE, Choi AL, 2011. Marine food pollutants as a risk factor for hypoinsulinemia and type 2 diabetes. Epidemiology 22(3):410–417.21364465
Gray LE, Wolf C, Lambright C, 1999. Administration of potentially antiandrogenic pesticides (procymidone, linuron, iprodione, chlozolinate, p,p’-DDE, and ketoconazole) and toxic substances (dibutyl- and diethylhexyl phthalate, PCB 169, and ethane dimethane sulphonate) during sexual differentiation produces diverse profiles of reproductive malformations in the male rat. Toxicol Ind Health 15(1–2):94–118.10188194
Green VA. 1969. Effects of pesticides on rat and chick embryo. Trace Subst Environ Health 3:183–209.
Griffin DE, Hill WE. 1978. In vitro breakage of plasmid DNA by mutagenesis and pesticides. Mutat Res 52:161–169.368611
Grindler NM, Allsworth JE, Macones GA, 2015. Persistent organic pollutants and early menopause in U.S. women. PLoS ONE 10(1):e0116057. 10.1371/journal.pone.0116057.25629726
Gunderson EL. 1995a. FDA Total Diet Study, July 1986-April 1991, dietary intakes of pesticides, selected elements, and other chemicals. J AOAC Int 78(6):1353–1363.8664570
Gunderson EL. 1995b. Dietary intakes of pesticides, selected elements, and other chemicals: FDA Total Diet Study, June 1984-April 1986. J AOAC Int 78(4):910–921.7580329
Guo H, Jin Y, Cheng Y, 2014. Prenatal exposure to organochlorine pesticides and infant birth weight in China. Chemosphere 110:1–7. 10.1016/j.chemosphere.2014.02.017.24880592
Gupta PH, Mehta S, Mehta SK. 1989. Effect of DDT on hepatic mixed-function oxidase activity in normal and vitamin A-deficient rats. Biochem Int 19(2):247–256.2818597
Guzzardi MA, Iozzo P, Salonen MK, 2016. Exposure to persistent organic pollutants predicts telomere length in older age: Results from the Helsinki Birth Cohort Study. Aging Dis 7(5):540–552. 10.14336/ad.2016.0209.27699078
Ha MH, Lee DH, Jacobs DR. 2007. Association between serum concentrations of persistent organic pollutants and self-reported cardiovascular disease prevalence: results from the National Health and Nutrition Examination Survey, 1999–2002. Environ Health Perspect 115(8):1204–1209. 10.1289/ehp.10184.17687448
Hagmar L, Bjork J, Sjodin A, 2001. Plasma levels of persistent organohalogens and hormone levels in adult male humans. Arch Environ Health 56(2):138–143. 10.1080/00039890109604065.11339677
Hamid J, Sayeed A, McFarlane H. 1974. The effect of 1-(o-chlorophenyl)-1-(p-chlorophenyl)-2,2-dichloroethane(o,p’-DDD) on the immune response in malnutrition. Br J Exp Pathol 55(1):94–100.4599344
Hammer T, Lophaven SN, Nielsen KR, 2019. Dietary risk factors for inflammatory bowel diseases in a high-risk population: Results from the Faroese IBD study. United European Gastroenterol J 7(7):924–932. 10.1177/2050640619852244.
Han L, Hsu WW, Todem D, 2016. In utero exposure to polychlorinated biphenyls is associated with decreased fecundability in daughters of Michigan female fisheaters: a cohort study. Environ Health 15(1):92. 10.1186/s12940-016-0175-3.27576526
Han X, Zhang F, Meng L, 2020. Exposure to organochlorine pesticides and the risk of type 2 diabetes in the population of East China. Ecotoxicol Environ Saf 190:110125. 10.1016/j.ecoenv.2019.110125.31887706
Hanrahan LP, Falk C, Anderson HA, 1999. Serum PCB and DDE levels of frequent Great Lakes sport fish consumers-a first look. The Great Lakes Consortium. Environ Res 80(2 Pt 2):S26–S37. 10.1006/enrs.1998.3914.10092417
Hansen S, Strom M, Olsen SF, 2014. Maternal concentrations of persistent organochlorine pollutants and the risk of asthma in offspring: results from a prospective cohort with 20 years of follow-up. Environ Health Perspect 122(1):93–99. 10.1289/ehp.1206397.24162035
Hansen S, Strom M, Olsen SF, 2016. Prenatal exposure to persistent organic pollutants and offspring allergic sensitization and lung function at 20 years of age. Clin Exp Allergy 46(2):329–336. 10.1111/cea.12631.26333063
Harada T, Yamaguchi S, Ohtsuka R, 2003. Mechanisms of promotion and progression of preneoplastic lesions in hepatocarcinogenesis by DDT in F344 rats. Toxicol Pathol 31(1):87–98. 10.1080/01926230390173941.12597452
Harada T, Ohtsuka R, Takeda M, 2006. Hepatocarcinogenesis by DDT in Rats. J Toxicol Pathol 19(4):155–167. 10.1293/tox.19.155.
Harada T, Takeda M, Kojima S, 2016. Toxicity and carcinogenicity of dichlorodiphenyltrichloroethane (DDT). Toxicol Res 32(1):21–33. 10.5487/TR.2016.32.1.021.26977256
Haraguchi K, Kuroki H, Masuda Y. 1989. Occurrence and distribution of chlorinated aromatic methylsulfones and sulfoxides in biological samples. Chemosphere 19(1–6):487–492.
Hardell E, Eriksson M, Lindstrom G, 2001. Case-control study on concentrations of organohalogen compounds and titers of antibodies to Epstein-Barr virus antigens in the etiology of non-Hodgkin lymphoma. Leuk Lymphoma 42(4):619–629. 10.3109/10428190109099322.11697490
Hardell L, van Bavel B, Lindstrom G, 2004. Adipose tissue concentrations of p,p’-DDE and the risk for endometrial cancer. Gynecol Oncol 95(3):706–711. 10.1016/j.ygyno.2004.08.022.15581986
Hardell L, Andersson S, Carlberg M, 2006a. Adipose tissue concentrations of persistent organic pollutants and the risk of prostate cancer. J Occup Environ Med 48(7):700–707. http://doi.org/I 10.1097/01.jom.0000205989.46603.43.16832227
Hardell L, van Bavel B, Lindstroem G, 2006b. In utero exposure to persistent organic pollutants in relation to testicular cancer risk. Int J Androl 29(1):228–234.16371110
Hardell L, Carlberg M, Hardell K, 2007. Decreased survival in pancreatic cancer patients with high concentrations of organochlorines in adipose tissue. Biomed Pharmacother 61(10):659–664. 10.1016/j.biopha.2007.04.006.17560068
Hardell K, Carlberg M, Hardell L, 2009. Concentrations of organohalogen compounds and titres of antibodies to Epstein-Barr virus antigens and the risk for non-Hodgkin lymphoma. Oncol Rep 21(6):1567–1576. 10.3892/or_00000389.19424638
Hargrave BT, Harding GC, Vass WP, 1992. Organochlorine pesticides and polychlorinated biphenyls in the Arctic Ocean food web. Arch Environ Contam Toxicol 22(1):41–54. 10.1007/BF00213301.1554252
Harley KG, Marks AR, Bradman A, 2008. DDT exposure, work in agriculture, and time to pregnancy among farmworkers in California. J Occup Environ Med 50(12):1335–1342. 10.1097/JOM.0b013e31818f684d.19092487
Harner T. 1997. Organochlorine contamination of the Canadian Arctic, and speculation on future trends. Int J Environ Pollut 8:5–72. 10.1504/IJEP.1997.028158.
Harris ML, Wilson LK, Elliott JE, 2000. Transfer of DDT and metabolites from fruit orchard soils to American robins (Turdus migratorius) twenty years after agricultural use of DDT in Canada. Arch Environ Contam Toxicol 39:205–220.10871424
Hart MM, Adamson RH, Fabro S. 1971. Prematurity and intrauterine growth retardation induced by DDT in the rabbit. Arch Int Pharmacodyn Ther 192(2):286–290.5093202
Hart MM, Whang-Peng J, Sieber SM, 1972. Distribution and effects of DDT in the pregnant rabbit. Xenobiotica 2(6):567–574. 10.3109/00498257209111084.4662547
Hatcher JM, Delea KC, Richardson JR, 2008. Disruption of dopamine transport by DDT and its metabolites. Neurotoxicology 29(4):682–690. 10.1016/j.neuro.2008.04.010.18533268
Haugen TB, Tefre T, Malm G, 2011. Differences in serum levels of CB-153 and p,p’-DDE, and reproductive parameters between men living south and north in Norway. Reprod Toxicol 32(3):261–267. 10.1016/j.reprotox.2011.06.072.21736938
Hauser R, Chen Z, Pothier L, 2003. The relationship between human semen parameters and environmental exposure to polychlorinated biphenyls and p,p’-DDE. Environ Health Perspect 111(12):1505–1511. 10.1289/ehp.6175.12948891
Hayes WJ. 1982. Chlorinated hydrocarbon insecticides. In: Pesticides studied in man. Baltimore, MD: Williams and Wilkins, 180–205.
Hayes WJ, Durham WF, Cueto C. 1956. The effect of known repeated oral doses of chlorophenothane (DDT) in man. J Am Med Assoc 162(9):890–897.13366680
Hayes WJ, Dale WE, Pirkle CI. 1971. Evidence of safety of long-term, high, oral doses of DDT for man. Arch Environ Health 22(1):119–135. 10.1080/00039896.1971.10665822.4992918
Heberer T, Dünnbier U. 1999. DDT metabolite bis(chlorophenyl)acetic acid: The neglected environmental contaminant. Environ Sci Technol 33(4):2346–2351.
Heggeseth B, Harley K, Warner M, 2015. Detecting associations between early-life DDT exposures and childhood growth patterns: A novel statistical approach. PLoS ONE 10(6):e0131443. 10.1371/journal.pone.0131443.26125556
Heindel JJ, Blumberg B, Cave M, 2017. Metabolism disrupting chemicals and metabolic disorders. Reprod Toxicol 68:3–33. 10.1016/j.reprotox.2016.10.001.27760374
Helzlsouer KJ, Alberg AJ, Huang HY, 1999. Serum concentrations of organochlorine compounds and the subsequent development of breast cancer. Cancer Epidemiol Biomarkers Prev 8(6):525–532.10385143
Henderson GL, Woolley DE. 1969. Studies on the relative insensitivity of the immature rat to the neurotoxic effects of 1,1,1-trichloro-2,2-bis(p-chlorophenyl)ethane (DDT). J Pharmacol Exp Ther 170(1):173–180.5351002
Henderson GL, Woolley DE. 1970. Mechanisms of neurotoxic action of 1,1,1-trichloro-2,2-bis(p-chlorophenyl)ethane (DDT) in immature and adult rats. J Pharmacol Exp Ther 175(1):60–68.5471454
Henriquez-Hernandez LA, Luzardo OP, Zumbado M, 2014. Blood pressure in relation to contamination by polychlorobiphenyls and organochlorine pesticides: Results from a population-based study in the Canary Islands (Spain). Environ Res 135:48–54. 10.1016/j.envres.2014.05.036.25262074
Herr DW, Tilson HA. 1987. Modulation of p,p’-DDT-induced tremor by catecholaminergic agents. Toxicol Appl Pharmacol 91(2):149–158. 10.1016/0041-008x(87)90096-2.3672520
Herr DW, Hong JS, Tilson HA. 1985. DDT-induced tremor in rats: effects of pharmacological agents. Psychopharmacology (Berl) 86(4):426–431. 10.1007/BF00427903.3929313
Hietanen E, Vainio H. 1976. Effect of administration route of DDT on acute toxicity and on drug biotransformation in various rodents. Arch Environ Contam Toxicol 4:201–216.817674
Hill KR, Robinson G. 1945. A fatal case of DDT poisoning in a child, with an account of two accidental deaths in dogs. Br Med J 2(Dec 15):845–847.
Hitch RK, Day HR. 1992. Unusual persistence of DDT in some western USA soils. Bull Environ Contam Toxicol 48:259–264.1536998
Hoff RM, Strachan MJ, Sweet CW, 1996. Atmospheric deposition of toxic chemicals to the Great Lakes: A review of the data through 1994. Atmos Environ 30(20):3505–3527.
Hojo H, Aoyama H, Takahashi KL, 2006. Two-generation reproduction toxicity study in rats with 1,1,1-trichloro-2,2-bis(4-chlorophenyl)ethane (p,p’-DDT). Congenit Anom (Kyoto) 46(2):105–114. 10.1111/j.1741-4520.2006.00110.x.16732769
Holloway AC, Petrik JJ, Younglai EV. 2007. Influence of dichlorodiphenylchloroethylene on vascular endothelial growth factor and insulin-like growth factor in human and rat ovarian cells. Reprod Toxicol 24(3–4):359–364. 10.1016/j.reprotox.2007.05.003.17574386
Hong JS, Herr DW, Hudson PM, 1986. Neurochemical effects of DDT in rat brain in vivo. Arch Toxicol Suppl 9:14–26. 10.1007/978-3-642-71248-7_2.2434059
Hoppin JA, Tolbert PE, Holly EA, 2000. Pancreatic cancer and serum organochlorine levels. Cancer Epidemiol Biomarkers Prev 9(2):199–205.10698482
Hou L, Andreotti G, Baccarelli AA, 2013. Lifetime pesticide use and telomere shortening among male pesticide applicators in the Agricultural Health Study. Environ Health Perspect 121(8):919–924. 10.1289/ehp.1206432.23774483
Hovinga ME, Sowers M, Humphrey HE. 1992. Historical changes in serum PCB and DDT levels in an environmentally-exposed cohort. Arch Environ Contam Toxicol 22(4):362–366. 10.1007/BF00212554.1489385
Hovinga ME, Sowers M, Humphrey HE. 1993. Environmental exposure and lifestyle predictors of lead, cadmium, PCB, and DDT levels in Great Lakes fish eaters. Arch Environ Health 48(2):98–104. 10.1080/00039896.1993.9938402.8476311
Howard PH, Neal MW. 1992. Dictionary of chemical names and synonyms. Boca Raton, FL: Lewis Publishers. I558, I769, I524–525.
Howard PH, Meylan WM, eds. 1997. In: Handbook of physical properties of organic chemicals. Boca Raton: CRC Lewis Publishers, 3, 12, 49, 518, 723.
Howell G, Mangum L. 2011. Exposure to bioaccumulative organochlorine compounds alters adipogenesis, fatty acid uptake, and adipokine production in NIH3T3-L1 cells. Toxicol in Vitro 25(1):394–402. 10.1016/j.tiv.2010.10.015.21044676
Howell GE, Meek E, Kilic J, 2014. Exposure to p,p’-dichlorodiphenyldichloroethylene (DDE) induces fasting hyperglycemia without insulin resistance in male C57BL/6H mice. Toxicology 320:6–14. 10.1016/j.tox.2014.02.004.24582731
Howell GE, Mulligan C, Meek E, 2015. Effect of chronic p,p’-dichlorodiphenyldichloroethylene (DDE) exposure on high fat diet-induced alterations in glucose and lipid metabolism in male C57BL/6H mice. Toxicology 328:112–122. 10.1016/j.tox.2014.12.017.25541407
Howsam M, Grimalt JO, Guino E, 2004. Organochlorine exposure and colorectal cancer risk. Environ Health Perspect 112(15):1460–1466. 10.1289/ehp.7143.15531428
Hoyer BB, Ramlau-Hansen CH, Henriksen TB, 2014. Body mass index in young school-age children in relation to organochlorine compounds in early life: a prospective study. Int J Obes (Lond) 38(7):919–925. 10.1038/ijo.2014.58.24718355
Hoyer BB, Ramlau-Hansen CH, Pedersen HS, 2015. Motor development following in utero exposure to organochlorines: a follow-up study of children aged 5–9 years in Greenland, Ukraine and Poland. BMC Public Health 15:146. 10.1186/s12889-015-1465-3.25885170
Hrdina PD, Singhal RL. 1972. Neurotoxic effects of DDT: protection by cycloheximide. J Pharm Pharmacol 24(2):167–169. 10.1111/j.2042-7158.1972.tb08956.x.4401977
Hrdina PD, Singhal RL, Peters DA V, 1973. Some neurochemical alterations during acute DDT poisoning. Toxicol Appl Pharmacol 25:276–288.4715490
Hsieh HC. 1954. DDT intoxication in a family in southern Taiwan. AMA Arch Ind Hyg Occup Med 10:344–346.
Huang X, Hites RA, Foran JA, 2006. Consumption advisories for salmon based on risk of cancer and noncancer health effects. Environ Res 101(2):263–274. 10.1016/j.envres.2005.08.011.16198332
Huang J, Eskenazi B, Bornman R, 2018. Maternal peripartum serum DDT/E and urinary pyrethroid metabolite concentrations and child infections at 2 years in the VHEMBE Birth Cohort. Environ Health Perspect 126(6):067006. 10.1289/EHP2657.29906263
Hudson PM, Chen PH, Tilson HA, 1985. Effects of p,p’-DDT on the rat brain concentrations of biogenic amine and amino acid neurotransmitters and their associations with p,p’-DDT-induced tremor and hyperthermia. J Neurochem 45(5):1349–1355.2864392
Hurd-Brown T, Udoji F, Martin T, 2013. Effects of DDT and triclosan on tumor-cell binding capacity and cell-surface protein expression of human natural killer cells. J Appl Toxicol 33(6):495–502. 10.1002/jat.2767.22729613
Hwang EC, Van Woert MH. 1978. p,p’-DDT-induced neurotoxic syndrome: experimental myoclonus. Neurology 28(10):1020–1025. 10.1212/wnl.28.10.1020.311446
Hyland JL, Snoots TR, Balthis WL. 1998. Sediment quality of estuaries in the southeastern U.S. Environ Monit Assess 51:331–343.
IARC. 2017. DDT. IARC monographs on the evaluation of carcinogenic risks to humans. Volume 113. DDT, lindane, and 2,4-D. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Monographs/vol113/mono113-01.pdf. January 10, 2018.
IARC. 2018. DDT, lindane, and 2,4-D. IARC monographs on the evaluation of carcinogenic risks to humans. Lyon, France: International Agency for Research on Cancer.
Ingber SZ, Buser MC, Pohl HR, 2013. DDT/DDE and breast cancer: a meta-analysis. Regul Toxicol Pharmacol 67(3):421–433. 10.1016/j.yrtph.2013.08.021.24021539
Innes JR, Ulland BM, Valerio MG, 1969. Bioassay of pesticides and industrial chemicals for tumorigenicity in mice: a preliminary note. J Natl Cancer Inst 42(6):1101–1114.5793189
IRIS. 2002a. p,p’-Dichlorodiphenyltrichloroethane (DDT); CASRN 50–29-3. Integrated Risk Information System. Chemical assessment summary. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0147_summary.pdf. April 26, 2017.
IRIS. 2002b. p,p’-Dichlorodiphenyl dichloroethane (DDD); CASRN 72–54-8. Integrated Risk Information System. Chemical assessment summary. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0347_summary.pdf. April 26, 2017.
IRIS. 2003. p,p’-Dichlorodiphenyldichloroethylene (DDE); CASRN 72–55-9. Integrated Risk Information System. Chemical assessment summary. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0328_summary.pdf. April 26, 2017.
Ishikawa T, Graham JL, Stanhope KL, 2015. Effect of DDT exposure on lipids and energy balance in obese Sprague-Dawley rats before and after weight loss. Toxicology Reports 2:990–995. 10.1016/h,tixreo,2915,07.005.28962439
Iszatt N, Stigum H, Verner MA, 2015. Prenatal and postnatal exposure to persistent organic pollutants and infant growth: A pooled analysis of seven European birth cohorts. Environ Health Perspect 123(7):730–736. 10.1289/ehp.1308005.25742056
Itoh H, Iwasaki M, Kasuga Y, 2014. Association between serum organochlorines and global methylation level of leukocyte DNA among Japanese women: a cross-sectional study. Sci Total Environ 490:603–609. 10.1016/j.scitotenv.2014.05.035.24880549
Iwata H, Tanabe S, Sakai N, 1993. Distribution of persistent organochlorines in the oceanic air and surface seawater and the role of ocean on their global transport and fate. Environ Sci Technol 27:1080–1098.
Jaga K, Dharmani C. 2003. Global surveillance of DDT and DDE levels in human tissues. Int J Occup Med Environ Health 16(1):7–20.12705713
Jandacek RJ, Rider T, Yang Q, 2009. Lymphatic and portal vein absorption of organochlorine compounds in rats. Am J Physiol Gastrointest Liver Physiol 296(2):G226–234. 10.1152/ajpgi.90517.2008.19056760
Janicki RH, Kinter WB. 1971. DDT inhibits Na+, K+, Mg2+-ATPase in the intestinal mucosae and gills of marine teleosts. Nature New Biology 233:148–149.4256052
Jasso-Pineda Y, Diaz-Barriga F, Yanez-Estrada L, 2015. DNA damage in Mexican children living in high-risk contaminated scenarios. Sci Total Environ 518–519:38–48. 10.1016/j.scitotenv.2015.02.073.
Jayasinghe S, Lind L, Salihovic S, 2018. High serum levels of p,p’-DDE are associated with an accelerated decline in GFR during 10years follow-up. Sci Total Environ 644:371–374. 10.1016/j.scitotenv.2018.07.020.29981985
Jeddy Z, Kordas K, Allen K, 2018. Prenatal exposure to organochlorine pesticides and early childhood communication development in British girls. Neurotoxicology 69:121–129. 10.1016/j.neuro.2018.10.003.30292654
Jellali R, Zeller P, Gilard F, 2018. Effects of DDT and permethrin on rat hepatocytes cultivated in microfluidic biochips: Metabolomics and gene expression study. Environ Toxicol Pharmacol 59:1–12. 10.1016/j.etap.2018.02.004.29477483
Jensen S, Jansson B. 1976. Methyl sulfone metabolites of PCB and DDE. Ambio 5(5–6):257–260.
Jensen JA, Cueto C, Dale WE, 1957. DDT metabolites in feces and bile of rats. Agric Food Chem 5(12):919–924.
Johansson U, Fredriksson A, Eriksson P. 1995. Bioallethrin causes permanent changes in behavioural and muscarinic acetylcholine receptor variables in adult mice exposed neonatally to DDT. Eur J Pharmacol 293(2):159–166. 10.1016/0926-6917(95)00012-7.7589230
Johansson U, Fredriksson A, Eriksson P. 1996. Low-dose effects of paraoxon in adult mice exposed neonatally to DDT: changes in behavioural and cholinergic receptor variables. Environ Toxicol Pharmacol 2(4):307–314. 10.1016/s1382-6689(96)00062-2.21781735
Johnsen RE. 1976. DDT metabolism in microbial systems. Residue Rev 61:1–28. 10.1007/978-1-4613-9401-3_1.778953
Johnson A, Norton D, Yake B. 1988. Persistence of DDT in the Yakima River drainage, Washington. Arch Environ Contam Toxicol 17(3):289–297. 10.1007/BF01055165.3377532
Johnson DC, Sen M, Dey SK. 1992. Differential effects of dichlorodiphenyltrichloroethane analogs, chlordecone, and 1,3,7,8-tetrachlorodibenzo-p-dioxin on establishment of pregnancy in the hypophysectomized rat. Proc Soc Exp Biol Med 199:42–48.1370187
Jones JL, Roberts LM. 1999. The relative merits of monitoring and domestic wells for ground water quality investigations. Ground Water Monit Remed 19(3):138–144.
Jonsson HT, Keil JE, Gaddy RG, 1976. Prolonged ingestion of commercial DDT and PCB; effects on progesterone levels and reproduction in the mature female rat. Arch Environ Contam Toxicol 3:479–490.
Jonsson HT, Walker EM, Greene WB, 1981. Effects of prolonged exposure to dietary DDT and PCB on rat liver morphology. Arch Environ Contam Toxicol 10(2):171–183. 10.1007/BF01055619.7224669
Jusko TA, Koepsell TD, Baker RJ, 2006. Maternal DDT exposures in relation to fetal and 5-year growth. Epidemiology 17(6):692–700. 10.1097/01.ede.0000232226.06807.90.17003683
Jusko TA, Klebanoff MA, Brock JW, 2012. In-utero exposure to dichlorodiphenyltrichloroethane and cognitive development among infants and school-aged children. Epidemiology 23(5):689–698. 10.1097/EDE.0b013e31825fb61d.22766752
Jusko TA, De Roos AJ, Lee SY, 2016a. A birth cohort study of maternal and infant serum PCB-153 and DDE concentrations and responses to infant tuberculosis vaccination. Environ Health Perspect 124(6):813–821. 10.1289/ehp.1510101.26649893
Jusko TA, De Roos AJ, Lee SY, 2016b. Supplemental material: A birth cohort study of maternal and infant serum PCB-153 and DDE concentrations and responses to infant tuberculosis vaccination. Environ Health Perspect 10.1289/ehp.1510101.
Kajta M, Wnuk A, Rzemieniec J, 2017. Depressive-like effect of prenatal exposure to DDT involves global DNA hypomethylation and impairment of GPER1/ESR1 protein levels but not ESR2 and AHR/ARNT signaling. J Steroid Biochem Mol Biol 171:94–109. 10.1016/j.jsbmb.2017.03.001.28263910
Kalayou S, Granum C, Berntsen HF, 2016. Label-free based quantitative proteomics analysis of primary neonatal porcine Leydig cells exposed to the persistent contaminant 3-methylsulfonyl-DDE. J Proteomics 137:68–82. 10.1016/j.jprot.2015.12.007.26691841
Kale SP, Murthy NB, Raghu K, 1999. Studies on degradation of 14C-DDT in the marine environment. Chemosphere 39(6):959–968. 10.1016/s0045-6535(99)00027-2.10448570
Kallenborn R, Oehme M, Wynn-Williams DD, 1998. Ambient air levels and atmospheric long-range transport of persistent organochlorines to Signy Island, Antarctica. Sci Total Environ 220:167–180.
Office KAN-DO and Team Pesticide. 1995. Accumulated pesticide and industrial chemical findings from a ten-year study of ready-to-eat foods. J AOAC Int 78(3):614–631.7756874
Kang IH, Kim HS, Shin JH, 2004. Comparison of anti-androgenic activity of flutamide, vinclozolin, procymidone, linuron, and p, p’-DDE in rodent 10-day Hershberger assay. Toxicology 199(2–3):145–159. 10.1016/j.tox.2004.02.019.15147789
Kar PP, Dikshith TS. 1970. Dermal toxicity of DDT. Experientia 26(6):634–635. 10.1007/BF01898732.5424345
Karami-Mohajeri S, Abdollahi M. 2011. Toxic influence of organophosphate, carbamate, and organochlorine pesticides on cellular metabolism of lipids, proteins, and carbohydrates: a systematic review. Hum Exp Toxicol 30(9):1119–1140. 10.1177/0960327110388959.
Karlsen M, Grandjean P, Weihe P, 2017. Early-life exposures to persistent organic pollutants in relation to overweight in preschool children. Reprod Toxicol 68:145–153. 10.1016/j.reprotox.2016.08.002.27496715
Karmaus W, Zhu X. 2004. Maternal concentration of polychlorinated biphenyls and dichlorodiphenyl dichlorethylene and birth weight in Michigan fish eaters: a cohort study. Environ Health 3(1):1. 10.1186/1476-069X-3-1.14748928
Karmaus W, Kuehr J, Kruse H. 2001. Infections and atopic disorders in childhood and organochlorine exposure. Arch Environ Health 56(6):485–492. 10.1080/00039890109602896.11958547
Karmaus W, Asakevich S, Indurkhya A, 2002. Childhood growth and exposure to dichlorodiphenyl dichloroethene and polychlorinated biphenyls. J Pediatr 140(1):33–39. 10.1067/mpd.2002.120764.11815761
Karmaus W, Davis S, Chen Q, 2003. Atopic manifestations, breast-feeding protection and the adverse effect of DDE. Paediatr Perinat Epidemiol 17(2):212–220. 10.1046/j.1365-3016.2003.00488.x.12675789
Karmaus W, Brooks KR, Nebe T, 2005a. Immune function biomarkers in children exposed to lead and organochlorine compounds: a cross-sectional study. Environ Health 4(1):5. 10.1186/1476-069x-4-5.15831097
Karmaus W, Brooks KR, Nebe T, 2005b. Supplementary material: Immune function biomarkers in children exposed to lead and organochlorine compounds: a cross-sectional study. Environ Health 10.1186/1476-069x-4-5. https://ehjournal.biomedcentral.com/articles/10.1186/1476-069X-4-5 (https://ehjournal.biomedcentral.com/articles/10.1186/1476). March 29, 2017.
Karmaus W, Osuch JR, Eneli I, 2009. Maternal levels of dichlorodiphenyl-dichloroethylene (DDE) may increase weight and body mass index in adult female offspring. Occup Environ Med 66(3):143–149. 10.1136/oem.2008.041921.19060027
Kashyap SK, Nigam SK, Karnik AB, 1977. Carcinogenicity of DDT (dichlorodiphenyl trichloroethane) in pure inbred Swiss mice. Int J Cancer 19(5):725–729. 10.1002/ijc.2910190519.863549
Kaur N, Starling AP, Calafat AM, 2020. Longitudinal association of biomarkers of pesticide exposure with cardiovascular disease risk factors in youth with diabetes. Environ Res 181:108916. 10.1016/j.envres.2019.108916.31761333
Kazantseva YA, Yarushkin AA, Pustylnyak VO. 2013. Dichlorodiphenyltrichloroethane technical mixture regulates cell cycle and apoptosis genes through the activation of CAR and ERalpha in mouse livers. Toxicol Appl Pharmacol 271(2):137–143. 10.1016/j.taap.2013.05.008.23684557
Keith LH, Garrison AW, Allen FR, 1979. Identification of organic compounds in drinking water from thirteen U.S. cities. In: Identification and analysis of organic pollutants in water. Ann Arbor, MI: Ann Arbor Science, 329–358.
Kelce W, Stone C, Laws S, 1995. Persistent DDT metabolite p,p-DDE is a potent androgen receptor antagonist. Nature 375:581–585.7791873
Kelce WR, Lambright CR, Gray LE, 1997. Vinclozolin and p,p’-DDE alter androgen-dependent gene expression: in vivo confirmation of an androgen receptor-mediated mechanism. Toxicol Appl Pharmacol 142(1):192–200. 10.1006/taap.1996.7966.9007049
Keller WC, Yeary RA. 1980. A comparison of the effects of mineral oil, vegetable oil, and sodium sulfate on the intestinal absorption of DDT in rodents. Clin Toxicol 16(2):223–231. 10.3109/15563658008989941.7398212
Kelly-Garvert F, Legator MS. 1973. Cytogenic and mutagenic effects of DDT and DDE in a Chinese hamster cell line. Mutat Res 17:223–229.4346226
Keplinger ML, Deichmann WB, Sala F. 1970. Effects of combinations of pesticides on reproduction in mice. In: Deichmann WB, Radomski JL, Penalver RA, eds. Collection of papers, Inter-American Conference on Toxicology and Occupational Medicine, 6th and 7th Pesticide Symposia. Miami, FL: Halos and Associates, 125–138.
Kezios KL, Liu X, Cirillo PM, 2013. Dichlorodiphenyltrichloroethane (DDT), DDT metabolites and pregnancy outcomes. Reprod Toxicol 35:156–164. 10.1016/j.reprotox.2012.10.013.23142753
Khairy M. 1959. Changes in behaviour associated with a nervous system poison (D.D.T.). Q J Exp Psychol 11:84–91.
Khanjani N, Sim MR. 2006. Maternal contamination with dichlorodiphenyltrichloroethane and reproductive outcomes in an Australian population. Environ Res 101(3):373–379. 10.1016/j.envres.2005.10.003.16360142
Khanna N, Santerre CR, Xu D, 1997. Changes in dieldrin and p,p’-DDE residues following cooking of channel catfish. J Food Prot 60(3):300–304.31195488
Kidd KA, Bootsma HA, Hesslein RH, 2001. Biomagnification of DDT through the benthic and pelagic food webs of Lake Malawi, East Africa: importance of trophic level and carbon source. Environ Sci Technol 35(1):14–20. 10.1021/es001119a.11351999
Kim JY, Choi CY, Lee KJ, 2004. Induction of inducible nitric oxide synthase and proinflammatory cytokines expression by o,p’-DDT in macrophages. Toxicol Lett 147(3):261–269. 10.1016/j.toxlet.2003.12.001.15104118
Kim KY, Kim DS, Lee SK, 2010. Association of low-dose exposure to persistent organic pollutants with global DNA hypomethylation in healthy Koreans. Environ Health Perspect 118(3):370–374. 10.1289/ehp.0901131.20064773
Kim S, Park J, Kim HJ, 2013. Association between several persistent organic pollutants and thyroid hormone levels in serum among the pregnant women of Korea. Environ Int 59:442–448. 10.1016/j.envint.2013.07.009.23928038
Kim KS, Lee YM, Kim SG, 2014. Associations of organochlorine pesticides and polychlorinated biphenyls in visceral vs. subcutaneous adipose tissue with type 2 diabetes and insulin resistance. Chemosphere 94:151–157. 10.1016/j.chemosphere.2013.09.066.24161582
Kim KS, Lee YM, Lee HW, 2015a. Associations between organochlorine pesticides and cognition in U.S. elders: National Health and Nutrition Examination Survey 1999–2002. Environ Int 75:87–92. 10.1016/j.envint.2014.11.003.25461417
Kim SA, Lee YM, Lee HW, 2015b. Greater cognitive decline with aging among elders with high serum concentrations of organochlorine pesticides. PLoS ONE 10(6):e0130623. 10.1371/journal.pone.0130623.26107947
Kim SA, Lee YM, Lee HW, 2015c. Can inconsistent association between hypertension and cognition in elders be explained by levels of organochlorine pesticides? PLoS ONE 10(12):e0144205. 10.1371/journal.pone.0144205.26630154
Kim S, Park J, Kim HJ, 2015d. Association between several persistent organic pollutants and thyroid hormone levels in cord blood serum and bloodspot of the newborn infants of Korea. PLoS ONE 10(5):e0125213. 10.1371/journal.pone.0125213.25965908
Kim HM, Youn CH, Ko HJ, 2016. The relationship between the blood level of persistent organic pollutants and common gastrointestinal symptoms. Korean J Fam Med 37(5):267–272. 10.4082/kjfm.2016.37.5.267.27688859
Kim S, Cho YH, Lee I, 2018. Prenatal exposure to persistent organic pollutants and methylation of LINE-1 and imprinted genes in placenta: A CHECK cohort study. Environ Int 119:398–406. 10.1016/j.envint.2018.06.039.30005188
Kim S, Cho YH, Won S, 2019. Maternal exposures to persistent organic pollutants are associated with DNA methylation of thyroid hormone-related genes in placenta differently by infant sex. Environ Int 130:104956. 10.1016/j.envint.2019.104956.31272017
Kimbrough R, Gaines TB, Sherman JD. 1964. Nutritional factors, long-term DDT inhalation and chloroleukemia in rats. J Natl Cancer Inst 33:215–225.14207841
King SE, McBirney M, Beck D, 2019a. Sperm epimutation biomarkers of obesity and pathologies following DDT induced epigenetic transgenerational inheritance of disease. Environ Epigenet 5(2):dvz008. 10.1093/eep/dvz008.31186947
King SE, Nilsson E, Beck D, 2019b. Adipocyte epigenetic alterations and potential therapeutic targets in transgenerationally inherited lean and obese phenotypes following ancestral exposures. Adipocyte 8(1):362–378. 10.1080/21623945.2019.1693747.31755359
Kiriluk RM, Servos MR, Whittle DM, 1995. Using ratios of stable nitrogen and carbon isotopes to characterize the biomagnification of DDE, mirex, and PCB in a Lake Ontario pelagic food web. Can J Fish Aquat Sci 52:2660–2674.
Kirk GR, Jensen HE. 1975. Toxic effects of o,p’-DDD in the normal dog. J Am Anim Hosp Assoc 11:765–768.
Kirk GR, Boyer S, Hutcheson DP. 1974. Effects of o,p’-DDD on plasma cortisol levels and histology of the adrenal gland in the normal dog. J Am Anim Hosp Assoc 10:179–182.
Kitagawa T, Hino O, Nomura K, 1984. Dose-response studies on promoting and anticarcinogenic effects of phenobarbital and DDT in the rat hepatocarcinogenesis. Carcinogenesis 5(12):1653–1656. 10.1093/carcin/5.12.1653.6499117
Kitamura S, Shimizu Y, Shiraga Y, 2002. Reductive metabolism of p,p’-DDT and o,p’-DDT by rat liver cytochrome P450. Drug Metab Dispos 30(2):113–118. 10.1124/dmd.30.2.113.11792678
Klaassen CD. 1990. Principles of toxicology. In: Gilman AG, Rall TW, Nies AS, , eds. The pharmacological basis of therapeutics. 8th ed. New York, NY: Mcgraw-Hill, 49–61.
Klil-Drori AJ, Kleinstern G, Seir RA, 2018a. Serum organochlorines and non-Hodgkin lymphoma: A case-control study in Israeli Jews and Palestinians. Chemosphere 213:395–402. 10.1016/j.chemosphere.2018.09.069.30241084
Klil-Drori AJ, Kleinstern G, Seir RA, 2018b. Supplemental material: Serum organochlorines and non-Hodgkin lymphoma: A case-control study in Israeli Jews and Palestinians. Chemosphere 213 10.1016/j.chemosphere.2018.09.069.
Kolmodin B, Azarnoff DL, Sjoqvist F. 1969. Effect of environmental factors on drug metabolism: decreased plasma half-life of antipyrine in workers exposed to chlorinated hydrocarbon insecticides. Clin Pharmacol Ther 10(5):638–642. 10.1002/cpt1969105638.5808460
Koner BC, Banerjee BD, Ray A. 1998. Organochlorine pesticide-induced oxidative stress and immune suppression in rats. Indian J Exp Biol 36(4):395–398.9717451
Kornbrust D, Gillis B, Collins B, 1986. Effects of 1,1-dichloro-2,2-bis[p-chlorophenyl]ethylene (DDE) on lactation in rats. J Toxicol Environ Health 17(1):23–36. 10.1080/15287398609530799.3950997
Korrick SA, Altshul LM, Tolbert PE, 2000. Measurement of PCBs, DDE, and hexachlorobenzene in cord blood from infants born in towns adjacent to a PCB-contaminated waste site. J Expo Anal Environ Epidemiol 10(6 Pt 2):743–754. 10.1038/sj.jea.7500120.11138666
Korrick SA, Chen C, Damokosh AI, 2001. Association of DDT with spontaneous abortion: a case-control study. Ann Epidemiol 11(7):491–496. 10.1016/s1047-2797(01)00239-3.11557181
Kostka G, Palut D, Kopec-Szlezak J, 2000. Early hepatic changes in rats induced by permethrin in comparison with DDT. Toxicology 142(2):135–143. 10.1016/s0300-483x(99)00164-x.10685513
Kratzer CR. 1999. Transport of sediment-bound organochlorine pesticides to the San Joaquin River, California. J Am Water Resour Assoc 35(4):957–981.
Krause W. 1977. Influence of DDT, DDVP and malathion on FSH, LH and testosterone serum levels and testosterone concentration in testis. Bull Environ Contam Toxicol 18(2):231–242. 10.1007/BF01686072.890160
Krause W, Hamm K, Weissmuller J. 1975. The effect of DDT on spermatogenesis of the juvenile rat. Bull Environ Contam Toxicol 14(2):171–179. 10.1007/BF01701310.1174726
Krauthacker B, Reiner E, Votava-Raic A, 1998. Organochlorine pesticides and PCBs in human milk from mothering nursing hospitalized children. Chemosphere 37(1):27–32.9637005
Kreiss K, Zack MM, Kimbrough RD, 1981. Association of blood pressure and polychlorinated biphenyl levels. JAMA 245(24):2505–2509.6785463
Krieger N, Wolff M, Hiatt R, 1994. Breast cancer and serum organochlorines: A prospective study among white, black, and Asian women. J Natl Cancer Inst 86(8):589–599.8145274
Krishnan K, Anderson ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kristensen SL, Ramlau-Hansen CH, Ernst E, 2016. Prenatal exposure to persistent organochlorine pollutants and female reproductive function in young adulthood. Environ Int 92–93:366–372. 10.1016/j.envint.2016.04.024.
Kubinski H, Gutzke GE, Kubinski ZO. 1981. DNA-cell-binding (DCB) assay for suspected carcinogens and mutagens. Mutat Res 89(2):95–136. 10.1016/0165-1218(81)90118-x.7290095
Kuhnlein HV, Receveur O, Muir DC G, 1995. Arctic indigenous women consume greater than acceptable levels of organochlorines. J Nutr 125:2501–2510.7562084
Kumar V, Yadav CS, Singh S, 2010. CYP 1A1 polymorphism and organochlorine pesticides levels in the etiology of prostate cancer. Chemosphere 81(4):464–468. 10.1016/j.chemosphere.2010.07.067.20817259
Kutz FW, Yobs AR, Strassman SC, 1977. Pesticides in people: Effects of reducing DDT usage on total DDT storage in humans. Pestic Monit J 11(2):61–63.600675
Kutz FW, Strassman SC, Sperling JF. 1979. Survey of selected organochlorine pesticides in the general population of the United States: fiscal years 1970–1975. Ann N Y Acad Sci 320:60–68. 10.1111/j.1749-6632.1979.tb56593.x.287404
Kutz FW, Wood PH, Bottimore DP. 1991. Organochlorine pesticides and polychlorinated biphenyls in human adipose tissue. Rev Environ Contam Toxicol 120:1–82. 10.1007/978-1-4612-3080-9_1.1899728
Kyriklaki A, Vafeiadi M, Kampouri M, 2016. Prenatal exposure to persistent organic pollutants in association with offspring neuropsychological development at 4 years of age: The Rhea mother-child cohort, Crete, Greece. Environ Int 97:204–211. 10.1016/j.envint.2016.09.012.27666324
La Merrill M, Cirillo PM, Terry MB, 2013. Prenatal exposure to the pesticide DDT and hypertension diagnosed in women before age 50: a longitudinal birth cohort study. Environ Health Perspect 121(5):594–599. 10.1289/ehp.1205921.23591545
La Merrill M, Karey E, Moshier E, 2014a. Perinatal exposure of mice to the pesticide DDT impairs energy expenditure and metabolism in adult female offspring. PLoS ONE 9(7):e103337. 10.1371/journal.pone.0103337.25076055
La Merrill M, Karey E, Moshier E, 2014b. Correction: Perinatal exposure of mice to the pesticide DDT impairs energy expenditure and metabolism in adult female offspring (vol 9, e103337, 2014). PLoS ONE 9(9):Article No.: e107332. http://doi.org/I 10.1371/journal.pone.0107332.
La Merrill MA, Sethi S, Benard L, 2016. Perinatal DDT exposure induces hypertension and cardiac hypertrophy in adult mice. Environ Health Perspect 124(11):1722–1727. 10.1289/EHP164.27325568
La Merrill MA, Lind PM, Salihovic S, 2018. The association between p,p’-DDE levels and left ventricular mass is mainly mediated by obesity. Environ Res 160:541–546. 10.1016/j.envres.2017.10.031.29106953
La Merrill MA, Johnson CL, Smith MT, 2019. Exposure to persistent organic pollutants (POPs) and their relationship to hepatic fat and insulin insensitivity among Asian Indian immigrants in the United States. Environ Sci Technol 53(23):13906–13918. 10.1021/acs.est.9b03373.31746186
Laden F, Neas LM, Spiegelman D, 1999. Predictors of plasma concentrations of DDE and PCBs in a group of U.S. women. Environ Health Perspect 107(1):75–81. 10.1289/ehp.9910775.9872720
Laden F, Collman G, Iwamoto K, 2001a. 1,1-Dichloro-2,2-bis(p-chlorophenyl)ethylene and polychlorinated biphenyls and breast cancer: Combined analysis of five U.S. studies. J Natl Cancer Inst 93(10):768–776. 10.1093/jnci/93.10.768.11353787
Laden F, Bertrand KA, Altshul L, 2010. Plasma organochlorine levels and risk of non-Hodgkin lymphoma in the Nurses’ Health Study. Cancer Epidemiol Biomarkers Prev 19(5):1381–1384. 10.1158/1055-9965.EPI-10-0125.20406963
LaKind JS, Berlin CM, Park CN, 2000. Methodology for characterizing distributions of incremental body burdens of 2,3,7,8-TCDD and DDE from breast milk in North American nursing infants. J Toxicol Environ Health A 59(8):605–639. 10.1080/009841000156628.10839496
Lam T, Williams PL, Lee MM, 2014. Prepubertal organochlorine pesticide concentrations and age of pubertal onset among Russian boys. Environ Int 73:135–142. 10.1016/j.envint.2014.06.020.25118086
Lam T, Williams PL, Lee MM, 2015. Prepubertal serum concentrations of organochlorine pesticides and age at sexual maturity in Russian boys. Environ Health Perspect 123(11):1216–1221. 10.1289/ehp.1409022.26009253
Langer P, Ukropec J, Kocan A, 2014. Obesogenic and diabetogenic impact of high organochlorine levels (HCB, p,p’-DDE, PCBs) on inhabitants in the highly polluted Eastern Slovakia. Endocr Regul 48(1):17–24. 10.4149/endo_2014_01_17.24524372
Larsen KD, Jalal SM. 1974. DDT induced chromosome mutations in mice: Further testing. Can J Genet Cytol 16:491–497.4378424
Lauenstein GG. 1995. Comparison of organic contaminants found in mussels and oysters from a current mussel watch project with those from archived mollusc samples of the 1970s. Mar Pollut Bull 30(12):826–833.
Laug E, Nelson A, Fitzhugh O, 1950. Liver cell alternation and DDT storage in the fat of the rat induced by dietary levels of 1 to 50 ppm DDT. J Pharmacol Exp Ther Suppl 98:268.
Law DC, Klebanoff MA, Brock JW, 2005. Maternal serum levels of polychlorinated biphenyls and 1,1-dichloro-2,2-bis(p-chlorophenyl)ethylene (DDE) and time to pregnancy. Am J Epidemiol 162(6):523–532. 10.1093/aje/kwi240.16093292
Laws ER, Curley A, Biros F. 1967. Men with intensive occupational exposure to DDT: A clinical and chemistry study. Arch Environ Health 15:766–775.6061300
Laws ER, Maddrey WC, Curley A, 1973. Long-term occupational exposure to DDT: effect on the human liver. Arch Environ Health 27:318–321.4743408
Leavens TL, Sparrow BR, Devito MJ. 2002. Lack of antiandrogenic effects in adult male rats following acute exposure to 2,2-bis(4-chlorophenyl)-1,1-dichloroethylene (p,p’-DDE). Toxicology 174(2):69–78. 10.1016/s0300-483x(02)00072-0.11985884
LeBlanc GA. 1995. Trophic-level differences in the bioconcentration of chemicals: implications in assessing environmental biomagnification. Environ Sci Technol 29(1):154–160. 10.1021/es00001a020.22200214
Ledoux TA, Lodge JR, Touchberry RW, 1977. The effects of low dietary levels of DDT on breeding performance in hybrid mice. Arch Environ Contam Toxicol 6(4):435–446. 10.1007/BF02097783.318535
Lee DH, Jacobs DR, Porta M. 2007a. Association of serum concentrations of persistent organic pollutants with the prevalence of learning disability and attention deficit disorder. J Epidemiol Community Health 61(7):591–596. 10.1136/jech.2006.054700.17568050
Lee DH, Lee IK, Song K, 2006. A strong dose-response relation between serum concentrations of persistent organic pollutants and diabetes: results from the National Health and Examination Survey 1999–2002. Diabetes Care 29(7):1638–1644. 10.2337/dc06-0543.16801591
Lee DH, Lee IK, Porta M, 2007b. Relationship between serum concentrations of persistent organic pollutants and the prevalence of metabolic syndrome among non-diabetic adults: Results from the National Health and Nutrition Examination Survey 1999–2002. Diabetologia 50(9):1841–1851. 10.1007/s00125-007-0755-4.17624515
Lee DH, Steffes MW, Sjodin A, 2010. Low dose of some persistent organic pollutants predicts type 2 diabetes: a nested case-control study. Environ Health Perspect 118(9):1235–1242. 10.1289/ehp.0901480.20444671
Lee DH, Lind PM, Jacobs DR, 2011a. Polychlorinated biphenyls and organochlorine pesticides in plasma predict development of Type 2 Diabetes in the elderly. The prospective investigation of the vasculature in Uppsala seniors (PIVUS) study. Diabetes Care 34(8):1778–1784.21700918
Lee DH, Steffes MW, Sjodin A, 2011b. Low dose organochlorine pesticides and polychlorinated biphenyls predict obesity, dyslipidemia, and insulin resistance among people free of diabetes. PLoS ONE 6(1):e15977. 10.1371/journal.pone.0015977.21298090
Lee DH, Lind L, Jacobs DR, 2012a. Associations of persistent organic pollutants with abdominal obesity in the elderly: The Prospective Investigation of the Vasculature in Uppsala Seniors (PIVUS) study. Environ Int 40:170–178. 10.1016/j.envint.2011.07.010.21835469
Lee DH, Lind PM, Jacobs DR, 2012b. Background exposure to persistent organic pollutants predicts stroke in the elderly. Environ Int 47:115–120. 10.1016/j.envint.2012.06.009.22809777
Lee DH, Porta M, Jacobs DR, 2014. Chlorinated persistent organic pollutants, obesity, and type 2 diabetes. Endocr Rev 35(4):557–601. 10.1210/er.2013-1084.24483949
Lee DH, Lind PM, Jacobs DR, 2016a. Association between background exposure to organochlorine pesticides and the risk of cognitive impairment: A prospective study that accounts for weight change. Environ Int 89–90:179–184. 10.1016/j.envint.2016.02.001.
Lee DH, Lind PM, Jacobs DR, 2016b. Supplemental material: Association between background exposure to organochlorine pesticides and the risk of cognitive impairment: A prospective study that accounts for weight change. Environ Int 10.1016/j.envint.2016.02.001.
Lee H, Park S, Hong Y, 2016c. The effect of exposure to persistent organic pollutants on metabolic health among KOREAN children during a 1-year follow-up. Int J Environ Res Public Health 13(3):270. 10.3390/ijerph13030270.26938545
Legator MS, Palmer KA, Adler ID. 1973. A collaborative study of in vivo cytogenetic analysis. I. Interpretation of slide preparations. Toxicol Appl Pharmacol 24(3):337–350. 10.1016/0041-008x(73)90040-9.4704808
Legler J, Fletcher T, Govarts E, 2015. Obesity, diabetes, and associated costs of exposure to endocrine-disrupting chemicals in the European Union. J Clin Endocrinol Metab 100(4):1278–1288. 10.1210/jc.2014-4326.25742518
Lehman A. 1965. DDT (a mixture of 1,1,1-trichloro-2,2-bis(p-chlorophenyl) ethane and 1,1,1-trichloro-2-(o-chlorophenyl)-2-(p-chlorophenyl) ethane). In: Summaries of pesticide toxicity. Topeka, KS: Association of Food and Drug Officials of the United States, 16–18.
Lenters V, Portengen L, Rignell-Hydbom A, 2016. Prenatal phthalate, perfluoroalkyl acid, and organochlorine exposures and term birth weight in three birth cohorts: Multi-pollutant models based on elastic net regression. Environ Health Perspect 124(3):365–372. 10.1289/ehp.1408933.26115335
Lenters V, Iszatt N, Forns J, 2019a. Early-life exposure to persistent organic pollutants (OCPs, PBDEs, PCBs, PFASs) and attention-deficit/hyperactivity disorder: A multi-pollutant analysis of a Norwegian birth cohort. Environ Int 125:33–42. 10.1016/j.envint.2019.01.020.30703609
Lenters V, Iszatt N, Forns J, 2019b. Supplemental material: Early-life exposure to persistent organic pollutants (OCPs, PBDEs, PCBs, PFASs) and attention-deficit/hyperactivity disorder: A multi-pollutant analysis of a Norwegian birth cohort. Environ Int 125 10.1016/j.envint.2019.01.020.
Lerro CC, Jones RR, Langseth H, 2018. A nested case-control study of polychlorinated biphenyls, organochlorine pesticides, and thyroid cancer in the Janus Serum Bank cohort. Environ Res 165:125–132. 10.1016/j.envres.2018.04.012.29698872
Letcher RJ, Norstrom RJ, Bergman A. 1995. Geographical distribution and identification of methylsulphone PCB and DDE metabolites in pooled polar bear (Ursus maritimus) adipose tissue from western hemisphere Arctic and Subarctic regions. Sci Total Environ 160/161:409–420.7892578
Letcher RJ, Norstrom RJ, Muir DC G. 1998. Biotransformation versus bioaccumulation: Sources of methyl sulfone PCB and 4,4’-DDE metabolites in the polar bear food chain. Environ Sci Technol 32:1656–1661.
Lewis RG, Fortmann RC, Camann DE. 1994. Evaluation of methods for monitoring the potential exposure of small children to pesticides in the residential environment. Arch Environ Contam Toxicol 26(1):37–46. 10.1007/BF00212792.8110022
Lewis-Mikhael AM, Olmedo-Requena R, Martinez-Ruiz V, 2015. Organochlorine pesticides and prostate cancer, Is there an association? A meta-analysis of epidemiological evidence. Cancer Causes Control 26(10):1375–1392. 10.1007/s10552-015-0643-z.26245248
Li C, Cheng Y, Tang Q, 2014. The association between prenatal exposure to organochlorine pesticides and thyroid hormone levels in newborns in Yancheng, China. Environ Res 129:47–51. 10.1016/j.envres.2013.12.009.24529002
Li G, Kim C, Kim J, 2015. Common pesticide, dichlorodiphenyltrichloroethane (DDT), increases amyloid-β levels by impairing the function of ABCA1 and IDE: Implication for Alzheimer’s Disease. J Alzheimers Dis 46(1):109–122. 10.3233/JAD-150024.25720399
Liang Y, Liu D, Zhan J, 2020. New insight into the mechanism of POP-induced obesity: Evidence from DDE-altered microbiota. Chemosphere 244:125123. 10.1016/j.chemosphere.2019.125123.32050320
Lichtenberg J, Eichelberger J, Dreeman R, 1970. Pesticides in surface water of the United States: A 5-year summary, 1964–1968. Pestic Monit J 4(2):71–86.4106141
Lichtenstein E, Schulz K. 1959. Persistence of some chlorinated hydrocarbon insecticides as influenced by soil types, rate of application and temperature. J Econ Entomol 52(1):124–131.
Lieberg-Clark P, Bacon C, Burns S, 1995. DDT in California sea-lions: A follow-up study after twenty years. Mar Pollut Bull 30(11):744–745.
Ligocki M, Leuenberger C, Pankow J. 1985. Trace organic compounds in rain. II. Gas scavenging of neutral organic compounds. Atmos Environ 19(10):1609–1617.
Liljegren G, Hardell L, Lindstrom G, 1998. Case-control study on breast cancer and adipose tissue concentrations of congener specific polychlorinated biphenyls, DDE and hexachlorobenzene. Eur J Cancer Prev 7(2):135–140.9818775
Lim JS, Son HK, Park SK, 2011. Inverse associations between long-term weight change and serum concentrations of persistent organic pollutants. Int J Obes (Lond) 35(5):744–747. 10.1038/ijo.2010.188.20820170
Lim JE, Park SH, Jee SH, 2015. Body concentrations of persistent organic pollutants and prostate cancer: a meta-analysis. Environ Sci Pollut Res Int 22(15):11275–11284. 10.1007/s11356-015-4315-z.25797015
Lind PM, Penell J, Salihovic S, 2014. Circulating levels of p,p’-DDE are related to prevalent hypertension in the elderly. Environ Res 129:27–31. 10.1016/j.envres.2013.12.003.24528999
Lind PM, Salihovic S, Lind L. 2018. High plasma organochlorine pesticide levels are related to increased biological age as calculated by DNA methylation analysis. Environ Int 113:109–113. 10.1016/j.envint.2018.01.019.29421399
Lind PM, Salihovic S, Stubleski J, 2019. Association of exposure to persistent organic pollutants with mortality risk: An analysis of data from the Prospective Investigation of Vasculature in Uppsala Seniors (PIVUS) Study. JAMA Netw Open 2(4):e193070. 10.1001/jamanetworkopen.2019.3070.31026035
Lindenau A, Fischer B, Seiler P, 1994. Effects of persistent chlorinated hydrocarbons on reproductive tissues in female rabbits. Hum Reprod 9(5):772–780. 10.1093/oxfordjournals.humrep.a138595.7523436
Linder RE, Strader LF, Slott VL, 1992. Endpoints of spermatotoxicity in the rat after short duration exposures to fourteen reproductive toxicants. Reprod Toxicol 6(6):491–505. 10.1016/0890-6238(92)90034-q.1288759
Lindstrom G, Hardell L, van Bavel B, 2004. Adipose tissue concentrations of PCB, HCB, chlordane, PBDE, and p,p’-DDE and the risk for endometrial cancer. Organohalogen Compounds 66:3182–3187.
Liu C, Ha M, Li L, 2014. PCB153 and p,p’-DDE disorder thyroid hormones via thyroglobulin, deiodinase 2, transthyretin, hepatic enzymes and receptors. Environ Sci Pollut Res Int 21(19):11361–11369. 10.1007/s11356-014-3093-3.24878560
Liu Q, Wang Q, Xu C, 2017a. Organochloride pesticides impaired mitochondrial function in hepatocytes and aggravated disorders of fatty acid metabolism. Sci Rep 7:46339. 10.1038/srep46339.28397872
Liu Q, Wang Q, Xu C, 2017b. Supplemental materials for Organochloride pesticides impaired mitochondrial function in hepatocytes and aggravated disorders of fatty acid metabolism [Scientific Reports 7:46339. 10.1038/srep46339]. Scientific Reports September 19, 2017.
Loeffler IK, Peterson RE. 1999. Interactive effects of TCDD and p,p’-DDE on male reproductive tract development in in utero and lactationally exposed rats. Toxicol Appl Pharmacol 154(1):28–39. 10.1006/taap.1998.8572.9882589
Long ER, MacDonald DD, Smith SL, 1995. Incidence of adverse biological effects within ranges of chemical concentrations in marine and estuarine sediments. Environ Manage 19:81–97.
Longnecker MP, Klebanoff MA, Zhou H, 2001. Association between maternal serum concentration of the DDT metabolite DDE and preterm and small-for-gestational-age babies at birth. Lancet 358:110–114.11463412
Longnecker MP, Klebanoff MA, Brock JW, 2002. Maternal serum level of 1,1-dichloro-2,2-bis(p-chlorophenyl)ethylene and risk of cryptorchidism, hypospadias, and polythelia among male offspring. Am J Epidemiol 155(4):313–322. 10.1093/aje/155.4.313.11836195
Longnecker MP, Klebanoff MA, Dunson DB, 2005. Maternal serum level of the DDT metabolite DDE in relation to fetal loss in previous pregnancies. Environ Res 97(2):127–133. 10.1016/s0013-9351(03)00108-7.15533328
Longnecker MP, Gladen BC, Cupul-Uicab LA, 2007. In utero exposure to the antiandrogen 1,1-dichloro-2,2-bis(p-chlorophenyl)ethylene (DDE) in relation to anogenital distance in male newborns from Chiapas, Mexico. Am J Epidemiol 165(9):1015–1022. 10.1093/aje/kwk109.17272288
Looser R, Froescheis O, Cailliet GM, 2000. The deep-sea as a final global sink of semivolatile persistent organic pollutants? Part II: Organochlorine pesticides in surface and deep-sea dwelling fish of the north and south Atlantic and the Monterey Bay Canyon (California). Chemosphere 40(6):661–670. 10.1016/s0045-6535(99)00462-2.10705542
Lopez-Carrillo L, Blair A, Lopez-Cervantes M, 1997. Dichlorodiphenyltrichloroethane serum levels and breast cancer risk: a case-control study from Mexico. Cancer Res 57(17):3728–3732.9288780
Lopez-Cervantes M, Torres-Sanchez L, Tobias A, 2004. Dichlorodiphenyldichloroethane burden and breast cancer risk: a meta-analysis of the epidemiologic evidence. Environ Health Perspect 112(2):207–214. 10.1289/ehp.112-1241830.14754575
Lopez-Espinosa MJ, Granada A, Carreno J, 2007. Organochlorine pesticides in placentas from Southern Spain and some related factors. Placenta 28(7):631–638. 10.1016/j.placenta.2006.09.009.17109956
Lopez-Espinosa MJ, Vizcaino E, Murcia M, 2009. Association between thyroid hormone levels and 4,4’-DDE concentrations in pregnant women (Valencia, Spain). Environ Res 109(4):479–485. 10.1016/j.envres.2009.02.003.19286173
Lopez-Espinosa MJ, Vizcaino E, Murcia M, 2010. Prenatal exposure to organochlorine compounds and neonatal thyroid stimulating hormone levels. J Expo Sci Environ Epidemiol 20(7):579–588. 10.1038/jes.2009.47.19707252
Lopez-Espinosa MJ, Murcia M, Iniguez C, 2011. Prenatal exposure to organochlorine compounds and birth size. Pediatrics 128(1):e127–134. 10.1542/peds.2010-1951.21669889
Lorber M, Phillips L. 2002. Infant exposure to dioxin-like compounds in breast milk. Environ Health Perspect 110(6):A325–332. 10.1289/ehp.021100325.12055063
Lorber M, Toms LL. 2017. Use of a simple pharmacokinetic model to study the impact of breast-feeding on infant and toddler body burdens of PCB 153, BDE 47, and DDE. Chemosphere 185:1081–1089. 10.1016/j.chemosphere.2017.07.118.28764132
Lordo RA, Dinh KT, Schwemberger JG. 1996. Semivolatile organic compounds in adipose tissue: estimated averages for the US population and selected subpopulations. Am J Public Health 86(9):1253–1259. 10.2105/ajph.86.9.1253.8806377
Loreto-Gomez C, Farias P, Moreno-Macias H, 2018. Prenatal exposure to persistent organic compounds and their association with anogenital distance in infants. Reprod Biomed Online 37(6):732–740. 10.1016/j.rbmo.2018.09.008.30539738
Lu FC, Jessup DC, Lavallee A. 1965. Toxicity of pesticides in young versus adult rats. Food Cosmet Toxicol 3(4):591–596. 10.1016/s0015-6264(65)80206-1.5867575
Lundberg C. 1973. Effects of long-term exposure to DDT on the oestrus cycle and the frequency of implanted ova in the mouse. Environ Physiol Biochem 3:127–131.
Lundberg T. 1974. Effect of DDT on cytochrome p-450 and oestrogen-dependent functions in mice. Environ Physiol Biochem 4(5):200–204.4461272
Luo D, Zhou T, Tao Y, 2016. Exposure to organochlorine pesticides and non-Hodgkin lymphoma: a meta-analysis of observational studies. Sci Rep 6:25768. 10.1038/srep25768.27185567
Lyall K, Croen LA, Sjodin A, 2017. Polychlorinated biphenyl and organochlorine pesticide concentrations in maternal mid-pregnancy serum samples: Association with autism spectrum disorder and intellectual disability. Environ Health Perspect 125(3):474–480. 10.1289/EHP277.27548254
MacBean. 2011. DDD, DDE, DDT. The e-pesticide manual. Version 5.1. Surrey, UK: British Crop Protection Council. January 19, 2018.
MacIntosh DL, Hammerstrom K, Ryan PB. 1999. Longitudinal exposure to selected pesticides in drinking water. Hum Ecol Risk Assess 5(3):575–588.
Maervoet J, Vermeir G, Covaci A, 2007. Association of thyroid hormone concentrations with levels of organochlorine compounds in cord blood of neonates. Environ Health Perspect 115(12):1780–1786. 10.1289/ehp.10486.18087600
Mahr U, Miltenburger HG. 1976. The effect of insecticides on Chinese hamster cell structure. Mutat Res 40:107–118.934173
Makita Y. 2005. Effects of perinatal combined exposure to 1,4-dichlorobenzene and 1,1-dichloro-2, 2-bis (p-chlorophenyl) ethylene on rat male offspring. Basic Clin Pharmacol Toxicol 96(5):361–365. 10.1111/j.1742-7843.2005.pto_04.x.15853928
Makita Y. 2008a. Effects of perinatal, combined exposure to 1,4-dichlorobenzene and 1,1-dichloro-2,2-bis(p-chlorophenyl)ethylene on rat female reproductive system. Basic & clinical pharmacology & toxicology 102(4):360–364. 10.1111/j.1742-7843.2007.00179.x.18341512
Makita Y. 2008b. Effects of perinatal combined exposure to 1,1-dichloro-2,2-bis(p-chlorophenyl)ethylene (p,p’-DDE) and tributyltin (TBT) on rat female reproductive system. Environ Toxicol Pharmacol 25(3):380–385. 10.1016/j.etap.2007.12.003.21783877
Makita Y, Matsuura T, Ogata R, 2003a. Systemic effects of orally administered p, p’-DDE on immature male Wistar rats during pubertal period. J Occup Health 45(4):223–227. 10.1539/joh.45.223.14646280
Makita Y, Tanaka A, Omura M, 2003b. Effects of simultaneous administration of tributyltin (TBT) and p,p(’)-DDE on female offspring of Wistar rats. J Toxicol Environ Health A 66(24):2337–2347. 10.1080/716100642.14630525
Maness SC, McDonnell DP, Gaido KW. 1998. Inhibition of androgen receptor-dependent transcriptional activity by DDT isomers and methoxychlor in HepG2 human hepatoma cells. Toxicol Appl Pharmacol 151(1):135–142. 10.1006/taap.1998.8431.9705896
Mangum LH, Howell GE, Chambers JE. 2015. Exposure to p,p’-DDE enhances differentiation of 3T3-L1 preadipocytes in a model of sub-optimal differentiation. Toxicol Lett 238(2):65–71. 10.1016/j.toxlet.2015.07.009.26200599
Mangum LH, Crow JA, Stokes JV, 2016. Exposure to p,p’-DDE alters macrophage reactivity and increases macrophage numbers in adipose stromal vascular fraction. Toxicol Sci 150(1):169–177. 10.1093/toxsci/kfv315.26748080
Marien K, Laflamme DM. 1995. Determination of a tolerable daily intake of DDT for consumers of DDT contaminated fish from the lower Yakima River, Washington. Risk Anal 15(6):709–717. 10.1111/j.1539-6924.1995.tb01343.x.8559982
Marouani N, Hallegue D, Sakly M, 2017. p,p’-DDT induces testicular oxidative stress-induced apoptosis in adult rats. Reprod Biol Endocrinol 15(1):40. 10.1186/s12958-017-0259-0.28549437
Martin SA Jr., Harlow SD, Sowers MF, 2002. DDT metabolite and androgens in African-American farmers. Epidemiology 13(4):454–458. 10.1097/00001648-200207000-00014.12094101
Maslansky CJ, Williams GM. 1981. Evidence for an epigenetic mode of action in organochlorine pesticide hepatocarcinogenicity: a lack of genotoxicity in rat, mouse, and hamster hepatocytes. J Toxicol Environ Health 8(1–2):121–130. 10.1080/15287398109530056.7328699
Masters PM, Inman DL. 2000. Transport and fate of organochlorines discharged to the salt marsh at upper Newport Bay, California, USA. Environ Toxicol Chem 19:2076–2084.
Matin MA, Jaffery FN, Siddiqui RA. 1981. A possible neurochemical basis of the central stimulatory effects of p,p’-DDT. J Neurochem 36(3):1000–1005.7205252
McAuliffe ME, Williams PL, Korrick SA, 2012. Environmental exposure to polychlorinated biphenyls and p,p’-DDE and sperm sex-chromosome disomy. Environ Health Perspect 120(4):535–540. 10.1289/ehp.1104017.22189045
McCann J, Choi E, Yamasaki E, 1975. Detection of carcinogens as mutagens in the Salmonella/microsome test: assay of 300 chemicals. Proc Natl Acad Sci U S A 72(12):5135–5139.1061098
McConnell L, Bidleman T, Cotham W, 1998. Air concentrations of organochlorine insecticides and polychlorinated biphenyls over Green Bay, WI, and the four lower Great Lakes. Environ Pollut 101:391–399.
McGlynn KA, Abnet CC, Zhang M, 2006. Serum concentrations of 1,1,1-trichloro-2,2-bis(p-chlorophenyl)ethane (DDT) and 1,1-dichloro-2,2-bis(p-chlorophenyl)ethylene (DDE) and risk of primary liver cancer. J Natl Cancer Inst 98(14):1005–1010. 10.1093/jnci/djj266.16849683
McGlynn KA, Quraishi SM, Graubard BI, 2008. Persistent organochlorine pesticides and risk of testicular germ cell tumors. J Natl Cancer Inst 100(9):663–671. 10.1093/jnci/djn101.18445826
Medehouenou TC, Ayotte P, Carmichael PH, 2014. Plasma polychlorinated biphenyl and organochlorine pesticide concentrations in dementia: the Canadian Study of Health and Aging. Environ Int 69:141–147. 10.1016/j.envint.2014.04.016.24846810
Meek EC, Jones DD, Crow JA, 2019. Association of serum levels of p,p’-Dichlorodiphenyldichloroethylene (DDE) with type 2 diabetes in African American and Caucasian adult men from agricultural (Delta) and non-agricultural (non-Delta) regions of Mississippi. J Toxicol Environ Health A 82(6):387–400. 10.1080/15287394.2019.1610678.31064277
Meeker JD, Altshul L, Hauser R. 2007. Serum PCBs, p,p’-DDE and HCB predict thyroid hormone levels in men. Environ Res 104(2):296–304. 10.1016/j.envres.2006.11.007.17189629
Meister R, Sine C. 1999. DDT. In: Farm chemical handbook ’99. Willoughby, OH: Meister Publishing Company, C123–C124.
Mendez MA, Garcia-Esteban R, Guxens M, 2011. Prenatal organochlorine compound exposure, rapid weight gain, and overweight in infancy. Environ Health Perspect 119(2):272–278. 10.1289/ehp.1002169.20923745
Mendonca GA, Eluf-Neto J, Andrada-Serpa MJ, 1999. Organochlorines and breast cancer: a case-control study in Brazil. Int J Cancer 83(5):596–600. 10.1002/(sici)1097-0215(19991126)83:5<596::aid-ijc4>3.0.co;2-p.10521792
Meng G, Feng Y, Nie Z, 2016. Internal exposure levels of typical POPs and their associations with childhood asthma in Shanghai, China. Environ Res 146:125–135. 10.1016/j.envres.2015.12.026.26748225
Menzie CM. 1980. Reaction types in the environment. In: Baughman GL, Burns LA, Cohen AS, , eds. Reactions and processes. Berlin, Germany: Springer-Verlag, 247–302.
Menzie CA, Burmaster DE, Freshman JS, 1992. Assessment of methods for estimating ecological risk in the terrestrial component: A case study at the Baird & McGuire Superfund site in Holbrook, Massachusetts. Environ Toxicol Chem 11:245–260.
Mes J, Malcolm S. 1992. Comparison of chlorinated hydrocarbon residues in human populations from the Great Lakes and other regions of Canada. Chemosphere 25(3):417–424.
Mes J, Davies DJ, Turton D, 1986. Levels and trends of chlorinated hydrocarbon contaminants in the breast milk of Canadian women. Food Addit Contam 3(4):313–322. 10.1080/02652038609373598.3803638
Mes J, Marchand L, Davies DJ. 1990. Specific polychlorinated biphenyl congener distribution in adipose tissue of Canadians. Environ Technol 11:747–756.
Messaros BM, Rossano MG, Liu G, 2009. Negative effects of serum p,p’-DDE on sperm parameters and modification by genetic polymorphisms. Environ Res 109(4):457–464. 10.1016/j.envres.2009.02.009.19303595
Metcalf PJ. 1989. Organolead compounds in the atmosphere. Analytical Procedures 26:134–136.
Metcalf RL. 1995. Insect control technology. In: Kroschwitz J, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. New York, NY: John Wiley & Sons, Inc., 524–602.
Metcalf RL, Booth GM, Schuth CK, 1973. Uptake and fate of di-2-ethylhexyl phthalate in aquatic organisms and in a model ecosystem. Environ Health Perspect 4:27–34. 10.1289/ehp.730427.4721303
Meylan WM, Howard PH. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26(2):2293–2299.
Meylan W, Howard PH, Boethling RS. 1992. Molecular topology/fragment contribution method for predicting soil sorption coefficients. Environ Sci Technol 26(8):1560–1567.
Miller M. 1994. Organochlorine concentration dynamics in Lake Michigan chinook salmon (Oncorlhlynchus tshawytscha). Arch Environ Contam Toxicol 27:367–374.
Miller GC, Zepp RG. 1979. Photoreactivity of aquatic pollutants sorbed on suspended sediments. Environ Sci Technol 13(7):860–863. 10.1021/es60155a019.
Millet M, Wortham H, Sanusi A, 1997. Atmospheric contamination by pesticides: Determination in the liquid, gaseous and particulate phases. Environ Sci Pollut Res Int 4(3):172–180. 10.1007/BF02986327.19002404
Mills KT, Blair A, Freeman LE, 2009. Pesticides and myocardial infarction incidence and mortality among male pesticide applicators in the Agricultural Health Study. Am J Epidemiol 170(7):892–900. 10.1093/aje/kwp214.19700503
Min JY, Cho JS, Lee KJ, 2011. Potential role for organochlorine pesticides in the prevalence of peripheral arterial diseases in obese persons: results from the National Health and Nutrition Examination Survey 1999–2004. Atherosclerosis 218(1):200–206. 10.1016/j.atherosclerosis.2011.04.044.21620405
Minelli EV, Ribeiro ML. 1996. DDT and HCH residues in the blood serum of malaria control sprayers. Bull Environ Contam Toxicol 57(5):691–696. 10.1007/s001289900245.8791542
Minyard JP, Roberts WE. 1991. Chemical contaminants monitoring: State findings on pesticide residues in foods--1988 and 1989. J Assoc Off Anal Chem 74(3):438–452.1874687
Miyake Y, Tanaka K, Masuzaki Y, 2011. Organochlorine concentrations in breast milk and prevalence of allergic disorders in Japanese women. Chemosphere 85(3):374–378. 10.1016/j.chemosphere.2011.07.001.21802112
Monosmith CL, Hermanson MH. 1996. Spatial and temporal trends of atmospheric organochlorine vapors in the central and upper Great Lakes. Environ Sci Technol 30:3464–3472.
Moody RP, Chu I. 1995. Dermal exposure to environmental contaminants in the Great Lakes. Environ Health Perspect 103(Suppl. 9):103–114.
Moreno-Aliaga MJ, Matsumura F. 2002. Effects of 1,1,1-trichloro-2,2-bis(p-chlorophenyl)-ethane (p,p’-DDT) on 3T3-L1 and 3T3-F442A adipocyte differentiation. Biochem Pharmacol 63(5):997–1007. 10.1016/s0006-2952(01)00933-9.11911853
Morgan DP, Roan CC. 1971. Absorption, storage, and metabolic conversion of ingested DDT and DDT metabolites in man. Arch Environ Health 22(3):301–308. 10.1080/00039896.1971.10665848.5541487
Morgan D, Roan C. 1974. The metabolism of DDT in man. In: Hayes W, ed. Essays in toxicology. New York, NY: Academic Press, 39–97.
Morgan DP, Lin LI. 1978. Blood organochlorine pesticide concentrations, clinical hematology and biochemistry in workers occupationally exposed to pesticides. Arch Environ Contam Toxicol 7(4):423–447. 10.1007/BF02332069.755444
Mota PC, Cordeiro M, Pereira SP, 2011. Differential effects of p,p’-DDE on testis and liver mitochondria: implications for reproductive toxicology. Reprod Toxicol 31(1):80–85. 10.1016/j.reprotox.2010.09.010.20951795
Moysich KB, Ambrosone CB, Vena JE, 1998. Environmental organochlorine exposure and postmenopausal breast cancer risk. Cancer Epidemiol Biomarkers Prev 7(3):181–188.9521429
Mrema EJ, Rubino FM, Brambilla G, 2013. Persistent organochlorinated pesticides and mechanisms of their toxicity. Toxicology 307:74–88. 10.1016/j.tox.2012.11.015.23219589
Muhlebach S, Moor MJ, Wyss PA, 1991. Kinetics of distribution and elimination of DDE in rats. Xenobiotica 21(1):111–120. 10.3109/00498259109039455.2003362
Muir DC, Norstrom RJ, Simon M. 1988. Organochlorine contaminants in arctic marine food chains: accumulation of specific polychlorinated biphenyls and chlordane-related compounds. Environ Sci Technol 22(9):1071–1079. 10.1021/es00174a012.22148662
Muir D, Grift N, Lockhart W, 1995. Special trends and historical profiles of organochlorine pesticides in Arctic lake sediments. Sci Total Environ 160:447–457.
Mulhens K. 1946. [The importance of bis(chlorophenyl)(trischloromethyl)-methane preparations as insecticides in combating infectious diseases]. Dtsch Med Wochenschr 71:164–169. (German)
Muller MH B, Polder A, Brynildsrud OB, 2017. Organochlorine pesticides (OCPs) and polychlorinated biphenyls (PCBs) in human breast milk and associated health risks to nursing infants in Northern Tanzania. Environ Res 154:425–434. 10.1016/j.envres.2017.01.031.28196346
Muller MH B, Polder A, Brynildsrud OB, 2019. Prenatal exposure to persistent organic pollutants in Northern Tanzania and their distribution between breast milk, maternal blood, placenta and cord blood. Environ Res 170:433–442. 10.1016/j.envres.2018.12.026.30634139
Murphy R, Harvey C. 1985. Residues and metabolites of selected persistent halogenated hydrocarbons in blood specimens from a general population survey. Environ Health Perspect 60:115–120. 10.1289/ehp.8560115.2411534
Mussalo-Rauhamaa H. 1991. Partitioning and levels of neutral organochlorine compounds in human serum, blood cells, and adipose and liver tissue. Sci Total Environ 103(2–3):159–175. 10.1016/0048-9697(91)90142-2.1909054
Nagayama J, Nagayama M, Nakagawa R, 2003. Frequency of SCEs in Japanese infants lactationally exposed to organochlorone pesticides. Fukuoka Igaku Zasshi 94(5):166–173.12872718
Nakagawa H, Hikiba Y, Hirata Y, 2014. Loss of liver E-cadherin induces sclerosing cholangitis and promotes carcinogenesis. Proc Natl Acad Sci U S A 111(3):1090–1095. 10.1073/pnas.1322731111.24395807
Nanes JA, Xia Y, Dassanayake RM, 2014. Selected persistent organic pollutants in human placental tissue from the United States. Chemosphere 106:20–27. 10.1016/j.chemosphere.2013.12.080.24485817
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press. 15–35.
Nash RG, Beall ML. 1970. Chlorinated hydrocarbon insecticides: Root uptake verses vapor contamination of soybean foliage. Science 168:1109–1111.5462437
NCI. 1978. Bioassays of DDT, TDE, and p,p’-DDE for possible Carcinogenicity. Natl Cancer Inst Carcinog Tech Rep Ser 131:1–251.12799661
Neal PA, von Oettingen WF, Smith WW, 1944. Toxicity and potential dangers of aerosols, mists, and dusting powders containing DDT. Public Health Rep (Suppl 177):1–32.19315955
Needham LL, Grandjean P, Heinzow B, 2011. Partition of environmental chemicals between maternal and fetal blood and tissues. Environ Sci Technol 45(3):1121–1126. 10.1021/es1019614.21166449
Neidert E, Saschenbrecker PW. 1996. Occurrence of pesticide residues in selected agricultural food commodities available in Canada. J AOAC Int 79(2):549–566.8920145
Nims RW, Lubet RA, Fox SD, 1998. Comparative pharmacodynamics of CYP2B induction by DDT, DDE, and DDD in male rat liver and cultured rat hepatocytes. J Toxicol Environ Health A 53(6):455–477. 10.1080/009841098159187.9537282
NIOSH. 2014. DDT. Immediately Dangerous to Life or Health Concentrations (IDLH). Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/idlh/50293.html. April 26, 2017.
NIOSH. 2016. DDT. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/npg/npgd0174.html. April 26, 2017.
Nishizumi M. 1979. Effect of phenobarbital, dichlorodiphenyltrichloroethane, and polychlorinated biphenyls on diethylnitrosamine-induced hepatocarcinogenesis. Gann 70(6):835–837.119661
NOAA. 1988. PCB and chlorinated pesticide contamination in U.S. fish and shellfish: A historical assessment report. Rockville, MD: National Oceanic and Atmospheric Administration. PB91172742.
Noguchi T, Charman WN A, Stella VJ. 1985. Lymphatic appearance of DDT in thoracic or mesenteric lymph duct cannulated rats. Int J Pharm 24:185–192.
Norén K. 1988. Changes in the levels of organochlorine pesticides, polychlorinated biphenyls, dibenzo-p-dioxins and dibenzofurans in human milk from Stockholm, 1972–1985. Chemosphere 17(1):39–49.
Norén K. 1993. Contemporary and retrospective investigations of human milk in the trend studies of organochlorine contaminants in Sweden. Sci Total Environ 139-140:347–355. 10.1016/0048-9697(93)90032-2.
Norén K, Meironyte D. 2000. Certain organochlorine and organobromine contaminants in Swedish human milk in perspective of past 20–30 years. Chemosphere 40(9–11):1111–1123. 10.1016/s0045-6535(99)00360-4.10739053
Norén K, Lunden A, Pettersson E, 1996. Methylsulfonyl metabolites of PCBs and DDE in human milk in Sweden, 1972–1992. Environ Health Perspect 104(7):766–772. 10.1289/ehp.104-1469405.8841763
Norén K, Weistrand C, Karpe F. 1999. Distribution of PCB congeners, DDE, hexachlorobenzene, and methylsulfonyl metabolites of PCB and DDE among various fractions of human blood plasma. Arch Environ Contam Toxicol 37:408–414.10473799
Norstrom RJ, Belikov SE, Born EW, 1998. Chlorinated hydrocarbon contaminants in polar bears from eastern Russia, North America, Greenland, and Svalbard: biomonitoring of Arctic pollution. Arch Environ Contam Toxicol 35(2):354–367. 10.1007/s002449900387.9680529
NTP. 2016. Dichlorodiphenyltrichloroethane. In: Report on carcinogens. 14th ed. National Toxicology Program, https://ntp.niehs.nih.gov/ntp/roc/content/profiles/dichlorodiphenyltrichloroethane.pdf. April 26, 2017.
Numoto S, Tanaka T, Williams GM. 1985. Morphologic and cytochemical properties of mouse liver neoplasm induced by diethylnitrosamine and promoted by 4,4’-dichlorodiphenyltrichloroethane, chlordane, or heptachlor. Toxicol Pathol 13:325–334.2422723
Odsjo T, Bignert A, Olsson M, 1997. The Swedish Environmental Specimen Bank- application in trend monitoring of mercury and some organohalogenated compounds. Chemosphere 34(9/10):2059–2066.9159905
Okey AB, Page DJ. 1974. Acute toxicity of o,p’-DDT to mice. Bull Environ Contam Toxicol 11(4):359–363. 10.1007/BF01684943.4433822
Oliver BG, Niimi AJ. 1985. Bioconcentration factors of some halogenated organics for rainbow trout: Limitations in their use for prediction of environmental residues. Environ Sci Technol 19(9):842–849.22196610
Orberg J, Lundberg C. 1974. Some effect of DDT and PCB on the hormonal system in the male mouse. Environ Physiol Biochem 4:116–120.
Orenstein ST, Thurston SW, Bellinger DC, 2014. Prenatal organochlorine and methylmercury exposure and memory and learning in school-age children in communities near the New Bedford Harbor Superfund site, Massachusetts. Environ Health Perspect 122(11):1253–1259. 10.1289/ehp.1307804.
Ortega P. 1956. DDT in the diet of the rat. Public Health Monogr 43:1–27.13370776
Ortelee MF. 1958. Study of men with prolonged intensive occupational exposure to DDT. AMA Arch Ind Health 18(5):433–440.
OSHA. 2020a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1. September 28, 2020.
OSHA. 2020b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000. September 28, 2020.
OSHA. 2020c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55 Appendix A. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55AppA. September 28, 2020.
Osorio-Valencia E, Torres-Sanchez L, Lopez-Carrillo L, 2015. Prenatal p,p’-DDE exposure and establishment of lateralization and spatial orientation in Mexican preschooler. Neurotoxicology 47:1–7. 10.1016/j.neuro.2014.12.011.
Ostrea EM, Bielawski DM, Posecion NC, 2008. A comparison of infant hair, cord blood and meconium analysis to detect fetal exposure to environmental pesticides. Environ Res 106(2):277–283. 10.1016/j.envres.2007.08.014.
Ottar B. 1981. The transfer of airborne pollutants to the Arctic region. Atmos Environ 15(8):1439–1445.
Ottoboni A. 1969. Effect of DDT on reproduction in the rat. Toxicol Appl Pharmacol 14(1):74–81. 10.1016/0041-008x(69)90166-5.5775562
Ottoboni A. 1972. Effect of DDT on the reproductive life-span in the female rat. Toxicol Appl Pharmacol 22(3):497–502. 10.1016/0041-008x(72)90257-8.5041377
Ottoboni A, Bissell GD, Hexter AC. 1977. Effects of DDT on reproduction in multiple generations of beagle dogs. Arch Environ Contam Toxicol 6(1):83–101. 10.1007/BF02097752.
Ouidir M, Buck Louis GM, Kanner J, 2020a. Association of maternal exposure to persistent organic pollutants in early pregnancy with fetal growth. JAMA Pediatr 174(2):149–161. 10.1001/jamapediatrics.2019.5104.
Ouidir M, Buck Louis GM, Kanner J, 2020b. Supplemental content: Association of maternal exposure to persistent organic pollutants in early pregnancy with fetal growth. JAMA Pediatr 174(2) 10.1001/jamapediatrics.2019.5104.
Ouyang F, Perry MJ, Venners SA, 2005. Serum DDT, age at menarche, and abnormal menstrual cycle length. Occup Environ Med 62(12):878–884. 10.1136/oem.2005.020248.
Ouyang F, Longnecker MP, Venners SA, 2014. Preconception serum 1,1,1-trichloro-2,2,bis(p-chlorophenyl)ethane and B-vitamin status: independent and joint effects on women’s reproductive outcomes. Am J Clin Nutr 100(6):1470–1478. 10.3945/ajcn.114.088377.
Palanza P, Parmigiani S, vom Saal FS. 2001. Effects of prenatal exposure to low doses of diethylstilbestrol, o,p’DDT, and methoxychlor on postnatal growth and neurobehavioral development in male and female mice. Horm Behav 40(2):252–265. 10.1006/hbeh.2001.1697.
Palanza P, Parmigiani S, Liu H, 1999. Prenatal exposure to low doses of the estrogenic chemicals diethylstilbestrol and o,p’-DDT alters aggressive behavior of male and female house mice. Pharmacol Biochem Behav 64(4):665–672. 10.1016/s0091-3057(99)00151-3.10593188
Palin KJ, Wilson CG, Davis SS, 1982. The effect of oils on the lymphatic absorption of DDT. J Pharm Pharmacol 34(11):707–710. 10.1111/j.2042-7158.1982.tb06204.x.6129299
Palmer KA, Green S, Legator MS. 1972. Cytogenetic effects of DDT and derivatives of DDT in a cultured mammalian cell line. Toxicol Appl Pharmacol 22(3):355–364. 10.1016/0041-008x(72)90241-4.5064916
Palmer KA, Green S, Legator MS. 1973. Dominant lethal study of p,p’-DDT in rats. Food Cosmet Toxicol 11(1):53–62. 10.1016/0015-6264(73)90061-8.4716130
Pan IJ, Daniels JL, Goldman BD, 2009. Lactational exposure to polychlorinated biphenyls, dichlorodiphenyltrichloroethane, and dichlorodiphenyldichloroethylene and infant neurodevelopment: an analysis of the pregnancy, infection, and nutrition babies study. Environ Health Perspect 117(3):488–494. 10.1289/ehp.0800063.19337527
Pan IJ, Daniels JL, Herring AH, 2010. Lactational exposure to polychlorinated biphenyls, dichlorodiphenyltrichloroethane, and dichlorodiphenyldichloroethylene and infant growth: an analysis of the Pregnancy, Infection, and Nutrition Babies Study. Paediatr Perinat Epidemiol 24(3):262–271. 10.1111/j.1365-3016.2010.01114.x.20415756
Pant N, Kumar R, Mathur N, 2007. Chlorinated pesticide concentration in semen of fertile and infertile men and correlation with sperm quality. Environ Toxicol Pharmacol 23(2):135–139. 10.1016/j.etap.2006.07.012.21783749
Parada H Jr., Wolff MS, Engel LS, 2016. Organochlorine insecticides DDT and chlordane in relation to survival following breast cancer. Int J Cancer 138(3):565–575. 10.1002/ijc.29806.26285160
Parada H, Sun X, Tse CK, 2019. Plasma levels of dichlorodiphenyldichloroethene (DDE) and dichlorodiphenyltrichloroethane (DDT) and survival following breast cancer in the Carolina Breast Cancer Study. Environ Int 125:161–171. 10.1016/j.envint.2019.01.032.30716576
Parajuli RP, Goodrich JM, Chan LH M, 2018. Genetic polymorphisms are associated with exposure biomarkers for metals and persistent organic pollutants among Inuit from the Inuvialuit Settlement Region, Canada. Sci Total Environ 634:569–578. 10.1016/j.scitotenv.2018.03.331.29635199
Pardio VT, Waliszewski SM, Aguirre AA, 1998. DDT and its metabolites in human milk collected in Veracruz City and suburban areas (Mexico). Bull Environ Contam Toxicol 60(6):852–857. 10.1007/s001289900705.9606260
Park JH, Cha ES, Ko Y, 2014. Exposure to dichlorodiphenyltrichloroethane and the risk of breast cancer: A systematic review and meta-analysis. Osong Public Health Res Perspect 5(2):77–84. 10.1016/j.phrp.2014.02.001.24955316
Park SH, Lim JE, Park H, 2016. Body burden of persistent organic pollutants on hypertension: a meta-analysis. Environ Sci Pollut Res Int 23(14):14284–14293. 10.1007/s11356-016-6568-6.27055888
Pasha ST. 1981. Changes in hepatic microsomal enzymes due to DDT, DDE and DDD feeding in CF-1 mice. Indian Journal of Medical Research 74:926–930.
Patrick SM, Bornman MS, Joubert AM, 2016. Effects of environmental endocrine disruptors, including insecticides used for malaria vector control on reproductive parameters of male rats. Reprod Toxicol 61:19–27. 10.1016/j.reprotox.2016.02.015.26928317
Patterson DG, Wong LY, Turner WE, 2009. Levels in the U.S. population of those persistent organic pollutants (2003–2004) included in the Stockholm Convention or in other long range transboundary air pollution agreements. Environ Sci Technol 43(4):1211–1218. 10.1021/es801966w.19320182
PDR. 1999. Physicians desk reference. Montvale, NJ: Medical Economics Company. 631.
Pelletier C, Doucet E, Imbeault P, 2002. Associations between weight loss-induced changes in plasma organochlorine concentrations, serum T(3) concentration, and resting metabolic rate. Toxicol Sci 67(1):46–51. 10.1093/toxsci/67.1.46.11961215
Peraino C, Fry RJ, Staffeldt E, 1975. Comparative enhancing effects of phenobarbital, amobarbital, diphenylhydantoin, and dichlorodiphenyltrichloroethane on 2-acetylaminofluorene-induced hepatic tumorigenesis in the rat. Cancer Res 35(10):2884–2890.1157054
Pereira WE, Domagalski JL, Hostettler FD, 1996. Occurrence and accumulation of pesticides and organic contaminants in river sediment, water and clam tissues from the San Joaquin River and tributaries, California. Environ Toxicol Chem 15(2):172–180.
Perez-Maldonado IN, Diaz-Barriga F, de la Fuente H, 2004. DDT induces apoptosis in human mononuclear cells in vitro and is associated with increased apoptosis in exposed children. Environ Res 94(1):38–46.14643285
Perez-Maldonado IN, Herrera C, Batres LE, 2005. DDT-induced oxidative damage in human blood mononuclear cells. Environ Res 98(2):177–184. 10.1016/j.envres.2004.11.001.15820723
Perez-Maldonado IN, Athanasiadou M, Yanez L, 2006. DDE-induced apoptosis in children exposed to the DDT metabolite. Sci Total Environ 370(2–3):343–351. 10.1016/j.scitotenv.2006.06.026.16904735
Perez-Maldonado IN, Perez-Vazquez FJ, Gaspar-Ramirez O, 2011. Variability in DDT-induced apoptosis in Mexican indigenous populations. Toxicol Mech Methods 21(9):675–680. 10.3109/15376516.2011.601354.22003925
Perla ME, Rue T, Cheadle A, 2015. Biomarkers of insecticide exposure and asthma in children: A National Health and Nutrition Examination Survey (NHANES) 1999–2008 analysis. Arch Environ Occup Health 70(6):309–322. 10.1080/19338244.2014.910490.25147971
Perry MJ, Ouyang F, Korrick S, 2005. Body mass index and serum 1,1,1-trichloro-2,2-bis(p-chlorophenyl)ethane in nulliparous Chinese women. Cancer Epidemiol Biomarkers Prev 14(10):2433–2438. 10.1158/1055-9965.EPI-05-0174.16214928
Perry MJ, Ouyang F, Korrick SA, 2006. A prospective study of serum DDT and progesterone and estrogen levels across the menstrual cycle in nulliparous women of reproductive age. Am J Epidemiol 164(11):1056–1064. 10.1093/aje/kwj329.17023545
Perry MJ, Young HA, Grandjean P, 2016. Sperm aneuploidy in Faroese men with lifetime exposure to dichlorodiphenyldichloroethylene (p,p-DDE) and polychlorinated biphenyl (PCB) pollutants. Environ Health Perspect 124(7):951–956. 10.1289/ehp.1509779.26535963
Persson EC, Graubard BI, Evans AA, 2012. Dichlorodiphenyltrichloroethane and risk of hepatocellular carcinoma. Int J Cancer 131(9):2078–2084. 10.1002/ijc.27459.22290210
Peterson JR, Adams RS, Cutkomp LK. 1971. Soil properties influencing DDT bioactivity. Soil Sci Soc Am Proc 35:43–59.
Philibert A, Schwartz H, Mergler D. 2009. An exploratory study of diabetes in a First Nation community with respect to serum concentrations of p,p’-DDE and PCBs and fish consumption. Int J Environ Res Public Health 6(12):3179–3189. 10.3390/ijerph6123179.20049255
Pi N, Chia SE, Ong CN, 2016a. Associations of serum organohalogen levels and prostate cancer risk: Results from a case-control study in Singapore. Chemosphere 144:1505–1512. 10.1016/j.chemosphere.2015.10.020.26498098
Pi N, Chia SE, Ong CN, 2016b. Supplemental material: Associations of serum organohalogen levels and prostate cancer risk: Results from a case-control study in Singapore. Chemosphere 144 10.1016/j.chemosphere.2015.10.020.
Pinto JD, Camien MN, Dunn MS. 1965. Metabolic fate of p,p’-DDT [1,1,1-trichloro-2,2-bis(p-chlorophenyl)ethane] in rats. J Biol Chem 240(5):2148–2154.14299640
Pocock DE, Vost A. 1974. DDT absorption and chylomicron transport in rat. Lipids 9(6):374–381. 10.1007/BF02532054.4365967
Poissant L, Koprivnjak JF, Matthieu R. 1997. Some persistent organic pollutants and heavy metals in the atmosphere over a St Lawrence River valley site (Villeroy) in 1992. Chemosphere 34(3):567–585.
Poland A, Smith D, Kuntzman R, 1970. Effect of intensive occupational exposure to DDT on phenylbutazone and cortisol metabolism in human subjects. Clin Pharmacol Ther 11(5):724–732. 10.1002/cpt1970115724.5455634
Porpora MG, Medda E, Abballe A, 2009. Endometriosis and organochlorinated environmental pollutants: a case-control study on Italian women of reproductive age. Environ Health Perspect 117(7):1070–1075. 10.1289/ehp.0800273.19654915
Powers JM, Hennigar GR, Grooms G, 1974. Adrenal cortical degeneration and regeneration following administration of DDD. Am J Pathol 75(1):181–194.4825614
Pranzatelli MR, Tkach K. 1992. Regional glycine receptor binding in the p,p’-DDT myoclonic rat model. Arch Toxicol 66(1):73–76. 10.1007/BF02307273.1316118
Pratt JA, Rothwell J, Jenner P, 1986. p,p’-DDT-induced myoclonus in the rat and its application as an animal model of 5-HT-sensitive action myoclonus. Adv Neurol 43:577–588.2418651
Preat V, de Gerlache J, Lans M, 1986. Comparative analysis of the effect of phenobarbital, dichlorodiphenyltrichloroethane, butylated hydroxytoluene and nafenopin on rat hepatocarcinogenesis. Carcinogenesis 7(6):1025–1028. 10.1093/carcin/7.6.1025.2871946
Preston BD, Miller JA, Miller EC. 1984. Reactions of 2,2’5,5’-tetrachlorobiphenyl 3,4-oxide with methionine, cysteine and glutathione in relation to the formation of methylthio-metabolites of 2,2’5,5’-tetrachlorobiphenyl in the rat and mouse. Chem Biol Interact 50:289–312.6430573
Probst GS, Hill LE. 1980. Chemically-induced DNA repair synthesis in primary rat hepatocytes: a correlation with bacterial mutagenicity. Ann N Y Acad Sci 349:405–406. 10.1111/j.1749-6632.1980.tb29551.x.6939370
Probst GS, McMahon RE, Hill LE, 1981. Chemically-induced unscheduled DNA synthesis in primary rat hepatocyte cultures: a comparison with bacteria mutagenicity using 218 compounds. Environ Mutagen 3:11–32.7021142
Procianoy RS, Schvartsman S. 1981. Blood pesticide concentration in mothers and their newborn infants: Relation to prematurity. Acta Paediatr Scand 70:925–928.7324948
Purdue MP, Engel LS, Langseth H, 2009. Prediagnostic serum concentrations of organochlorine compounds and risk of testicular germ cell tumors. Environ Health Perspect 117(10):1514–1519. 10.1289/ehp.0800359.20019899
Quan C, Shi Y, Wang C, 2016. p,p’-DDE damages spermatogenesis via phospholipid hydroperoxide glutathione peroxidase depletion and mitochondria apoptosis pathway. Environ Toxicol 31(5):593–600. 10.1002/tox.22072.25410718
Quaranta MG, Porpora MG, Mattioli B, 2006. Impaired NK-cell-mediated cytotoxic activity and cytokine production in patients with endometriosis: a possible role for PCBs and DDE. Life Sci 79(5):491–498. 10.1016/j.lfs.2006.01.026.16499933
Quensen JF, Tiedje JM, Jain MK, 2001. Factors controlling the rate of DDE dechlorination to DDMU in Palos Verdes margin sediments under anaerobic conditions. Environ Sci Technol 35(2):286–291. 10.1021/es0012873.11347599
Quintana PJ, Delfino RJ, Korrick S, 2004. Adipose tissue levels of organochlorine pesticides and polychlorinated biphenyls and risk of non-Hodgkin’s lymphoma. Environ Health Perspect 112(8):854–861. 10.1289/ehp.6726.15175172
Rabello MN, Dealmeida WF, Pigati P, 1975. Cytogenetic study on individuals occupationally exposed to DDT. Mutat Res 28(3):449–454. 10.1016/0027-5107(75)90238-9.1134514
Racke K, Skidmore M, Hamilton D, 1997. Pesticide fate in tropical soils. Pure Appl Chem 69(6):1349–1371.
Rapaport R, Urban N, Capel P, 1985. "New" DDT inputs to North America: Atmospheric deposition. Chemosphere 14(9):1167–1173.
Reed A, Dzon L, Loganathan BG, 2004. Immunomodulation of human natural killer cell cytotoxic function by organochlorine pesticides. Hum Exp Toxicol 23(10):463–471. 10.1191/0960327104ht477oa.15553171
Rehana T, Rao PR. 1992. Effect of DDT on the immune system in Swiss albino mice during adult and perinatal exposure: humoral responses. Bull Environ Contam Toxicol 48(4):535–540. 10.1007/BF00199070.1504498
Reich AR, Perkins JL, Cutter G. 1986. DDT contamination of a north Alabama aquatic ecosystem. Environ Toxicol Chem 5:725–736.
Reif VD, Sinsheimer JE. 1975. Metabolism of 1-(o-chlorophenyl)-1-(p-chlorophenyl)-2,2-dichloroethane (o,p’-DDD) in rats. Drug Metab Dispos 3(1):15–25.234830
Reingold IM, Lasky II. 1947. Acute fatal poisoning following ingestion of a solution of DDT. Ann Intern Med 26(6):945–947. 10.7326/0003-4819-26-6-945.20242663
Reish DJ, Kauwling TJ, Mearns AJ, 1978. Marine and estuarine pollution. J Water Pollut Control Fed 50:1424–1469.
Ren A, Qiu X, Jin L, 2011. Association of selected persistent organic pollutants in the placenta with the risk of neural tube defects. Proc Natl Acad Sci U S A 108(31):12770–12775. 10.1073/pnas.1105209108.21768370
RePORTER. 2021. DDT. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. July 13, 2021.
Ribas-Fito N, Sala M, Cardo E, 2002. Association of hexachlorobenzene and other organochlorine compounds with anthropometric measures at birth. Pediatr Res 52(2):163–167. 10.1203/00006450-200208000-00006.12149491
Ribas-Fito N, Cardo E, Sala M, 2003a. Breastfeeding, exposure to organochlorine compounds, and neurodevelopment in infants. Pediatrics 111(5 Pt 1):e580–585.12728113
Ribas-Fito N, Sala M, Cardo E, 2003b. Organochlorine compounds and concentrations of thyroid stimulating hormone in newborns. Occup Environ Med 60(4):301–303.12660379
Ribas-Fito N, Gladen BC, Brock JW, 2006. Prenatal exposure to 1,1-dichloro-2,2-bis (p-chlorophenyl)ethylene (p,p’-DDE) in relation to child growth. Int J Epidemiol 35(4):853–858. 10.1093/ije/dyl067.16606643
Richardson JR, Roy A, Shalat SL, 2014. Elevated serum pesticide levels and risk for Alzheimer disease. JAMA Neurol 71(3):284–290. 10.1001/jamaneurol.2013.6030.24473795
Rignell-Hydbom A, Rylander L, Giwercman A, 2004. Exposure to CB-153 and p,p’-DDE and male reproductive function. Hum Reprod 19(9):2066–2075. 10.1093/humrep/deh362.15284211
Rignell-Hydbom A, Rylander L, Elzanaty S, 2005a. Exposure to persistent organochlorine pollutants and seminal levels of markers of epididymal and accessory sex gland functions in Swedish men. Human reproduction (Oxford, England) 20(7):1910–1914. 10.1093/humrep/deh856.15802324
Rignell-Hydbom A, Rylander L, Giwercman A, 2005b. Exposure to PCBs and p,p’-DDE and human sperm chromatin integrity. Environ Health Perspect 113(2):175–179.15687046
Rignell-Hydbom A, Rylander L, Hagmar L. 2007. Exposure to persistent organochlorine pollutants and type 2 diabetes mellitus. Hum Exp Toxicol 26(5):447–452. 10.1177/0960327107076886.17623770
Rignell-Hydbom A, Skerfving S, Lundh T, 2009a. Exposure to cadmium and persistent organochlorine pollutants and its association with bone mineral density and markers of bone metabolism on postmenopausal women. Environ Res 109(8):991–996. 10.1016/j.envres.2009.08.008.19733845
Rignell-Hydbom A, Lidfeldt J, Kiviranta H, 2009b. Exposure to p,p’-DDE: a risk factor for type 2 diabetes. PLoS ONE 4(10):e7503. 10.1371/journal.pone.0007503.19838294
Rignell-Hydbom A, Elfving M, Ivarsson SA, 2010. A nested case-control study of intrauterine exposure to persistent organochlorine pollutants in relation to risk of type 1 diabetes. PLoS ONE 5(6):e11281. 10.1371/journal.pone.0011281.20585661
Risebrough R, Jarman W, Springer A, 1986. A metabolic derivation of DDE from Kelthane. Environ Toxicol Chem 5:13–19.
Ritchie JM, Vial SL, Fuortes LJ, 2003. Organochlorines and risk of prostate cancer. J Occup Environ Med 45(7):692–702. 10.1097/01.jom.0000071510.96740.0b.12855910
Riva E, Grandi F, Massetto N, 2004. Polychlorinated biphenyls in colostral milk and visual function at 12 months of life. Acta Paediatr 93(8):1103–1107.15456203
Rivero-Rodriguez L, Borja-Aburto VH, Santos-Burgoa C, 1997. Exposure assessment for worker applying DDT to control malaria in Veracruz, Mexico. Environ Health Perspect 105(1):98–101.9074888
Roan C, Morgan D, Paschal EH. 1971. Urinary excretion of DDA following ingestion of DDT and DDT metabolites in man. Arch Environ Health 22(3):309–315. 10.1080/00039896.1971.10665849.5100105
Roberts JR, Karr CJ. 2012. Pesticide exposure in children. Pediatrics 130(6):e1765–1788. 10.1542/peds.2012-2758.23184105
Roberts DR, Laughlin LL, Hsheih P, 1997. DDT, global strategies, and a malaria control crisis in South America. Emerg Infect Dis 3(3):295–302. 10.3201/eid0303.970305.9284373
Robertson BK, Alexander M. 1998. Sequestration of DDT and dieldrin in soil: Disappearance of acute toxicity but not the compounds. Environ Toxicol Chem 17(6):1034–1038.
Robledo CA, Yeung E, Mendola P, 2015. Preconception maternal and paternal exposure to persistent organic pollutants and birth size: the LIFE study. Environ Health Perspect 123(1):88–94. 10.1289/ehp.1308016.25095280
Rocha-Amador D, Navarro M, Trejo-Acevedo A, 2009. Use of the Rey-Osterrieth Complex Figure Test for neurotoxicity evaluation of mixtures in children. Neurotoxicology 30(6):1149–1154. 10.1016/j.neuro.2009.09.003.19770001
Rogan WJ, Gladen BC. 1991. PCBs, DDE, and child development at 18 and 24 months. Ann Epidemiol 1(5):407–413. 10.1016/1047-2797(91)90010-a.1669521
Rogan WJ, Gladen BC, McKinney JD, 1986. Polychlorinated biphenyls (PCBs) and dichlorophenyl dichloroethene (DDE) in human milk: Effects of maternal factors and previous lactation. Am J Public Health 76:172–177.3080910
Rojanapo W, Tepsuwan A, Kupradinum P, 1988. Modulation of hepatocarcinogenicity of aflatoxin B1 by the chlorinated insecticide DDT. In: Nigam SK, McBrien DC H, Slater TF, eds. Eicosanoids, lipid peroxidation and cancer. Berlin, Germany: Spring-Verlag, 327–338.
Rojanapo W, Kupradinun P, Tepsuwan A, 1993. Effect of varying the onset of exposure to DDT on its modulation of AFB1-induced hepatocarcinogenesis in the rat. Carcinogenesis 14(4):663–667. 10.1093/carcin/14.4.663.8097137
Romieu I, Hernandez-Avila M, Lazcano-Ponce E, 2000. Breast cancer, lactation history, and serum organochlorines. Am J Epidemiol 152(4):363–370. 10.1093/aje/152.4.363.10968381
Roos V, Ronn M, Salihovic S, 2013. Circulating levels of persistent organic pollutants in relation to visceral and subcutaneous adipose tissue by abdominal MRI. Obesity (Silver Spring) 21(2):413–418. 10.1002/oby.20267.23532994
Rosenquist AH, Hoyer BB, Julvez J, 2017. Prenatal and postnatal PCB-153 and p,p’-DDE exposures and behavior scores at 5–9 years of age among children in Greenland and Ukraine. Environ Health Perspect 125(10):107002. 10.1289/ehp553.28974479
Rossi L, Ravera M, Repetti G, 1977. Long-term administration of DDT or phenobarbital-Na in Wistar rats. Int J Cancer 19(2):179–185. 10.1002/ijc.2910190207.838519
Rossi L, Barbieri O, Sanguineti M, 1983. Carcinogenicity study with technical-grade dichlorodiphenyltrichloroethane and 1,1-dichloro-2,2-bis(p-chlorophenyl)ethylene in hamsters. Cancer Res 43(2):776–781.6848191
Rossi M, Scarselli M, Fasciani I, 2017. Dichlorodiphenyltrichloroethane (DDT) induced extracellular vesicle formation: a potential role in organochlorine increased risk of Parkinson’s disease. Acta Neurobiol Exp (Wars) 77(2):113–117. 10.21307/ane-2017-043.28691715
Rothe CF, Mattson AM, Nueslein RM, 1957. Metabolism of chlorophenothane (DDT). AMA Arch Ind Health 16:82–86.13434502
Rothman N, Cantor KP, Blair A, 1997. A nested case-control study of non-Hodgkin lymphoma and serum organochlorine residues. Lancet 350(9073):240–244. 10.1016/S0140-6736(97)02088-6.9242800
Rowlands SA, Hall AK, McCormick PG, 1994. Destruction of toxic materials. Nature 367:223.
Rubin JG, Payne GT, Soderlund DM. 1993. Structure-activity relationships for pyrethroids and DDT analogs as modifiers of [3H]batrachotoxinin A 20-α-benzoate binding to mouse brain sodium channels. Pestic Biochem Physiol 45(2):130–140.
Ruel MV M, Bos AF, Soechitram SD, 2019. Prenatal exposure to organohalogen compounds and children’s mental and motor development at 18 and 30 months of age. Neurotoxicology 72:6–14. 10.1016/j.neuro.2019.01.003.30664974
Rusiecki JA, Baccarelli A, Bollati V, 2008. Global DNA hypomethylation is associated with high serum-persistent organic pollutants in Greenlandic Inuit. Environ Health Perspect 116(11):1547–1552. 10.1289/ehp.11338.19057709
Russ K, Howard S. 2016. Developmental exposure to environmental chemicals and metabolic changes in children. Curr Probl Pediatr Adolesc Health Care 46(8):255–285. 10.1016/j.cppeds.2016.06.001.27401018
Russell RW, Hecnar SJ, Haffner D. 1995. Organochlorine pesticide residues in southern Ontario spring peepers. Environ Toxicol Chem 14(5):815–817.
Rylander L, Rignell-Hydbom A, Hagmar L. 2005. A cross-sectional study of the association between persistent organochlorine pollutants and diabetes. Environ Health 4:28. 10.1186/1476-069X-4-28.16316471
Rylander L, Wallin E, Jonssson BA, 2006. Associations between CB-153 and p,p’-DDE and hormone levels in serum in middle-aged and elderly men. Chemosphere 65(3):375–381. 10.1016/j.chemosphere.2006.02.012.16554082
Ryu DH, Yu HT, Kim SA, 2018. Is chronic exposure to low-dose organochlorine pesticides a new risk factor of T-cell immunosenescence? Cancer Epidemiol Biomarkers Prev 27(10):1159–1167. 10.1158/1055-9965.epi-17-0799.29991517
Sa C, Pestana D, Calhau C, 2018. Unravelling the effect of p,p’-Dichlorodiphenyldichloroethylene (DDE) in hypertension of Wistar rats. J Agric Food Chem 66(48):12847–12854. 10.1021/acs.jafc.8b05001.30415545
Sabljic A. 1984. Predictions of the nature and strength of soil sorption of organic pollutants by molecular topology. J Agric Food Chem 32:243–246.
Sadler-Riggleman I, Klukovich R, Nilsson E, 2019. Epigenetic transgenerational inheritance of testis pathology and Sertoli cell epimutations: generational origins of male infertility. Environ Epigenet 5(3):dvz013. 10.1093/eep/dvz013.31528361
Sagiv SK, Tolbert PE, Altshul LM, 2007. Organochlorine exposures during pregnancy and infant size at birth. Epidemiology 18(1):120–129. 10.1097/01.ede.0000249769.15001.7c.17179760
Sagiv SK, Nugent JK, Brazelton TB, 2008. Prenatal organochlorine exposure and measures of behavior in infancy using the Neonatal Behavioral Assessment Scale (NBAS). Environ Health Perspect 116(5):666–673. 10.1289/ehp.10553.18470320
Sagiv SK, Thurston SW, Bellinger DC, 2010. Prenatal organochlorine exposure and behaviors associated with attention deficit hyperactivity disorder in school-aged children. Am J Epidemiol 171(5):593–601. 10.1093/aje/kwp427.20106937
Sagiv SK, Thurston SW, Bellinger DC, 2012. Neuropsychological measures of attention and impulse control among 8-year-old children exposed prenatally to organochlorines. Environ Health Perspect 120(6):904–909. 10.1289/ehp.1104372.22357172
Salihovic S, Ganna A, Fall T, 2016. The metabolic fingerprint of p,p’-DDE and HCB exposure in humans. Environ Int 88:60–66. 10.1016/j.envint.2015.12.015.26720637
Samuel T, Pillai MK. 1989. The effect of temperature and solar radiations on volatilisation, mineralisation and degradation of [14C]-DDT in soil. Environ Pollut 57(1):63–77. 10.1016/0269-7491(89)90130-9.15092467
Sanger DM, Holland AF, Scott GI. 1999. Tidal creek and salt marsh sediments in South Carolina coastal estuaries: II. Distribution of organic contaminants. Arch Environ Contam Toxicol 37(4):458–471. 10.1007/s002449900540.10508893
Sanyal S, Agarwal N, Subrahmanyam D. 1986. Effect of acute sublethal and chronic administration of DDT (chlorophenotane) on brain lipid metabolism of rhesus monkeys. Toxicol Lett 34(1):47–54. 10.1016/0378-4274(86)90144-x.3787664
Savitz DA, Klebanoff MA, Wellenius GA, 2014a. Persistent organochlorines and hypertensive disorders of pregnancy. Environ Res 132:1–5. 10.1016/j.envres.2014.03.020.24742720
Savitz DA, Klebanoff MA, Wellenius GA, 2014b. Supplemental material: Persistent organochlorines and hypertensive disorders of pregnancy. Environ Res 132 10.1016/j.envres.2014.03.020.
Sawada N, Iwasaki M, Inoue M, 2010. Plasma organochlorines and subsequent risk of prostate cancer in Japanese men: a nested case-control study. Environ Health Perspect 118(5):659–665. 10.1289/ehp.0901214.20435560
Sax E. 1979. DDT. In: Dangerous properties of industrial materials. 5th ed. New York, NY: Van Nostrand Reinhold, 534–535.
Saxena MC, Siddiqui MK, Bhargava AK, 1980. Role of chlorinated hydrocarbon pesticides in abortions and premature labour. Toxicology 17(3):323–331. 10.1016/0300-483x(80)90013-x.7210017
Saxena MC, Siddiqui MK, Seth TD, 1981. Organochlorine pesticides in specimens from women undergoing spontaneous abortion, premature of full-term delivery. J Anal Toxicol 5(1):6–9. 10.1093/jat/5.1.6.7218781
Saxena MC, Siddiqui MK, Agarwal V, 1983. A comparison of organochlorine insecticide contents in specimens of maternal blood, placenta, and umbilical-cord blood from stillborn and live-born cases. J Toxicol Environ Health 11(1):71–79. 10.1080/15287398309530321.6186820
Saxena SP, Khare C, Farooq A, 1987. DDT and its metabolites in leiomyomatous and normal human uterine tissue. Arch Toxicol 59(6):453–455. 10.1007/BF00316214.3606393
Schattenberg HJ, Hsu JP. 1992. Pesticide residue survey of produce from 1989–1991. J AOAC Int 75(5):925–933.
Schecter A, Toniolo P, Dai LC, 1997. Blood levels of DDT and breast cancer risk among women living in the north of Vietnam. Arch Environ Contam Toxicol 33:453–456.9419265
Schecter A, Cramer P, Boggess K, 2001. Intake of dioxins and related compounds from food in the U.S. population. J Toxicol Environ Health A 63(1):1–18. 10.1080/152873901750128326.11346131
Schecter A, Haffner D, Colacino J, 2010. Polybrominated diphenyl ethers (PBDEs) and hexabromocyclodecane (HBCD) in composite U.S. food samples. Environ Health Perspect 118(3):357–362. 10.1289/ehp.0901345.20064778
Scheele JS. 1998. A comparison of the concentrations of certain pesticides and polychlorinated hydrocarbons in bone marrow and fat tissue. J Environ Pathol Toxicol Oncol 17(1):65–68.9490321
Scheele J, Teufel M, Niessen KH. 1995. A comparison of the concentrations of certain chlorinated hydrocarbons and polychlorinated biphenyls in bone marrow and fat tissue of children and their concentrations in breast milk. J Environ Pathol Toxicol Oncol 14(1):11–14.7473068
Schell LM, Gallo MV, Ravenscroft J, 2009. Persistent organic pollutants and anti-thyroid peroxidase levels in Akwesasne Mohawk young adults. Environ Res 109(1):86–92. 10.1016/j.envres.2008.08.015.18995849
Schell LM, Gallo MV, Deane GD, 2014. Relationships of polychlorinated biphenyls and dichlorodiphenyldichloroethylene (p,p’-DDE) with testosterone levels in adolescent males. Environ Health Perspect 122(3):304–309. 10.1289/ehp.1205984.24398050
Schildkraut JM, Demark-Wahnefried W, DeVoto E, 1999. Environmental contaminants and body fat distribution. Cancer Epidemiol Biomarkers Prev 8(2):179–183.10067817
Schmid K, Lederer P, Goen T, 1997. Internal exposure to hazardous substances of persons from various continents: investigations on exposure to different organochlorine compounds. Int Arch Occup Environ Health 69:399–406.9215926
Schmitt CJ, Zajicek JL, Peterman PH. 1990. National contaminant biomonitoring program: Residues of organochlorine chemicals in U.S. Freshwater Fish, 1976–1984. Arch Environ Contam Toxicol 19(5):748–781. 10.1007/BF01183992.21318506
Schwack W. 1988. Photoinduced additions of pesticides to biomolecules. 2. Model reactions of DDT and methoxyclor with methyl oleate. J Agric Food Chem 36:645–648.
Seiler JP. 1977. Inhibition of testicular DNA synthesis by chemical mutagens and carcinogens. Preliminary results in the validation of a novel short term test. Mutat Res 46(4):305–310. 10.1016/0165-1161(77)90007-3.895760
Seiler P, Fischer B, Lindenau A, 1994. Effects of persistent chlorinated hydrocarbons on fertility and embryonic development in the rabbit. Hum Reprod 9(10):1920–1926. 10.1093/oxfordjournals.humrep.a138359.7531205
Serdar B, LeBlanc WG, Norris JM, 2014. Potential effects of polychlorinated biphenyls (PCBs) and selected organochlorine pesticides (OCPs) on immune cells and blood biochemistry measures: a cross-sectional assessment of the NHANES 2003–2004 data. Environ Health 13:114. 10.1186/1476-069X-13-114.25515064
Sexton K, Adgate JL, Fredrickson AL, 2006. Using biologic markers in blood to assess exposure to multiple environmental chemicals for inner-city children 3–6 years of age. Environ Health Perspect 114(3):453–459. 10.1289/ehp.8324.16507471
Shabad LM, Kolesnichenko TA, Nikonova TV. 1973. Transplacental and combined long-term effect of DDT in five generations of A-strain mice. Int J Cancer 11(3):688–693. 10.1002/ijc.2910110320.4791226
Sharma E, Mustafa M, Pathak R, 2012. A case control study of gene environmental interaction in fetal growth restriction with special reference to organochlorine pesticides. Eur J Obstet Gynecol Reprod Biol 161(2):163–169. 10.1016/j.ejogrb.2012.01.008.22310945
Shi Y, Song Y, Wang Y, 2009. p,p’-DDE induces apoptosis of rat Sertoli cells via a FasL-dependent pathway. J Biomed Biotechnol 2009:181282. 10.1155/2009/181282.19644561
Shi YQ, Li HW, Wang YP, 2013. p,p’-DDE induces apoptosis and mRNA expression of apoptosis-associated genes in testes of pubertal rats. Environ Toxicol 28(1):31–41. 10.1002/tox.20694.21384494
Shin JY, Choi YY, Jeon HS, 2010. Low-dose persistent organic pollutants increased telomere length in peripheral leukocytes of healthy Koreans. Mutagenesis 25(5):511–516. 10.1093/mutage/geq035.20616147
Shiplov J, Graber CD, Keil JE, 1972. Effect of DDT on antibody response to typhoid vaccine in rabbits and man. Immunol Commun 1(4):385–394. 10.3109/08820137209022951.4680354
Shirasu Y, Moriya M, Kato K, 1976. Mutagenicity screening of pesticides in the microbial system. Mutat Res 40(1):19–30. 10.1016/0165-1218(76)90018-5.814455
Shutoh Y, Takeda M, Ohtsuka R, 2009. Low dose effects of dichlorodiphenyltrichloroethane (DDT) on gene transcription and DNA methylation in the hypothalamus of young male rats: implication of hormesis-like effects. J Toxicol Sci 34(5):469–482. 10.2131/jts.34.469.19797855
Siddarth M, Datta SK, Mustafa M, 2014. Increased level of organochlorine pesticides in chronic kidney disease patients of unknown etiology: role of GSTM1/GSTT1 polymorphism. Chemosphere 96:174–179. 10.1016/j.chemosphere.2013.10.029.24216264
Siddiqui MK, Srivastava S, Srivastava SP, 2003. Persistent chlorinated pesticides and intra-uterine foetal growth retardation: a possible association. Int Arch Occup Environ Health 76(1):75–80. 10.1007/s00420-002-0393-6.12592586
Sieber SM. 1976. The lymphatic absorption of p,p’-DDT and some structurally-related compounds in the rat. Pharmacology 14:443–454.1031215
Silinskas KC, Okey AB. 1975. Protection by 1,1,1-trichloro-2,2-bis(p-chlorophenyl)ethane (DDT) against mammary tumors and leukemia during prolonged feeding of 7,12-dimethylbenz(a)anthracene to female rats. J Natl Cancer Inst 55(3):653–657. 10.1093/jnci/55.3.653.808643
Singh BK, Kuhad RC, Singh A, 1999. Biochemical and molecular basis of pesticide degradation by microorganisms. Crit Rev Biotechnol 19(3):197–225. 10.1080/0738-859991229242.10526405
Singhal RL, Valadares JR E, Schwark WS. 1970. Metabolic control mechanisms in mammalian systems-IX: Estrogen-like stimulation of uterine enzymes by o,p’-1,1,1-trichloro-2–2-bis (p-chlorophenyl) ethane. Biochem Pharmacol 19:2145–2155.4105300
Sioen I, Den Hond E, Nelen V, 2013. Prenatal exposure to environmental contaminants and behavioural problems at age 7–8years. Environ Int 59:225–231. 10.1016/j.envint.2013.06.014.23845936
Sjoeib F, Anwar E, Tungguldihardjo MS. 1994. Laboratory studies of dissipation of 14C-DDT from soil and plywood surfaces. Journal of Environmental science and health B 29(1):153–159.
Skinner MK, Ben Maamar M, Sadler-Riggleman I, 2018. Alterations in sperm DNA methylation, non-coding RNA and histone retention associate with DDT-induced epigenetic transgenerational inheritance of disease. Epigenetics Chromatin 11(1):8. 10.1186/s13072-018-0178-0.29482626
Sleicher CA, Hopcraft J. 1984. Persistence of pesticides in surface soil and relation to sublimation. Environ Sci Technol 18(7):514–518.
Smith D. 1999. Worldwide trends in DDT levels in human breast milk. Int J Epidemiol 28(2):179–188. 10.1093/ije/28.2.179.10342677
Sobotka TJ. 1971. Behavioral effects of low doses of DDT. Proc Soc Exp Biol Med 137(3):952–955. 10.3181/00379727-137-35703.5560687
Sohoni P, Sumpter J. 1998. Several environmental oestrogens are also anti-androgens. J Endocrinol 158:327–339.9846162
Son HK, Kim SA, Kang JH, 2010. Strong associations between low-dose organochlorine pesticides and type 2 diabetes in Korea. Environ Int 36(5):410–414. 10.1016/j.envint.2010.02.012.20381150
Song Y, Yang L. 2017. Transgenerational pancreatic impairment with Igf2/H19 epigenetic alteration induced by p,p’-DDE exposure in early life. Toxicol Lett 280:222–231. 10.1016/j.toxlet.2017.08.083.28867213
Song Y, Yang L. 2018. Transgenerational impaired spermatogenesis with sperm H19 and Gtl2 hypomethylation induced by the endocrine disruptor p,p’-DDE. Toxicol Lett 297:34–41. 10.1016/j.toxlet.2018.08.015.30153481
Song Y, Liang X, Hu Y, 2008. p,p’-DDE induces mitochondria-mediated apoptosis of cultured rat Sertoli cells. Toxicology 253(1–3):53–61. 10.1016/j.tox.2008.08.013.18817839
Song Y, Shi Y, Yu H, 2011. p,p’-Dichlorodiphenoxydichloroethylene induced apoptosis of Sertoli cells through oxidative stress-mediated p38 MAPK and mitochondrial pathway. Toxicol Lett 202(1):55–60. 10.1016/j.toxlet.2011.01.020.21281706
Song S, Ma X, Pan M, 2018. Excretion kinetics of three dominant organochlorine compounds in human milk within the first 6 months postpartum. Environ Monit Assess 190(8):457. 10.1007/s10661-018-6850-9.29995278
Sonne C, Gustavson K, Riget FF, 2014. Physiologically based pharmacokinetic modeling of POPs in Greenlanders. Environ Int 64:91–97. 10.1016/j.envint.2013.12.006.24382481
Soto AM, Fernandez MF, Luizzi MF, 1997. Developing a marker of exposure to xenoestrogen mixtures in human serum. Environ Health Perspect 105(Suppl 3):647–654. 10.1289/ehp.97105s3647.9168009
Soto AM, Lin TM, Justicia H, 1998. An "in culture" bioassay to assess the estrogenicity of xenobiotics (e-screen). J Clean Technol Environ Toxicol Occup Med 7(3):331–343.
Spano M, Toft G, Hagmar L, 2005. Exposure to PCB and p, p’-DDE in European and Inuit populations: impact on human sperm chromatin integrity. Hum Reprod 20(12):3488–3499. 10.1093/humrep/dei297.16223788
Spencer WF, Singh G, Taylor CD, 1996. DDT persistence and volatility as affected by management practices after 23 years. J Environ Qual 25:815–821.
Spinelli JJ, Ng CH, Weber JP, 2007. Organochlorines and risk of non-Hodgkin lymphoma. Int J Cancer 121(12):2767–2775. 10.1002/ijc.23005.17722095
Stanley MR, Barney JE, Helton MR, 1971. Measurement of atmospheric levels of pesticides. Environ Sci Technol 5(5):430–435.
Staples CA, Werner AF, Hoogheem TJ. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4:131–142.
Steenland K, Mora AM, Barr DB, 2014. Organochlorine chemicals and neurodegeneration among elderly subjects in Costa Rica. Environ Res 134:205–209. 10.1016/j.envres.2014.07.024.25173053
Stehr-Green PA. 1989. Demographic and seasonal influences on human serum pesticide residue levels. J Toxicol Environ Health 27(4):405–421. 10.1080/15287398909531312.2760935
Stellman SD, Djordjevic MV, Muscat JE, 1998. Relative abundance of organochlorine pesticides and polychlorinaed biphenyls in adipose tissue and serum of women in Long Island, New York. Cancer Epidemiol Biomarkers Prev 7:489–496.9641493
Stewart DK R, Chisholm D. 1971. Long-term persistence of BHC, DDT and chlordane in a sandy loam soil. Can J Soil Sci 51:379–383.
Stewart P, Reihman J, Lonky E, 2000. Prenatal PCB exposure and neonatal behavioral assessment scale (NBAS) performance. Neurotoxicol Teratol 22(1):21–29. 10.1016/s0892-0362(99)00056-2.10642111
Streck G, Herrmann R. 2000. Distribution of endocrine disrupting semivolatile organic compounds in several compartments of a terrestrial ecosystem. Water Sci Technol 42(7–8):39–44.
Street JC, Chadwick RW. 1967. Stimulation of dieldrin metabolism by DDT. Toxicol Appl Pharmacol 11(1):68–71. 10.1016/0041-008x(67)90027-0.6056156
Street JC, Sharma RP. 1975. Alteration of induced cellular and humoral immune responses by pesticides and chemicals of environmental concern: quantitative studies of immunosuppression by DDT, aroclor 1254, carbaryl, carbofuran, and methylparathion. Toxicol Appl Pharmacol 32(3):587–602. 10.1016/0041-008x(75)90123-4.50651
Strom PF. 2000. Pesticide in yard compost. Compost Sci Util 8(1):54–60.
Strom M, Hansen S, Olsen SF, 2014. Persistent organic pollutants measured in maternal serum and offspring neurodevelopmental outcomes--a prospective study with long-term follow-up. Environ Int 68:41–48. 10.1016/j.envint.2014.03.002.24704638
Strompl C, Thiele JH. 1997. Comparative fate of 1,1-diphenylethylene (DPE), 1,1-dichloro-2,2-bis(4-Chlorophenyl)-ethylene (DDE), and pentachlorophenol (PCP) under alternating aerobic and anaerobic conditions. Arch Environ Contam Toxicol 33(4):350–356. 10.1007/s002449900264.9419253
Stronati A, Manicardi GC, Cecati M, 2006. Relationships between sperm DNA fragmentation, sperm apoptotic markers and serum levels of CB-153 and p,p’-DDE in European and Inuit populations. Reproduction 132(6):949–958. 10.1530/rep.1.01034.17127755
Sturgeon SR, Brock JW, Potischman N, 1998. Serum concentrations of organochlorine compounds and endometrial cancer risk (United States). Cancer Causes Control 9(4):417–424. 10.1023/a:1008823802393.9794174
Sunyer J, Torrent M, Munoz-Ortiz L, 2005. Prenatal dichlorodiphenyldichloroethylene (DDE) and asthma in children. Environ Health Perspect 113(12):1787–1790. 10.1289/ehp.8127.16330365
Sunyer J, Torrent M, Garcia-Esteban R, 2006. Early exposure to dichlorodiphenyldichloroethylene, breastfeeding and asthma at age six. Clin Exp Allergy 36(10):1236–1241. 10.1111/j.1365-2222.2006.02560.x.17014430
Sunyer J, Alvarez-Pedrerol M, To-Figueras J, 2008. Urinary porphyrin excretion in children is associated with exposure to organochlorine compounds. Environ Health Perspect 116(10):1407–1410. 10.1289/ehp.11354.18941586
Sunyer J, Garcia-Esteban R, Alvarez M, 2010. DDE in mothers’ blood during pregnancy and lower respiratory tract infections in their infants. Epidemiology 21(5):729–735. 10.1097/EDE.0b013e3181e5ea96.20616741
Svensson BG, Hallberg T, Nilsson A, 1994. Parameters of immunological competence in subjects with high consumption of fish contaminated with persistent organochlorine compounds. Int Arch Occup Environ Health 65(6):351–358. 10.1007/BF00383243.8034358
Swann RL, McCall PJ, Laskowski DA, 1981. Estimation of soil sorption constants of organic chemicals by high-performance liquid chromatography. ASTM Spec Tech Publ 737:43–48.
Takayama S, Sieber SM, Dalgard DW, 1999. Effects of long-term oral administration of DDT on nonhuman primates. J Cancer Res Clin Oncol 125(3–4):219–225. 10.1007/s004320050266.10235477
Takei GH, Kauahikaua SM, Leong GH. 1983. Analysis of human milk samples collected in Hawaii for residues of organochlorine pesticides and polychlorobiphenyls. Bull Environ Contam Toxicol 30:606–613.6407553
Takser L, Mergler D, Baldwin M, 2005. Thyroid hormones in pregnancy in relation to environmental exposure to organochlorine compounds and mercury. Environ Health Perspect 113(8):1039–1045. 10.1289/ehp.7685.16079076
Talts U, Talts JF, Eriksson P. 1998. Differential expression of muscarinic subtype mRNAs after exposure to neurotoxic pesticides. Neurobiol Aging 19(6):553–559.10192214
Tan J, Loganath A, Chong YS, 2009. Exposure to persistent organic pollutants in utero and related maternal characteristics on birth outcomes: a multivariate data analysis approach. Chemosphere 74(3):428–433. 10.1016/j.chemosphere.2008.09.045.18986677
Tanaka T, Mori H, Williams GM. 1987. Enhancement of dimethylnitrosamine-initiated hepatocarcinogenesis in hamsters by subsequent administration of carbon tetrachloride but not phenobarbital or p,p’-dichlorodiphenyltrichloroethane. Carcinogenesis 8(9):1171–1178.3304690
Tang M, Chen K, Yang F, 2014. Exposure to organochlorine pollutants and type 2 diabetes: a systematic review and meta-analysis. PLoS ONE 9(10):e85556. 10.1371/journal.pone.0085556.25329153
Tang-Peronard JL, Andersen HR, Jensen TK, 2011. Endocrine-disrupting chemicals and obesity development in humans: a review. Obes Rev 12(8):622–636. 10.1111/j.1467-789X.2011.00871.x.21457182
Tang-Peronard JL, Heitmann BL, Andersen HR, 2014. Association between prenatal polychlorinated biphenyl exposure and obesity development at ages 5 and 7 y: a prospective cohort study of 656 children from the Faroe Islands. Am J Clin Nutr 99(1):5–13. 10.3945/ajcn.113.066720.24153349
Tang-Peronard JL, Jensen TK, Andersen HR, 2015a. Associations between exposure to persistent organic pollutants in childhood and overweight up to 12 years later in a low exposed Danish population. Obesity facts 8(4):282–292. 10.1159/000438834.26228100
Tang-Peronard JL, Heitmann BL, Jensen TK, 2015b. Prenatal exposure to persistent organochlorine pollutants is associated with high insulin levels in 5-year-old girls. Environ Res 142:407–413. 10.1016/j.envres.2015.07.009.26232659
Tarjan R, Kemeny T. 1969. Multigeneration studies on DDT in mice. Food Cosmet Toxicol 7(3):215–222. 10.1016/s0015-6264(69)80325-1.5804863
Tavares RS, Mansell S, Barratt CL, 2013. p,p’-DDE activates CatSper and compromises human sperm function at environmentally relevant concentrations. Hum Reprod 28(12):3167–3177. 10.1093/humrep/det372.24067601
Tavares RS, Amaral S, Paiva C, 2015. In vitro exposure to the organochlorine p,p’-DDE affects functional human sperm parameters. Chemosphere 120:443–446. 10.1016/j.chemosphere.2014.08.075.25240159
Taylor LG, Canfield SE, Du XL. 2009. Review of major adverse effects of androgen-deprivation therapy in men with prostate cancer. Cancer 115(11):2388–2399. 10.1002/cncr.24283.19399748
Taylor KW, Novak RF, Anderson HA, 2013. Evaluation of the association between persistent organic pollutants (POPs) and diabetes in epidemiological studies: a national toxicology program workshop review. Environ Health Perspect 121(7):774–783. 10.1289/ehp.1205502.23651634
Teeyapant P, Ramchiun S, Polputpisatkul D, 2014. Serum concentrations of organochlorine pesticides p,p’-DDE in adult Thai residents with background levels of exposure. J Toxicol Sci 39(1):121–127. 10.2131/jts.39.121.24418716
Telang S, Tong C, Williams GM. 1981. Induction of mutagenesis by carcinogenic polycyclic aromatic hydrocarbons but not by organochlorine pesticides in the ARL/HGPRT mutagenesis assay. Environ Mutagen 3:359.
Terracini B, Testa M, Cabral J, 1973. The effects of long-term feeding of DDT to BALB/c mice. Int J Cancer 11:747–764.4364722
Thomas RG. 1990. Volatilization from soil. In: Handbook of chemical property estimation methods: environmental behavior of organic compounds. Washington, DC: American Chemical Society, 16–24 to 16–28.
Thomas A, Toms LL, Harden FA, 2017. Concentrations of organochlorine pesticides in pooled human serum by age and gender. Environ Res 154:10–18. 10.1016/j.envres.2016.12.009.27992738
Thorpe E, Walker AI T. 1973. The toxicology of dieldrin (HEOD). II. Comparative long-term oral toxicity studies in mice with dieldrin, DDT, phenobarbitone, β-BHC and λ-BHC. Food Cosmet Toxicol 11:433–442.4125578
Tiido T, Rignell-Hydbom A, Jonsson B, 2005. Exposure to persistent organochlorine pollutants associates with human sperm Y:X chromosome ratio. Hum Reprod 20(7):1903–1909. 10.1093/humrep/deh855.15860497
Tiido T, Rignell-Hydbom A, Jonsson BA, 2006. Impact of PCB and p,p’-DDE contaminants on human sperm Y:X chromosome ratio: studies in three European populations and the Inuit population in Greenland. Environ Health Perspect 114(5):718–724.16675426
Tilson HA, Hudson PM, Hong JS. 1986. 5,5-Diphenylhydantoin antagonizes neurochemical and behavioral effects of p,p’-DDT but not of chlordecone. J Neurochem 47(6):1870–1878.2430063
Tilson HA, Shaw S, McLamb RL. 1987. The effects of lindane, DDT, and chlordecone on avoidance responding and seizure activity. Toxicol Appl Pharmacol 88(1):57–65. 10.1016/0041-008x(87)90269-9.2436354
Tinwell H, Friry-Santini C, Rouquie D, 2007. Evaluation of the antiandrogenic effects of flutamide, DDE, and linuron in the weanling rat assay using organ weight, histopathological, and proteomic approaches. Toxicol Sci 100(1):54–65. 10.1093/toxsci/kfm208.17686919
Toft G, Rignell-Hydbom A, Tyrkiel E, 2006. Semen quality and exposure to persistent organochlorine pollutants. Epidemiology 17(4):450–458. 10.1097/01.ede.0000221769.41028.d2.16755259
Toft G, Axmon A, Lindh CH, 2008. Menstrual cycle characteristics in European and Inuit women exposed to persistent organochlorine pollutants. Hum Reprod 23(1):193–200. 10.1093/humrep/dem349.17989067
Tomatis L, Turusov V, Day N, 1972. The effect of long-term exposure to DDT on CF-1 mice. Int J Cancer 10(3):489–506. 10.1002/ijc.2910100308.4358037
Tomatis L, Turusov V, Charles R, 1974a. Effect of long-term exposure to 1,1-dichloro-2,2-bis(p-chlorophenyl)ethylene, to 1,1-dichloro-2,2-bis(p-chlorophenyl)ethane, and to the two chemicals combined on CF-1 mice. J Natl Cancer Inst 52:883–891.4826570
Tomatis L, Turusov V, Charles RT, 1974b. Liver tumours in CF-1 mice exposed for limited periods to technical DDT. Z Krebsforsch Klin Onkol Cancer Res Clin Oncol 82:25–35.4373976
Tomita M, Yoshida T, Fukumori J, 2013. p,p’-DDT induces microcytic anemia in rats. J Toxicol Sci 38(5):775–782. 10.2131/jts.38.775.24067725
Tomiyama N, Watanabe M, Takeda M, 2003. A comparative study on the reliability of toxicokinetic parameters for predicting hepatotoxicity of DDT in rats receiving a single or repeated administration. J Toxicol Sci 28(5):403–413. 10.2131/jts.28.403.14746344
Tomiyama N, Takeda M, Watanabe M, 2004. A further study on the reliability of toxicokinetic parameters for predicting hepatotoxicity in rats receiving a 28-day repeated administration of DDT. J Toxicol Sci 29(5):505–516. 10.2131/jts.29.505.15729006
Tong C, Fazio M, Williams GM. 1981. Rat hepatocyte-mediated mutagenesis of human cells by carcinogenic polycyclic aromatic hydrocarbons but not organochlorine pesticides. Proc Soc Exp Biol Med 167:572–575.6269115
Torres-Arreola L, Lopez-Carrillo L, Torres-Sanchez L, 1999. Levels of dichloro-dyphenyl-trichloroethane (DDT) metabolites in maternal milk and their determinant factors. Arch Environ Health 54(2):124–129.10094291
Torres-Arreola L, Berkowitz G, Torres-Sanchez L, 2003. Preterm birth in relation to maternal organochlorine serum levels. Ann Epidemiol 13(3):158–162. 10.1016/s1047-2797(02)00424-6.12604158
Torres-Sanchez L, Rothenberg SJ, Schnaas L, 2007. In utero p,p’-DDE exposure and infant neurodevelopment: A perinatal cohort in Mexico. Environ Health Perspect 115(3):435–439. 10.1289/ehp.9566.17431495
Torres-Sanchez L, Zepeda M, Cebrian ME, 2008. Dichlorodiphenyldichloroethylene exposure during the first trimester of pregnancy alters the anal position in male infants. Ann N Y Acad Sci 1140:155–162. 10.1196/annals.1454.004.18991914
Torres-Sanchez L, Schnaas L, Cebrian ME, 2009. Prenatal dichlorodiphenyldichloroethylene (DDE) exposure and neurodevelopment: a follow-up from 12 to 30 months of age. Neurotoxicology 30(6):1162–1165. 10.1016/j.neuro.2009.08.010.19733589
Torres-Sanchez L, Schnaas L, Rothenberg SJ, 2013. Prenatal p,p -DDE exposure and neurodevelopment among children 3.5–5 years of age. Environ Health Perspect 121(2):263–268. 10.1289/ehp.1205034.23151722
Trabert B, Chen Z, Kannan K, 2015. Persistent organic pollutants (POPs) and fibroids: results from the ENDO study. J Expo Sci Environ Epidemiol 25(3):278–285. 10.1038/jes.2014.31.24802554
Traglia M, Croen LA, Lyall K, 2017. Independent Maternal and Fetal Genetic Effects on Midgestational Circulating Levels of Environmental Pollutants. G3 (Bethesda) 7(4):1287–1299. 10.1534/g3.117.039784.28235828
Treon J, Boyd J, Berryman G, 1954. Final report on the effects on the reproductive capacity of three generations of rats being fed on diets containing aldrin, dieldrin, or DDT. Cincinnati, OH: Kettering Laboratory, University of Cincinnati, College of Medicine.
Tsushimoto G, Chang CC, Trosko JE, 1983. Cytotoxic, mutagenic, and cell-cell communication inhibitory properties of DDT, lindane, and chlordane on Chinese hamster cells in vitro. Arch Environ Contam Toxicol 12(6):721–729. 10.1007/BF01060757.6197034
Tully DB, Cox VT, Mumtaz MM, 2000. Six high-priority organochlorine pesticides, either singly or in combination, are nonestrogenic in transfected HeLa cells. Reprod Toxicol 14:95–102.10825672
Turner JC, Shanks V. 1980. Absorption of some organochlorine compounds by the rat small intestine-in vivo. Bull Environ Contam Toxicol 24:652–655.6161652
Turusov VS, Day NE, Tomatis L, 1973. Tumors in CF-1 mice exposed for six consecutive generations to DDT. J Natl Cancer Inst 51(3):983–997. 10.1093/jnci/51.3.983.4355226
Turyk ME, Anderson HA, Persky VW. 2007. Relationships of thyroid hormones with polychlorinated biphenyls, dioxins, furans, and DDE in adults. Environ Health Perspect 115(8):1197–1203. 10.1289/ehp.10179.17687447
Turyk M, Anderson HA, Hanrahan LP, 2006. Relationship of serum levels of individual PCB, dioxin, and furan congeners and DDE with Great Lakes sport-caught fish consumption. Environ Res 100(2):173–183. 10.1016/j.envres.2005.04.005.15979066
Turyk M, Anderson HA, Knobeloch L, 2009. Prevalence of diabetes and body burdens of polychlorinated biphenyls, polybrominated diphenyl ethers, and p,p’-diphenyldichloroethene in Great Lakes sport fish consumers. Chemosphere 75(5):674–679. 10.1016/j.chemosphere.2008.12.035.19157498
Udoji F, Martin T, Etherton R, 2010. Immunosuppressive effects of triclosan, nonylphenol, and DDT on human natural killer cells in vitro. J Immunotoxicol 7(3):205–212. 10.3109/15476911003667470.20297919
Ukropec J, Radikova Z, Huckova M, 2010. High prevalence of prediabetes and diabetes in a population exposed to high levels of an organochlorine cocktail. Diabetologia 53(5):899–906. 10.1007/s00125-010-1683-2.20182860
UNEP. 2015. Road map for the development of alternatives to DDT. Switzerland: UNEP Chemicals Branch. United Nations Environment Programme. https://www.unep.org/resources/publication/road-map-development-alternatives-ddt. August 10, 2021.
Unger M, Kiaer H, Blichert-Toft M, 1984. Organochlorine compounds in human breast fat from deceased with and without breast cancer and in a biopsy material from newly diagnosed patients undergoing breast surgery. Environ Res 34:24–28.6426947
Uppala PT, Roy SK, Tousson A, 2005. Induction of cell proliferation, micronuclei and hyperdiploidy/polyploidy in the mammary cells of DDT- and DMBA-treated pubertal rats. Environ Mol Mutagen 46(1):43–52. 10.1002/em.20131.15880734
Upson K, De Roos AJ, Thompson ML, 2013. Organochlorine pesticides and risk of endometriosis: findings from a population-based case-control study. Environ Health Perspect 121(11–12):1319–1324. 10.1289/ehp.1306648.24192044
USDA. 2016. Pesticide data program. Annual summary, calendar year 2014. Washington, DC: U.S. Department of Agriculture.
USGS. 1999. The quality of our nation’s waters: Nutrients and pesticide. U.S. Geological Survey. http://water.usgs.gov/pubs/circ/circ1225/. October 7, 2004.
Vafeiadi M, Vrijheid M, Fthenou E, 2014. Persistent organic pollutants exposure during pregnancy, maternal gestational weight gain, and birth outcomes in the mother-child cohort in Crete, Greece (RHEA study). Environ Int 64:116–123. 10.1016/j.envint.2013.12.015.24389008
Vafeiadi M, Georgiou V, Chalkiadaki G, 2015. Association of prenatal exposure to persistent organic pollutants with obesity and cardiometabolic traits in early childhood: The Rhea Mother-Child Cohort (Crete, Greece). Environ Health Perspect 123(10):1015–1021. 10.1289/ehp.1409062.25910281
Vafeiadi M, Roumeliotaki T, Chalkiadaki G, 2017. Persistent organic pollutants in early pregnancy and risk of gestational diabetes mellitus. Environ Int 98:89–95. 10.1016/j.envint.2016.10.005.27743729
Valera B, Ayotte P, Poirier P, 2013a. Associations between plasma persistent organic pollutant levels and blood pressure in Inuit adults from Nunavik. Environ Int 59:282–289. 10.1016/j.envint.2013.06.019.23872387
Valera B, Jorgensen ME, Jeppesen C, 2013b. Exposure to persistent organic pollutants and risk of hypertension among Inuit from Greenland. Environ Res 122:65–73. 10.1016/j.envres.2012.12.006.23375553
Valvi D, Mendez MA, Martinez D, 2012. Prenatal concentrations of polychlorinated biphenyls, DDE, and DDT and overweight in children: A prospective birth cohort study. Environ Health Perspect 120(3):451–457. 10.1289/ehp.1103862.22027556
Valvi D, Mendez MA, Garcia-Esteban R, 2014. Prenatal exposure to persistent organic pollutants and rapid weight gain and overweight in infancy. Obesity (Silver Spring) 22(2):488–496. 10.1002/oby.20603.23963708
Valvi D, Oulhote Y, Weihe P, 2017. Gestational diabetes and offspring birth size at elevated environmental pollutant exposures. Environ Int 107:205–215. 10.1016/j.envint.2017.07.016.28753482
van den Berg H. 2009. Global status of DDT and its alternatives for use in vector control to prevent disease. Environ Health Perspect 117(11):1656–1663. 10.1289/ehp.0900785.20049114
van den Berg M, Kypke K, Kotz A, 2017. WHO/UNEP global surveys of PCDDs, PCDFs, PCBs and DDTs in human milk and benefit-risk evaluation of breastfeeding. Arch Toxicol 91(1):83–96. 10.1007/s00204-016-1802-z.27438348
Van Metre PC, Callender E. 1997. Water-quality trends in White Rock Creek Basin from 1912–1994 identified using sediment cores from White Rock Lake reservoir, Dallas, Texas. Journal of Paleolimnnology 17:239–249.
Van Metre PC, Callender E, Fuller C. 1997. Historical trends in organochlorine compounds in river basins identified using sediment cores from reservoirs. Environ Sci Technol 31:2339–2344.
van ’t Veer P, Lobbezoo IE, Martin-Moreno JM, 1997. DDT (dicophane) and postmenopausal breast cancer in Europe: case-control study. Br Med J 315:81–85.9240045
Vasiliu O, Muttineni J, Karmaus W. 2004. In utero exposure to organochlorines and age at menarche. Hum Reprod 19(7):1506–1512. 10.1093/humrep/deh292.15131079
Veith GD, DeFoe VD, Bergstedt BV. 1979. Measuring and estimating the bioconcentration factor of chemicals in fish. J Fish Res Board Can 36:1040–1048.
Velbinger H. 1947a. [On the question of DDT toxicity of man]. Dtsch Gesundheitwes 2:355–358 (German).
Velbinger H. 1947b. [Contribution to the toxicology of "DDT"-agent, dichlorodiphenyl-trichloromethylmethane]. Pharmazie 2:268–274.
Venkatesan MI, Greene GE, Ruth E, 1996. DDTs and dumpsite in the Santa Monica Basin, California. Sci Total Environ 179:61–71.
Venners SA, Korrick S, Xu X, 2005. Preconception serum DDT and pregnancy loss: a prospective study using a biomarker of pregnancy. Am J Epidemiol 162(8):709–716. 10.1093/aje/kwi275.16120699
Verhulst SL, Nelen V, Hond ED, 2009. Intrauterine exposure to environmental pollutants and body mass index during the first 3 years of life. Environ Health Perspect 117(1):122–126. 10.1289/ehp.0800003.19165398
Verma A, Pillai MK K. 1991a. Bioavailability of soil-bound residues of DDT and HCH to certain plants. Soil Biol Biochem 23(4):347–351. 10.1016/0038-0717(91)90190-U.
Verma A, Pillai MK K. 1991b. Bioavailability of soil-bound residues of DDT and HCH to earthworms. Curr Sci 61(12):840–843.
Verner MA, Charbonneau M, Lopez-Carrillo L, 2008. Physiologically based pharmacokinetic modeling of persistent organic pollutants for lifetime exposure assessment: a new tool in breast cancer epidemiologic studies. Environ Health Perspect 116(7):886–892. 10.1289/ehp.10917.18629310
Verner MA, Ayotte P, Muckle G, 2009. A physiologically based pharmacokinetic model for the assessment of infant exposure to persistent organic pollutants in epidemiologic studies. Environ Health Perspect 117(3):481–487. 10.1289/ehp.0800047.19337526
Verner MA, Sonneborn D, Lancz K, 2013. Toxicokinetic modeling of persistent organic pollutant levels in blood from birth to 45 months of age in longitudinal birth cohort studies. Environ Health Perspect 121(1):131–137. 10.1289/ehp.1205552.23086694
Verner MA, Gaspar FW, Chevrier J, 2015. Increasing sample size in prospective birth cohorts: back-extrapolating prenatal levels of persistent organic pollutants in newly enrolled children. Environ Sci Technol 49(6):3940–3948. 10.1021/acs.est.5b00322.25698216
Verschueren K. 1983. DDT. In: Handbook of environmental data on organic chemicals. 2nd ed. New York, NY: Van Nostrand Reinhold Co. Inc, 433–445.
Vested A, Ramlau-Hansen CH, Olsen SF, 2014. In utero exposure to persistent organochlorine pollutants and reproductive health in the human male. Reproduction 148(6):635–646. 10.1530/REP-13-0488.25190505
Vetter W, Luckas B, Heidemann G, 1996. Organochlorine residue in marine mammals from the Northern hemisphere-A consideration of the composition of organochlorine residues in the blubber of marine mammals. Sci Total Environ 186:29–39.8685708
Viel JF, Floret N, Deconinck E, 2011. Increased risk of non-Hodgkin lymphoma and serum organochlorine concentrations among neighbors of a municipal solid waste incinerator. Environ Int 37(2):449–453. 10.1016/j.envint.2010.11.009.21167603
Vijverberg HP, van der Zalm JM, van der Bercken J. 1982. Similar mode of action of pyrethroids and DDT on sodium channel gating in myelinated nerves. Nature 295(5850):601–603. 10.1038/295601a0.6276777
Vine MF, Stein L, Weigle K, 2000. Effects on the immune system associated with living near a pesticide dump site. Environ Health Perspect 108(12):1113–1124. 10.1289/ehp.001081113.11133390
Vine MF, Stein L, Weigle K, 2001. Plasma 1,1-dichloro-2,2-bis(p-chlorophenyl)ethylene (DDE) levels and immune response. Am J Epidemiol 153(1):53–63. 10.1093/aje/153.1.53.11159147
Vollner L, Klotz D. 1994. Behaviour of DDT under laboratory and outdoor conditions in Germany. J Environ Sci Health B 29(1):161–167.
vom Saal FS, Nagel SC, Palanza P, 1995. Estrogenic pesticides: binding relative to estradiol in MCF-7 cells and effects of exposure during fetal life on subsequent territorial behaviour in male mice. Toxicol Lett 77(1–3):343–350. 10.1016/0378-4274(95)03316–5.7618160
Waliszewski SM, Aguirre AA, Infanzon RM, 2000. Partitioning coefficients of organochlorine pesticides between mother blood serum and umbilical blood serum. Bull Environ Contam Toxicol 65:293–299.10903351
Waliszewski SM, Aguirre AA, Infanzon RM, 2001. Organochlorine pesticide levels in maternal adipose tissue, maternal blood serum, umbilical blood serum, and milk from inhabitants of Veracruz, Mexico. Arch Environ Contam Toxicol 40(3):432–438. 10.1007/s002440010194.11443377
Walker AI T, Thorpe E, Stevenson DE. 1972. The toxicology of dieldrin (HEOD). I. Long-term oral toxicity studies in mice. Food Cosmet Toxicol 11:415–432.
Wallin E, Rylander L, Jonssson BA, 2005. Exposure to CB-153 and p,p’-DDE and bone mineral density and bone metabolism markers in middle-aged and elderly men and women. Osteoporos Int 16(12):2085–2094. 10.1007/s00198-005-2004-3.16234998
Wang JS, Simpson KL. 1996. Accumulation and depuration of DDTs in the food chain from Artemia to brook trout (Salvelinus fontinalis). Bull Environ Contam Toxicol 56(6):888–895. 10.1007/s001289900129.8661872
Wania F, Mackay D. 1993. Global fractionation and cold condensation of low volatility organochlorine compounds in polar regions. Ambio 22(1):10–18.
Ward AB, Dail MB, Chambers JE. 2016. In Vitro effect of DDE exposure on the regulation of lipid metabolism and secretion in McA-RH7777 hepatocytes: A potential role in dyslipidemia which may increase the risk of type 2 diabetes mellitus. Toxicol in Vitro 37:9–14. 10.1016/j.tiv.2016.08.011.27565303
Ward EM, Schulte P, Grajewski B, 2000. Serum organochlorine levels and breast cancer: a nested case-control study of Norwegian women. Cancer Epidemiol Biomarkers Prev 9(12):1357–1367.11142422
Ware GW, Good EE. 1967. Effects of insecticides on reproduction in the laboratory mouse. II. Mirex, telodrin, and DDT. Toxicol Appl Pharmacol 10(1):54–61. 10.1016/0041-008x(67)90127-5.6031928
Ware GW, Crosby DG, Giles JW. 1980. Photodecomposition of DDA. Arch Environ Contam Toxicol 9(2):135–146. 10.1007/BF01055369.7387184
Ware GW, Estesen BJ, Buck NA, 1978. DDT moratorium in Arizona--agricultural residues after seven years. Pestic Monit J 12(1):1–3.704291
Warner M, Aguilar Schall R, Harley KG, 2013. In utero DDT and DDE exposure and obesity status of 7-year-old Mexican-American children in the CHAMACOS cohort. Environ Health Perspect 121(5):631–636. 10.1289/ehp.1205656.23512307
Warner M, Wesselink A, Harley KG, 2014. Prenatal exposure to dichlorodiphenyltrichloroethane and obesity at 9 years of age in the CHAMACOS study cohort. Am J Epidemiol 179(11):1312–1322. 10.1093/aje/kwu046.24722999
Warner M, Ye M, Harley K, 2017. Prenatal DDT exposure and child adiposity at age 12: The CHAMACOS study. Environ Res 159:606–612. 10.1016/j.envres.2017.08.050.28917205
Warner M, Rauch S, Coker ES, 2018. Obesity in relation to serum persistent organic pollutant concentrations in CHAMACOS women. Environ Epidemiol 2(4) 10.1097/EE9.0000000000000032.
Wattigney WA, Irvin-Barnwell E, Pavuk M, 2015. Regional Variation in Human Exposure to Persistent Organic Pollutants in the United States, NHANES. J Environ Public Health 2015:571839. 10.1155/2015/571839.26839572
Webber EC, Bayne DR, Seesock WC. 1989. DDT contamination of benthic macroinvertebrates and sediments from tributaries of Wheeler Reservoir, Alabama. Arch Environ Contam Toxicol 18(5):728–733. 10.1007/BF01225010.2802676
Weihe P, Steuerwald U, Taheri S, 2003. The human health programme in the Faroe Islands 1985–2001. In: AMAP Greenland and the Faroe Islands 1997–2001 Copenhagen: Danish Environmental Protection Agency, 135–212.
Weisskopf MG, Anderson HA, Hanrahan LP, 2005. Maternal exposure to Great Lakes sport-caught fish and dichlorodiphenyl dichloroethylene, but not polychlorinated biphenyls, is associated with reduced birth weight. Environ Res 97(2):149–162. 10.1016/j.envres.2004.01.014.15533331
Weisskopf MG, Knekt P, O’Reilly EJ, 2010. Persistent organochlorine pesticides in serum and risk of Parkinson disease. Neurology 74(13):1055–1061. 10.1212/WNL.0b013e3181d76a93.20350979
Weistrand C, Norén K. 1997. Methylsulfonyl metabolites of PCBs and DDE in human tissues. Environ Health Perspect 105(6):644–649. 10.1289/ehp.97105644.9288499
Weistrand C, Norén K. 1998. Polychlorinated naphthalenes and other organochlorine contaminants in human adipose and liver tissue. J Toxicol Environ Health A 53(4):293–311. 10.1080/009841098159295.9490327
Welch RM, Levin W, Conney AH. 1969. Estrogenic action of DDT and its analogs. Toxicol Appl Pharmacol 14(2):358–367. 10.1016/0041-008x(69)90117-3.5772860
Welfinger-Smith G, Minholz JL, Byrne S, 2011. Organochlorine and metal contaminants in traditional foods from St. Lawrence Island, Alaska. J Toxicol Environ Health A 74(18):1195–1214. 10.1080/15287394.2011.590099.21797772
Wessel JR, Yess NJ. 1991. Pesticide residues in food imported into the USA. Rev Environ Contam Toxicol 120:83–104.1994461
Wester RC, Maibach HI, Bucks DA, 1990. Percutaneous absorption of [14C]DDT and [14C]benzo[a]pyrene from soil. Fundam Appl Toxicol 15(3):510–516.2258015
Whitehead TP, Crispo Smith S, Park JS, 2015. Concentrations of persistent organic pollutants in California children’s whole blood and residential dust. Environ Sci Technol 49(15):9331–9340. 10.1021/acs.est.5b02078.26147951
Whitmore RW, Immerman FW, Camann DE, 1994. Non-occupational exposures to pesticides for residents of two U.S. cities. Arch Environ Contam Toxicol 26:47–59.8110023
WHO. 1979. DDT and its derivatives. Geneva, Switzerland: World Health Organization. Environmental Health Criteria 9. https://wedocs.unep.org/20.500.11822/29274. August 10, 2021.
WHO. 2000. Pesticide residues in food. Report of the 2000 FAO/WHO joint meeting of experts. Geneva, Switzerland: World Health Organization.
WHO. 2004. DDT and its derivatives in drinking-water. Background document for development of WHO guidelines for drinking-water quality. Geneva, Switzerland: World Health Organization. WHO/SDE/WSH/03.04/89.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. January 08, 2014.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
Wickstrom K, Pyysalo H, Siimes MA. 1983. Levels of chlordane, hexachlorobenzene, PCB and DDT compounds in Finnish human milk in 1982. Bull Environ Contam Toxicol 31(3):251–256. 10.1007/BF01608694.6414557
Williams G, Weisburger J. 1991. Chemical carcinogens. In: Amdur MO, Doull J, Klaasen CD, eds. Casarett and Doull’s toxicology: The basic science of poisons. 4th ed. New York, NY: Pergamon Press, 127–200.
Wilson ND, Shear NM, Paustenbach DJ, 1998. The effect of cooking practices on the concentration of DDT and PCB compounds in the edible tissue of fish. J Expo Anal Environ Epidemiol 8(3):423–440.9679221
Windham GC, Lee D, Mitchell P, 2005. Exposure to organochlorine compounds and effects on ovarian function. Epidemiology 16(2):182–190. 10.1097/01.ede.0000152527.24339.17.15703532
Wojtyniak BJ, Rabczenko D, Jonsson BA, 2010. Association of maternal serum concentrations of 2,2’, 4,4’5,5’-hexachlorobiphenyl (CB-153) and 1,1-dichloro-2,2-bis (p-chlorophenyl)-ethylene (p,p’-DDE) levels with birth weight, gestational age and preterm births in Inuit and European populations. Environ Health 9:56. 10.1186/1476-069X-9-56.20819217
Wolfe HR, Armstrong JF. 1971. Exposure of formulating plant workers to DDT. Arch Environ Health 23(3):169–176. 10.1080/00039896.1971.10665981.5123149
Wolfe MF, Seiber JN. 1993. Environmental activation of pesticides. Occup Med 8(3):561–573.8272979
Wolfe JL, Esher RJ, Robinson KM, 1979. Lethal and reproductive effects of dietary mirex and DDT in old-field mice, Peromyscus polionotus. Bull Environ Contam Toxicol 21:397–402.444732
Wolff MS, Toniolo PG, Lee EW, 1993. Blood levels of organochlorine residues and risk of breast cancer. J Natl Cancer Inst 85(8):648–652. 10.1093/jnci/85.8.648.8468722
Wolff MS, Berkowitz GS, Brower S, 2000a. Organochlorine exposures and breast cancer risk in New York City women. Environ Res 84(2):151–161.11068929
Wolff MS, Zeleniuch-Jacquotte A, Dubin N, 2000b. Risk of breast cancer and organochlorine exposure. Cancer Epidemiol Biomarkers Prev 9:271–277.10750665
Wolff MS, Engel S, Berkowitz G, 2007. Prenatal pesticide and PCB exposures and birth outcomes. Pediatr Res 61(2):243–250. 10.1203/pdr.0b013e31802d77f0.17237730
Wong O, Brocker W, Davis HV, 1984. Mortality of workers potentially exposed to organic and inorganic brominated chemicals, DBCP, TRIS, PBB, and DDT. Br J Ind Med 41(1):15–24. 10.1136/oem.41.1.15.6318800
Wood SL, Jarrell JJ, Swaby C, 2007. Endocrine disruptors and spontaneous premature labor: a case control study. Environ Health 6:35. 10.1186/1476-069X-6-35.18005447
Woodwell G, Craig P, Johnson H. 1971. DDT in the biosphere: Where does it go? Science 174:1101–1107.5133727
Woolley DE, Talens GM. 1971. Distribution of DDT, DDD, and DDE in tissues of neonatal rats and in milk and other tissues of mother rats chronically exposed to DDT. Toxicol Appl Pharmacol 18(4):907–916. 10.1016/0041-008x(71)90238-9.5570242
WQP. 2017. DDT, DDE, and DDD Water Quality Portal, Water quality data. Advisory Committee on Water Information (ACWI); Agricultural Research Service (ARS); Environmental Protection Agency (EPA); National Water Quality Monitoring Council (NWQMC); United States Geological Survey (USGS). https://www.waterqualitydata.us/portal/. January 9, 2018.
Wrenn TR, Weyant JR, Fries GF, 1971. Effect of several dietary levels of o,p’-DDT on reproduction and lactation in the rat. Bull Environ Contam Toxicol 6(5):471–480.5153787
Wu Y, Foster WG, Younglai EV. 2006. Rapid effects of pesticides on human granulosa-lutein cells. Reproduction 131(2):299–310. 10.1530/rep.1.00922.16452723
Wu H, Bertrand KA, Choi AL, 2013. Persistent organic pollutants and type 2 diabetes: a prospective analysis in the nurses’ health study and meta-analysis. Environ Health Perspect 121(2):153–161. 10.1289/ehp.1205248.23131992
Wu HC, Cohn BA, Cirillo PM, 2020. DDT exposure during pregnancy and DNA methylation alterations in female offspring in the Child Health and Development Study. Reprod Toxicol 92:138–147. 10.1016/j.reprotox.2019.02.010.30822522
Xiong X, Wang A, Liu G, 2006. Effects of p,p’-dichlorodiphenyldichloroethylene on the expressions of transferrin and androgen-binding protein in rat Sertoli cells. Environ Res 101(3):334–339. 10.1016/j.envres.2005.11.003.16380112
Xu X, Dailey AB, Talbott EO, 2010. Associations of serum concentrations of organochlorine pesticides with breast cancer and prostate cancer in U.S. adults. Environ Health Perspect 118(1):60–66. 10.1289/ehp.0900919.20056587
Yaglova NV, Yaglov VV. 2014. Changes in thyroid status of rats after prolonged exposure to low dose dichlorodiphenyltrichloroethane. Bull Exp Biol Med 156(6):760–762. 10.1007/s10517-014-2443-y.24824690
Yaglova NV, Yaglov VV. 2015a. Altered thyroid hormone production induced by long-term exposure to low doses of the endocrine disruptor dichlorodiphenyltrichloroethane. Biochem Suppl Ser B: Biomed Chem 9(4):339–342. 10.1134/s1990750815040083.
Yaglova NV, Yaglov VV. 2015b. Mechanisms of disruptive action of dichlorodiphenyltrichloroethane (DDT) on the function of thyroid follicular epitheliocytes. Bull Exp Biol Med 160(2):231–233. 10.1007/s10517-015-3136-x.26621281
Yaglova NV, Yaglov VV. 2017. Cytophysiological changes in the follicular epithelium of the thyroid gland after long-term exposure to low doses of dichlorodiphenyltrichloroethane (DDT). Bull Exp Biol Med 162(5):699–702. 10.1007/s10517-017-3691-4.28361414
Yaglova NV, Timokhina EP, Yaglov VV. 2013. Effects of low-dose dichlorodiphenyltrichloroethane on the morphology and function of rat thymus. Bull Exp Biol Med 155(5):701–704. 10.1007/s10517-013-2230-1.24288744
Yaglova NV, Sledneva YP, Yaglov VV. 2016. Morphofunctional changes in the thyroid gland of pubertal and postpubertal rats exposed to low dose of DDT. Bull Exp Biol Med 162(2):260–263. 10.1007/s10517-016-3590-0.27905040
Yaglova NV, Tsomartova DA, Yaglov VV. 2017. Effect of prenatal and postnatal exposure to low doses of DDT on catecholamine secretion in rats in different period of ontogeny. Bull Exp Biol Med 163(4):422–424. 10.1007/s10517-017-3819-6.28853094
Yaglova NV, Tsomartova DA, Obernikhin SS, 2018. Changes in secretory activity of adrenal zona fasciculata cells in pubertal rats exposed to low doses of DDT in different periods of ontogeny. Bull Exp Biol Med 166(2):283–286. 10.1007/s10517-018-4333-1.30488200
Yaglova NV, Tsomartova ES, Obernikhin SS, 2020. Developmental exposure to low doses of dichlorodiphenyltrichloroethane impairs proliferative response of thymic lymphocytes to Concanavalin A in rats. Heliyon 6(3):e03608. 10.1016/j.heliyon.2020.e03608.32195406
Yamasaki K, Okuda H, Takeuchi T, 2009. Effects of in utero through lactational exposure to dicyclohexyl phthalate and p,p’-DDE in Sprague-Dawley rats. Toxicol Lett 189(1):14–20. 10.1016/j.toxlet.2009.04.023.19410640
Yan M, Shi Y, Wang Y, 2013. Effects of p,p’-DDE on the mRNA and protein expressions of vimentin, N-cadherin and FSHR in rats testes: an in vivo and in vitro study. Environ Toxicol Pharmacol 35(3):486–494. 10.1016/j.etap.2013.02.008.23501609
Yanez L, Borja-Aburto VH, Rojas E, 2004. DDT induces DNA damage in blood cells. Studies in vitro and in women chronically exposed to this insecticide. Environ Res 94(1):18–24. 10.1016/s0013-9351(03)00047-1.14643282
Ye M, Beach J, Martin JW, 2015. Association between lung function in adults and plasma DDT and DDE levels: results from the Canadian Health Measures Survey. Environ Health Perspect 123(5):422–427. 10.1289/ehp.1408217.25536373
Yess NJ, Gunderson EL, Roy RR. 1993. U.S. Food and Drug Administration monitoring of pesticide residues in infant foods and adult foods eaten by infants/children. J AOAC Int 76(3):492–507.8318840
You L, Brenneman KA, d’A HH. 1999a. In utero exposure to antiandrogens alters the responsiveness of the prostate to p,p’-DDE in adult rats and may induce prostatic inflammation. Toxicol Appl Pharmacol 161:258–266.10620483
You L, Casanova M, Archibeque-Engle S, 1998. Impaired male sexual development in perinatal Sprague-Dawley and Long-Evans hooded rats exposed in utero and lactationally to p,p’-DDE. Toxicol Sci 45(2):162–173. 10.1093/toxsci/45.2.162.9848123
You L, Gazi E, Archibeque-Engle S, 1999b. Transplacental and lactational transfer of p,p’-DDE in Sprague-Dawley rats. Toxicol Appl Pharmacol 157:134–144.10366546
You L, Chan SK, Bruce JM, 1999c. Modulation of testosterone-metabolizing hepatic cytochrome P-450 enzymes in developing Sprague-Dawley rats following in utero exposure to p,p’-DDE. Toxicol Appl Pharmacol 158:197–205.10406934
Younglai EV, Kwan TK, Kwan CY, 2004a. Dichlorodiphenylchloroethylene elevates cytosolic calcium concentrations and oscillations in primary cultures of human granulosa-lutein cells. Biol Reprod 70(6):1693–1700. 10.1095/biolreprod.103.026187.14766722
Younglai EV, Holloway AC, Lim GE, 2004b. Synergistic effects between FSH and 1,1-dichloro-2,2-bis(P-chlorophenyl)ethylene (P,P’-DDE) on human granulosa cell aromatase activity. Hum Reprod 19(5):1089–1093. 10.1093/humrep/deh252.15070871
Zeng E, Yu C, Tran K. 1999. In situ measurements of chlorinated hydrocarbons in the water column off the Palos Verdes Peninsula, California. Environ Sci Technol 33:392–398.
Zepp RG, Wolfe NL, Azarraga LV, 1977. Photochemical transformation of the DDT and methoxychlor degradation products, DDE and DMDE, by sunlight. Arch Environ Contam Toxicol 6(2–3):305–314. 10.1007/BF02097771.901009
Zhang X, Wu X, Lei B, 2018. Transplacental transfer characteristics of organochlorine pesticides in paired maternal and cord sera, and placentas and possible influencing factors. Environ Pollut 233:446–454. 10.1016/j.envpol.2017.10.075.29100182
Zhao B, Shen H, Liu F, 2012. Exposure to organochlorine pesticides is an independent risk factor of hepatocellular carcinoma: a case-control study. J Expo Sci Environ Epidemiol 22(6):541–548. 10.1038/jes.2011.29.21915153
Zheng T, Holford TR, Mayne ST, 1999. DDE and DDT in breast adipose tissue and risk of female breast cancer. Am J Epidemiol 150(5):453–458. 10.1093/oxfordjournals.aje.a010033.10472944
Zheng T, Holford TR, Mayne ST, 2000. Risk of female breast cancer associated with serum polychlorinated biphenyls and 1,1-dichloro-2,2’-bis(p-chlorophenyl)ethylene. Cancer Epidemiol Biomarkers Prev 9(2):167–174.10698477
Zong G, Valvi D, Coull B, 2018. Persistent organic pollutants and risk of type 2 diabetes: A prospective investigation among middle-aged women in Nurses’ Health Study II. Environ Int 114:334–342. 10.1016/j.envint.2017.12.010.29477570
Zook C, Feng J. 1999. 1,1,1-trichloro-2,2-bis-(4’-chlorophenyl)ethane (DDT) pathway map. University of Minnesota. http://www.labmed.umn.edu/umbdd/ddt/ddt_map.html. June 23, 1999.
Zuk AM, Tsuji LJ S, Nieboer E, 2019. Examining environmental contaminant mixtures among adults with type 2 diabetes in the Cree First Nation communities of Eeyou Istchee, Canada. Sci Rep 9(1):15909. 10.1038/s41598-019-52200-x.31685843