# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding DDT, DDE, and DDD in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for DDT, DDE, and DDD.

Table 7-1 Regulations and Guidelines Applicable to DDT, DDE, and DDD

Agency | Description | Information | Reference
Air
EPA | RfC | No data | IRIS 2002a, 2002b, 2003
WHO | Air quality guidelines | No data | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | Not listed | EPA 2018a
| National primary drinking water regulations | Not listed | EPA 2009
| RfD | | IRIS 2002a
| p,p’-DDT | 5×10^−4^ mg/kg/day
| Provisional peer reviewed toxicity value
| p,p’-DDE | | EPA 2017c
| Provisional subchronic RfD | 3×10^−4^ mg/kg/day
| p,p’-DDD | | EPA 2017b
| Screening provisional subchronic RfD | 3×10^−5^ mg/kg/day
| Screening provisional chronic RfD | 3×10^−5^ mg/kg/day
WHO | Drinking water quality guidelines for DDT and metabolites | | WHO 2017
| Guideline value | 0.001 mg/L (1 μg/L)
| Provisional tolerable daily intake | 0.01 mg/kg-body weight
FDA | Substances added to food^a^ | Not listed | FDA 2021
Cancer
HHS | Carcinogenicity classification | | NTP 2016
| DDT | Reasonably anticipated to be a human carcinogen
EPA | Carcinogenicity classification | | IRIS 2002a, 2002b, 2003
| p,p’-DDT, p,p’-DDE, p,p’-DDD | Group B2^b^ | IRIS 2002a, 2002b, 2003
| Oral slope factor
| p,p’-DDT | 3.4×10^−1^ per mg/kg/day | IRIS 2002a
| p,p’-DDE | 3.4×10^−1^ per mg/kg/day | IRIS 2003
| p,p’-DDD | 2.4×10^−1^ per mg/kg/day | IRIS 2002b
| Inhalation unit risk
| p,p’-DDT | 9.7×10^−5^ per μg/m^3^ ^c^ | IRIS 2002a
IARC | Carcinogenicity classification | | IARC 2018
| DDT | Group 2A^d^
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards, and construction | | OSHA 2020a, 2020b, 2020c
| DDT | 1 mg/m^3^ ^e^
NIOSH | REL (up to 10-hour TWA) | | NIOSH 2016
| DDT | 0.5 mg/m^3^ ^f^
| IDLH | | NIOSH 2014
| DDT | 500 mg/m^3^ ^f^
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2018a
DOE | PACs-air | | DOE 2018b
| DDT
| PAC-1^g^ | 3 mg/m^3^
| PAC-2^g^ | 34 mg/m^3^
| PAC-3^g^ | 210 mg/m^3^
| DDE
| PAC-1^g^ | 6.5 mg/m^3^
| PAC-2^g^ | 72 mg/m^3^
| PAC-3^g^ | 170 mg/m^3^
| DDD
| PAC-1^g^ | 2.4 mg/m^3^
| PAC-2^g^ | 26 mg/m^3^
| PAC-3^g^ | 160 mg/m^3^

a The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited from use in food, delisted color additives, and some substances “no longer FEMA GRAS.”

b Group B2: probable human carcinogen.

c The unit risk should not be used if the air concentration exceeds 1×10^2^ μg/m^3^, since above this concentration the unit risk may not be appropriate.

d Group 2A: probably carcinogenic to humans.

e Skin designation.

f Potential occupational carcinogen.

g Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018a).

AEGL = acute exposure guideline levels; DDD = dichlorodiphenyldichloroethane; DDE = dichlorodiphenyldichloroethylene; DDT = dichlorodiphenyltrichloroethane; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association of the United States; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = Protective Action Criteria; PEL = permissible exposure limit; rEl = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; WHO = World Health Organization