# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

When we refer to DDT, we are generally referring to p,p’-DDT, which was produced and used for its insecticidal properties. However, technical-grade DDT, the grade that was generally used as an insecticide, was composed of up to 14 chemical compounds, of which only 65–80% was the active ingredient, p,p’-DDT. The other components included 15–21% of the nearly inactive o,p’-DDT, up to 4% of p,p’-DDD, and up to 1.5% of 1-(p-chlorophenyl)-2,2,2-trichloroethanol (Metcalf 1995).

The chemical formulas, structures, and identification numbers for p,p’-DDT, p,p’-DDE, p,p’-DDD, o,p’-DDT, o,p’-DDE, and o,p’-DDD are listed in Table 4-1. The latter five compounds are either impurities or metabolites of technical DDT.

Table 4-1 Chemical Identity of p,p’- and o,p’-DDT, DDE, and DDD^a^

Characteristic | Information
Chemical name | p,p’-DDT | p,p’-DDE | p,p’-DDD
Synonym(s) and registered trade names | 4,4’-DDT; 1,1,1-trichloro-2,2-bis(p-chlorophenyl) ethane; dichlorodiphenyltrichloroethane; DDT; 1,1’-(2,2,2-trichloroethylidene) bis(4-chlorobenzene); α-α-bis(p-chlorophenyl)-β,β,β-trichloroethane; Genitox; Anofex; Detoxan; Neocid; Gesarol; Pentachlorin; Dicophane; Chlorophenothane^b^ | 4,4’-DDE; dichlorodiphenyldichloroethane; 1,1-dichloro-2,2-bis (p-chlorophenyl) ethylene; 1,1’-(2,2-dichloroethylidene) bis(4-chlorobenzene); DDE | 4,4’-DDD; dichlorodiphenyldichloroethane; DDD; 1,1 -dichloro-2,2-bis(p-chlorophenyl) ethane; 1,1-bis(4-chlorophenyl)-2,2-dichloroethane; TDE; tetrachlorodiphenylethane; DDD; Rothane; Dilene; TDE
Characteristic | Information
Chemical formula | C_14_H_9_Cl_5_ | C_14_H_8_Cl_4_ | C_14_H_10_Cl_4_
Chemical structure | [image] | [image] | [image]
CAS Registry Number | 50-29-3 | 72-55-9 | 72-54-8
Chemical name | o,p’-DDT | o,p’-DDE | o,p’-DDD
Synonym(s) and registered trade names | 2,4’-DDT; 1,1,1-trichloro-2-(o-chlorophenyl)-2-(p-chlorophenyl)ethane; o,p’-dichlorodiphenyltrichloroethane | 2,4’-DDE; 1,1-dichloro-2-(o-chlorophenyl)-2-(p-chlorophenyl) ethylene; 1-chloro-2-(2,2-dichloro-1-(4-chlorophenyl)ethenylbenzene | 2,4’-DDD; Mitotane; o,p’-DDD; 1,1-dichloro-2-(o-chlorophenyl)-2-(p-chlorophenyl)ethane; o,p’-TDE; Choditane; 2-(o-chlorophenyl)-2-(p-chlorophenyl; Lysodren
Chemical formula | C14H9Cl5 | C14H8Cl4 | C14H10Cl4
Chemical structure | [image] | [image] | [image]
CAS Registry Number | 789-02-6 | 3424-82-6 | 53-19-0

a Howard and Neal (1992) except where noted.

b Klassen et al. 1991.

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Technical DDT is a white amorphous powder that melts over the range of 80–94°C (Metcalf 1995). Physical and chemical properties of p,p’-DDT, p,p’-DDE, p,p’-DDD, o,p’-DDT, o,p’-DDE, and o,p’-DDD are listed in Table 4-2.

Table 4-2 Physical and Chemical Properties of p,p’- and o,p’-DDT, DDE, and DDD^a^

Property | p,p’-DDT | p,p’-DDE | p,p’-DDD
Molecular weight | 354.5 | 318.03^b^ | 320.05^b^
Color | Colorless crystals | White | Colorless crystals, white powder
Physical state | Solid | Crystalline solid | Solid
Melting point | 108.5–109°C | 89°C^b^ | 109–110°C^b^
Boiling point | Decomposes; 185–187 at 0.05 mmHg | 336°C^b^ | 350°C^b^
Density at 20°C | 1.56 g/cm^3^ | No data | 1.385 g/cm^3^
Odor | Odorless or weak aromatic odor^c^ | No data | Odorless
Odor threshold:
Water | 0.35 mg/kg^d^ | No data | No data
Air | No data | No data | No data
Solubility:
Water | 0.025 mg/L at 25°C^b^ | 0.12 mg/L at 25°C^b^ | 0.05 mg/L at 25°C
Organic solvents | 1,000 g/L in cyclohexane and dioxane; 850 g/L in dichloromethane; 770 g/L in benzene; 600 g/L in xylene; 50 g/L in acetone; 470 g/L in carbon tetrachloride; 310 g/L in chloroform; 270 g/L in diethyl ether; 60g/L in ethanol; 40 g/L in methanol | Lipids and most organic solvents | No data
Partition coefficients:
Log K_ow_ | 6.91^b^ | 6.51^b^ | 6.02^b^
Log K_oc_ | 5.18^e^ | 4.70^f^ | 5.180
Vapor pressure at 20°C | 1.60×10^−7^, torr^b^ | 6.0×10^−6^ at 25°C, torr^b^ | 1.35×10^−6^ at 25°C, torr^b^
Henry’s law constant at 25°C | 8.3×10^−6^ atm-m^3^/mol^b^ | 2.1×10^−5^ atm-m^3^/mol^b^ | 4.0×10−6 atm-m^3^/mol^b^
Autoignition temperature | No data | No data | No data
Flashpoint | 72.2–77.2 °C | No data | No data
Flammability limits | No data | No data | No data
Conversion factors
Ppm (v/v) to mg/m^3^ in air at 20°C | Not applicable^h^ | Not applicable^h^ | Not applicable^h^
mg/m^3^ to ppm (v/v) in air at 20°C | Not applicable | Not applicable | Not applicable
Explosive limits | No data | No data | No data
Property | o,p’-DDT | o,p’-DDE | o,p’-DDD
Molecular weight | 354.49^b^ | 318.03^b^ | 320.05^b^
Color | White crystalline powder^d^ | No data | No data
Physical state | Solid | No data | Solid
Melting point | 74.2°C^c^ | No data | 76–78°C
Boiling point | No data | No data | No data
Density at 20°C | 0.98–0.99 g/cm^3^ | No data | No data
Odor | Odorless or weak aromatic odor^c^ | No data | No data
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water | 0.085 mg/L at 25°C^b^ | 0.14 mg/L at 25°C | 0.1 mg/L at 25°C^b^
Organic solvents | No data^j^ | No data^j^ | Soluble in ethanol, isooctane, carbon tetrachloride^h^
Partition coefficients:
Log K_ow_ | 6.79^e^ | 6.00^b^ | 5.87^b^
Log K_oc_ | 5.35^g^ | 5.19^g^ | 5.19^g^
Vapor pressure at 20°C | 1.1×10^−7^, torr^b^ | 6.2×10^−6^ at 25°C, torr^b^ | 1.94×10^−6^ at 30°C, torr^b^
Henry’s law constant at 25°C | 5.9×10^−7^ atm-m^3^/mol^b^ | 1.8×10^−5^ atm-m^3^/mol^b^ | 8.17×10^−6^ atm-m^3^/mol^b^
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability limits | No data | No data | No data
Conversion factors
ppm (v/v) to mg/m^3^ in air at 20°C | Not applicable^h^ | Not applicable^h^ | Not applicable^h^
mg/m^3^ to ppm (v/v) in air at 20°C | Not applicable | Not applicable | Not applicable
Explosive limits | No data | No data | No data

a Macbean 2011, unless otherwise noted.

b Howard and Meylan 1997.

c Sax 1979.

d Verschueren 1983.

e Swann et al. 1981.

f Sabljic 1984.

g Meylan et al. 1992 (values estimated from a fragment constant method).

h Exists partially in particulate form in air. Conversion factors are only applicable for compounds that are entirely in the vapor phase.