# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR DDT, DDE, and DDD

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to DDT, DDE, and DDD.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen was conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for DDT, DDE, and DDD. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of DDT, DDE, and DDD have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of DDT, DDE, and DDD are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Health Effects
Species
Human
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
Health outcome
Death
Systemic effects
Body weight effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects
Renal effects
Dermal effects
Ocular effects
Endocrine effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Other noncancer effects
Cancer
Toxicokinetics
Absorption
Distribution
Metabolism
Excretion
PBPK models
Biomarkers
Biomarkers of exposure
Biomarkers of effect
Interactions with other chemicals
Potential for human exposure
Releases to the environment
Air
Water
Soil
Environmental fate
Transport and partitioning
Transformation and degradation
Environmental monitoring
Air
Water
Sediment and soil
Other media
Biomonitoring
General populations
Occupation populations

### B.1.1 Literature Search

The current literature search was intended to update the draft toxicological profile for DDT, DDE, and DDD released for public comment in 2019; thus, the literature search was restricted to studies published between November 2015 and April 2020. The following main databases were searched in April 2020:

- PubMed
- National Technical Reports Library (NTRL)
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for DDT, DDE, and DDD. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to DDT, DDE, and DDD were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
04/2020 | ((((“DDT/toxicity”[mh] OR “DDT/adverse effects”[mh] OR “DDT/poisoning”[mh] OR “DDT/pharmacokinetics”[mh]) OR (“DDT”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“DDT”[mh] AND toxicokinetics[mh:noexp]) OR (“DDT/blood”[mh] OR “DDT/cerebrospinal fluid”[mh] OR “DDT/urine”[mh]) OR (“DDT”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“DDT”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“DDT/antagonists and inhibitors”[mh]) OR (“DDT/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“DDT”[mh] AND cancer[sb]) OR (“DDT/pharmacology”[majr] AND (to[sh] OR po[sh] OR ae[sh] OR pk[sh] OR (me[sh] AND (“humans”[mh] OR “animals”[mh])) OR ci[sh] OR bl[sh] OR cf[sh] OR ur[sh]))) OR ((“dichlorodiphenyl dichloroethylene/toxicity”[mh] OR “dichlorodiphenyl dichloroethylene/adverse effects”[mh] OR “dichlorodiphenyl dichloroethylene/poisoning”[mh] OR “dichlorodiphenyl dichloroethylene/pharmacokinetics”[mh]) OR (“dichlorodiphenyl dichloroethylene”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“dichlorodiphenyl dichloroethylene”[mh] AND toxicokinetics[mh:noexp]) OR (“dichlorodiphenyl dichloroethylene/blood”[mh] OR “dichlorodiphenyl dichloroethylene/cerebrospinal fluid”[mh] OR “dichlorodiphenyl dichloroethylene/urine”[mh]) OR (“dichlorodiphenyl dichloroethylene”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“dichlorodiphenyl dichloroethylene”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (rna[mh] OR dna[mh])) OR “rna, messenger”[mh] OR “rna, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“dichlorodiphenyl dichloroethylene/antagonists and inhibitors”[mh]) OR (“dichlorodiphenyl dichloroethylene/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“dichlorodiphenyl dichloroethylene”[mh] AND cancer[sb]) OR (“dichlorodiphenyl dichloroethylene/pharmacology”[majr] AND (to[sh] OR po[sh] OR ae[sh] OR pk[sh] OR (me[sh] AND (“humans”[mh] OR “animals”[mh])) OR ci[sh] OR bl[sh] OR cf[sh] OR ur[sh])) OR (“Dichlorodiphenyldichloroethane/toxicity”[mh] OR “Dichlorodiphenyldichloroethane/adverse effects”[mh] OR “Dichlorodiphenyldichloroethane/poisoning”[mh] OR “Dichlorodiphenyldichloroethane/pharmacokinetics”[mh]) OR (“Dichlorodiphenyldichloroethane”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“Dichlorodiphenyldichloroethane”[mh] AND toxicokinetics[mh:noexp]) OR (“Dichlorodiphenyldichloroethane/blood”[mh] OR “Dichlorodiphenyldichloroethane/cerebrospinal fluid”[mh] OR “Dichlorodiphenyldichloroethane/urine”[mh]) OR (“Dichlorodiphenyldichloroethane”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Dichlorodiphenyldichloroethane”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (rna[mh] OR dna[mh])) OR “rna, messenger”[mh] OR “rna, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Dichlorodiphenyldichloroethane/antagonists and inhibitors”[mh]) OR (“Dichlorodiphenyldichloroethane/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Dichlorodiphenyldichloroethane”[mh] AND cancer[sb]) OR (“Dichlorodiphenyldichloroethane/pharmacology”[majr] AND (to[sh] OR po[sh] OR ae[sh] OR pk[sh] OR (me[sh] AND (“humans”[mh] OR “animals”[mh])) OR ci[sh] OR bl[sh] OR cf[sh] OR ur[sh])) OR (“Mitotane/toxicity”[mh] OR “Mitotane/adverse effects”[mh] OR “Mitotane/poisoning”[mh] OR “Mitotane/pharmacokinetics”[mh]) OR (“Mitotane”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“Mitotane”[mh] AND toxicokinetics[mh:noexp]) OR (“Mitotane/blood”[mh] OR “Mitotane/cerebrospinal fluid”[mh] OR “Mitotane/urine”[mh]) OR (“Mitotane”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Mitotane”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (rna[mh] OR dna[mh])) OR “rna, messenger”[mh] OR “rna, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Mitotane/antagonists and inhibitors”[mh]) OR (“Mitotane/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Mitotane”[mh] AND cancer[sb]) OR (“Mitotane/pharmacology”[majr] AND (to[sh] OR po[sh] OR ae[sh] OR pk[sh] OR (me[sh] AND (“humans”[mh] OR “animals”[mh])) OR ci[sh] OR bl[sh] OR cf[sh] OR ur[sh])) OR (“2,2-(2-chlorophenyl-4’-chlorophenyl)-1,1-dichloroethene”[nm])))) AND (2016/11/01:3000[mhda] OR 2016/11/01:3000[crdt] OR 2016/11/01:3000[edat] OR 2015/11/01:3000[dp]); ((“(o-Chlorophenyl)-1-(p-chlorophenyl)-2,2,2-trichloroethane”[tw] OR “1-(2-Chlorophenyl)-1-(4-chlorophenyl)-2,2,2-trichloroethane”[tw] OR “1-(2’-Chlorophenyl)-1-(4’-chlorophenyl)-2,2-dichloroethane”[tw] OR “1-(2-Chlorophenyl)-1-(4-chlorophenyl)-2,2-dichloroethane”[tw] OR “1-(2-Chlorophenyl)-1-(4-chlorophenyl)-2,2-dichloroethylene”[tw] OR “1-(o-Chlorophenyl)-1-(p-chlorophenyl)-2,2-dichloroethane”[tw] OR “1,1’-(2,2,2-Trichloroethylidene)bis(4-chlorobenzene)”[tw] OR “1,1’-(2,2-Dichloroethylidene)bis(4-chlorobenzene)”[tw] OR “1,1’-(Dichloroethenylidene)bis(4-chlorobenzene)”[tw] OR “1,1,1-Trichloro-2-(o-chlorophenyl)-2-(p-chlorophenyl)ethane”[tw] OR “1,1,1-Trichloro-2-(p-chlorophenyl)-2-(o-chlorophenyl)ethane”[tw] OR “1,1,1-Trichloro-2,2-bis (p-chlorophenyl)ethane”[tw] OR “1,1,1-Trichloro-2,2-bis(4,4’-dichlorodiphenyl)ethane”[tw] OR “1,1,1-Trichloro-2,2-bis(4-chlorophenyl) ethane”[tw] OR “1,1,1-Trichloro-2,2-bis(4-chlorophenyl)ethane”[tw] OR “1,1,1-Trichloro-2,2-bis(p-chlorophenyl)ethane”[tw] OR “1,1,1-Trichloro-2,2-di(4-chlorophenyl)-ethane”[tw] OR “1,1,1-Trichloro-2,2-di(p-chlorophenyl)ethane”[tw] OR “1,1,1-Trichloro-2-2,2-bis(p-chlorophenyl)ethane”[tw] OR “1,1-Bis(4-chlorophenyl)-2,2,2-trichloroethane”[tw] OR “1,1-Bis(4-chlorophenyl)-2,2-dichloroethane”[tw] OR “1,1-Bis(4-chlorophenyl)-2,2-dichloroethene”[tw] OR “1,1-Bis(p-chlorophenyl)-2,2,2-trichloroethane”[tw] OR “1,1-Bis-(p-chlorophenyl)-2,2,2-trichloroethane”[tw] OR “1,1-Bis(p-chlorophenyl)-2,2-dichloroethane”[tw] OR “1,1-Bis(p-chlorophenyl)-2,2-dichloroethylene”[tw] OR “1,1-Dichloro-2-(o-chlorophenyl)-2-(p-chlorophenyl)ethane”[tw] OR “1,1-Dichloro-2-(o-chlorophenyl)-2-(p-chlorophenyl)ethene”[tw] OR “1,1-Dichloro-2-(o-chlorophenyl)-2-(p-chlorophenyl)ethylene”[tw] OR “1,1-Dichloro-2-(p-chlorophenyl)-2-(o-chlorophenyl)ethane”[tw] OR “1,1-Dichloro-2,2-bis(2,4’-dichlorophenyl)ethane”[tw] OR “1,1’-Dichloro-2,2-bis(4-chlorophenyl)ethane”[tw] OR “1,1-Dichloro-2,2-bis(4-chlorophenyl)ethane”[tw] OR “1,1-Dichloro-2,2-bis(para-chlorophenyl) ethylene”[tw] OR “1,1-Dichloro-2,2-bis(parachlorophenyl)ethane”[tw] OR “1,1-Dichloro-2,2-bis(p-chlorophenyl)ethane”[tw] OR “1,1-Dichloro-2,2-bis(p-chlorophenyl)ethene”[tw] OR “1,1-Dichloro-2,2-bis(p-chlorophenyl)ethylene”[tw] OR “1,1-Dichloro-2,2-di(4-chlorophenyl)ethane”[tw] OR “1,1-Dichloro-2,2-di(p-chlorophenyl)ethylene”[tw] OR “1,1-Dichloroethylididenebis(4-chlorobenzene)”[tw] OR “1-Chloro-2-(2,2,2-trichloro-1-(4-chlorophenyl)ethyl)benzene”[tw] OR “1-Chloro-2-(2,2-dichloro-1-(4-chlorophenyl)ethyl)benzene”[tw] OR “2-(2-Chlorophenyl)-2-(4-chlorophenyl)-1,1,1-trichloroethane”[tw] OR “2-(2-Chlorophenyl)-2-(4-chlorophenyl)-1,1-dichloroethane”[tw] OR “2-(2-Chlorophenyl)-2-(4-chlorophenyl)-1,1-dichloroethylene”[tw] OR “2-(o-Chlorophenyl)-2-(p-chlorophenyl)-1,1-dichloroethane”[tw] OR “2-(p-Chlorophenyl)-2-(o-chlorophenyl)-1,1-dichloroethane”[tw] OR “2,2-(2-Chlorophenyl-4’-chlorophenyl)-1,1-dichloroethene”[tw] OR “2,2,2,o,p’-Pentachlorethylidenbisbenzol”[tw] OR “2,2,2,o,p’-pentachloroethylidenebisbenzene”[tw] OR “2,2,2-Trichloro-1,1-bis(4-chlorophenyl)ethane”[tw] OR “2,2,o,p’-tetrachlorovinylidenebisbenzene”[tw] OR “2,2,o,p’-Tetrachlorvinylidenbisbenzol”[tw] OR “2,2-Bis(2-chlorophenyl-4-chlorophenyl)-1,1-dichloroethane”[tw] OR “2,2-Bis(4-chlorophenyl)-1,1-dichloroethane”[tw] OR “2,2-Bis(4-chlorophenyl)-1,1-dichloroethene”[tw] OR “2,2-Bis(4-chlorophenyl)-1,1-dichloroethylene”[tw] OR “2,2-Bis(o,p-chlorophenyl)-1,1,1-trichloroethane”[tw] OR “2,2-bis(para-Chlorophenyl)-1,1-dichloroethane”[tw] OR “2,2-bis(p-Chlorophenyl)-1,1,1-trichloroethane”[tw] OR “2,2-Bis(p-chlorophenyl)-1,1-dichloroethane”[tw] OR “2,2-Bis(p-chlorophenyl)-1,1-dichloroethylene”[tw] OR “2,2-Bis(p-chlorphenyl)-1,1-dichlorethylen”[tw] OR “2,2-Di(p-chlorophenyl)-1,1-dichloroethane”[tw] OR “2,2-Di(p-chlorophenyl)-1,1-dichloroethylene”[tw] OR “2,2-Dichloro-1,1-bis(4-chlorophenyl)ethylene”[tw] OR “2,4’-Dichlorodiphenyldichloroethane”[tw] OR “2,4’-Dichlorodiphenyldichloroethylene”[tw] OR “2,4’-Dichlorodiphenyltrichloroethane”[tw] OR “2,4’-Dichlorophenyldichlorethane”[tw] OR “2-o-Chlorophenyl-2-p-chlorophenyl-1,1,1-trichloroethane”[tw] OR “4,4’-1,1-Dichloro-2,2-bis(p-chlorophenyl)ethane”[tw] OR “4,4’-Dichlorodiphenyldichloroethane”[tw] OR “4,4’-Dichlorodiphenyldichloroethene”[tw] OR “4,4’-Dichlorodiphenyldichloroethylene”[tw] OR “4,4’-Dichlorodiphenyltrichloroethane”[tw] OR “4,4-Dichlorodiphenyl-trichloroethane”[tw] OR “alpha,alpha-Bis(p-chlorophenyl)- beta,beta,beta-trichlorethane”[tw] OR “alpha,alpha-Bis(p-chlorophenyl)-beta,beta,beta-trichloroethane”[tw] OR “D.D.T.”[tw] OR “DDE”[tw] OR “DDT”[tw] OR “DDT3”[tw] OR “DDTs”[tw] OR “Dichloro dichlorophenyl ethylene”[tw] OR “Dichloro diphenyl dichlorethane”[tw] OR “Dichloro diphenyl dichloroethane”[tw] OR “Dichloro diphenyl trichloroethane”[tw] OR “Dichlorodifeniltrichlorethane”[tw] OR “Dichlorodiphenydichloroethane”[tw] OR “Dichlorodiphenyl dichloroethane”[tw] OR “Dichlorodiphenyl dichloroethene”[tw] OR “Dichlorodiphenyl dichloroethylene”[tw] OR “Dichlorodiphenyldichloroethane”[tw] OR “Dichlorodiphenyldichloroethene”[tw] OR “Dichlorodiphenyldichloroethylene”[tw] OR “Dichlorodiphenyltrichloroethane”[tw] OR “MITOTANE”[tw] OR “o,p’-1,1,1-Trichloro-2-2,2-bis(p-chlorophenyl)ethane”[tw] OR “o,p’-Chlorophenothane”[tw] OR “o,p’-Dichlorodiphenyldichloroethane”[tw] OR “O,P’-DICHLORODIPHENYLDICHLOROETHYLENE”[tw] OR “o,p’-Dichlorodiphenyltrichloroethane”[tw] OR “p,p’-(Dichlorodiphenyl)-2,2-dichloroethylene”[tw] OR “p,p-DDX”[tw] OR “p,p’-Dichlorodiphenoldichloroethylene”[tw] OR “p,p’-Dichlorodiphenyl dichloroethylene”[tw] OR “p,p’-Dichlorodiphenyl-2,2-dichloroethylene”[tw] OR “p,p’-Dichlorodiphenyldichloroethane”[tw] OR “p,p’-Dichlorodiphenyldichloroethene”[tw] OR “p,p’-Dichlorodiphenyldichloroethylene”[tw] OR “p,p’-Dichlorodiphenylethylenedichloride”[tw] OR “p,p’-Dichlorodiphenyltrichloroethane”[tw] OR “p,p’-Dichlorodiphenyltrichloromethylmethane”[tw] OR “para,para’-Dichlorodiphenyldichloroethane”[tw] OR “para,para’-Dichlorodiphenyldichloroethene”[tw] OR “para,para’-Dichlorodiphenyldichloroethylene”[tw] OR “para,para’-Dichlorodiphenyltrichloroethane”[tw] OR “Tetrachlorodiphenylethane”[tw] OR “Trichlorobis(4’-chlorophenyl)ethane”[tw] OR “Trichlorobis(4-chlorophenyl)ethane”[tw] OR “2,4’-DDD”[tw] OR “2,4-DDD”[tw] OR “4,4’ DDD”[tw] OR “4,4’-DDD”[tw] OR “4,4-DDD”[tw] OR “DDD o p”[tw] OR “DDD, 2,4’-”[tw] OR “DDD, o,p’-”[tw] OR “DDD, p,p’-”[tw] OR “o,p’-DDD”[tw] OR “p,p’-DDD”[tw] OR “para,para’-DDD”[tw] OR “para-para DDD”[tw] OR “pp-DDD total”[tw] OR “4,4’-TDE”[tw] OR “o,p’-TDE”[tw] OR “o,p-TDE”[tw] OR “p,p’-TDE”[tw] OR “p,p-TDE”[tw] OR “TDE (ISO)”[tw] OR “CB 313”[tw] OR “CB313”[tw] OR “ME 1700”[tw] OR “Me-700”[tw] OR “PEB1”[tw] OR “Aavero-extra”[tw] OR “Agritan”[tw] OR “Anofex”[tw] OR “Arkotine”[tw] OR “Azotox M 33”[tw] OR “Benzochloryl”[tw] OR “Bosan Supra”[tw] OR “Bovidermol”[tw] OR “Chloditan”[tw] OR “Chlodithan”[tw] OR “Chlodithane”[tw] OR “Chlofenotan”[tw] OR “Chlorophenothan”[tw] OR “Chlorophenothane”[tw] OR “Chlorophenothanum”[tw] OR “Chlorophenotoxum”[tw] OR “Chlorphenothan”[tw] OR “Chlorphenotoxum”[tw] OR “Citox”[tw] OR “Clofenotan”[tw] OR “Clofenotane”[tw] OR “Clofenotanum”[tw] OR “De De tane”[tw] OR “Deoval”[tw] OR “Detoxan”[tw] OR “Dibovin”[tw] OR “Dicophane”[tw] OR “Dicophaner”[tw] OR “Didigam”[tw] OR “Didimac”[tw] OR “Dilene”[tw] OR “Dodat”[tw] OR “Dykol”[tw] OR “Estonate”[tw] OR “Genitox”[tw] OR “Gesafid”[tw] OR “Gesapon”[tw] OR “Gesarex”[tw] OR “Gesarol”[tw] OR “Guesapon”[tw] OR “Guesarol”[tw] OR “Gyron”[tw] OR “HEPT”[tw] OR “Hildit”[tw] OR “Ivoran”[tw] OR “Ixodex”[tw] OR “Khlodithan”[tw] OR “Klorfenoton”[tw] OR “Kopsol”[tw] OR “Lysodren”[tw] OR “Mitotan”[tw] OR “Mitotanum”[tw] OR “Mutoxan”[tw] OR “Neocid”[tw] OR “Neocidol”[tw] OR “Opeprim”[tw] OR “Parachlorocidum”[tw] OR “Pentachlorin”[tw] OR “Pentech”[tw] OR “Penticidum”[tw] OR “p’-Zeidane”[tw] OR “Rhothane”[tw] OR “Rhothane D-3”[tw] OR “Rodentrak”[tw] OR “Rothane”[tw] OR “Rukseam”[tw] OR “Santobane”[tw] OR “Tafidex”[tw] OR “Zerdane”[tw] OR (“DDD”[tw] NOT (“ATC-DDD”[tw] OR “daily defined dose”[tw] OR “daily defined doses”[tw] OR “data-driven detection”[tw] OR “ddd pacemaker”[tw] OR “DDD-028”[tw] OR “ddd/100”[tw] OR “ddd/1000”[tw] OR “ddd/sgn”[tw] OR “defined daily dose”[tw] OR “defined daily doses”[tw] OR “degenerative disc disease”[tw] OR “degenerative disk disease”[tw] OR “dense deposit disease”[tw] OR “depersonalization/derealization disorder”[tw] OR “Depression due to Dementia”[tw] OR “digital differential display”[tw] OR “direct disk diffusion”[tw] OR “disc degenerative disease”[tw] OR “disk degenerative disease”[tw] OR “difference-in-difference-in-differences”[tw] OR “direct detection device” OR “direct detector device”[tw] OR “Direct electron detectors”[tw] OR “distal-dorsal difference”[tw] OR “Dowling-Degos disease”[tw] OR “Drew-Dickerson dodecamer”[tw] OR “drinking day”[tw] OR “Drug Discovery and Development”[tw] OR “drunk driving detection”[tw] OR “lumbar disc disease”[tw] OR “lumbar disk disease”[tw] OR “pacing”[tw] OR (“dual chamber”[tw] AND “pacemaker”[tw]) OR “DDD Study”[Corporate Author]))) NOT medline[sb]) AND (2016/11/01:3000[mhda] OR 2016/11/01:3000[crdt] OR 2016/11/01:3000[edat] OR 2015/11/01:3000[dp]); (“(o-Chlorophenyl)-1-(p-chlorophenyl)-2,2,2-trichloroethane”[tw] OR “1-(2-Chlorophenyl)-1-(4-chlorophenyl)-2,2,2-trichloroethane”[tw] OR “1-(2’-Chlorophenyl)-1-(4’-chlorophenyl)-2,2-dichloroethane”[tw] OR “1-(2-Chlorophenyl)-1-(4-chlorophenyl)-2,2-dichloroethane”[tw] OR “1-(2-Chlorophenyl)-1-(4-chlorophenyl)-2,2-dichloroethylene”[tw] OR “1-(o-Chlorophenyl)-1-(p-chlorophenyl)-2,2-dichloroethane”[tw] OR “1,1’-(2,2,2-Trichloroethylidene)bis(4-chlorobenzene)”[tw] OR “1,1’-(2,2-Dichloroethylidene)bis(4-chlorobenzene)”[tw] OR “1,1’-(Dichloroethenylidene)bis(4-chlorobenzene)”[tw] OR “1,1,1-Trichloro-2-(o-chlorophenyl)-2-(p-chlorophenyl)ethane”[tw] OR “1,1,1-Trichloro-2-(p-chlorophenyl)-2-(o-chlorophenyl)ethane”[tw] OR “1,1,1-Trichloro-2,2-bis (p-chlorophenyl)ethane”[tw] OR “1,1,1-Trichloro-2,2-bis(4,4’-dichlorodiphenyl)ethane”[tw] OR “1,1,1-Trichloro-2,2-bis(4-chlorophenyl) ethane”[tw] OR “1,1,1-Trichloro-2,2-bis(4-chlorophenyl)ethane”[tw] OR “1,1,1-Trichloro-2,2-bis(p-chlorophenyl)ethane”[tw] OR “1,1,1-Trichloro-2,2-di(4-chlorophenyl)-ethane”[tw] OR “1,1,1-Trichloro-2,2-di(p-chlorophenyl)ethane”[tw] OR “1,1,1-Trichloro-2-2,2-bis(p-chlorophenyl)ethane”[tw] OR “1,1-Bis(4-chlorophenyl)-2,2,2-trichloroethane”[tw] OR “1,1-Bis(4-chlorophenyl)-2,2-dichloroethane”[tw] OR “1,1-Bis(4-chlorophenyl)-2,2-dichloroethene”[tw] OR “1,1-Bis(p-chlorophenyl)-2,2,2-trichloroethane”[tw] OR “1,1-Bis-(p-chlorophenyl)-2,2,2-trichloroethane”[tw] OR “1,1-Bis(p-chlorophenyl)-2,2-dichloroethane”[tw] OR “1,1-Bis(p-chlorophenyl)-2,2-dichloroethylene”[tw] OR “1,1-Dichloro-2-(o-chlorophenyl)-2-(p-chlorophenyl)ethane”[tw] OR “1,1-Dichloro-2-(o-chlorophenyl)-2-(p-chlorophenyl)ethene”[tw] OR “1,1-Dichloro-2-(o-chlorophenyl)-2-(p-chlorophenyl)ethylene”[tw] OR “1,1-Dichloro-2-(p-chlorophenyl)-2-(o-chlorophenyl)ethane”[tw] OR “1,1-Dichloro-2,2-bis(2,4’-dichlorophenyl)ethane”[tw] OR “1,1’-Dichloro-2,2-bis(4-chlorophenyl)ethane”[tw] OR “1,1-Dichloro-2,2-bis(4-chlorophenyl)ethane”[tw] OR “1,1-Dichloro-2,2-bis(para-chlorophenyl) ethylene”[tw] OR “1,1-Dichloro-2,2-bis(parachlorophenyl)ethane”[tw] OR “1,1-Dichloro-2,2-bis(p-chlorophenyl)ethane”[tw] OR “1,1-Dichloro-2,2-bis(p-chlorophenyl)ethene”[tw] OR “1,1-Dichloro-2,2-bis(p-chlorophenyl)ethylene”[tw] OR “1,1-Dichloro-2,2-di(4-chlorophenyl)ethane”[tw] OR “1,1-Dichloro-2,2-di(p-chlorophenyl)ethylene”[tw] OR “1,1-Dichloroethylididenebis(4-chlorobenzene)”[tw] OR “1-Chloro-2-(2,2,2-trichloro-1-(4-chlorophenyl)ethyl)benzene”[tw] OR “1-Chloro-2-(2,2-dichloro-1-(4-chlorophenyl)ethyl)benzene”[tw] OR “2-(2-Chlorophenyl)-2-(4-chlorophenyl)-1,1,1-trichloroethane”[tw] OR “2-(2-Chlorophenyl)-2-(4-chlorophenyl)-1,1-dichloroethane”[tw] OR “2-(2-Chlorophenyl)-2-(4-chlorophenyl)-1,1-dichloroethylene”[tw] OR “2-(o-Chlorophenyl)-2-(p-chlorophenyl)-1,1-dichloroethane”[tw] OR “2-(p-Chlorophenyl)-2-(o-chlorophenyl)-1,1-dichloroethane”[tw] OR “2,2-(2-Chlorophenyl-4’-chlorophenyl)-1,1-dichloroethene”[tw] OR “2,2,2,o,p’-Pentachlorethylidenbisbenzol”[tw] OR “2,2,2,o,p’-pentachloroethylidenebisbenzene”[tw] OR “2,2,2-Trichloro-1,1-bis(4-chlorophenyl)ethane”[tw] OR “2,2,o,p’-tetrachlorovinylidenebisbenzene”[tw] OR “2,2,o,p’-Tetrachlorvinylidenbisbenzol”[tw] OR “2,2-Bis(2-chlorophenyl-4-chlorophenyl)-1,1-dichloroethane”[tw] OR “2,2-Bis(4-chlorophenyl)-1,1-dichloroethane”[tw] OR “2,2-Bis(4-chlorophenyl)-1,1-dichloroethene”[tw] OR “2,2-Bis(4-chlorophenyl)-1,1-dichloroethylene”[tw] OR “2,2-Bis(o,p-chlorophenyl)-1,1,1-trichloroethane”[tw] OR “2,2-bis(para-Chlorophenyl)-1,1-dichloroethane”[tw] OR “2,2-bis(p-Chlorophenyl)-1,1,1-trichloroethane”[tw] OR “2,2-Bis(p-chlorophenyl)-1,1-dichloroethane”[tw] OR “2,2-Bis(p-chlorophenyl)-1,1-dichloroethylene”[tw] OR “2,2-Bis(p-chlorphenyl)-1,1-dichlorethylen”[tw] OR “2,2-Di(p-chlorophenyl)-1,1-dichloroethane”[tw] OR “2,2-Di(p-chlorophenyl)-1,1-dichloroethylene”[tw] OR “2,2-Dichloro-1,1-bis(4-chlorophenyl)ethylene”[tw] OR “2,4’-Dichlorodiphenyldichloroethane”[tw] OR “2,4’-Dichlorodiphenyldichloroethylene”[tw] OR “2,4’-Dichlorodiphenyltrichloroethane”[tw] OR “2,4’-Dichlorophenyldichlorethane”[tw] OR “2-o-Chlorophenyl-2-p-chlorophenyl-1,1,1-trichloroethane”[tw] OR “4,4’-1,1-Dichloro-2,2-bis(p-chlorophenyl)ethane”[tw] OR “4,4’-Dichlorodiphenyldichloroethane”[tw] OR “4,4’-Dichlorodiphenyldichloroethene”[tw] OR “4,4’-Dichlorodiphenyldichloroethylene”[tw] OR “4,4’-Dichlorodiphenyltrichloroethane”[tw] OR ”4,4-Dichlorodiphenyl-trichloroethane”[tw] OR “alpha,alpha-Bis(p-chlorophenyl)- beta,beta,beta-trichlorethane”[tw] OR “alpha,alpha-Bis(p-chlorophenyl)-beta,beta,beta-trichloroethane”[tw] OR “D.D.T.”[tw] OR “DDE”[tw] OR “DDT”[tw] OR “DDT3”[tw] OR “DDTs”[tw] OR “Dichloro dichlorophenyl ethylene”[tw] OR “Dichloro diphenyl dichlorethane”[tw] OR “Dichloro diphenyl dichloroethane”[tw] OR “Dichloro diphenyl trichloroethane”[tw] OR “Dichlorodifeniltrichlorethane”[tw] OR “Dichlorodiphenydichloroethane”[tw] OR “Dichlorodiphenyl dichloroethane”[tw] OR “Dichlorodiphenyl dichloroethene”[tw] OR “Dichlorodiphenyl dichloroethylene”[tw] OR “Dichlorodiphenyldichloroethane”[tw] OR “Dichlorodiphenyldichloroethene”[tw] OR “Dichlorodiphenyldichloroethylene”[tw] OR “Dichlorodiphenyltrichloroethane”[tw] OR “MITOTANE”[tw] OR “o,p’-1,1,1-Trichloro-2-2,2-bis(p-chlorophenyl)ethane”[tw] OR “o,p’-Chlorophenothane”[tw] OR “o,p’-Dichlorodiphenyldichloroethane”[tw] OR “O,P’-DICHLORODIPHENYLDICHLOROETHYLENE”[tw] OR “o,p’-Dichlorodiphenyltrichloroethane”[tw] OR “p,p’-(Dichlorodiphenyl)-2,2-dichloroethylene”[tw] OR “p,p-DDX”[tw] OR “p,p’-Dichlorodiphenoldichloroethylene”[tw] OR “p,p’-Dichlorodiphenyl dichloroethylene”[tw] OR “p,p’-Dichlorodiphenyl-2,2-dichloroethylene”[tw] OR “p,p’-Dichlorodiphenyldichloroethane”[tw] OR “p,p’-Dichlorodiphenyldichloroethene”[tw] OR “p,p’-Dichlorodiphenyldichloroethylene”[tw] OR “p,p’-Dichlorodiphenylethylene dichloride”[tw] OR “p,p’-Dichlorodiphenyltrichloroethane”[tw] OR “p,p’-Dichlorodiphenyltrichloromethylmethane”[tw] OR “para,para’-Dichlorodiphenyldichloroethane”[tw] OR “para,para’-Dichlorodiphenyldichloroethene”[tw] OR “para,para’-Dichlorodiphenyldichloroethylene”[tw] OR “para,para’-Dichlorodiphenyltrichloroethane”[tw] OR “Tetrachlorodiphenylethane”[tw] OR “Trichlorobis(4’-chlorophenyl)ethane”[tw] OR “Trichlorobis(4-chlorophenyl)ethane”[tw] OR “2,4’-DDD”[tw] OR “2,4-DDD”[tw] OR “4,4’ DDD”[tw] OR “4,4’-DDD”[tw] OR “4,4-DDD”[tw] OR “DDD o p”[tw] OR “DDD, 2,4’-”[tw] OR “DDD, o,p’-”[tw] OR “DDD, p,p’-”[tw] OR “o,p’-DDD”[tw] OR “p,p’-DDD”[tw] OR “para,para’-DDD”[tw] OR “para-para DDD”[tw] OR “pp-DDD total”[tw] OR “4,4’-TDE”[tw] OR “o,p’-TDE”[tw] OR “o,p-TDE”[tw] OR “p,p’-TDE”[tw] OR “p,p-TDE”[tw] OR “TDE (ISO)”[tw] OR “CB 313”[tw] OR “CB313”[tw] OR “ME 1700”[tw] OR “Me-700”[tw] OR “PEB1”[tw] OR “Aavero-extra”[tw] OR “Agritan”[tw] OR “Anofex”[tw] OR “Arkotine”[tw] OR “Azotox M 33”[tw] OR “Benzochloryl”[tw] OR “Bosan Supra”[tw] OR “Bovidermol”[tw] OR “Chloditan”[tw] OR “Chlodithan”[tw] OR “Chlodithane”[tw] OR “Chlofenotan”[tw] OR “Chlorophenothan”[tw] OR “Chlorophenothane”[tw] OR “Chlorophenothanum”[tw] OR “Chlorophenotoxum”[tw] OR “Chlorphenothan”[tw] OR “Chlorphenotoxum”[tw] OR “Citox”[tw] OR “Clofenotan”[tw] OR “Clofenotane”[tw] OR “Clofenotanum”[tw] OR “De De tane”[tw] OR “Deovar[tw] OR “Detoxan”[tw] OR “Dibovin”[tw] OR “Dicophane”[tw] OR “Dicophaner”[tw] OR “Didigam”[tw] OR “Didimac”[tw] OR “Dilene”[tw] OR “Dodat”[tw] OR “Dykol”[tw] OR “Estonate”[tw] OR “Genitox”[tw] OR “Gesafid”[tw] OR “Gesapon”[tw] OR “Gesarex”[tw] OR “Gesarol”[tw] OR “Guesapon”[tw] OR “Guesarol”[tw] OR “Gyron”[tw] OR “HEPT”[tw] OR “Hildit”[tw] OR “Ivoran”[tw] OR “Ixodex”[tw] OR “Khlodithan”[tw] OR “Klorfenoton”[tw] OR “Kopsol”[tw] OR “Lysodren”[tw] OR “Mitotan”[tw] OR “Mitotanum”[tw] OR “Mutoxan”[tw] OR “Neocid”[tw] OR “Neocidol”[tw] OR “Opeprim”[tw] OR “Parachlorocidum”[tw] OR “Pentachlorin”[tw] OR “Pentech”[tw] OR “Penticidum”[tw] OR “p’-Zeidane”[tw] OR “Rhothane”[tw] OR “Rhothane D-3”[tw] OR “Rodentrak”[tw] OR “Rothane”[tw] OR “Rukseam”[tw] OR “Santobane”[tw] OR “Tafidex”[tw] OR “Zerdane”[tw] OR (“DDD”[tw] NOT (“ATC-DDD”[tw] OR “daily defined dose”[tw] OR “daily defined doses”[tw] OR “data-driven detection”[tw] OR “ddd pacemaker”[tw] OR “DDD-028”[tw] OR “ddd/100”[tw] OR “ddd/1000”[tw] OR “ddd/sgn”[tw] OR “defined daily dose”[tw] OR “defined daily doses”[tw] OR “degenerative disc disease”[tw] OR “degenerative disk disease”[tw] OR “dense deposit disease”[tw] OR “depersonalization/derealization disorder”[tw] OR “Depression due to Dementia”[tw] OR “digital differential display”[tw] OR “direct disk diffusion”[tw] OR “disc degenerative disease”[tw] OR “disk degenerative disease”[tw] OR “difference-in-difference-in-differences”[tw] OR “direct detection device” OR “direct detector device”[tw] OR “Direct electron detectors”[tw] OR “distal-dorsal difference”[tw] OR “Dowling-Degos disease”[tw] OR “Drew-Dickerson dodecamer”[tw] OR “drinking day”[tw] OR “Drug Discovery and Development”[tw] OR “drunk driving detection”[tw] OR “lumbar disc disease”[tw] OR “lumbar disk disease”[tw] OR “pacing”[tw] OR (“dual chamber”[tw] AND “pacemaker”[tw]) OR “DDD Study”[Corporate Author]))) AND (((“pesticides/toxicity”[mh] OR “pesticides/adverse effects”[mh] OR “pesticides/poisoning”[mh] OR “pesticides/pharmacokinetics”[mh]) OR (“pesticides”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“pesticides”[mh] AND toxicokinetics[mh:noexp]) OR (“pesticides/blood”[mh] OR “pesticides/cerebrospinal fluid”[mh] OR “pesticides/urine”[mh]) OR (“pesticides”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“pesticides”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“pesticides/antagonists and inhibitors”[mh]) OR (“pesticides/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“pesticides”[mh] AND cancer[sb]) OR (“endocrine disruptors/toxicity”[mh] OR “endocrine disruptors/adverse effects”[mh] OR “endocrine disruptors/poisoning”[mh] OR “endocrine disruptors/pharmacokinetics”[mh]) OR (“endocrine disruptors”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“endocrine disruptors”[mh] AND toxicokinetics[mh:noexp]) OR (“endocrine disruptors/blood”[mh] OR “endocrine disruptors/cerebrospinal fluid”[mh] OR “endocrine disruptors/urine”[mh]) OR (“endocrine disruptors”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“endocrine disruptors”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“endocrine disruptors/antagonists and inhibitors”[mh]) OR (“endocrine disruptors/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“endocrine disruptors”[mh] AND cancer[sb]) OR (“environmental pollutants/toxicity”[mh] OR “environmental pollutants/adverse effects”[mh] OR “environmental pollutants/poisoning”[mh] OR “environmental pollutants/pharmacokinetics”[mh]) OR (“environmental pollutants”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“environmental pollutants”[mh] AND toxicokinetics[mh:noexp]) OR (“environmental pollutants/blood”[mh] OR “environmental pollutants/cerebrospinal fluid”[mh] OR “environmental pollutants/urine”[mh]) OR (“environmental pollutants”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “environmental pollutants”[mh])) OR (“environmental pollutants”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“environmental pollutants/antagonists and inhibitors”[mh]) OR (“environmental pollutants/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“environmental pollutants”[mh] AND cancer[sb])) OR (“Hydrocarbons, Chlorinated/toxicity”[mh] OR “Hydrocarbons, Chlorinated/adverse effects”[mh] OR “Hydrocarbons, Chlorinated/poisoning”[mh] OR “Hydrocarbons, Chlorinated/pharmacokinetics”[mh]) OR (“Hydrocarbons, Chlorinated”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR ((“Hydrocarbons, Chlorinated”[mh] AND toxicokinetics[mh:noexp]) OR (“Hydrocarbons, Chlorinated/blood”[mh] OR “Hydrocarbons, Chlorinated/cerebrospinal fluid”[mh] OR “Hydrocarbons, Chlorinated/urine”[mh]) OR (“Hydrocarbons, Chlorinated”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Hydrocarbons, Chlorinated”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Hydrocarbons, Chlorinated/antagonists and inhibitors”[mh]) OR (“Hydrocarbons, Chlorinated/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Hydrocarbons, Chlorinated”[mh] AND cancer[sb]))) AND (2016/11/01:3000[mhda] OR 2016/11/01:3000[crdt] OR 2016/11/01:3000[edat] OR 2015/11/01:3000[dp]); (DDT OR DDE) AND (“environmental pollutants”[mh] OR “environmental pollution”[mh] OR “animals, wild”[mh] OR “ecotoxicology”[mh] OR “fishes”[mh] OR “birds”[mh] OR “amphibians”[mh] OR “reptiles”[mh] OR “Mammals”[Mesh:noexp] OR “Artiodactyla”[mh] OR “Carnivora”[mh] OR “Cetacea”[mh] OR “Chiroptera”[mh] OR “Hyraxes”[mh] OR “Lagomorpha”[mh] OR “Marsupialia”[mh] OR “Monotremata”[mh] OR “Perissodactyla”[mh] OR “Proboscidea Mammal”[mh] OR “Rodentia ”[mh] OR “Scandentia”[mh] OR “Sirenia ”[mh] OR “Xenarthra”[mh] OR “Gorilla”[mh] OR “Pan paniscus”[mh] OR “Pan troglodytes”[mh] OR “Pongo”[mh] OR “hominidae”[Mesh:noexp] OR “Cercopithecidae”[mh] OR “Hylobatidae”[mh] OR “catarrhini” OR “Platyrrhini”[mh] OR “Tarsii”[mh] OR “haplorhini”[mh:noexp] OR “Strepsirhini”[mh] OR “primates”[mh:noexp] OR “Oligochaeta”[mh] OR “Bees”[mh] OR ecotox* OR phytotox* OR ec50* OR lc50* OR “lethal concentration”[tw] OR aquatic OR wildlife OR Alga OR Algae OR Amphibian* OR Avian OR bird OR birds OR Chironomid* OR Chironomus OR Collembolan OR Daphnia OR Daphnid* OR Earthworm* OR Fish OR Medaka OR Minnow OR plant OR Mollusc* OR bioaccumulat* OR biomagnifica* OR biomonitor* OR biotransform* OR bioconcentrat*) AND 2015 : 3000[dp] Filter: Reviews
NTRL
04/2020 | searched in fulltext or in title/keyword (names found in Pubmed):; “50-29-3” OR “72-55-9” OR “72-54-8” OR “789-02-6” OR “3424-82-6” OR “53-19-0” “o-Chlorophenyl -1- p-chlorophenyl -2,2,2-trichloroethane” OR “1- 2-Chlorophenyl -1- 4-chlorophenyl -2,2,2-trichloroethane” OR “1- 2-Chlorophenyl -1- 4-chlorophenyl -2,2-dichloroethane” OR “1- 2-Chlorophenyl -1- 4-chlorophenyl -2,2-dichloroethylene” OR “1- o-Chlorophenyl -1- p-chlorophenyl -2,2-dichloroethane” OR “1,1 - 2,2,2-Trichloroethylidene bis 4-chlorobenzene ” OR “1,1 - 2,2-Dichloroethylidene bis 4-chlorobenzene ” OR “1,1,1-Trichloro-2- o-chlorophenyl -2- p-chlorophenyl ethane” OR “1,1,1-Trichloro-2- p-chlorophenyl -2- o-chlorophenyl ethane” OR “1,1,1-Trichloro-2,2-bis p-chlorophenyl ethane” OR “1,1,1-Trichloro-2,2-bis 4-chlorophenyl ethane” OR “1,1,1-Trichloro-2,2-bis 4-chlorophenyl ethane” OR “1,1,1-Trichloro-2,2-bis p-chlorophenyl ethane” OR “1,1,1-Trichloro-2,2-di 4-chlorophenyl -ethane” OR “1,1,1-Trichloro-2,2-di p-chlorophenyl ethane” OR “1,1 -Bis 4-chlorophenyl -2,2,2-trichloroethane” OR “1,1 -Bis 4-chlorophenyl -2,2-dichloroethane” OR; “1,1-Bis 4-chlorophenyl -2,2-dichloroethene” OR “1,1-Bis p-chlorophenyl -2,2,2-trichloroethane” OR “1,1-Bis- p-chlorophenyl -2,2,2-trichloroethane” OR “1,1-Bis p-chlorophenyl -2,2-dichloroethane” OR “1,1-Bis p-chlorophenyl -2,2-dichloroethylene” OR “1,1-Dichloro-2- o-chlorophenyl -2- p-chlorophenyl ethane” OR “1,1-Dichloro-2- o-chlorophenyl -2- p-chlorophenyl ethylene” OR “1,1-Dichloro-2- p-chlorophenyl -2- o-chlorophenyl ethane” OR “1,1 -Dichloro-2,2-bis 4-chlorophenyl ethane” OR “1,1-Dichloro-2,2-bis 4-chlorophenyl ethane” OR “1,1-Dichloro-2,2-bis p-chlorophenyl ethane” OR “1,1-Dichloro-2,2-bis p-chlorophenyl ethene” OR “1,1-Dichloro-2,2-bis p-chlorophenyl ethylene” OR “1,1-Dichloro-2,2-di 4-chlorophenyl ethane” OR “1-Chloro-2- 2,2,2-trichloro-1- 4-chlorophenyl ethyl benzene” OR “2- 2-Chlorophenyl -2- 4-chlorophenyl -1,1,1-trichloroethane” OR “2- 2-Chlorophenyl -2- 4-chlorophenyl -1,1-dichloroethane” OR “2- o-Chlorophenyl -2- p-chlorophenyl -1,1-dichloroethane” OR “2,2- 2-Chlorophenyl-4 -chlorophenyl -1,1-dichloroethene” OR “2,2-Bis 2-chlorophenyl-4-chlorophenyl -1,1-dichloroethane” OR “2,2-Bis 4-chlorophenyl -1,1-dichloroethane” OR “2,2-Bis 4-chlorophenyl -1,1-dichloroethene” OR “2,2-Bis 4-chlorophenyl -1,1-dichloroethylene” OR “2,2-Bis o, p-chlorophenyl -1,1,1-trichloroethane” OR “2,2-bis p-Chlorophenyl -1,1,1-trichloroethane” OR “2,2-Bis p-chlorophenyl -1,1-dichloroethane” OR “2,2-Bis p-chlorophenyl -1,1-dichloroethylene” OR “2,4 -Dichlorodiphenyldichloroethane” OR “2,4 -Dichlorodiphenyldichloroethylene” OR “2,4 -Dichlorodiphenyltrichloroethane” OR “2-o-Chlorophenyl-2-p-chlorophenyl-1,1,1-trichloroethane” OR “4,4 - Dichlorodiphenyldichloroethane” OR “4,4 -Dichlorodiphenyldichloroethene” OR “4,4 - Dichlorodiphenyldichloroethylene” OR “4,4 -Dichlorodiphenyltrichloroethane” OR “4,4-Dichlorodiphenyl-trichloroethane” OR “Dichloro dichlorophenyl ethylene” OR “Dichloro diphenyl dichloroethane” OR “Dichloro diphenyl trichloroethane” OR “Dichlorodiphenyl dichloroethane” OR “Dichlorodiphenyl dichloroethene” OR “Dichlorodiphenyl dichloroethylene” OR “Dichlorodiphenyldichloroethane” OR “Dichlorodiphenyldichloroethene” OR “Dichlorodiphenyldichloroethylene” OR “Dichlorodiphenyltrichloroethane” OR “MITOTANE” OR “o, p -Dichlorodiphenyldichloroethane” OR “O, P - DICHLORODIPHENYLDICHLOROETHYLENE” OR “o, p -Dichlorodiphenyltrichloroethane” OR “p, p - Dichlorodiphenyl -2,2-dichloroethylene” OR “p, p-DDX” OR “p, p - Dichlorodiphenyl dichloroethylene” OR “p, p -Dichlorodiphenyl-2,2-dichloroethylene” OR “p, p -Dichlorodiphenyldichloroethane” OR “p, p -Dichlorodiphenyldichloroethene” OR “p, p -Dichlorodiphenyldichloroethylene” OR “p, p -Dichlorodiphenyltrichloroethane” OR “para, para -Dichlorodiphenyldichloroethylene” OR “Tetrachlorodiphenylethane” OR “2,4 -DDD” OR “2,4-DDD” OR “4,4 DDD” OR “4,4 -DDD” OR “4,4-DDD” OR “o, p -DDD” OR “p, p -DDD” OR “4,4 -TDE” OR “o, p -TDE” OR “o, p-TDE” OR “p, p -TDE” OR “p, p-TDE” OR “PEB1” OR “Chloditan” OR “Chlodithan” OR “Chlodithane” OR “Chlorophenothane” OR “Dicophane” OR “Dilene” OR “Dodat” OR “Gyron” OR “HEPT” OR “Ixodex” OR “Lysodren” OR “Mitotan” OR “Neocid” OR “Neocidol” OR “Opeprim” OR “Rhothane” OR “Rothane” “2,4 -DDE” OR “2,4-DDE” OR “4,4 -DDE” OR “4,4-DDE” OR “DDE o p” OR “DDE, 2,4 -” OR “DDE, o,p -” OR “DDE, p,p -” OR “o,p -DDE” OR “ortho-para DDE” OR “p,p - DDE” OR “p,p -DDE” OR “para,para -DDE” OR “para-para DDE” OR “pp-DDE total”
Toxcenter
04/2020 | (FILE ‘HOME’ ENTERED AT 13:07:33 ON 01 APR 2020); FILE ‘TOXCENTER’ ENTERED AT 13:07:58 ON 01 APR 2020; CHARGED TO COST=EH038.06.01 .LB.02; L1 50073 SEA FILE=TOXCENTER 50-29-3 OR 72-55-9 OR 72-54-8 OR 789-02-6 OR 3424-82-6 OR 53-19-0; L2 0 SEA FILE=TOXCENTER 8017-34-3; L3 48315 SEA FILE=TOXCENTER L1 NOT PATENT/DT; L4 1894 SEA FILE=TOXCENTER L3 AND ED>=20161101; L5 2407 SEA FILE=TOXCENTER L3 AND PY>2015 ACT TOXQUERY/Q ---------; L6 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L7 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L8 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L9 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L10 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L11 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L12 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L13 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L14 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L15 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L16 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L17 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L18 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L19 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L20 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L21 QUE (ENDOCRIN? AND DISRUPT?); L22 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L23 QUE (WEAN? OR OFFSPRING OR AGE(W) FACT OR?); L24 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L25 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L26 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L27 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L28 QUE (NEPHROTOX? OR HEPATOTOX?); L29 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L30 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L31 QUE L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30; L32 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L33 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L34 QUE L31 OR L32 OR L33; L35 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L36 QUE L34 OR L35 ---------; L37 2489 SEA FILE=TOXCENTER L4 OR L5; L38 1588 SEA FILE=TOXCENTER L37 AND L36; L39 1355 SEA FILE=TOXCENTER L37 AND L31; L40 1045 SEA FILE=TOXCENTER L39 AND L4; L41 358 SEA FILE=TOXCENTER L39 AND MEDLINE/FS; L42 997 SEA FILE=TOXCENTER L39 NOT MEDLINE/FS; L43 1138 DUP REM L41 L42 (217 DUPLICATES REMOVED) ANSWERS ‘1-1138’ FROM FILE TOXCENTER; L*** DEL 358 S L39 AND MEDLINE/FS; L*** DEL 358 S L39 AND MEDLINE/FS; L44 358 SEA FILE=TOXCENTER L43; L*** DEL 997 S L39 NOT MEDLINE/FS; L*** DEL 997 S L39 NOT MEDLINE/FS; L45 780 SEA FILE=TOXCENTER L43; L46 780 SEA FILE=TOXCENTER (L44 OR L45) NOT MEDLINE/FS; L47 51562 SEA FILE=TOXCENTER L1 OR DDT/TI OR DDE/TI; L48 49787 SEA FILE=TOXCENTER L47 NOT PATENT/DT; L49 2118 SEA FILE=TOXCENTER L48 AND ED>20161101; L50 1140 SEA FILE=TOXCENTER L49 AND (ENVIRONMENT? OR ECOTOX? OR ECOLOG? OR PHYTOTOX? OR EC50? OR LC50? OR “LETHAL CONCENTRATION” OR AQUATIC OR WILDLIFE OR ALGA OR ALGAE OR AMPHIBIAN? OR AVIAN OR BIRD OR BIRDS OR CHIRONOMID? OR CHIRONOMUS OR COLLEMBOLAN); L51 513 SEA FILE=TOXCENTER L49 AND (DAPHNIA OR DAPHNID? OR EARTHWORM? OR FISH OR FISHES OR MEDAKA OR MINNOW OR PLANT OR MOLLUSC? OR BIOACCUMULAT? OR BIOMAGNIFICA? OR BIOMONITOR? OR BIOTRANSFORM? OR BIOCONCENTRAT?); L52 1318 SEA FILE=TOXCENTER L50 OR L51; L53 191 SEA FILE=TOXCENTER L52 AND BIOSIS/FS; L54 14 SEA FILE=TOXCENTER L53 AND (REVIEW? OR SYNTHESIS OR METASYNTHES IS OR SEARCH? OR SYSTEMATIC?); L55 14 DUP REM L54 (0 DUPLICATES REMOVED) ANSWERS ‘1-14’ FROM FILE TOXCENTER; L56 9 SEA FILE=TOXCENTER L54 NOT L46; D SCAN L56; D SCAN L46

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS^a^
04/2020 | Compounds searched: 50-29-3; 72-55-9; 72-54-8; 789-02-6; 3424-82-6; 53-19-0
NTP
04/2020 | limited 2015-present; 50-29-3; 72-55-9; 72-54-8; 789-02-6; 3424-82-6; 53-19-0
NIH RePORTER
07/2021 | Searched only names found in Pubmed.; (advanced)Limit to: Project Title, Project Terms, Project Abstracts; Fiscal Year: Active Projects; Text Search:; “D.DT.” OR “DDE” OR “DDT” OR “DDT3” OR “DDTs” OR “Dichloro dichlorophenyl ethylene” OR “Dichloro diphenyl dichloroethane” OR “Dichloro diphenyl trichloroethane” OR “Dichlorodiphenyl dichloroethane” OR “Dichlorodiphenyl dichloroethene” OR “Dichlorodiphenyl dichloroethylene” OR “Dichlorodiphenyldichloroethane” OR “Dichlorodiphenyldichloroethene” OR “Dichlorodiphenyldichloroethylene” OR “Dichlorodiphenyltrichloroethane” OR “MITOTANE” OR “o, p’-Dichlorodiphenyldichloroethane” OR “O, P’-DICHLORODIPHENYLDICHLOROETHYLENE” OR “o, p’-Dichlorodiphenyltrichloroethane” OR “p, p’-(Dichlorodiphenyl)-2,2-dichloroethylene” OR “p, p-DDX” OR “p, p’-Dichlorodiphenyl dichloroethylene” OR “p, p’-Dichlorodiphenyl-2,2-dichloroethylene” OR “p, p’-Dichlorodiphenyldichloroethane” OR “p, p’-Dichlorodiphenyldichloroethene” OR “p, p’-Dichlorodiphenyldichloroethylene” OR “p, p’-Dichlorodiphenyltrichloroethane” OR “para, para’-Dichlorodiphenyldichloroethylene” OR “Tetrachlorodiphenylethane” OR “2,4’-DDD” OR “2,4-DDD” OR “4,4’ DDD” OR “4,4’-DDD” OR “4,4-DDD” OR “o, p’-DDD” OR “p, p’-DDD” OR “4,4’-TDE” OR “o, p’-TDE” OR “o, p-TDE” OR “p, p’-TDE” OR “p, p-TDE” OR “PEB1” OR “Chloditan” OR “Chlodithan” OR “Chlodithane” OR “Chlorophenothane” OR “Dicophane” OR “Dilene” OR “Dodat” OR “Gyron” OR “HEPT” OR “Ixodex” OR “Lysodren” OR “Mitotan” OR “Neocid” OR “Neocidol” OR “Opeprim” OR “Rhothane” OR “Rothane” OR “DDD”; “(o-Chlorophenyl)-1-(p-chlorophenyl)-2,2,2-trichloroethane” OR “1-(2-Chlorophenyl)-1-(4-chlorophenyl)-2,2,2-trichloroethane” OR “1-(2-Chlorophenyl)-1-(4-chlorophenyl)-2,2-dichloroethane” OR “1-(2-Chlorophenyl)-1-(4-chlorophenyl)-2,2-dichloroethylene” OR “1-(o-Chlorophenyl)-1-(p-chlorophenyl)-2,2-dichloroethane” OR “1,1’-(2,2,2-Trichloroethylidene)bis(4-chlorobenzene)” OR “1,1’-(2,2-Dichloroethylidene)bis(4-chlorobenzene)” OR “1,1,1-Trichloro-2-(o-chlorophenyl)-2-(p-chlorophenyl)ethane” OR “1,1,1-Trichloro-2-(p-chlorophenyl)-2-(o-chlorophenyl)ethane” OR “1,1,1-Trichloro-2,2-bis (p-chlorophenyl)ethane” OR “1,1,1-Trichloro-2,2-bis(4-chlorophenyl) ethane” OR “1,1,1-Trichloro-2,2-bis(4-chlorophenyl)ethane” OR “1,1,1-Trichloro-2,2-bis(p-chlorophenyl)ethane” OR “1,1,1-Trichloro-2,2-di(4-chlorophenyl)-ethane” OR “1,1,1-Trichloro-2,2-di(p-chlorophenyl)ethane” OR “1,1-Bis(4-chlorophenyl)-2,2,2-trichloroethane” OR “1,1-Bis(4-chlorophenyl)-2,2-dichloroethane” OR “1,1 -Bis(4-chlorophenyl)-2,2-dichloroethene” OR “1,1-Bis(p-chlorophenyl)-2,2,2-trichloroethane” OR “1,1-Bis-(p-chlorophenyl)-2,2,2-trichloroethane” OR “1,1-Bis(p-chlorophenyl)-2,2-dichloroethane” OR “1,1-Bis(p-chlorophenyl)-2,2-dichloroethylene” OR “1,1-Dichloro-2-(o-chlorophenyl)-2-(p-chlorophenyl)ethane” OR “1,1-Dichloro-2-(o-chlorophenyl)-2-(p-chlorophenyl)ethylene” OR “1,1-Dichloro-2-(p-chlorophenyl)-2-(o-chlorophenyl)ethane”; “1,1’-Dichloro-2,2-bis(4-chlorophenyl)ethane” OR “1,1-Dichloro-2,2-bis(4-chlorophenyl)ethane” OR “1,1-Dichloro-2,2-bis(p-chlorophenyl)ethane” OR “1,1-Dichloro-2,2-bis(p-chlorophenyl)ethene” OR “1,1-Dichloro-2,2-bis(p-chlorophenyl)ethylene” OR “1,1-Dichloro-2,2-di(4-chlorophenyl)ethane” OR “1-Chloro-2-(2,2,2-trichloro-1-(4-chlorophenyl)ethyl)benzene” OR “2-(2-Chlorophenyl)-2-(4-chlorophenyl)-1,1,1-trichloroethane” OR “2-(2-Chlorophenyl)-2-(4-chlorophenyl)-1,1-dichloroethane” OR “2-(o-Chlorophenyl)-2-(p-chlorophenyl)-1,1-dichloroethane” OR “2,2-(2-Chlorophenyl-4’-chlorophenyl)-1,1-dichloroethene” OR “2,2-Bis(2-chlorophenyl-4-chlorophenyl)-1,1-dichloroethane” OR “2,2-Bis(4-chlorophenyl)-1,1-dichloroethane” OR “2,2-Bis(4-chlorophenyl)-1,1-dichloroethene” OR “2,2-Bis(4-chlorophenyl)-1,1-dichloroethylene” OR “2,2-Bis(o, p-chlorophenyl)-1,1,1-trichloroethane” OR “2,2-bis(p-Chlorophenyl)-1,1,1-trichloroethane” OR “2,2-Bis(p-chlorophenyl)-1,1-dichloroethane” OR “2,2-Bis(p-chlorophenyl)-1,1-dichloroethylene” OR “2,4’-Dichlorodiphenyldichloroethane” OR “2,4’-Dichlorodiphenyldichloroethylene” OR “2,4’-Dichlorodiphenyltrichloroethane” OR “2-o-Chlorophenyl-2-p-chlorophenyl-1,1,1-trichloroethane” OR “4,4’-Dichlorodiphenyldichloroethane” OR “4,4’-Dichlorodiphenyldichloroethene” OR “4,4’-Dichlorodiphenyldichloroethylene” OR “4,4’-Dichlorodiphenyltrichloroethane” OR “4,4-Dichlorodiphenyl-trichloroethane”
Other | Identified throughout the assessment process

The 2020 results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 2,008
- Number of records identified from other strategies: 28
- Total number of records to undergo literature screening: 2,036

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on DDT, DDE, and DDD:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 2,036
- Number of studies considered relevant and moved to the next step: 156

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 156
- Number of studies cited in the pre-public draft of the toxicological profile: 1,037
- Total number of studies cited in the profile: 1,114

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 November 2016 Literature Search Results and Screen for DDT, DDE, and DDD

Figure B-1 description