# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | DDT, DDE, DDD, and their isomers
CAS Numbers: | 50-29-3, 72-55-9, 72-54-8
Date: | April 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: No acute-duration inhalation studies were identified.

Agency Contacts (Chemical Manager): Obaid Faroon

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | DDT, DDE, DDD, and their isomers
CAS Numbers: | 50-29-3, 72-55-9, 72-54-8
Date: | April 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL.

Rationale for Not Deriving an MRL: No intermediate-duration inhalation studies were identified.

Agency Contacts (Chemical Manager): Obaid Faroon

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | DDT, DDE, DDD, and their isomers
CAS Numbers: | 50-29-3, 72-55-9, 72-54-8
Date: | April 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: No chronic-duration inhalation studies were identified.

Agency Contacts (Chemical Manager): Obaid Faroon

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | DDT, DDE, DDD, and their isomers
CAS Numbers: | 50-29-3, 72-55-9, 72-54-8
Date: | April 2022
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL: | 0.0005 mg/kg/day (0.5 μg/kg/day)
Critical Effect: | Developmental neurobehavioral and neurological effects
Reference: | Johansson et al. 1995, 1996; Eriksson and Nordberg 1986; Eriksson et al. 1990a, 1990b, 1992, 1993
Point of Departure: | LOAEL of 0.5 mg/kg
Uncertainty Factor: | 1,000
LSE Graph Keys: | 59, 60, 61, 62, 63, 66, 67
Species: | Mouse

MRL Summary: An acute-duration oral MRL of 0.0005 mg/kg/day (0.5 µg/kg/day) was derived for DDT, DDE, and DDD based on increased spontaneous motor activity, delayed habituation, and decreased density of muscarinic receptors in the cerebral cortex of NMRI mice at various timepoints after a single exposure to technical DDT on PND 10. The MRL is based on a LOAEL of 0.5 mg/kg on PND 10 and a total uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability).

Selection of the Critical Effect: At least 30 animal studies have evaluated the acute-duration oral toxicity of DDT, DDE, or DDD and their related isomers in a variety of animal models including monkeys, rats, mice, dogs, and rabbits. These studies examined a wide range of potentially sensitive targets: developmental, neurodevelopmental, endocrine, hepatic, neurological, reproductive, and diabetes-related effects. The LOAELs for these outcomes range from 0.5 to 500 mg/kg/day. The lowest LOAELs for these effects (and associated NOAELs) are summarized in Table A-1; given the number of studies, data in the table are limited to studies that identified LOAELs ≤50 mg/kg/day.

A comparison of the LOAELs suggest that the neurodevelopmental outcomes are the most sensitive effect following acute-duration oral exposure, followed by other developmental, diabetes-related, liver, reproductive, neurological, and endocrine outcomes. The lowest reliable LOAEL was 0.5 mg technical DDT/kg for neurodevelopmental effects in mice identified in a group of seven related studies. Following a single exposure on PND 10, mice exhibited delays in habituation behaviors, increased motor activities, and reductions in muscarinic receptor densities in the cerebral cortex (Eriksson and Nordberg 1986; Eriksson et al. 1990a, 1990b, 1992, 1993; Johansson et al. 1995, 1996). Other developmental effects including decreases in fetal weight (Fabro et al. 1984; Hart et al. 1972), retained thoracic nipples (You et al. 1998), delayed vaginal opening (Gellert and Heinrichs 1975), and increases in body weight of adult offspring (Gellert and Heinrichs 1975) were observed at doses ≥1.0 mg/kg/day. At 1 mg DDT(NS)/kg/day, a 33% decrease in fetal weight was observed in rabbits (Fabro et al. 1984); it is noted that changes in offspring weight status was a common effect following in utero exposure; however, the direction of change was not consistent across studies. At 2 mg p,p’-DDE/kg/day, increases in fasting blood glucose levels were observed in mice (Howell et al. 2014); no increases in glucose tolerance or alterations in indicators of insulin-induced glucose disposal were observed. Increased relative and/or absolute liver weights were commonly observed in rats acutely exposed to p,p’-DDT, p,p’-DDE, or technical DDT at doses ≥5 mg/kg/day (Kang et al. 2004; Kostka et al. 2000; Leavens et al. 2002; Nims et al. 1998; Tomiyama et al. 2004). Kostka et al. (2000) was the only study reporting histological alterations; necrotic liver changes were observed in rats exposed to 12 mg p,p’-DDT/kg/day for 14 days.

Table A-1 Summary of Relevant NOAEL and LOAEL Values Following Acute Oral Exposure to DDT, DDE, and DDD Isomers

Species | Duration | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference/compound
Liver effects
F344 rat | 2 weeks | ND | 5 | Increased relative liver weight | Tomiyama et al. 2004; p,p’-DDT
Wistar rat | 2 weeks | ND | 12 | Increased relative liver weight; necrotic changes | Kostka et al. 2000; Technical DDT
F344 rat | 2 weeks | 7.6 | 23 | Increased relative liver weight | Nims et al. 1998; p,p’-DDE
F344 rat | 2 weeks | 8.5 | 25 | Increased relative liver weight | Nims et al. 1998; p,p’-DDT
Long-Evans rat | 4 days | 12.5 | 25 | Increased relative liver weight | Leavens et al. 2002; p,p’-DDE
Sprague-Dawley rat | 10 days | ND | 25 | Increased absolute liver weight (42%) | Kang et al. 2004; p,p’-DDE
Wistar rat | 5 or 12 days | ND | 40 | Increased in relative liver weight | dtze Waziers and Azais 1987; DDT(NS)
Neurodevelopmental effects
NMRI mouse | Once PND 10 | ND | 0.5 | Decreased muscarinic receptors in cerebral cortex; increased spontaneous activity at 5 months | Johansson et al. 1995; Technical DDT
NMRI mouse | Once PND 10 | ND | 0.5 | Decreased muscarinic receptors in cerebral cortex; increased spontaneous activity at 5 and 7 months | Johansson et al. 1996; Technical DDT
NMRI mouse | Once at PND 3, 10, or 19 | ND | 0.5 | Decrease in cerebral cortex muscarinic acetylcholine receptor binding; delayed habituation in males at 4 months of age and dosed on PND 10; no change in proportion of HA and LA binding sites or affinity constants; no changes in mice dosed on PND 3 or 19 | Eriksson et al. 1992; Technical DDT
NMRI mouse | Once, PND 10 | ND | 0.5 | Increased motor activity (delayed habituation) at 4 months, increased potassium evoked acetylcholine release, reduced density of muscarinic receptors in cerebral cortex at 3 months; no change in choline acetyltransferase activity | Eriksson et al. 1990b; Technical DDT
NMRI mouse | Once, PND 10 | ND | 0.5 | Delayed habituation observed as increased motor activity at 4 months | Eriksson et al. 1990a; DDT(NS)
NMRI mouse | Once, PND 10 | ND | 0.5 | At 5 months of age: delayed habituation (increased motor activity), decrease in cortical muscarinic acetylcholine receptors, no change in high affinity or low affinity muscarinic binding sites | Eriksson et al. 1993; DDT(NS)
NMRI mouse | Once, PND 10 | ND | 0.5 | At 7 days after exposure: increased muscarinic receptor binding, decreased high affinity and increased low affinity muscarinic binding; no effect on sodium-dependent choline uptake; no changes 24 hours after exposure | Eriksson and Nordberg 1986; DDT(NS)
Other developmental effects
New Zealand rabbit | GDs 4–7 | ND | 1.0 | On GD 28, 33% decreased fetal weight; decreased fetal brain and kidney weights | Fabro et al. 1984; DDT(NS)
New Zealand rabbit | GDs 7–9 | ND | 10 | 11% decreased fetal weight on day 28 | Hart et al. 1972; p,p’-DDT
Sprague-Dawley rat | GDs 14–18 | ND | 10 | PND 13 males retained thoracic nipples; no effect on postnatal body weights, AGD, age of preputial separation; no effect on reproductive organ weights or serum testosterone | You et al. 1998; p,p;-DDE
Sprague-Dawley rat | GDs 15–19 | ND | 28 | Delayed vaginal opening (2 days) | Gellert and Heinrichs 1975; o,p’-DDD
Sprague-Dawley rat | GDs 15–19 | ND | 28 | Adult offspring: 11.9% increase in body weight; No effects on estrous cycle, vaginal opening, or ovary, adrenal or anterior pituitary weights | Gellert and Heinrichs 1975; o,p’-DDE
Sprague-Dawley rat | GDs 15–19 | ND | 28 | Offspring: 13% increase in body weight; no effects on estrous cycle, vaginal opening, or ovary, adrenal or anterior pituitary weights | Gellert and Heinrichs 1975; o,p’-DDT
Sprague-Dawley rat | GDs 15–19 | ND | 28 | In offspring: 26% decrease in ovary weight; 9% increase body weight; no effects on estrous cycle or vaginal opening | Gellert and Heinrichs 1975; p,p’-DDT
Neurological effects (adults)
F344 rat | Once | 25 | 50 | Hyperirritability and tremors; more severe at 100 mg/kg/day | Tilson et al. 1987; p,p’-DDT
F344 rat | Once | 25 | 50 | Tremors, more severe at 75 and 100 mg/kg/day; increased brain 5-HIAA, aspartate, and glutamate | Hong et al. 1986; Hudson et al. 1985; p,p’-DDT
Endocrine effects
Sprague-Dawley rat | Once | 25 | 50 | Reduced capacity to concentrate iodine in thyroid | Goldman 1981; Technical DDT
Dog | 14 days | ND | 50 | Decreased plasma glucocorticoids | Cueto 1970; o,p’-DDD
Reproductive effects
New Zealand rabbit | GDs 7–9 or 21–23 | ND | 10 | Increased resorptions and prematurity | Hart et al. 1972; p,p’-DDT
New Zealand rabbit | GDs 7–9 | ND | 50 | Increased resorptions | Hart et al. 1971; p,p’-DDT
Diabetes-related effects
Sprague-Dawley rat | 14 days | ND | 2 | Altered glucose homeostasis (increased fasting glucose and insulin, insulin resistance, impaired glucose tolerance) | Liang et al. 2020; p,p’-DDE
C57BL/6H mouse | 5 days | 0.4 | 2 | Hyperglycemia | Howell et al. 2014; p,p’-DDE

5-HIAA = 5-hydroxyindoleacetic acid; AGD = anogenital distance; DDD = dichlorodiphenyldichloroethane; DDE = dichlorodiphenyldichloroethylene; DDT = dichlorodiphenyltrichloroethane; GD = gestation day; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; NS = not specified; ND = not determined; PND = postnatal day

Increases in resorptions were observed in rabbits exposed to 10 mg/kg/day on GDs 7–9 (Hart et al. 1972). Neurological and endocrine effects have been observed at higher doses (≥50 mg/kg/day). The effects included tremors in adult rats after single exposures to p,p’-DDT (Hong et al. 1986; Hudson et al. 1985; Hwang and Van Woert 1978; Tilson et al. 1986, 1987) and decreased plasma glucocorticoids and reduced capacity to concentrate iodine in the thyroid were observed in dogs exposed to o,p’-DDD for 14 days (Cueto 1970) and in rats receiving a single dose to technical DDT (Goldman 1981), respectively. Neurodevelopmental effects were selected as the critical effect for derivation of the acute-duration oral MRL since it occurred at the lowest LOAEL of 0.5 mg/kg.

Selection of the Principal Studies: A group of seven related neurodevelopmental studies by the same investigators have consistently demonstrated an increase in spontaneous behaviors resulting in delayed habituation in 3–7-month-old mice (Eriksson and Nordberg 1986; Eriksson et al. 1990a, 1990b, 1992, 1993; Johansson et al. 1995, 1996). Additionally, five of these studies consistently reported a decrease in the density of muscarinic cholinergic receptors in the cerebral cortex at various time points following exposure. The seven studies were selected as co-principal studies.

Summary of the Principal Studies:

Eriksson P, Nordberg A. 1986. The effects of DDT, DDOH-palmitic acid, and chlorinated paraffin on muscarinic receptors and the sodium-dependent choline uptake in the central nervous system of immature mice. Toxicol Appl Pharmacol 85:121–127.3764899

Eriksson P, Archer T, Fredriksson A. 1990a. Altered behaviour in adult mice exposed to a single low dose of DDT and its fatty acid conjugate as neonates. Brain Res 514:141–142.2357521

Eriksson P, Nilsson-Hakansson L, Nordberg A, 1990b. Neonatal exposure to DDT and its fatty acid conjugate: Effects on cholinergic and behavioural variables in the adult mouse. Neurotoxicology 11:345–354.2234550

Eriksson P, Ahlbom J, Fredriksson A. 1992. Exposure to DDT during a defined period in neonatal life induces permanent changes in brain muscarinic receptors and behaviour in adult mice. Brain Res 582:277–281.1393550

Eriksson P, Johansson U, Ahlbom J, 1993. Neonatal exposure to DDT induces increased susceptibility to pyrethroid (bioallethrin) exposure at adult age - changes in cholinergic muscarinic receptor and behavioural variables. Toxicology 77:21–30 8442015

Johansson U, Fredriksson A, Eriksson P. 1995. Bioallethrin causes permanent changes in behavioural and muscarinic acetylcholine receptor variables in adult mice exposed neonatally to DDT. Eur J Pharmacol 293:159–166.7589230

Johansson U, Fredriksson A, Eriksson P. 1996. Low-dose effects of paraoxon in adult mice exposed neonatally to DDT: Changes in behavioural and cholinergic receptor variables. Environ Toxicol Pharmacol 2:307–314.21781735

In each study, groups of 10-day-old male NMRI mice were treated by gavage with a single dose of 0 (vehicle control) or 0.5 mg DDT (technical or NS)/kg in a 20% fat emulsion vehicle. Spontaneous behavior tests evaluating locomotion, rearing, and total activity were performed at either 4 (Eriksson et al. 1990a, 1990b, 1992), 5 (Eriksson et al. 1993; Johansson et al. 1996), or 7 months of age (Johansson et al. 1995, 1996). To determine the importance of exposure time during development, Eriksson et al. (1992) also dosed groups of mice on PND 3 or 19. To evaluate densities of muscarinic receptors, mice were sacrificed 24 hours, 7 days (Eriksson and Nordberg 1986), or 4, 5, or 7 months following exposure (Eriksson et al. 1990b, 1992; Johansson et al. 1995, 1996). Behavioral tests of spontaneous activity were conducted on 9–12 mice/group for 1 hour, and scores were summed for three 20-minute periods. During the last 40 minutes of testing, mice treated on PND 10 consistently showed significantly more activity than untreated controls (see Table A-2). This was interpreted as disruption of a simple, non-associative learning process (i.e., habituation) or a retardation in adjustment to a new environment. Mice dosed on PND 3 or 19 responded similarly to vehicle controls indicating that the developmental processes occurring on or immediately after PND 10 is particularly sensitive to exposure to technical DDT (Eriksson et al. 1992). To try to relate behavioral effects to specific neurological changes in the brain, several of the studies evaluated whether technical DDT affected the density of muscarinic acetylcholine (MACh) receptors in the brain, which are known to modulate neuronal excitability. Mice were sacrificed at various time points and crude synaptosomal P2 fractions were prepared from the cerebral cortex for measurement of MACh receptor densities. Details of sample preparation are less well described across studies; Eriksson and Nordberg (1986) reported pooling fractions from two to three animals, thereby generating a single biological replicate that was assayed in duplicate. More animals were used in other studies, but whether these samples were also pooled is unclear.

A summary of the results of these studies is found in Table A-2. Increases in motor activity were observed in mice exposed at PND 10 and tested at ≥4 months of age. Exposure at PND 10 also alters the density of MACh receptors, showing a significant ∼10% increase when evaluated in the neonatal brain at 7 days post-exposure (Eriksson and Nordberg 1986), with a significant 3–30% increase when evaluated in the adult mouse brain at 3–7 months of age (Eriksson et al. 1990b, 1992, 1993; Johansson et al. 1995, 1996). The authors suggested that the changes in MACh density and behavior might be the consequence of early interference with muscarinic cholinergic transmission specifically around the age of 10 days (Eriksson et al. 1992). The differential findings at 7 days post-exposure, compared to 3–7 months post-exposure, are likely due to initial upregulation of MACh receptors followed-by downregulation, potentially due to DDT and/or metabolite levels that peak 1–7 days post-exposure (Eriksson et al. 1990b). Eriksson et al. (1990b) also measured MACh densities from P2 fractions prepared from the hippocampus and striatum, but only MACh densities within the cerebral cortex were reduced. A few studies also measured proportions of muscarinic high- and low-affinity binding sites. In 7-day-old mice, there was a significant increase in the percentage of low-affinity binding sites and a significant decrease in high-affinity binding sites (Eriksson and Nordberg 1986). According to the authors, these low-affinity binding sites correspond to the M1 receptor in the cerebral cortex, which is thought to be associated with neuronal excitation. At later time points, no differences in high- or low-affinity proportions were observed. Other neurological tests described in these studies that yielded no significant effects include: measurements of sodium dependent choline uptake in the cerebral cortex (Eriksson and Nordberg 1986); choline acetyltransferase (ChAT) activity and potassium evoked release of ACh from the cerebral cortex (Eriksson et al. 1990b); acetylcholinesterase activity; proportions of nicotinic high- and low-affinity binding sites; and swim maze tests (Johansson et al. 1995, 1996).

Table A-2 Spontaneous Activity Test Results After a Single Oral Exposure of NMRI Mice to 0.5 mg/kg Technical DDT on PND 10

Reference | Treatment (PND) | Evaluation age (months)^a^ | Locomotion^b^ | Rearing^b^ | Total activity^b^ | Muscarinic receptor density
Eriksson and Nordberg 1986 | 10 | 24 hours after dose | NT | NT | NT | -
Eriksson and Nordberg 1986 | 10 | 7 days after dose | NT | NT | NT | ↑
Eriksson et al. 1990a | 10 | 4 | - ↑ ↑ | ↑ ↑ ↑ | - ↑ ↑ | NT
Eriksson et al. 1990b | 10 | 4 | - ↑ ↑ | ↑ ↑ ↑ | - ↑ ↑ | ↓
Eriksson et al. 1992 | 10 | 4 | - ↑ ↑ | ↑ ↑ ↑ | - ↑ ↑ | ↓
Eriksson et al. 1992 | 3 | 4 | - - - | - - - | - - - | -
Eriksson et al. 1992 | 19 | 4 | - - - | - - - | - - - | -
Eriksson et al. 1993 | 10 | 5 | - ↑ ↑ | ↑ ↑ ↑ | - ↑ ↑ | ↓
Johansson et al. 1995 | 10 | 7 | - ↑ ↑ | ↑ ↑ ↑ | - ↑ ↑ | ↓
Johansson et al. 1996 | 10 | 5 | - ↑ ↑ | ↑↑ ↑ | - ↑ ↑ | NT
Johansson et al. 1996 | 10 | 7 | - ↑ ↑ | ↑ ↑ ↑ | - ↑ ↑ | ↓

a Age at evaluation expressed in months unless indicated otherwise.

b Results reported (from left to right) for the 0–20-, 20–40-, and 40–60-minute measurement periods, respectively.

- (dashes) = no significant difference from vehicle controls; ↑ = increased at a particular time point, as compared with controls; ↓ = decreased, as compared with controls; DDT = dichlorodiphenyltrichloroethane; NT = not tested; PND = postnatal day

Within the group of studies, other tests were performed in attempts to further identify other exposure-related neurological effects in the cerebral cortex. Conclusions drawn from these results include: (1) DDT did not significantly alter acetylcholinesterase activity; (2) none of the treatments altered the density of nicotinic cholinergic receptors in the cortex; (3) none of the treatments altered performance in the swim maze test; (4) DDT exposure did not alter K^+^-stimulated acetylcholine release; and (5) DDT did not significantly alter sodium-dependent choline uptake in the cerebral cortex.

Selection of the Point of Departure for the MRL: The data were not amenable to benchmark dose (BMD) modeling because only a single dose was evaluated. The LOAEL of 0.5 mg/kg/day was therefore chosen as the POD.

Uncertainty Factor: The LOAEL of 0.5 mg/kg was divided by a total uncertainty factor of 1,000:

- 10 for use of a LOAEL
- 10 for animal to human extrapolation
- 10 for human variability
  - MRL = LOAEL ÷ UFs
  - MRL = 0.5 mg/kg/day ÷ (10 × 10 × 10) = 0.0005 mg/kg/day (0.5 µg/kg/day)

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Three additional studies by a different group of investigators evaluated neurobehavioral effects in mouse offspring after exposure in utero to doses ranging from 0.018 to 100 mg o,p’-DDT/kg/day during GDs 11–17 (Palanza et al. 1999, 2001; vom Saal et al. 1995). Palanza et al. (2001) reported no effects of o,p’-DDT exposure up to a high dose of 100 mg/kg/day on cliff avoidance or righting reflexes in postnatal pups. Palanza et al. (1999) administered doses of 0.018 and 0.18 o,p’-DDT/kg/day to pregnant dams and evaluated male offspring territorial aggression at 3 months of age. Compared to controls, treated males showed no statistically significant changes in the percent of attacking males per group or in other marks of aggression (latency to attack, number of bites, total attack time, tail rattling, or defensive behaviors). When only the attacking males from the control or the exposed groups were compared, the authors reported a reduction in aggressive behaviors in exposed males. Males exposed to 0.018 mg o,p’-DDT/kg/day showed a significant decrease in bite frequency and total attack time, and those exposed to 0.18 o,p’-DDT/kg/day also showed less tail rattling (Palanza et al. 1999). This is in contrast with a previous study reporting an increase in urine marking behavior, which is often considered a territorial behavior linked to displays of dominance and aggression (vom Saal et al. 1995). Palanza et al. (1999) also reported a small (∼<12%), but significant, reduction in paired testes weight in males exposed to 0.018 mg o,p’-DDT/kg/day, but not 0.18 mg o,p’-DDT/kg/day. These studies were not considered suitable for MRL derivation due to a variety of issues, including poor reporting (e.g., no description or inclusion of statistical analysis; vom Saal et al. 1995) and inconsistencies in results across doses (Palanza et al. 1999, 2001). Since the decreased aggressive behavior effects described by Palanza et al. (1999) were observed only when select subsets of individuals were included in the analysis and vom Saal et al. (1995) reported an apparent increased aggressive behavior (e.g., increased urine marking), the collective interpretation of these results is unclear.

Agency Contacts (Chemical Managers): Obaid Faroon

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | DDT, DDE, DDD, and their isomers
CAS Numbers: | 50-29-3, 72-55-9, 72-54-8
Date: | April 2022
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.0005 mg/kg/day (0.5 μg/kg/day)
Critical Effect: | Hepatocyte hypertrophy
Reference: | Harada et al. 2003, 2006
Point of Departure: | BMDL_10_ of 0.05 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 155
Species: | Rat

MRL Summary: The chronic-duration oral MRL of 0.0005 mg/kg/day (0.5 µg/kg/day) was adopted as the intermediate-duration oral MRL for DDT, DDE, and DDD based on an increased incidence of hepatocyte hypertrophy in male rats administered p,p’-DDT in their diets for 78 weeks (Harada et al. 2003, 2006). The MRL is based on a BMDL of 0.05 mg/kg/day and a total uncertainty factor of 100 (10 for extrapolation from animals to humans, and 10 for human variability).

Selection of the Critical Effect: Numerous animal studies have evaluated the oral toxicity of DDT, DDE, or DDD and their related isomers following intermediate-duration exposure. These studies examined a wide range of potentially sensitive targets. The LOAELs for these effects range from 0.25 to 200 mg/kg/day. The most sensitive outcomes were hepatic, reproductive, developmental, immunological, and neurological effects. A summary of lowest LOAELs (and associated NOAELs) for relevant endpoints is presented in Table A-3; given the number of studies evaluating these endpoints, only LOAELs ≤20 mg/kg/day are included in the table.

As shown in Table A-3, several effects associated with intermediate-duration exposure have been observed at levels ≤0.17 mg/kg/day. These include: (1) liver effects such as hepatic hypertrophy (Harada et al. 2003, 2006; Laug et al. 1950) and hepatocyte cytoplasmic vacuolation, mitochondrial changes, and lipid droplets (Liu et al. 2017a, 2017b); (2) developmental effects including cardiac hypertension and hypertrophy (La Merrill et al. 2016) and metabolic effects consisting of impaired glucose tolerance, hyperinsulinemia, dyslipidemia, and impaired cold tolerance (La Merrill et al. 2014a, 2014b); (3) reproductive effects including decreased corpora lutea and number of implants (Lundberg 1974); and (4) metabolic syndrome (Liang et al. 2020). The lowest LOAELs for immunological effects, including decreased immunoglobulins or antibody titers in response to antigens (Banerjee 1987a, 1987b; Banerjee et al. 1997a; Banerjee et al. 1995, 1996, 1997a, 1997b; Koner et al. 1998) and for neurological effects including decreased brain lipids (Sanyal et al. 1986) were observed at higher doses.

The liver is considered a primary target for DDT, DDE, DDD, and their related isomers, and hepatic toxicity (hepatocellular hypertrophy) was chosen as the critical effect for intermediate-duration exposures. Sixteen intermediate-duration studies evaluated liver toxicity, including two recent multi-dose studies that provide incidence data for non-neoplastic lesions in the liver (Harada et al. 2003, 2006; Hojo et al. 2006). Observed effects include hepatocellular hypertrophy in rats at 0.17 mg/kg/day (Harada et al. 2003, 2006), increases in liver weight in mice exposed to 5 mg p,p’-DDT/kg/day (Tomiyama et al. 2004), fatty changes in hepatocytes in male rats exposed to 3.44 p,p’-DDT/kg/day (Hojo et al. 2006), and focal necrosis in rats at 6.6 mg DDT(NS)/kg/day (Jonsson et al. 1981). Although several other effects also identified low LOAEL values, there is more supporting and consistent evidence that the liver is the critical target.

Table A-3 Summary of Relevant LOAEL and NOAEL Values Following Intermediate Oral Exposure to DDT, DDE, or DDD Isomers

Species | Duration | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference/compound
Liver effects
Osborne-Mendel rat | 15–27 weeks | 0.05 | 0.25 | Cellular hypertrophy and cytoplasmic eosinophilia; only qualitative data reported; effects described appear to have been minimal | Laug et al. 1950; Technical DDT
C57BL/6N mouse | 8 weeks | ND | 1.0 | Cytoplasmic vacuolation in hepatocytes, mitochondrial changes and lipid droplets (qualitative data only); no change in AST, ALT, ALP | Liu et al. 2017a, 2017b; p,p’-DDE
F344/DuCrj rat | 26 weeks | 0.21 F | 0.17 M; 2.2 F | Increased incidence of hepatocellular hypertrophy (6/6 exposed versus 0/6 controls) in both males and females at 1.7 and 2.2 mg/kg/day, respectively; 2/6 males at 0.17 mg/kg/day | Harada et al. 2003, 2006; p,p’-DDT
Sherman rat | 2–6 months | 0.5 M; 5 F | 1.7 M; 20 F | Mild hypertrophy, presence of lipospheres and cell margination; effects were dose-related and more pronounced at 5 mg/kg/day; qualitative data only | Ortega 1956; Technical DDT
Sprague-Dawley rat | 2 generations, 10 weeks before mating, then through mating, gestation, and lactation | 0.343 M; 0.73 F | 3.44 M; 3.75 F | P and F1 males: centrilobular hypertrophy, fatty change of hepatocytes (males only); increased relative liver weights | Hojo et al. 2006; p,p’-DDT
F344 rat | 28 days | ND | 5 | Increased absolute and relative liver weight, no liver histology done | Tomiyama et al. 2004; p,p’-DDT
NMRI mouse | 28 days | ND | 6.25 | increased absolute and relative liver weight | Orberg and Lundberg 1974; p,p’-DDT
Sprague-Dawley rat | 36 weeks | ND | 6.6 | Hepatic focal necrosis/regeneration | Jonsson et al. 1981; DDT (NS)
Hissar albino mouse | 3–12 weeks | 4.0 | 10 | Increased relative liver weight (14.7%); no liver histology done | Banerjee et al. 1986; p,p’-DDT
Wistar rat | 3 weeks | ND | 15 | Significant increase in liver weight; no liver histology done | Gupta et al. 1989; p,p’-DDT
Wistar rat | 6 weeks | ND | 20.2 | Increased relative liver weight (14.7%); no liver histology done | Banerjee et al. 1996; p,p’-DDT
Wistar rat | 6 weeks | ND | 20.2 | Increased relative liver weight (17.1% increase); no liver histology done | Banerjee et al. 1996; p,p’-DDE
Neurological effects
Rhesus monkey | 100 days | ND | 10 | 15–20% decrease in brain lipids, central nervous system phospholipids, and cholesterol | Sanyal et al. 1986; Technical DDT
Developmental effects
C57BL/6J mouse | GD 12–PND 5 | ND | 1.7 | Cardiac hypertension: increased systolic and diastolic blood pressure in male offspring at 5 months; increase systolic in males and females at 7 months; cardiac hypertrophy (increased left ventricular wall thickness) in females, but not males | La Merrill et al. 2016; Prepared mixture of p,p’-DDT (77.2%) and o,p’-DDT (22.8%)
C57BL/6J mouse | GD 12–PND 5 | ND | 1.7 | In females on high-fat diets for 12 weeks: metabolic syndrome (impaired glucose tolerance, hyperinsulinemia, dyslipidemia, impaired cold tolerance, altered bile acid metabolism); no effect on timing of puberty | La Merrill et al. 2016; Prepared mixture of p,p’-DDT (77.2%) and o,p’-DDT (22.8%)
Sprague-Dawley rat | GD 6–PND 20 | 5 | 15 | Increased relative liver weight (10.1%) | Yamasaki et al. 2009 p,p’-DDE
Wistar rat | GDs 1–21 and LDs 1–21 | 1.7 | 16.8 | Decreased body weights and growth of nursing pups | Clement and Okey 1974; o,p’-DDT
Immunological effects
Albino rat | 31 days | ND | 1.9 | Decreased mast cells | Gabliks et al. 1975; DDT (NS)
Albino rat | 8–22 weeks | 2.2 | 5.5 | Decreased relative spleen weight (17% decrease), increased serum albumin/globulin ratio and reduced IgG titers after tetanus toxoid stimulation; no effect on IgM titers, relative thymus weight, or body weight | Banerjee 1987b; p,p’-DDT
Wistar rat | 4 weeks | 2.3 | 5.7 | Decreased IgG and IgM; increased albumin/globulin ratio | Banerjee et al. 1995; p,p’-DDT
Hissar mouse | 3–12 weeks | 4.2 | 10.5 | Decreased splenic plaque-forming cell response to T-antigen independent lipopolysaccharide at weeks 6–12; decreased IgM antibody titer at 21 mg/kg/day | Banerjee 1987a; p,p’-DDT
Rockfeller mouse | 24 weeks | 4.3 | 10.7 | Increased growth of Mycobacterium leprae in footpad | Banerjee et al. 1997a; p,p’-DDT
Wistar rat | 6 weeks | ND | 20.2 | After ovalbumin immunization: decreased serum IgG and IgM, and ovalbumin antibody titre; increased percent migration of leukocytes and macrophages; decreased footpad thickness; decreased relative spleen weight; no effect on thymus weight | Banerjee et al. 1996; p,p’-DDT
Reproductive effects
NMRI mouse | 28 days | ND | 1.67 | Prolonged length of estrus cycle; decreased number of implants (223 versus 250 in controls) | Lundberg 1973; p,p’-DDT
NMRI Mouse | 72–74 days | ND | 2.0 | Decreased corpora lutea (17.2%) and small decrease in implants (125 versus 128) | Lundberg 1974; p,p’-DDT
New Zealand rabbit | 12 weeks (3 times/week) | ND | 3.0 | Decreased ovulation rate and slight decrease in circulating progesterone post-insemination | Lindenau et al. 1994; Technical DDT
Sprague-Dawley rat | 2-generations, 10 weeks before mating, then through mating, gestation, and lactation | 0.73 | 3.75 | F0 females: decreased estradiol levels; increased progesterone at 27.7 mg/kg/day, but no effects on F0 or F1 indices of mating and fertility, or viability of F1 and F2 offspring in any exposure group | Hojo et al. 2006; p,p’-DDT
B6C3F1 mouse | 86–130 days | 3.4 | 5.1 | Decreased number of pups/litter at birth or PND 1; decreased fertility | Ledoux et al. 1977; Technical DDT
NMRI mouse | 28 days | ND | 6.25 | Reduced seminal vesicles weight (28% reduced) in castrated males only; no effect on seminal vesicles or testes weight in intact animals | Orberg and Lundberg 1974; p,p’-DDT
Sprague-Dawley rat | 104 days; 14 days in utero, 20 lactational days, 70 days directly | ND | 35 | Increased serum testosterone, increased testicular mass and relative testes weight, and decreased seminiferous tubule diameter, seminiferous epithelium thickness, and lumen diameter | Patrick et al. 2016; DDE (NS)
Sprague-Dawley rat | GD 6–PND 20 | 15 | 50 | Significantly reduced weaning index and number of pups live on PND 21; no significant effects on number of litters, gestation index, gestational length, number of pups born, delivery index, birth index, or viability on PND 4 | Yamasaki et al. 2009; p,p’-DDE
Metabolic effects
Sprague-Dawley rat | 21 days | ND | 2 | Metabolic syndrome (increased fat pad weight and percent body fat, altered plasma lipid profile) | Liang et al. 2020; p,p’-DDE

ALP = alkaline phosphatase; ALT = alanine aminotransferase; AST = aspartate aminotransferase; DDD = dichlorodiphenyldichloroethane; DDE = dichlorodiphenyldichloroethylene; DDT = dichlorodiphenyltrichloroethane; F = female(s); GD = gestation day; LOAEL = lowest observed adverse effect level; M = male(s); ND = not detected; NOAEL = no observed-adverse-effect level; NS = not specified; P gen = parental generation; PND = postnatal day; LD = lactation day

Selection of the Principal Study: Harada et al. (2003, 2006) reported increases in the incidence of hepatocellular hypertrophy in males exposed to ≥0.17 mg/kg/day p,p’-DDT. Although the incidence (2/6) was not statistically different from controls (0/6), ATSDR considered this dose associated with a 33% increased incidence to be a LOAEL. At the next highest dose (1.7 mg/kg/day), hypertrophy was observed in 6/6 males and 6/6 females. This LOAEL is supported by the Laug et al. (1950) and Liu et al. (2017a, 2017b) studies. Other liver effects included microsomal enzyme activity, proliferation, inhibition of cell communication, and oxidative stress, in both males and females made at several timepoints between 4 and 52 weeks. Laug et al. (1950) reported hepatocellular hypertrophy in rats exposed to 0.25 mg technical DDT/kg/day for 15–27 weeks. However, Laug et al. (1950) provided no incidence data or statistical analysis, and only noted that at 0.25 mg/kg/day, “some of the rats were unaffected,” and the liver effects “were truly minimal.” Similarly, the Liu et al. (2017a, 2017b) studies only provided qualitative evidence of hepatocellular cytoplasmic vacuolation, mitochondrial changes, and lipid droplets in mice exposed to 1.0 mg p,p’-DDE/kg/day for 8 weeks. Hojo et al. (2006), reported quantitative hepatocyte hypertrophy incidence results that were consistent with the findings in Harada et al. (2003, 2006) and identified a LOAEL of 3.44 mg p,p’-DDT/kg/day and a NOAEL of 0.343 mg/kg/day. Because the Harada et al. (2003, 2006) study provides a better description of the dose-response relationship for liver lesions, it was selected as the basis of the MRL.

Summary of the Principal Study:

Harada T, Yamaguchi S, Ohtsuka R, 2003. Mechanisms of promotion and progression of preneoplastic lesions in hepatocarcinogenesis by DDT in F344 rats. Toxicol Pathol 31(1):87–98.12597452

Harada T, Ohtsuka R, Takeda M, 2006. Hepatocarcinogenesis by DDT in rats. J Toxicol Pathol 19:155–167.

Groups of 20 male and 20 female Fisher (F344/DuCrj) rats, 5 weeks of age, were administered 0, 5, 50, or 500 ppm p,p’-DDT in feed for 26 weeks (Harada et al. 2003, 2006). The study report provided intakes of 0, 0.17, 1.7, or 19.1 mg p,p’-DDT/kg/day (males) and 0, 0.21, 2.2, or 25.2 mg/kg/day (females), based on average feed consumption and body weight throughout a 2-year feeding study. These were adopted as the exposure doses for the 26-week collection point and are considered accurate for the following reasons: (1) the reported average food consumptions at all doses were comparable between the 2-year study and a pilot 4-week study; and (2) mean body weights of rats exposed to at least the two lowest doses were comparable to controls. Animals were sacrificed and livers were examined for: (1) cell proliferation (percent proliferating cell nuclear antigen [PCNA] labeling index), (2) GJIC (number of GJIC protein Cx32 spots), (3) microsomal enzyme induction (e.g., PROD activity and P450 isozyme contents, (4) oxidative stress (LPO and 8-OHdG), and (5) histopathology.

No clinical signs, mortalities, or body weight changes compared with controls were noted during the first year of this 2-year study. At 26 weeks, the liver lesions included: (1) hepatocellular hypertrophy at 26 weeks in 100% (6/6) of male and female rats treated with doses of ≥1.7 and 2.2 mg/kg/day, respectively. In low-dose males (0.17 mg/kg/day), 2/6 rats had hypertrophy (0/6 in controls), but the incidence was not statistically significantly elevated compared with controls and (2) large eosinophilic altered hepatocellular foci (AHF) were observed in high-dose males (19.1 mg/kg/day), but not females. In addition to these lesions, the following effects were noted in the livers: (1) significantly decreased hepatic levels of GJIC protein Cx32 spots were observed in males starting at 1.7 mg/kg/day and in females at 25.2 mg/kg/day, (2) statistically significantly increased hepatic levels of CYP1A2 and CYP3A2 protein were observed starting at 0.17 mg/kg/day and increased PROD activity and CYP2B1 and CYP4A1 levels starting at 1.7 mg/kg/day in males. In females, PROD activity, and CYP2B1 and CYP3A2 levels increased starting at 2.2 mg/kg/day, and (3) signs of oxidative stress were only observed at higher doses. Hepatic LPO contents significantly increased starting at 1.7 or 2.2 mg/kg/day in males and females, respectively, and 8-OHdG levels increased in males only at 19.2 mg/kg/day. No significant changes in cell proliferation were noted in the livers of exposed animals compared with controls.

Selection of the Point of Departure for the MRL: Male rat incidence data for 26 weeks of exposure (Table A-4) were fit to all available dichotomous models in EPA’s Benchmark Dose Software (BMDS; version 3.2) using a benchmark response (BMR) of 10% extra risk. Adequate model fit was judged by four criteria: goodness-of-fit statistics (chi-square p-value >0.1), visual inspection of the dose-response curve, BMDL that is not 10 times lower than the lowest non-zero dose, and scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest BMDL10 values were selected as potential PODs when the difference between the BMDL10 estimated from these models was >3-fold; otherwise, the BMCL from the model with the lowest Akaike’s Information Criterion (AIC) was chosen.

Table A-4 Incidences for Hepatic Hypertrophy in Male F344/DuCrj Rats After a 26-Week Exposure to p,p’-DDT in the Diet

Dose (mg/kg/day) | Incidence at 26 weeks/number
0 | 0/6
0.17 | 2/6
1.7 | 6/6
19.1 | 6/6

DDT = dichlorodiphenyltrichloroethane; N = total number of animals examined

Source: Harada et al. 2003, 2006

Only the Logistic and Probit models provided an adequate fit to the data. BMDLs were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Logistic). The frequentist, restricted Logistic model estimated a BMD_10_ and BMDL_10_ of 0.14 and 0.064 mg/kg/day, respectively. The results of the BMD modeling are summarized in Table A-5 and the model fit for the selected model is shown in Figure A-1.

Table A-5 Model Predictions for Hepatocyte Hypertrophy in Male F344/DuCrj Rats Administered p,p’-DDT in Their Diet For 26 Weeks (Harada et al. 2003, 2006)

| | | | | Scaled residuals^c^
Model | BMC_10_^a^ | BMCL_10_^a^ | p-Value^b^ | AIC | Dose below BMD | Dose above BMD
Dichotomous Hill | | | 1.00 | 11.64 | −0.0003 | −0.0006
Gamma^d^ | | | 1.00 | 9.65 | −0.0003 | −0.005
Log-Logistic^e^ | | | 1.00 | 11.64 | −0.002 | −0.0007
Multistage Degree 3^f^ | | | 1.00 | 13.64 | −0.0003 | 3.45×10^−8^
Multistage Degree 2^f^ | | | 1.00 | 11.64 | −0.0003 | −1.38×10^−7^
Multistage Degree 1^f^ | | | 0.95 | 11.79 | −0.0003 | −0.19
Weibull^d^ | | | 0.99 | 11.67 | −0.0003 | −0.03
Logistic ^g^ | 0.14 | 0.064 | 0.77 | 11.37 | −0.85 | 0.62
Log-Probit | | | 1.00 | 11.64 | −0.0003 | 1.12×10^−9^
Probit | 0.24 | 0.15 | 0.35 | 15.44 | 0.24 | 1.18

a BMCLs <10 times the lowest non-zero dose and their corresponding BMDs are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMD.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Selected model. BMCLs for models providing adequate fit differed by <3-fold; therefore, the model with the lowest AIC was selected (Logistic).

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL_10_ = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., 10 = dose associated with 10% extra risk); BMD = benchmark dose; DDT = dichlorodiphenyltrichloroethane

Figure A-1 Fit of Logistic Model to Data for Hepatocyte Hypertrophy in Rats Administered p,p’-DDT in Their Diet for 26 Weeks (Harada et al. 2003, 2006)

Uncertainty Factor: The BMDL is divided by a total uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

- MRL = BMDL ÷ UFs
- MRL = 0.064 mg/kg/day ÷ (10 × 10) = 0.0006 mg/kg/day

Since the MRL based on hepatocellular hypertrophy at 26 weeks is slightly higher than the acute-oral MRL of 0.0005 mg/kg/day, the intermediate-duration oral database was not considered adequate for derivation of an MRL. ATSDR opted to adopt the chronic-duration oral MRL of 0.0005 mg/kg/day based on hepatocellular hypertrophy at 78 weeks (see chronic oral MRL worksheet) as the intermediate-duration oral MRL.

Other Additional Studies or Pertinent Information that Lend Support to this MRL: The identification of the liver as the most sensitive target of toxicity is supported by a number of laboratory animal species reporting liver effects following intermediate-duration oral exposure to several DDT, DDE, and DDD isomers (Banerjee et al. 1986, 1996; Gupta et al. 1989; Harada et al. 2003, 2006; Hojo et al. 2006; Jonsson et al. 1981; Laug et al. 1950; Liu et al. 2017a, 2017b; Orberg and Lundberg 1974; Ortega 1956; Yamasaki et al. 2009). Four epidemiology studies have evaluated the possible associations between serum or cord blood DDT or DDE levels and serum or urinary biomarkers of liver damage or dysfunction (Freire et al. 2015a, 2015b; Morgan and Lin 1978; Serdar et al. 2014; Sunyer et al. 2008). The results of these studies do not provide consistent evidence for associations between levels of DDT/DDE/DDD biomarkers and alterations in serum levels of alanine aminotransferase, aspartate aminotransferase, γ-glutamyl transferase, lactate dehydrogenase, or bilirubin (Freire et al. 2015a, 2015b; Morgan and Lin 1978; Serdar et al. 2014). One study did find an association between cord blood DDE or DDT levels and urinary porphyrin levels (Sunyer et al. 2008).

Agency Contacts (Chemical Managers): Obaid Faroon

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | DDT, DDE, DDD, and their isomers
CAS Numbers: | 50-29-3, 72-55-9, 72-54-8
Date: | April 2022
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL: | 0.005 mg/kg/day (0.5 μg/kg/day)
Critical Effect: | Hepatocellular hypertrophy
Reference: | Harada et al. 2003, 2006
Point of Departure: | BMDL_10_ of 0.05 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 155
Species: | Rat

MRL Summary: A chronic-duration oral MRL of 0.0005 mg/kg/day (0.5 µg/kg/day) was derived for DDT, DDE, and DDD based on an increased incidence of hepatocyte hypertrophy in rats administered p,p’-DDT in their diets for 78 weeks (Harada et al. 2003, 2006). The MRL is based on a BMDL_10_ of 0.05 mg/kg/day and a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: At least 35 animal studies have evaluated the chronic oral toxicity of DDT, DDE, or DDD and their related isomers. These studies examined a wide range of potentially sensitive targets; the most sensitive effects appear to be hepatic, body weight, developmental, hematological, and neurological outcomes. A summary of the lowest reliable LOAELs (and associated NOAELs) for these sensitive endpoints is presented in Table A-6; the table is limited to LOAELs of ≤27 mg/kg/day, because of the large number of chronic-duration studies.

A comparison of the lowest LOAELs identified in animal studies suggests that the liver may be the most sensitive target, followed by body weight, developmental, neurological, and hematological alterations. Sixteen studies examined the liver in rats, mice, monkeys, hamsters, and dogs chronically exposed to DDT, DDE, or DDD (Cabral et al. 1982a; Deichmann et al. 1967; Del Pup et al. 1978; Durham et al. 1963; Fitzhugh and Nelson 1947; Graillot et al. 1975; Harada et al. 2003, 2006; Lehman 1965; NCI 1978 [six studies]; Rossi et al. 1983; Takayama et al. 1999). Additionally, a human study examined potential liver effects following 12–18-month dietary exposure to 0.5 mg/kg/day but did not find alterations in parameters of liver function (Hayes et al. 1956). In laboratory animals, fatty metamorphosis, hepatocellular hypertrophy, necrosis, altered hepatocellular foci, or amyloidosis have been observed at LOAELs of 0.17–49 mg/kg for technical DDT, p,p’-DDT, or p,p’-DDE. In contrast to these findings, NCI (1978) reported NOAELs of 231 and 142 mg/kg/day in rats and mice, respectively, exposed to technical DDD for 78 weeks, suggesting that the rodent liver may be less sensitive from chronic exposure to DDD, compared with DDT or DDE. At 0.4 mg/kg/day, increases in body weight gain were observed in the P0 and F1 (categorized as a developmental effect) rats exposed to p,p’-DDT in a 2-generation study involving lifetime exposure (Tomatis et al. 1972). The lowest LOAEL for both neurological and hematological effects is 19.1 mg p,p’-DDT/kg/day (Harada et al. 2003, 2006; Tomita et al. 2013); effects observed at this dose level included tremors, reductions in hemoglobin levels, and increased hematopoiesis in the bone marrow. Liver effects were selected as the critical effect because the lowest LOAEL was for liver effects, and there are extensive data supporting it as a critical effect.

Table A-6 Summary of Relevant LOAEL and NOAEL Values Following Chronic Oral Exposure to DDT, DDE, and DDD Isomers

Species | Duration | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference/compound
Hepatic effects
F344/DuCrj rat | 2 years | ND | 0.17 M; 2.2 F | Increased incidence of hepatocellular hypertrophy | Harada et al. 2003, 2006; p,p’-DDT
B6C3F1 mouse | 78 weeks | ND | 3.7 M | Amyloidosis (males only) | NCI 1978; Technical DDT
Cynomolgus monkey | 130 months | ND | 6.4 F | Fatty changes | Takayama et al. 1999; p,p’-DDT
Osborne-Mendel rat | 2 years | ND | 7 | Focal hepatocellular necrosis | Fitzhugh and Nelson 1947; Technical DDT
Osborne-Mendel rat | 27 months | ND | 20 | Focal hepatocellular necrosis | Deichmann et al. 1967; DDT (NS)
Syrian hamster | Lifetime | 10 M | 20 M | Focal necrosis, hepatocyte hypertrophy, no increase in tumors | Cabral et al. 1982a; Technical DDT
Osborne-Mendel rat | 78 weeks | ND | 23 M | Fatty metamorphosis | NCI 1978; Technical DDT
Neurological effects
F344/DuCrj rat | 2 years | 1.7 M; 2.2 F | 19.1 M; 25.2 F | Whole body tremors weeks 70–104 | Harada et al. 2003, 2006; p,p’-DDT
Developmental effects
CF1 mouse | 2-generation study involving lifetime exposure | | 0.4 | Increased offspring body weight: >50% increase at some time-points (particularly in males) between 5 and 18 months; no dose-dependent pattern | Tomatis et al. 1972; p,p’-DDT
Sprague-Dawley rat | 2-generation | 1.9 | 18.6 | Tail abnormalities (constriction rings in 13.2–25.5% incidence); no effect on birth weights or body weights at weaning | Ottoboni 1969; Technical DDT
Hematological effects
F344 rat | Up to 104 weeks | 0.17 | 1.7 | Reduced hemoglobin and mean corpuscular volume at week 78, but not at 104 weeks; increased hematopoiesis in bone marrow | Tomita et al. 2013; p,p’-DDT
Osborne-Mendel rat | 27 months | | 20 | Hemolysis in spleen | Deichmann et al. 1967; DDT (NS)
Body weight effects
CF1 mouse | 2-generation study involving lifetime exposure | | 0.4 | Significant increase in body weights in P0 females (up to 60% increase) compared with controls between 3 and 18 months; largest increases at lowest dose | Tomatis et al. 1972; p,p’-DDT
F344/DuCrj rat | 2 years | 1.7 | 19.1 | 12% decreased mean body weight | Harada et al. 2003, 2006; p,p’-DDT

DDD = dichlorodiphenyldichloroethane; DDE = dichlorodiphenyldichloroethylene; DDT = dichlorodiphenyltrichloroethane; F = female(s); LOAEL = lowest observed adverse effect level; M = male(s); NOAEL = no observed-adverse-effect level; NS = not specified

Selection of the Principal Study: The Harada et al. (2003, 2006) study was selected as the basis of the chronic-duration oral MRL because it identified the lowest LOAEL for liver effects and provides adequate data to describe the dose-response relationship at low-dose levels.

Summary of the Principal Study:

Harada T, Yamaguchi S, Ohtsuka R, 2003. Mechanisms of promotion and progression of preneoplastic lesions in hepatocarcinogenesis by DDT in F344 rats. Toxicol Pathol 31(1):87–98.12597452

Harada T, Ohtsuka R, Takeda M, 2006. Hepatocarcinogenesis by DDT in rats. J Toxicol Pathol 19:155–167.

Starting at 5 weeks of age, groups of 40 male and 40 female Fisher (F344/DuCrj) rats and a satellite group of 20 males and 20 females were fed p,p’-DDT in their diets at dietary concentrations of 0, 5, 50, or 500 ppm (Harada et al. 2003, 2006). The study report provided intakes of 0, 0.17, 1.7, or 19.1 mg p,p’-DDT/kg/day (males) and 0, 0.21, 2.2, or 25.2 mg/kg/day (females), based on average feed consumption and body weight throughout the 2-year feeding study. Six males and six females from each dose group were sacrificed after 26, 52, and 78 weeks of treatment and the following endpoints in the liver were monitored: (1) cell proliferation activity in the liver (immunohistochemistry staining for PCNA); (2) GJIC (immunohistochemistry analysis for hepatic gap junction protein connexin 32 [Cx32]); (3a) hepatic microsomal enzyme activity (PROD activity) and (3b) cytochrome P450 isozyme contents; hepatic levels of oxidative stress markers: (4a) LPO and (4b) 8-OHdG; (5) absolute and relative liver weights; and (6) histopathological examination of livers with morphometry.

Male and female rats in the high-dose group (19.1 and 25.2 mg/kg/day) had whole body tremors in weeks 70–104; females appeared more sensitive to tremors. There was no treatment-related mortality during the study. Mean body weight decreases of 12 and 25% were observed in males at 19.1 mg/kg/day and females at 25.2 mg/kg/day, respectively, but it is unclear when this was determined during the study. Body weights of rats at lower doses were not significantly different from controls. There was a tendency for increased food intake in males at 19.1 mg/kg/day, though not statistically different from controls. Non-neoplastic and neoplastic lesions were observed in the liver. Absolute and relative liver weight data were provided for the treated groups but not for the control group, so the magnitude of the changes (increases) compared with controls cannot be determined. Centrilobular hepatocellular hypertrophy was reported in males at all doses and in females at 2.2 and 25.2 mg/kg/day; incidence and severity showed a dose-related response and were related to elevated microsomal activity. Increased incidences of eosinophilic altered hepatocellular foci (AHF) were observed in males dosed with ≥1.7 mg/kg/day and females dosed with ≥2.2 mg/kg/day. The number and size of AHF increased with treatment time and dose and appeared earlier in males; AHFs were often located close to, or within, hypertrophic regions. Males in the 1.7 and 19.1 mg/kg/day groups had a significantly increased incidence of hepatocellular adenomas first seen on week 104. Females in the 25.2 mg/kg/day group also showed a significantly increased incidence of hepatocellular adenomas on week 104. Total incidences in the 0, 0.17, 1.7, and 19.1 mg/kg/day males were 0/40, 0/40, 5/40, and 22/40, respectively; corresponding incidences in females at 0, 0.21, 2.2, and 25.2 mg/kg/day were 0/40, 0/40, 0/40, and 16/40. Significantly increased incidence of hepatocellular carcinomas occurred only in males at 19.1 mg/kg/day (14/40 versus 0/40 in all other groups).

There was no cell proliferation in the liver (as measured by the percent PCNA LI in the liver) at any dose for either sex. Significant decreases in liver GJIC (as measured by number of GJIC protein Cx32) occurred at the mid- and high-dose throughout the duration of the study. A significant decrease in GJIC protein Cx32 was found in males in the low-dose group at 78 weeks, but not at any other time point. There were significant changes in hepatic microsomal enzyme activity and P450 isozyme contents.

Significantly increased PROD activity (males: ≥0.17 mg/kg/day; females: ≥2.2 mg/kg/day) occurred throughout the study; except for males at the highest dose where the increase was not significant after 52 weeks of exposure. Rats of both sexes in the mid- and high-dose groups showed dose-dependent significant increases of CYP2B1 and CYP3A2 enzymes. There were no dose-dependent, treatment-related changes in CYP1A2 or CYP4A1 enzymes in either sex. Oxidative stress was evident in increased hepatic lipid peroxide in males at 50 and 500 ppm; females showed inconsistent increases with significant differences occurring at 26 and 104 weeks at the mid dose, and only at 26 weeks at the high dose. Increased 8-OHdG levels were significant at the highest dose in both males and females.

Selection of the Point of Departure for the MRL: The Harada et al. (2003, 2006) study identified a LOAEL of 0.17 mg/kg/day for hepatocellular hypertrophy in male rats exposed to p,p’-DDT for 78 or 104 weeks. The lowest LOAEL in female rats was 2.2 mg/kg/day also for hepatocellular hypertrophy. BMD modeling was conducted to identify a POD using incidence data for hepatocellular hypertrophy in males because consistent evidence across multiple studies suggest males are more sensitive to liver toxicity due to exposure to DDT isomers than females.

Male rat incidence data for 78 and 104 weeks of exposure (Table A-7) were fit to all available dichotomous models in EPA’s BMDS (version 3.2) using a BMR of 10% extra risk. Adequate model fit and model selection were done as described in the intermediate-duration oral MRL section.

No dichotomous models provided adequate fit to the increased incidence of hepatocyte hypertrophy in male rats at 104 weeks using the full dataset or with the highest dose dropped. For the 78-week data, only the Logistic and Probit models provided an adequate fit to the data. BMDLs were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Logistic). The frequentist, restricted Logistic model estimated a BMD_10_ and a BMDL_10_ of 0.10 and 0.055 mg/kg/day, respectively. The results of the BMD modeling are summarized in Table A-8 and the model fit for the selected model is shown in Figure A-2.

Table A-7 Incidences for Hepatic Hypertrophy in Male F344/DuCrj Rats after 78- and 104-Week Exposure to p,p’-DDT in the Diet

Dose (mg/kg/day) | Incidence at 78 weeks/N | Incidence at 104 weeks/N
0 | 0/8 | 0/35
0.17 | 4/8 | 15/30
1.7 | 8/8 | 33/36
19.1 | 7/7 | 31/33

N = total number of animals examined; DDT = dichlorodiphenyltrichloroethane

Source: Harada et al. 2003, 2006

Table A-8 Model Predictions for Hepatocyte Hypertrophy in Male F344/DuCrj Rats Administered p,p’-DDT in Their Diet For 78 Weeks (Harada et al. 2003, 2006)

| | | | | Scaled residuals^c^
Model | BMC_10_^a^ | BMCL_10_^a^ | p-Value^b^ | AIC | Dose below BMD | Dose above BMD
Dichotomous Hill | | | 0.97 | 17.09 | −0.0003 | −0.0004
Gamma^d^ | | | 1.00 | 13.09 | −0.0003 | −0.002
Log-Logistic^e^ | | | 1.00 | 15.09 | −0.0005 | −0.0004
Multistage Degree 3^f^ | | | 1.00 | 17.09 | −0.0003 | 7.34×10^−9^
Multistage Degree 2^f^ | | | 1.00 | 15.09 | −0.0003 | −1.26×10^−7^
Multistage Degree 1^f^ | | | 1.00 | 15.11 | −0.0004 | −0.03
Weibull^d^ | | | 1.00 | 13.10 | −0.0003 | −0.006
Logistic ^g^ | 0.10 | 0.055 | 0.45 | 17.03 | −1.28 | 1.01
Log-Probit | | | 1.00 | 17.09 | −0.0004 | −6.07×10^−6^
Probit | 0.21 | 0.14 | 0.14 | 21.90 | 0.85 | 1.15

a BMCLs <10 times the lowest non-zero dose and their corresponding BMDs are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMD.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Selected model. BMCLs for models providing adequate fit differed by <3-fold; therefore, the model with the lowest AIC was selected (Logistic).

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL_10_ = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., 10 = dose associated with 10% extra risk); BMD = benchmark dose; DDT = dichlorodiphenyltrichloroethane

Figure A-2 Fit of Logistic Model to Data for Hepatocyte Hypertrophy in Rats Administered p,p’-DDT in Their Diet for 78 Weeks (Harada et al. 2003, 2006)

Uncertainty Factor: The BMDL_10_ is divided by a total uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

- MRL = BMDL_10_ ÷ UFs
- MRL = 0.055 mg/kg/day ÷ (10 × 10) = 0.0005 mg/kg/day (0.5 µg/kg/day)

Other Additional Studies or Pertinent Information that Lend Support to this MRL: The identification of the liver as the most sensitive target of toxicity is supported by studies in several laboratory animal species reporting liver effects following chronic-duration oral exposure to DDT, DDE, and DDD isomers (Cabral et al. 1982a; Deichmann et al. 1967; Del Pup et al. 1978; Durham et al. 1963; Fitzhugh and Nelson 1947; Graillot et al. 1975; Harada et al. 2003, 2006; Lehman 1965; NCI 1978; Rossi et al. 1983; Takayama et al. 1999). The observed effects included fatty metamorphosis, hepatocellular hypertrophy, necrosis, altered hepatocellular foci, and amyloidosis. No liver effects (as assessed via serum liver enzyme levels) were observed in an experimental human study involving exposure to 0.5 mg technical DDT/kg/day (Hayes et al. 1956). Similarly, environmental exposure studies did not find alterations in serum clinical markers of liver damage or dysfunction associated with serum blood DDT or DDE levels (Freire et al. 2015a, 2015b; Morgan and Lin 1978; Serdar et al. 2014). Sunyer et al. (2008) did find an association between cord blood DDE or DDT levels and urinary porphyrin levels (Sunyer et al. 2008).

Agency Contacts (Chemical Managers): Obaid Faroon