# 9 REFERENCES

* Cited in text

*Abukutsa MO, Chweya JA, Mochoge BO, . 1993. Effect of nitrogen sources and storage on thiocyanate content of kale (Brassica oleracea var. Acephala) leaves. Discov Innov 5(4):367–371.
ACGIH. 1995. 1995-1996 Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
ACGIH. 2001a. Cyanogen. Documentation of the threshold limit values for chemical substances. 7th ed. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
ACGIH. 2001b. Cyanogen chloride. Documentation of the threshold limit values for chemical substances. 7th ed. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
ACGIH. 2001c. Hydrogen cyanide and cyanide salts. Documentation of the threshold limit values for chemical substances. 7th ed. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
*ACGIH. 2003. Cyanide. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
*Adams DJ, Takeda K, Umbach JA. 1985. Inhibitors of calcium buffering depress evoked transmitter release at the squid giant synapse. J Physiol 369:145–159.2419546
*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Agar NS, Harley JD. 1972. Erythrocytic methaemoglobin reductases of various mammalian species. Experientia 28:1248–1249.4404479
*Agarwal PK, Kumari R. 2003. Nitroprusside in critically ill patients with aortic stenosis. N Engl J Med 349:811–813.
*Agency for Toxic Substance and Disease Registry. 1989a. Health assessment for ALSCO Anaconda National priorities list. Atlanta, GA: U.S. Agency for Toxic Substance and Disease Registry. PB90100330.
*Agency for Toxic Substances and Disease Registry. 1989b. Decision guide for identifying substance-specific data needs related to toxicological profiles. Atlanta, GA: Agency for Toxic Substances and Disease Registry, Division of Toxicology.
*Agency for Toxic Substances and Disease Registry. 1998. Public health assessment for MRI Corporation Tampa, Hillsborough County, Florida CERCLIS no. FLD088787585. July 28, 1998. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry. PB98159841.
*Agency for Toxic Substances and Disease Registry. 1999a. Public health assessment for Greenwood Chemical Company, Greenwood, Albemarle County, Virginia, Region 3. Atlanta, GA: Virginia State Department of Health, Agency for Toxic Substances and Disease Registry. PB99132987.
*Agency for Toxic Substances and Disease Registry. 1999b. Public health assessment for Byron Salvage Yard (a/k/a Byron Johnson) Byron, Ogle County, Illinois CERCLIS no. ILD010236230. May 20, 1999. Atlanta, GA: Department of Health and Human Services, Agency for Toxic Substances and Disease Registry. PB99149239.
*Agency for Toxic Substances and Disease Registry/Centers for Disease Control and Prevention. 1990. Subcommittee report on biological indicators of organ damage. Atlanta, GA: Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention.
*Agrawal V, Cherian L, Gupta VK. 1991. Extraction spectrophotometric method for the determination of hydrogen cyanide in environmental samples using 4-aminosalicylic acid. Int J Environ Anal Chem 45:235–244.
*Ahmed AE, Farooqui MYH. 1982. Comparative toxicities of aliphatic nitriles. Toxicol Lett 12:157–163.6287676
*Aitken PG, Braitman DJ. 1989. The effects of cyanide on neural and synaptic function in hippocampal slices. Neurotoxicology 10:239–248.2559376
*Aitken D, West D, Smith F, . 1977. Cyanide toxicity following nitroprusside-induced hypotension. Can Anaesth Soc J 24:651–660.589503
*Akcil A, Mudder T. 2003. Microbial destruction of cyanide wastes in gold mining: Process review. Biotechnol Lett 25:445–450.12882268
Alarie Y. 2002. Toxicity of fire smoke. Crit Rev Toxicol 32(4):259–289.12184505
*Aletor VA. 1993. Cyanide in garri. 1. Distribution of total, bound and free hydrocyanic acid in commercial garri, and the effect of fermentation time on residual cyanide content. Int J Food Sci Nutr 44(4):281–287.
Alexander K, Baskin SI. 1987. Mechanistic studies of guinea-pig liver rhodanese [Abstract]. Fed Proc 46:954.
*Allen DG, Smith GL. 1985. Intracellular calcium in metabolically depleted ferret ventricular muscle during exposure to cyanide and its removal. J Physiol 269:1–92.
*Altman PL, Dittmer DS, eds. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
Aminlari M, Li A, Kunanithy V, . 2002. Rhodanese distribution in porcine (Sus scrofa) tissues. Comp Biochem Physiol B 132(2):309–313.12031455
*Amoore JE, Hautala E. 1983. Odor as an aid to chemical safety: Odor thresholds compared with threshold limit values and volatilities for 214 industrial chemicals in air and water dilution. J Appl Toxicol 3:272–290.6376602
*AMRL. 1971. The acute toxicity of brief exposures to hydrogen fluoride, hydrogen chloride, nitrogen dioxide, and hydrogen cyanide singly and in combination with carbon monoxide. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory. AD751442.
*Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically-based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives. New York, NY: Marcel Dekker Inc., 9–25.
*Andersen ME, Clewell HJ III, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
*Andrews JM, Sweeney ES, Grey TC, . 1989. The biohazard potential of cyanide poisoning during postmortem examination. J Forensic Sci 34:1280–1284.2809551
*Ansell M, Lewis FAS. 1970. A review of cyanide concentrations found in human organs: A survey of literature concerning cyanide metabolism, normal, non-fatal, and fatal body cyanide levels. J Forensic Med 17:148–155.4924688
*APHA. 1992. Cyanide (4500-CN)/thiocyanate. Standard methods for the examination of water and wastewater, 18th edition. Washington, DC: American Public Health Association.
Arai M, Imai H, Koumura T, . 1999. Mitochondrial phospholipid hydroperoxide glutathione peroxidase plays a major role in preventing oxidative injury to cells. J Biol Chem 274:4924–4933.9988735
*Ardelt BK, Borowitz JL, Isom GE. 1989. Brain lipid peroxidation and antioxidant protectant mechanisms following acute cyanide intoxication. Toxicology 56:147–154.2734799
*Ardelt BK, Borowitz JL, Maduh EU, . 1994. Cyanide-induced lipid peroxidation in different organs: Subcellular distribution and hydroperoxide generation in neuronal cells. Toxicology 89(2):127–137.8197590
*Arun P, Moffett JR, Ives JA, . 2005. Rapid sodium cyanide depletion in cell culture media: Outgassing of hydrogen cyanide at physiological pH. Anal Biochem 339(2):282–289.15797569
*ASTM. 1994a. Standard test methods for thiocyanate in water. Annual book of ASTM standards. Vol. 11.02 Water(II). Philadelphia, PA: American Association for the Testing of Materials, 136–139.
*ASTM. 1994b. Standard test methods for cyanide in water- Automated method for total cyanide, dissociable cyanide and thiocyanate. Annual book of ASTM standards. Vol. 11.02 Water(II). Philadelphia, PA: American Association for the Testing of Materials, 102–111.
ASTM. 1994c. Standard test methods for cyanide in water. Annual book of ASTM standards. Vol. 11.02 Water(II). Philadelphia, PA: American Association for the Testing of Materials, 79–95.
*ASTM. 1999. Standard test methods for cyanides in water. In: Allen RF, Baldini NC, Donofrio PE, ., eds. 1999 Annual book of ASTM standards. Section 11. Water and environmental technology. 11.02. West Conshohocken, PA: American Society for Testing and Materials, 78–96.
*Atkinson R. 1989. In: Lide DR JR., ed. Kinetics and mechanisms of the gas-phase reactions of the hydroxyl radical with organic compounds. New York, NY: American Chemical Society. American Institute of Standards and Technology, 191, 198.
Backofen U, Matysik F, Werner G. 1996. Determination of cyanide in microsamples by means of capillary flow injection analysis with amperometric detection. Fresenius J Anal Chem 356:271–273.
*Baker RR, Proctor CJ. 1990. The origins and properties on environmental tobacco smoke. Environ Int 16:231–245.
*Ballantyne B. 1983a. The influence of exposure route and species on the acute lethal toxicity and tissue concentrations of cyanide. In: Hayes AW, Schnell RC, Miya TS, eds. Developments in the science and practice of toxicology. New York, NY: Elsevier Science Publishers, 583–586.
*Ballantyne B. 1983b. Acute systemic toxicity of cyanides by topical application to the eye. J Toxicol Cutan Ocular Toxicol 2:119–129.
*Ballantyne B. 1983c. Artifacts in the definition of toxicity by cyanides and cyanogens. Fundam Appl Toxicol 3:400–408.6315515
Ballantyne B. 1987a. Hydrogen cyanide as a product of combustion and a factor in morbidity and mortality from fires. In: Ballantyne B, Marrs TC, eds. Clinical and experimental toxicology of cyanides. Bristol, UK: IOP Publishing Limited, 248–291.
Ballantyne B. 1987b. Toxicology of cyanide. In: Ballantyne B, Marrs TC, eds. Clinical and experimental toxicology of cyanides. Bristol, UK: IOP Publishing Limited, 41–126.
*Ballantyne B. 1988. Toxicology and hazard evaluation of cyanide fumigation powders. Clin Toxicol 26:325–335.
*Ballantyne B. 1994. Acute percutaneous systemic toxicity of cyanides. J Toxicol Cutaneous Ocul Toxicol 13(3):249–262.
Ballantyne G, Bright J, Swanston DW, . 1972. Toxicity and distribution of free cyanides given intramuscularly. Med Sci Law 12:209–219.5038516
*Banerjee KK, Muthu PM. 1994. Effect of cigarette smoking on thyroid hormone homeostasis. Indian J Med Res 99:74–76.8005642
Banerjee KK, Bishayee A, Marimuthu P. 1997. Evaluation of cyanide exposure and its effect on thyroid function of workers in a cable industry. J Occup Environ Med 39(3):258–260.9093978
*Barber TR, Lutes CC, Doorn MRJ, . 2003. Aquatic ecological risks due to cyanide releases from biomass burning. Chemosphere 50:343–348.12656253
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessment. Regul Toxicol Pharmacol 8:471–486.3222488
*Basheer S, Kut O, Prenosil J, . 1992. Kinetics of enzymatic degradation of cyanide. Biotech Bioeng 39:629–634.
Baskin SI. 2001. The pharmacology and toxicology of cyanide and its derivatives. In: Young CA, Twidwell LG, Anderson CG, eds. Cyanide: Social, industrial and economic aspects. Warrendale, PA: TMS (The Minerals, Metals and Materials Society).
Baskin S, Kirby S. 1990. Effect of sodium tetrathionate on cyanide conversion to thiocyanate by enzymatic and non-enzymatic mechanisms [Abstract]. Toxicologist 10:326.
*Baskin SI, Nealley EW, Lempka JC. 1996. Cyanide toxicity in mice pretreated with diethylamine nitric oxide complex. Hum Exp Toxicol 15(1):13–18.8845203
*Baskin SI, Porter DW, Rockwood GA, . 1999. In vitro and in vivo comparison of sulfur donors as antidotes to acute cyanide intoxication. J Appl Toxicol 19:173–183.10362268
*Baskin SI, Wilkerson G, Blitstein AG, . 1987. Cardiac effects of cyanide. In: Ballantyne B, Marrs TC, eds. Clinical and experimental toxicology of cyanides. Bristol: IOP Publishing Limited, 62–79.
*Bass NH. 1968. Pathogenesis of myelin lesions in experimental cyanide encephalopathy. Neurology 18:167–177.5688758
*Basu TK. 1983. High-dose ascorbic acid decreases detoxification of cyanide derived from amygdalin (laetrile): Studies in guinea pigs. Can J Physiol Pharmacol 61:1426–1430.6661693
*Baud FJ, Borron SW, Bavoux E, . 1996. Relation between plasma lactate and blood cyanide concentrations in acute cyanide poisoning. Br Med J 312:26–27.8555853
*Baud FJ, Borron SW, Megarbane B, . 2002. Value of lactic acidosis in the assessment of the severity of acute cyanide poisoning. Crit Care Med 30(9):2044–2050.12352039
Beasley DMG, Glass WI. 1998. Cyanide poisoning: Pathophysiology and treatment recommendations. Occup Med 48(7):427–431.
*Bedding ND, McIntyre AE, Perry R, . 1982. Organic contaminants in the aquatic environment. I. Sources and occurrence. Sci Total Environ 25:143–167.
*Belly RT, Goodhue CT. 1976. A radiorespirometric technique for measuring the biodegradation of specific components in a complex effluent. In: Sharpley JM, Kaplan AM, eds. Proceedings of the 3rd international biodegradation symposium, 1975. Barking, England: Applied Science, 1103–1107.
*Benabid MAS, Decorps M, Remy C. 1987. ^31^P nuclear magnetic resonance in vivo spectroscopy of the metabolic changes induced in the awake rat brain during KCN intoxication and its reversal by hydroxocobalamine. J Neurochem 48:804–808.3027259
*Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag.
*Berlin C. 1977. Cyanide poisoning--A challenge. Arch Intern Med 137:993–994.879954
Bernaudin M, Nouvelot A, MacKenzie ET, . 1998. Selective neuronal vulnerability and specific glial reactions in hippcampal and neocortical organotype cultures submitted to ischemia. Exp Neurol 150:30–39.9514820
*Betts PM, Rinder DF, Fleeker JR. 1979. Thiocyanate utilization by an Arthobacter. Can J Microbiol 25:1277–1282.120217
Bhatt HR, Linnell JC. 1987. The role of rhodanese in cyanide detoxification: Its possible use in acute cyanide poisoning in man. In: Ballantyne B, Marrs TC, eds. Clinical and experimental toxicology of cyanides. Bristol, UK: IOP Publishing Limited, 440–450.
*Bhattacharya R. 1995. Therapeutic efficacy of sodium nitrite and 4-dimethylaminophernol or hydroxylamine co-administration against cyanide poisoning in rats. Hum Exp Toxicol 14:29–33.7748613
*Bhattacharya R, Laskshmana Rao PV. 1997. Cyanide induced DNA fragmentation in mammalian cell cultures. Toxicology 123:207–215.9355939
*Bhattacharya R, Lakshmana Rao PV. 2001. Pharmacological interventions of cyanide-induced cytotoxicity and DNA damage in isolated rat thymocytes and their protective efficacy in vivo. Toxicol Lett 119:59–70.11275422
*Bhattacharya R, Vijayaraghavan R. 2002. Promising role of α-ketoglutarate in protecting against the lethal effects of cyanide. Hum Exp Toxicol 21:297–303.12195933
*Bhattacharya R, Jeevaratnam K, Raza SK, . 1991. Cyanide antagonism in a rodent model. Arch Toxicol Suppl 14:231–235.
*Bhattacharya R, Jeevaratnam K, Raza SK, . 1993. Protection against cyanide poisoning by the co-administration of sodium nitrite and hydroxylamine in rats. Hum Exp Toxicol 12:33–36.8094969
*Bhattacharya R, Kumar P, Sachan AS, . 1994. Cyanide induced changes in dynamic pulmonary mechanics in rats. Indian J Physiol Pharmacol 38(4):281–284.7883293
Bhattacharya R, Kumar D, Sugendran K, . 2001. Acute toxicity studies of α-ketoglutarate: A promising antidote for cyanide poisoning. J Appl Toxicol 21:495–499.11746197
Bhattacharya R, Lakshmana Rao PV, Vijayaraghavan R. 2002. In vitro and in vivo attenuation of experimental cyanide poisoning by α-ketoglutarate. Toxicol Lett 128:185–195.11869829
*Bible B, Chong C. 1975. Correlation of temperature and rainfall with thiocyanate ion content in roots of radishes grown on two soil types. Hort Sci 10(5):484–485.
*Bible BB, Ju H-K, Chong C. 1980. Influence of cultivar, season, irrigation and date of planting on thiocyanate ion content in cabbages. J Amer Soc Hort Sci 105(1):88–91.
*Birky MM, Clarke FB. 1981. Inhalation of toxic products from fires. Bull NY Acad Med 57:997–1013.
Bismuth C, Borron SW, Baud FJ, . 2004. Chemical weapons: Documented use and compounds on the horizon. Toxicol Lett 149:11–18.15093243
*Blakley RL, Coop IE. 1949. The metabolism and toxicity of cyanides and cyanogenic blycosides in sheep. II. Detoxication of hydrocyanic acid. NZ J Sci Technol 31A(3):1–16.
*Blanc P, Hogan M, Mallin K, . 1985. Cyanide intoxication among silver-reclaiming workers. J Am Med Assoc 253:367–371.
Blumer C, Haas D. 2000. Mechanism, regulation, and ecological role of bacterial cyanide biosynthesis. Arch Microbiol 173(3):170–177.10763748
*Bolstad-Johnson DM, Burgess JL, Crutchfield CD, . 2000. Characterization of firefighter exposures during fire overhaul. Am Ind Hyg Assoc J 61:636–641.
*Bonsall JL. 1984. Survival without sequelae following exposure to 500 mg/m^3^ of hydrogen cyanide. Hum Toxicol 3:57–60.6321328
Borak J. 1995. Pharmacologic mechanism of antidotes in cyanide and nitrile poisoning. J Occup Environ Med 37:793–794.7552462
Borgohain R, Singh AK, Radhakrishna H, . 1995. Case report: Delayed onset generalised dystonia after cyanide poisoning. Clin Neurol Neurosurg 97:213–215.7586851
*Borowitz JL, Born GS, Isom GE. 1988. Potentiation of evoked adrenal catecholamine release by cyanide: Possible role of calcium. Toxicology 50:37–45.3388429
Borowitz JL, Gunasekar PG, Isom GE. 1997. Hydrogen cyanide generation by μ-opiate receptor activation: Possible neuromodulatory role of endogenous cyanide. Brain Res 768:294–300.9369328
Borowitz JL, Rathinavelu A, Kanthasamy A, . 1994. Accumulation of labeled cyanide in neuronal tissue. Toxicol Appl Pharmacol 129:80–85.7974498
*Bottoms SF, Kuhnert BR, Kuhnert PM, . 1982. Maternal passive smoking and fetal serum thiocyanate levels. Am J Obstet Gynecol 144(7):787–791.7148902
*Boucabeille C, Bories A, Ollivier P. 1994a. Degradation of thiocyanate by a bacterial coculture. Biotechnol Lett 16(4):425–430.
*Boucabeille C, Bories A, Ollivier P, . 1994b. Microbial degradation of metal complexed cyanides and thiocyanate from mining wastewaters. Environ Poll 84(1):59–67.
*Boxer GE, Rickards JC. 1952. Studies on the metabolism of the carbon of cyanide and thiocyanate. Arch Biochem Biophys 36:7–26.
Brancaccio A, Cutruzzola F, Allocatelli CT, . 1994. Structural factors governing azide and cyanide binding to mammalian metmyoglobins. J Biol Chem 269:13843–13853.8188662
*Brandt-Rauf PW, Fallon LF Jr, Tarantini T, . 1988. Health hazards of fire fighters exposure assessment. Br J Ind Med 45:606–612.3179235
*Breen PH, Isserles SA, Tabac E, . 1996. Protective effect of stroma-free methemoglobin during cyanide poisoning in dogs. Anesthesiology 85:558–564.8853086
Brierley JB. 1975. Comparison between effects of profound arterial hypotension, hypoxia, and cyanide on the brain of Macaca mulatta. Adv Neurol 10:213–221.1146646
*Brierley JB, Brown AW, Calverley J. 1976. Cyanide intoxication in the rat: Physiological and neuropathological aspects. J Neurol Neurosurg Psychiatry 39:129–140.4588
Brierley JB, Prior PF, Calverley J, . 1977. Cyanide intoxication in Macaca mulatta: Physiological and neuropathological aspects. J Neurol Sci 31:133–157.13159
*Bright JE, Marrs TC. 1987. Effect of p-aminopropiophenone (PAPP), a cyanide antidote, on cyanide given by intravenous infusion. Hum Toxicol 6:133–137.3557470
Bright JE, Marrs TC. 1988. Pharmacokinetics of intravenous potassium cyanide. Hum Toxicol 7:183–186.3378806
Brimer L, Rosling H. 1993. Microdiffusion method with solid state detection of cyanogenic glycosides from cassava in human urine. Food Chem Toxicol 31(8):599–603.8349206
*Bromley J, Hughes BGM, Leong DCS, . 2005. Life-threatening interaction between complementary medicines: Cyanide toxicity following ingestion of amygdalin and vitamin C. Ann Pharmacother 39:1566–1569.16014371
*Brown PD, Morra MJ. 1991. Ion chromatographic determination of SCN in soils. J Agric Food Chem 39:1226–1228.
*Brown PD, Morra MJ. 1993. Fate of ionic thiocyanate (SCN–) in soil. J Agric Food Chem 41(6):978–982.
*Brown PD, Morra MJ, McCaffrey JP, . 1991. Allelochemicals produced during glucosinolate degradation in soil. J Chem Ecol 17(10):2021–2034.24258495
*Brown PN, Jayson GG, Wilkinson MC. 1986. Determination of cyanogen and cyanogen chloride using gas chromatography with a flame ionization detector. Chromatographia 21:161–164.
Brueske PJ. 1997. ED management of cyanide poisoning. J Emerg Nurs 23:569–573.9460393
*Budavari S, ed. 1989. Merck index: An encyclopedia of chemicals, drugs, and biologicals. 11th ed. Rahway, NJ: Merck & Co., Inc.
*Burrows GE, Liu DHW, Way JL. 1973. Effect of oxygen on cyanide intoxication: V. Physiologic effects. J Pharmacol Exp Ther 184:739–748.4687234
Buzaleh AM, Vazquez EB, Batlle AMC. 1989. Cyanide intoxication--I. An oral chronic animal model. Gen Pharmacol 20:323–327.2545508
Bywood PT, Johnson SM. 2000. Dendrite loss is a characteristic early indicator of toxin-induced neurodegeneration in rat midbrain slices. Exp Neurol 161(1):306–316.10683296
Calafat AM, Stanfill SB. 2002. Rapid quantitation of cyanide in whole blood by automated headspace gas chromatography. J Chromatogr B Analyt Technol Biomed Life Sci 772:131–137.
*Cancho B, Ventura F, Galceran MT. 2000. Simultaneous determination of cyanogen chloride and cyanogen bromide in treated water at sub-μg/L levels by a new solid-phase microextraction–gas chromatographic–electron-capture detection method. J Chromatogr A 897:307–315.11128214
*Cannon EP, Leung P, Hawkins A, . 1994. Antagonism of cyanide intoxication with murine carrier erythrocytes containing bovine rhodanese and sodium thiosulfate. J Toxicol Environ Health 41(3):267–274.8126749
*Cardeal ZL, Pradeau D, Hamon M. 1993. Determination of HCN by headspace gas chromatography using an improved method of standardization. Chromatographia 37(11–12):613–617.
*Carella F, Grassi MP, Savoiardo M, . 1988. Dystonic-parkinsonian syndrome after cyanide poisoning: Clinical and MRI findings. J Neurol Neurosurg Psychiatry 51:1345–1348.3225591
Carelli V, Ross-Cisneros FN, Sadun AA. 2002. Optic nerve degeneration and mitochondrial dysfunction: Genetic and acquired optic neuropathies. Neurochem Int 40:573–584.11850115
Carini R, Autelli R, Bellomo G, . 1995. Sodium-mediated cell swelling is associated with irreversible damage in isolated hepatocytes exposed to hypoxia or mitochondrial toxins. Biochem Biophys Res Commun 206(1):180–185.7818518
*Carini R, Bellomo G, Grazia De Cesaris M, . 1997. Glycine protects against hepatocyte killing by KCN or hypoxia by preventing intracellular NA^+^ overload in the rat. Hepatology 26(1):107–112.9214458
*Carlson DG, Daxenbichler ME, Van Etten CH, . 1985. Glucosinolates in radish cultivars. J Am Soc Hort Sci 110(5):634–638.
*Carlson DG, Daxenbichler ME, Van Etten CH, . 1987. Glucosinolates in cruciferous vegetables: broccoli, sprouts, cauliflower, collards, kale, mustard greens, and kohlrabi. J Am Soc Hort Sci 112(1):173–178.
*Carotti AA, Kaiser ER. 1972. Concentrations of twenty gaseous chemical species in the flue gas of a municipal incinerator. J Air Pollut Control Assoc 22:224–253.
Cassel GE. 1995. Estimation of the convulsive effect of cyanide in rats. Pharmacol Toxicol 77:259–263.8577637
*Cassel GE, Koch M, Tiger G. 1995. The effects of cyanide on the extracellular levels of dopamine, 3,4,-dihydroxyphenylacetic acid, homovanillic acid, 5-hydroxyindoleacetic acid and inositaol phospholipid breakdown in the brain. Neurotoxicology 16(1):73–82.7541518
*Cassel GE, Persson S-A, Stenstrom A. 1994. Effects of cyanide in vitro and the activity of monoamine oxidase in striatal tissue from rat and pig. Biochem Pharmacol 47(3):499–504.8117318
CELDs. 1994. Computer-aided Environmental Legislative Data systems. Urbana, IL: United States Army Corps of Engineers Environmental Technical Information Systems University of Illinois.
*CEPA. 1997. Public health goal for cyanide in drinking water. California Environmental Protection Agency. www.oehha.ca.gov/water/phg/cyan_c.pdf. June 17, 2004.
Chance B, Erecinska M. 1971. Flow flash kinetics of the cytochrome 3-oxygen reaction in coupled and uncoupled mitochondria using the liquid dye laser. Biochem Biophys. 143(2):675–687.
*Chand K, Dixit ML, Arora SK. 1992. Yield and quality of forage sorghum as affected by phosphorus fertilization. J Indian Soc Soil Sci 40(2):302–306.
*Chandra H, Gupta BN, Ghargava SK, . 1980. Chronic cyanide exposure: A biochemical and industrial hygiene study. J Anal Toxicol 4:161–165.6257975
*Chandra H, Gupta BN, Mathur N. 1988. Threshold limit value of cyanide: A reappraisal in Indian context. Indian J Environ Protection 8:170–174.
*Chao KF, Liu SH, Lin-Shiau SY. 1996. Suppression of potassium currents by cyanide on the mouse motor nerve terminals. Neurosci Lett 203:105–108.8834104
Chapatwala KD, Babu GRV, Vijaya OK, . 1998. Biodegradation of cyanides, cyanates and thiocyanates to ammonia and carbon dioxide by immobilized cells of Pseudomonas putida. J Ind Microbiol Biotechnol 20(1):28–33.9523454
*Chapatwala KD, Babu GRV, Wolfram JH. 1993. Screening of encapsulated microbial cells for the degradation of inorganic cyanides. J Ind Microbiol 11(2):69–72.
Chatgtopadhyay B, Gangopadhyay P, Janee Alam S. 2000. Long term effect of cyanide fumes from exposure on ventilatory pulmonary function among the workers of a metal tempering plant. Biomedicine 20(3):207–218.
*Chattaraj S, Das A. 1991. Indirect determination of free cyanide in industrial waste effluent by atomic absorption spectrometry. Analyst (London) 116(7):739–741.1928737
*Chattaraj S, Das AK. 1992. Indirect determination of thiocyanate in biological fluids using atomic absorption spectrometry. Spectrochica Acta 47(5):675–680.
Chaturvedi AK, Sanders DC, Endecott BR, . 1995. Exposures to carbon monoxide, hydrogen cyanide and their mixtures: Interrelationship between gas exposure concentration, time to incapacitation, carboxyhemoglobin and blood cyanide in rats. J Appl Toxicol 15(5):357–363.8666718
Chaturvedi AK, Smith DR, Canfield DV. 2001. Blood carbon monoxide and hydrogen cyanide concentrations in the fatalities of fire and non-fire associated civil aviation accidents, 1991-1998. Forensic Sci Int 121:183–188.11566422
*Chen KK, Rose CL. 1952. Nitrite and thiosulfate therapy in cyanide poisoning. J Am Med Assoc 149:113–119.14917568
*Chen S-H, Wu S-M, Kou H-S, . 1994. Electron-capture gas chromatographic determination of cyanide, iodide, nitrite, sulfide and thiocyanate anions by phase-transfer-catalyzed derivatization with pentafluorobenzyl bromide. J Anal Toxicol 18(2):81–85.8207938
*Chen Y, Pederson LL, Lefcoe NM. 1990. Exposure to environmental tobacco smoke (ETS) and serum thiocyanate level in infants. Arch Environ Health 45(3):163–167.2386421
*Chepiga TA, Morton MJ, Murphy PA, . 2000. A comparison of the mainstream smoke chemistry and mutagenicity of a representative sample of the U.S. cigarette market with two Kentucky reference cigarettes (K1R4F and K1R5F). Food Chem Toxicol 38:949–962.11039328
*Cherian MA, Richmond I. 2000. Fatal methane and cyanide poisoning as a result of handling industrial fish: A case report and review of the literature. J Clin Pathol 53:794–795.11064677
*Cherryholmes KL, Cornils WJ, McDonald DB, . 1985. Biological degradation of complex iron cyanides in natural aquatic systems. In: Cardwell RD, Purdy R, Bahner RC, eds. Aquatic toxicology and hazard assessment seventh symposium. ASTM STP 854. Philadelphia, PA: American Society for Testing and Material, 502–511.
*Chin RG, Calderon Y. 2000. Acute cyanide poisoning: A case report. J Emerg Med 18:441–445.10802422
*Chinaka S, Takayama N, Michigami Y, . 1998. Simultaneous determination of cyanide and thiocyanate in blood by ion chromatography with fluorescence and ultraviolet detection. J Chromatogr B Biomed Sci Appl 713:353–359.9746250
*Chinaka S, Tanaka S, Takayama N, . 2001. High-sensitivity analysis of cyanide by capillary electrophoresis with fluorescence detection. Anal Sci 17:649–652.11708148
*Choi W, Han S. 2002. Effects of melatonin on KCN-induced neurodegeneration in mice. Int J Neurosci 112(2):187–194.12325406
Chou Y. 1998. Corticosterone exacerbates cyanide-induced cell death in hippocampal cultures: Role of astrocytes. Neurochem Int 32:219–226.9587916
*Cicerone RJ, Zellner R. 1983. The atmospheric chemistry of hydrogen cyanide (HCN). J Geophys Res 88:10689–10696.
*Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1:111–113.3843496
*Cliff J, Lundquist P, Rosling H, . 1986. Thyroid function in a cassava-eating population affected by epidemic spastic paraparesis. Acta Endocrinol (Copenh) 113:523–528.3788422
CLPSD. 1989. Contract Laboratory Program Statistical Database. July 12, 1989.
CMR. 1982. Chemical profile: Hydrogen cyanide. Chemical Marketing Reporter, October 11, 1982, 62.
CMR. 1990. Chemical profile: Hydrogen cyanide. Chemical Marketing Reporter, June 18, 1990, 54.
*CMR. 1993. Chemical profile: Hydrogen cyanide. Chemical Marketing Reporter, May 24, 1993.
*CMR. 2001. Chemical profile: Hydrogen cyanide. Chemical Market Reporter, November 6, 2001. http://www.the-innovation-group.com/chemprofile.htm. June 14, 2004.
Cohrssen B. 2001. Cyanides and nitriles. In: Bingham E, Cohrssen B, Powell CH, eds. Patty’s toxicology. John Wiley and Sons, Inc. http://www.mrw.interscience.wiley.com/pattys/tox/articles/tox061/sec1_1.html. May 28, 2004.
*Colborn T, Clement C. 1992. Chemically induced alterations in sexual and functional development. The Wildlife/Human Connection. In: Advances in modern environmental toxicology. Volume XXI. Princeton, NJ: Princeton Scientific Publishing Co.
*Cole RH, Frederick RE, Healy RP, . 1984. Preliminary findings of the priority pollutant monitoring project of the nationwide urban runoff program. J Water Pollut Control Fed 56:898–908.
Collins JF, Alexeeff GV, Lewis DC, . 2004. Development of acute inhalation reference exposure levels (RELs) to protect the public from predictable excursions of airborne toxicants. J Appl Toxicol 24(2):155–166.15052612
Cook TM. 1996. Plasma lactate and blood cyanide in acute cyanide poisoning: Confounding factors should have been considered. Br Med J 312:1039.
Cooper M, Powers K, Rusnack R, . 1998. Cyanide ingestion: Preventing the cascade. Dimens Crit Care Nurs 17:83–90.9624949
*Cotton FA, Wilkinson G. 1980. Advanced inorganic chemistry. A comprehensive text. 4th ed. New York: John Wiley and Sons, 367–369.
CRISP. 1990. Crisp Data Base, National Institutes of Health. July, 1990.
Criteria Group for Occupational Standards. 2001. Consensus report for hydrogen cyanide, sodium cyanide and potassium cyanide. In: Montelius J, ed. Scientific basis for Swedish occupational standards XXII. Stockholm, Sweden: National Institute for Working Life, 43–59.
*Croen LA, Shaw GM, Sanbonmatsu L, . 1997. Maternal residential proximity to hazardous waste sites and risk for selected congenital malformations. Epidemiology 8:347–354.9209846
*Crutzen PJ, Andreae M. 1990. Biomass burning in the tropics: Impact on atmospheric chemistry and biogeochemical cycles. Science 250:1669–1678.17734705
*Crutzen PJ, Carmichael GR. 1993. Modeling the influence of fires on atmospheric chemistry. In: Crutzen PJ, Goldammer JG, eds. Fire in the environment: The ecological, atmospheric and climatic importance of vegetation fires. John Wiley and Sons, Ltd., 89–105.
*Cruz M, Kaiser A, Rowxhat PG, . 1974. Absorption and transformation of HCN on the surface of copper and calcium montmorillonite. Clays Clay Mineral 22:417–425.
*Cruz-Landeira A, Lopez-Rivadulla M, Concheiro-Carro L, . 2000. A new spectrophotometric method for the toxicological diagnosis of cyanide poisoning. J Anal Toxicol 24(4):266–270.10872573
*Csikal NJ, Barnard AJ, Jr. 1983. Determination of total cyanide in thiocyanate containing wastewaters. Anal Chem 55:1677–1682.
Cummings TF. 2004. In depth review: The treatment of cyanide poisoning. Occup Med 54(2):82–85.
*Curry SC. 1992. Hydrogen cyanide and inorganic cyanide salts. In: Sullivan JB, Krieger GR, eds. Hazardous materials toxicology: Clinical principles of environmental health. Baltimore, MD: Williams & Wilkins, 698–710.
*Curry SC, Carlton MW, Raschke RA. 1997. Prevention of fetal and maternal cyanide toxicity from nitroprusside with coinfusion of sodium thiosulfate in gravid ewes. Anesth Analg 84:1121–1126.9141943
*Dahl AR. 1989. The cyanide-metabolizing enzyme rhodanese in rat nasal respiratory and olfactory mucosa. Toxicol Lett 45:199–205.2919401
Daly MD, Jones JFX. 1998. Respiratory modulation of carotid and aortic body reflex left ventricular inotropic responses in the cat. J Physiol 509:895–907.9596808
Davey GP, Clark JB. 1996. Threshold effects and control of oxidative phosphorylation in nonsynaptic rat brain mitochondria. J Neurochem 66:1617–1624.8627318
Davey GP, Canevari L, Clark JB. 1997. Threshold effects in synaptosomal and nonsynaptic mitochondria from hippocampal CA1 and paramedian neocortex brain regions. J Neurochem 69:2564–2570.9375690
Dawson R, Felheim R, Nguyen S. 1995. Mechanism of sodium nitroprusside-mediated inhibition of aromatic amino acid decarboxylase activity. Pharmacology 50:74–85.7716178
*Daya S, Walker RB, Anoopkumar-Dukie S. 2000. Cyanide-induced free radical production and lipid peroxidation in rat brain homogenate is reduced by aspirin. Metab Brain Dis 15:203–210.11206589
*De Flora S. 1981. Study of 106 organic and inorganic compounds in the Salmonella/microsome test. Carcinogenesis 2:283–298.7023727
*De Flora S, Camoirano A, Zanacchi P, . 1984. Mutagenicity testing with TA97 and TA102 of 30 DNA-damaging compounds, negative with other Salmonella strains. Mutat Res 134:159–165.6390191
*Delange F, Ermans AM. 1971. Role of a dietary goitrogen in the etiology of endemic goiter on Idjwi Island. Am J Clin Nutr 24:1354–1360.5116479
De Lorenzo RA. 1999. Cyanide: The deadly terror weapon that every EMS provider must know about. JEMS 24(10):54–58, 60–61, 64–65.
*Devlin DJ, Mills JW, Smith RP. 1989a. Histochemical localization of rhodanese activity in rat liver and skeletal muscle. Toxicol Appl Pharmacol 97:247–255.2922757
*Devlin DJ, Smith RP, Thron CD. 1989b. Cyanide metabolism in the isolated, perfused, bloodless hindlimbs or liver of the rat. Toxicol Appl Pharmacol 98:338–349.2540545
Dierickx PJ. 2003. Evidence for delayed cytotoxicity effects following exposure of rat hepatoma-derived Fa32 cells: Implications for predicting human acute toxicity. Toxicol in Vitro 17:797–801.14599480
Dirikolu L, Hughes C, Harkins D, . 2003. The toxicokinetics of cyanide and mandelonitrile in the horse and their relevance to the mare reproductive loss syndrome. Toxicol Mech Methods 13:199–211.20021160
Djerad A, Monier C, Houzé P, . 2001. Effects of respiratory acidosis and alkalosis on the distribution of cyanide into the rat brain. Toxicol Sci 61(2):273–282.11353136
Djuric D, Raicevic P, Konstantinovic I. 1962. Excretion of thiocyanates in urine of smokers. Arch Environ Health 5:12–15.13886695
D’Mello GD. 1987. Neuropathological and behavioural sequelae of acute cyanide toxicosis in animal species. In: Ballantyne B, Marrs TC, eds. Clinical and experimental toxicology of cyanides. Bristol, UK: IOP Publishing Limited, 156–183.
*DOA. 1976. Estimates of the toxicity of hydrocyanic acid vapors in man. Aberdeen Proving Ground, MD: Department of the Army. EBTR76023. ADA028501.
*Dodds C, McKnight C. 1985. Cyanide toxicity after immersion and the hazards of dicobalt edetate. Br Med J 291:785–786.
*Dodds RG, Penney DG, Sutariya BB. 1992. Cardiovascular, metabolic and neurologic effects of carbon monoxide and cyanide in the rat. Toxicol Lett 61(2–3):243–254.1641871
*Doherty PA, Ferm VH, Smith RP. 1982. Congenital malformations induced by infusion of sodium cyanide in the Golden hamster. Toxicol Appl Pharmacol 64:456–464.7135396
*Doherty PA, Smith RP, Ferm VH. 1983. Comparison of the teratogenic potential of two aliphatic nitriles in hamsters: Succinonitrile and tetramethylsuccinonitrile. Fundam Appl Toxicol 3:41–48.6884622
*Dolzine TW, Esposito GG, Rinehart DS. 1982. Determination of hydrogen cyanide in air by ion chromatography. Anal Chem 54:470–473.
do Nascimento PC, Bohrer D, Carvalho LM. 1998. Cyanide determination in biological fluids using a microdiffusion method with a flow system and polarographic detection. Analyst 123(5):1151–1154.9709498
Dorea JG. 2004. Maternal thiocyanate and thyroid status during breast feeding. J Am Coll Nutr 23(2):97–101.15047674
Dou Y, Olson JS, Wilkinson AJ, . 1996. Mechanism of hydrogen cyanide binding to myoglobin. Biochemistry 35:7107–7113.8679537
Downing JEG. 1997. Transient block of respiratory chain by cyanide triggers NADPH-diaphorase activity (a marker for nitric oxide synthase) in Dunning rat prostatic epithelium. Cancer Lett 121:91–97.9459179
*Drawbaugh RB, Marrs TC. 1987. Interspecies differences in rhodanese (thiosulfate sulfurtransferase, EC 2.8.1.1) activity in liver, kidney and plasma. Comp Biochem Physiol 86B:307–310.
*Drikas M, Routley BI. 1988. Spectrophotometric method for the determination of total cyanide in wastewater samples. Analyst 113:1273–1276.3232838
*Drinker P. 1932. Hydrocyanic acid gas poisoning by absorption through the skin. J Ind Hyg 14:1–2.
*Dudley HC, Sweeney TR, Miller JW. 1942. Toxicology of acrylonitrile (vinyl cyanide). II: Studies of effects of daily inhalation. J Ind Hyg Toxicol 24:255–258.
Duboudin C, Ciffroy P, Magaud H. 2004. Acute-to-chronic species sensitivity distribution extrapolation. Environ Toxicol Chem 23(7):1774–1785.15230330
*Dufour DL. 1988. Dietary cyanide intake and serum thiocyanate levels in Tukanoan Indians in Northwest Amazonia. Am J Phys Anthropol 75:205.
*Dumas P, Gingras G, LeBlanc A. 2005. Isotope dilution-mass spectrometry determination of blood cyanide by headspace gas chromatography. J Anal Toxicol 29(1):71–75.15808018
*Egekeze JO, Oehme FW. 1979. Direct potentiometric method for the determination of cyanide in biological materials. J Anal Toxicol 3:119–124.
*El Ghawabi SH, Gaafar MA, El-Saharti AA, . 1975. Chronic cyanide exposure: A clinical, radioisotope, and laboratory study. Br J Ind Med 32:215–219.1156569
*Ellenhorn MJ, Barceloux DG. 1997. Respiratory toxicology: Cyanide poisoning. In: Ellenhorn MJ, Barceloux DG, eds. Ellenhorn’s medical toxicology: Diagnosis and treatment of human poisoning. New York, NY: Elsevier Science Publishing Company, Inc., 1476–1482.
Engel RR, Delpy DT, Parker D. 1979. The effect of topical potassium cyanide on transcutaneous gas measurements. Birth Defects 15:117–121.
EPA. 1971. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.
EPA. 1973. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136.3.
EPA. 1974. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 424 Subpart B.
*EPA. 1975a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 424 Subpart D.
*EPA. 1975b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 185.3600.
EPA. 1976. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.3.
EPA. 1978a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4.
EPA. 1978b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 152.175.
*EPA. 1978c. Reviews of the environmental effects of pollutants. V. Cyanide. Cincinnati, OH: U.S. Environmental Protection Agency Health Effects Research Laboratory, Office of Research and Development. PB289920.
*EPA. 1978d. Method 335.3. Cyanide, total (colorimetric, automated UV). Cincinnati, OH: U.S. Environmental Protection Agency. National Environmental Methods Index. http://www.nemi.gov. August 30, 2004.
*EPA. 1979. Cyanides. In: Water-related environmental fate of 129 priority pollutants. Vol. 1. Washington, DC: U.S. Environmental Protection Agency, Office of Water Planning and Standards, Office of Water and Waste Management. EPA440479029a. PB80204373. 12-1-12-12.
*EPA. 1980a. Water quality criteria documents: Availability. U.S. Environmental Protection Agency. Fed Regist 45:79318–79379.
EPA. 1980b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.
*EPA. 1980c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264 App. 1.
EPA. 1980d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 265 App. 1.
*EPA. 1980e. Method 335.2. Cyanide, total (titrimetric; spectrophotometric). Cincinnati, OH: U.S. Environmental Protection Agency. National Environmental Methods Index. www.nemi.gov. August 30, 2004.
EPA. 1981a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 403.12.
EPA. 1981b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 413.
*EPA. 1981c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.
EPA. 1981d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264, App V.
*EPA. 1981e. Exposure and risk assessment for cyanide. Washington, DC: U.S. Environmental Protection Agency. Office of Water. EPA440485008. PB85220572.
EPA. 1982a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 415.
EPA. 1982b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 420.
EPA. 1982c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 423, App A.
EPA. 1982d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 465.
EPA. 1982e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264.316.
EPA. 1982f. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 712.30.
*EPA. 1983a. Methods for chemical analysis of water and wastes. Method 335.2. Cyanide, total. Cincinnati, OH: Environmental Monitoring and Support Laboratory, U.S. Environmental Protection Agency.
EPA. 1983b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 60.489.
EPA. 1983c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 122.
EPA. 1983d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 433, Subpart A.
EPA. 1983e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 439.
EPA. 1983f. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 467.
*EPA. 1984a. Health effects assessment for cyanide. Washington, DC: U.S. Environmental Protection Agency. EPA540186011.
EPA. 1984b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 403.7.
EPA. 1984c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 403, App. E.
EPA. 1984d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 421.
EPA. 1984e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 461, Subpart G.
EPA. 1984f. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, App IX.
EPA. 1984g. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 300, App C.
*EPA. 1985a. Ambient water quality for cyanide - 1984. Washington, DC: Office of Water Regulations and Standards, Criteria and Standards Division. EPA440584028. PB85227460.
EPA. 1985b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 123.45.
EPA. 1985c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 421.
EPA. 1985d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 471.
EPA. 1985e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
EPA. 1985f. Physical and chemical properties and categorization of RCRA wastes according to volatility. Springfield, VA: U.S. Environmental Protection Agency. PB85204527.
EPA. 1986a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3.
EPA. 1986b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.
*EPA. 1987a. Extremely hazardous substances list and threshold planning quantities: Emergency planning and release notification requirements. U.S. Environmental Protection Agency. Fed Regist 52:13378–13410.
EPA. 1987b. List (Phase 1) of hazardous constituents for ground-water monitoring. U.S. Environmental Protection Agency. Fed Regist 52:25942–25953.
EPA. 1987c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.32.
EPA. 1987d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 414.
EPA. 1987e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264, App IX.
EPA. 1987f. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355, App. A.
EPA. 1987g. Drinking water criteria document for cyanide. Washington, DC: U.S. Environmental Protection Agency, Office of Drinking Water.
EPA. 1988a. Environmental Protection Agency. Calcium cyanide: Tolerances for residues. Code of Federal Regulations. 40 CFR 180.125.
EPA. 1988b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, App. VIII.
*EPA. 1988c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.43.
EPA. 1988d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65.
EPA. 1989a. Interim methods for development of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA600888066F.
EPA. 1989b. Land disposal restrictions for third scheduled wastes: Proposed rule. U.S. Environmental Protection Agency. Fed Regist 54:48515–48518.
EPA. 1989c. Reportable quantity adjustments: Delisting of ammonium thiosulfate. U.S. Environmental Protection Agency. Fed Regist 54:33426–33484.
*EPA. 1990a. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066A
EPA. 1990b. Summary review of health effects associated with hydrogen cyanide: Health issue assessment. Research Triangle Park, NC: Environmental Criteria and Assessment Office, U.S. Environmental Protection Agency. EPA600890002F.
EPA. 1990c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 60.617.
EPA. 1990d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 60.667.
EPA. 1990e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 122.26.
EPA. 1990f. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.3.
EPA. 1990g. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 300.915.
*EPA. 1991a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.
EPA. 1991b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 258, App II.
EPA. 1991c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266, App VII.
EPA. 1992a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.3.
EPA. 1992b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.
EPA. 1992c. Method 9010A. Total and amenable cyanide. Test methods for evaluating solid waste, physical/chemical methods, SW-846. 3rd edition. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1992d. Method 9013. Cyanide extraction procedure for solids and oils. Test methods for evaluating solid waste, physical/chemical methods, SW-846. 3rd edition. Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1992e. Drinking water criteria document for cyanide. Washington, DC: U.S. Environmental Protection Agency. PB92173319.
*EPA. 1992f. U.S. Environmental Protection Agency. Fed Regist 57:26248.
EPA. 1993a. U.S. Environmental Protection Agency. Fed Regist 58:20802.
EPA. 1993b. U.S. Environmental Protection Agency. Fed Regist 58:65622.
EPA. 1993c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.37.
EPA. 1993d. U.S. Environmental Protection Agency. Fed Regist 58:48092.
EPA. 1993e. U.S. Environmental Protection Agency. Fed Regist 58:54702.
EPA. 1993f. U.S. Environmental Protection Agency. Fed Regist 58:4836.
*EPA. 1993g. Toxic Chemical Release Inventory Reporting Form R and Instructions. Revised 1992 Version. Washington, DC: U.S. Environmental Protection Agency. Office of Pollution Prevention and Toxics.
*EPA. 1993h. Methods for the determination of inorganic substances in environmental samples. U.S. Environmental Protection Agency, Office of Research and Development. EPA600R93100.
EPA. 1994a. U.S. Environmental Protection Agency. Fed Regist 59:5504.
EPA. 1994b. U.S. Environmental Protection Agency. Fed Regist 59:6332.
*EPA. 1994c. Technical report: Treatment of cyanide heap leaches and tailings. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste. EPA530R94037. PB94201837.
EPA. 1995. Drinking water regulations and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water.
*EPA. 1996. Method 9012A. Total and amenable cyanide (automated colorimetric, with off-line distillation). Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste Methods Team.
*EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
*EPA. 1998. Status of pesticides in registration reregistration and special review (Rainbow report). Washington, DC: U.S. Environmental Protection Agency, Special Review and Reregistration Division, Office of Pesticide Programs.
*EPA. 1999. A review of contaminant occurrence in public water systems. Washington, DC: U.S. Environmental Protection Agency. EPA816R99006.
*EPA. 2001. Consolidated list of chemicals subject to the Emergency Planning and Community Right-to-Know Act (EPCRA) and Section 112(r) of the Clean Air Act. U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response. EPA550B01003.
*EPA. 2004a. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA 822R04005. http://www.epa.gov/waterscience/drinking/standards/dwstandards.pdf. June 06, 2004.
*EPA. 2004b. Chemical accident prevention provisions: List of substances. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 68.130. http://www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004c. Chemical accident prevention provisions: Table of toxic endpoints. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 68, Appendix A. http://www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004d. Designation, reportable quantities, and notification: Designation of hazardous substance. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004e. Emergency planning and notification: The list of extremely hazardous substances and their threshold planning quantities. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355, Appendix A. http://www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004f. Identification and listing of hazardous waste: Hazardous constituents. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, Appendix VIII. http://www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004g. National primary drinking water regulations: Maximum contaminant levels for inorganic contaminants. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.62. http://www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004h. National primary water regulations: Public notification. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.32. http://www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004i. Pesticide programs: Pesticides classified for restricted use. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 152.175. http://www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004j. Programs and activities: Hazardous air pollutants. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 42 USC 7412. http://www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004k. Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3. http://www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004l. Standards for the management of specific hazardous wastes and specific types of hazardous waste management facilities: Reference air concentrations. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266, Appendix IV. http://www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004m. Tolerances and exemptions from tolerances for pesticide chemicals in food: Hydrogen cyanide; tolerances for residues. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.130. http://www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004n. Tolerances and exemptions from tolerances for pesticide chemicals in food: Inert ingredients used pre-harvest; exemptions from the requirement of a tolerance. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.920. http://www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004o. Tolerances and exemptions from tolerances for pesticide chemicals in food: Tolerances for related pesticide chemicals. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.3. http://www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004p. Toxic chemical release reporting: Community right-to-know: Chemicals and chemical categories to which this part applies. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. http://www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004q. Toxic chemical release inventory reporting forms and instructions: Revised 2003 version: Section 313 of the emergency planning and community right-to-know act (title III of the superfund amendments and reauthorization act of 1986). U.S. Environmental Protection Agency. EPA260B04001.
*EPA. 2004r. Toxic Substances Control Act: Chemical information rules: Chemical lists and reporting periods. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 712.30. http://www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004s. Toxic Substances Control Act: Health and safety data reporting: Substances and listed mixtures to which this subpart applies. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 716.120. http://www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2004t. Water programs: Designation of hazardous substances. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4. http://www.epa.gov/epahome/cfr40.htm. June 06, 2004.
*EPA. 2005a. Chemical accident prevention provisions: List of substances. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 68.130. http://www.epa.gov/epahome/cfr40.htm. September 07, 2005.
*EPA. 2005b. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. Office of Environmental Information. EPA260B05001.
Erkkila K, Suomalainen L, Wikstrom M, . 2003. Chemical anoxia delays germ cell apoptosis in the human testis. Biol Reprod 69:617–626.12700196
*Ermans AM, Delange F, Van Der Velden M, . 1972. Possible role of cyanide and thiocyanate in the etiology of endemic cretinism. Adv Exp Med Biol 30:455–486.4582012
*Ermans AM, Nbulamoko NM, Delange F, ., eds. 1980. Role of cassava in the etiology of endemic goitre and cretinism. Ottawa, Canada: International Development Research Centre, 1–182.
Evans EF, Klinke R. 1982. The effects of intraocochlear cyanide and tetrodotoxin on the properties of single cochlear nerve fibres in the cat. J Physiol 331:385–408.7153908
Eybl V, Kotyzová D, Míčková V, . 2000. Changes in organ distribution of cadmium, lead and manganese caused by cyanide in mice. Biologia (Bratislava) 8:33–38.
*Fairley A, Linton EC, Wild FE. 1934. The absorption of hydrocyanic acid vapour through the skin with notes on other matters relating to acute cyanide poisoning. J Hyg 34:283–294.20475235
*Farm Chemicals Handbook. 1994. Directory of chemicals. Willoughby, OH: Meister Publishing Co., C1–C3.
*Farooqui MYH, Ahmed AE. 1982. Molecular interaction of acrylonitrile and potassium cyanide with rat blood. Chem Biol Interact 38:145–159.7055848
*FAS. 2005. Chemical agent fact sheet–Cyanide. Federation of American Scientists. http://www.fas.org/resource/08262005180731.pdf. October 03, 2005.
Fass U, Panickar K, Williams K, . 2004. The role of glutathione in nitric oxide toxicity of SN56 cholinergic neuron-like cells. Brain Res 1005:90–100.15044069
*FDA. 2003. Part 175– Indirect food additives– adhesives and components of coatings: Adhesives. Washington, DC: Food and Drug Administration. 21 CFR 175.105. http://www.access.gpo.gov/cgi-bin/cfrassemble.cgi?title=200321. June 06, 2003.
*FDA. 2004. Part 175– Indirect food additives– adhesives and components of coatings: Adhesives. Washington, DC: Food and Drug Administration. Code of Federal Regulations. 21 CFR 175.105. http://www.access.gpo.gov/cgi-bin/cfrassemble.cgi?title=200321. June 06, 2004.
*Fechter LD, Chen G, Johnson DL. 2002. Potentiation of noise-induced hearing loss by low concentrations of hydrogen cyanide in rats. Toxicol Sci 66(1):131–138.11861980
*FEDRIP. 2005. Federal Research in Progress. September 2005.
*Feldman JM, Feldman MD. 1990. Sequelae of attempted suicide by cyanide ingestion: A case report. Int J Psychiatry Med 20(2):173–179.2394544
*Feldstein M, Klendshoj NC. 1954. The determination of cyanide in biologic fluids by microdiffusion analysis. J Lab Clin Med 44:166–170.13174934
*Felshcer D, Wulfmeyer M. 1998. A new specific method to detect cyanide in body fluids, especially whole blood, by fluorimetry. J Anal Toxicol 22(5):363–366.9737330
*Ferguson HC. 1962. Dilution of dose and acute oral toxicity. Toxicol Appl Pharmacol 4:759–762.13944738
Ferrari LA, Arado MG, Giannuzzi L, . 2001. Hydrogen cyanide and carbon monoxide in blood of convicted dead in a polyurethane combustion: A proposition for the data analysis. Forensic Sci Int 121:140–143.11516899
*Fielding M, Packham RF. 1977. Organic compounds in drinking water and public health. J Inst Water Eng Sci 31:353–375.
*Fields S. 2001. Tarnishing the earth: Gold mining’s dirty secret. Environ Health Perspect 109:A474–A481.11675279
*FIFRA. 2004. Federal Insecticide, Fungicide, and Rodenticide Act (as amended through P.L. 108-199, January 23, 2004). United States Code. 7 U.S.C. 136 et seq. http://www.epa.gov/opp00001/regulating/fifra.pdf. June 15, 2004.
*Finck PA. 1969. Postmortem distribution studies of cyanide: Report of three cases. Med Ann Dist Columbia 38:357–358.5255151
Fogg AG, Alonso RM. 1987. Oxidative amperometric flow injection determination of cyanide at an electrochemically pre-treated glassy carbon electrode. Analyst 112:1071–1072.
*Fomon SJ. 1966. Body composition of the infant: Part I: The male reference infant. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
*Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
*Fonong T. 1987. Enzyme method for the spectrophotometric determination of micro-amounts of cyanide. Analyst 112:1033–1035.3619065
Forslund T, Sundqvist T. 1995. Nitric oxide reduces hydrogen peroxide production from human polymorphonuclear neutrophils. Eur J Clin Invest 25:9–14.7705391
Fowles JR, Alexeeff GV, Dodge D. 1999. The use of benchmark dose methodology with acute inhalation lethality data. Regul Toxicol Pharmacol 29(3):262–278.10388612
Fox MA, Tran NL, Groopman JD. 2004. Toxicological resources for cumulative risk: An example with hazardous air pollutants. Regul Toxicol Pharmacol 40(3):305–311.15546684
*Frakes RA, Sharma RP, Willhite CC. 1985. Developmental toxicity of the canogenic glycoside linamarin in the Golden Hamster. Teratology 31:241–246.3992492
*Frakes RA, Sharma RP, Willhite CC, . 1986a. Effect of cyanogenic glycosides and protein content in cassava diets on hamster prenatal development. Fundam Appl Toxicol 7:191–198.3758536
*Frakes RA, Sharma RP, Willhite CC, . 1986b. Comparative metabolism of linamarin and amygdalin in hamsters. Food Chem Toxicol 24(5):417–420.3744195
*Franchini KG, Krieger EM. 1993. Cardiovascular responses of conscious rats to carotid body chemoreceptor stimulation by intravenous KCN. J Auton Nerv Syst 42(1):63–69.8436807
Franchini KG, Oliveira VLL, Krieger EM. 1997. Hemodynamics of chemoreflex activation in unanesthetized rats. Hypertension 30:699–703.9323008
Franchini KG, Moreira ED, Ida F, . 1996. Alterations in the cardiovascular control by the chemoreflex and the baroreflex in the old rats. Am J Physiol 270:R310–R313.8769816
*Frank SN, Bard AJ. 1977. Heterogeneous photocatalyst oxidation of cyanide ion in aqueous solutions at titanium dioxide powder. J Amer Chem Soc 99(1):303–304.
Frank L, Price LT, Whitney PL. 1996. Possible mechanism for late gestational development of the antioxidant enzymes in the fetal rat lung. Biol Neonate 70:116–127.8864431
*Frankenberg L. 1980. Enzyme therapy in cyanide poisoning: Effect of rhodanese and sulfur compounds. Arch Toxicol 45(4):315–323.6934715
*Friedman MA, Staub J. 1976. Inhibition of mouse testicular DNA synthesis by mutagens and carcinogens as a potential simple mammalian assay for mutagenesis. Mutat Res 37:67–76.967187
*Fritz B, Lorenz K, Steinert W, . 1982. Laboratory kinetic investigation of the tropospheric oxidation of selected industrial emissions. EUR 7624:192–202.
FSTRAC. 1990. Summary of state and federal drinking water standards and guidelines. Chemical Communication Subcommittee, Federal-State Toxicology and Regulatory Alliance Committee.
*Fueller WH. 1985. Cyanides in the environment with particular attention to the soil. In: Van Zyl D, ed. Cyanide and the environment: Proceedings of a conference Tucson, Arizona December 11-14, 1984: Volume 1. Fort Collins, CO: Colorado State University, 19–46.
*Fukayama H, Nasu M, Murakami S, . 1992. Examination of antithyroid effects of smoking products in cultured thyroid follicles: Only thiocyanate is a potent antithyroid agent. Acta Endocrinol (Copenh) 127(6):520–525.1283478
*Gaffney JS, Streit GE, Spall WD, . 1987. Beyond acid rain: Do soluble oxidants and organic toxins interact with SO_2_ and NO_X_ to increase ecosystem effects? Environ Sci Technol 21:519–523.19994967
Gajendragad MR, Gopalakrishna S, Ravikumar SB. 1992. Pathology of the brain in acute hydrocyanic acid poisoning in sheep. Indian Vet J 69(3):206–210.
*Gamoh K, Imamichi S. 1991. Postcolumn liquid chromatographic method for the determination of cyanide with fluorimetric detection. Anal Chim Acta 251(102):255–259.
*Ganczarczyk JJ. 1979. Second-stage activated sludge treatment of coke plant effluents. Water Res 13(4):337–342.
*Ganjeloo A, Isom GE, Morgan RL, . 1980. Fluorometric determination of cyanide in biological fluids with p-benzoquinone. Toxicol Appl Pharm 55:103–107.
*Gaudy AF, Gaudy ET, Feng YJ, . 1982. Treatment of cyanide waste by the extended aeration process. J Water Pollut Control Fed 54:153–164.
Ger J, Chung HM, Yang GY, . 1988. A clinical survey of cyanide poisoning in Taiwan [Abstract]. Vet Hum Toxicol 30:377.
*Gerhart JM. 1986. Ninety-day oral toxicity study of copper cyanide (CuCN) in Sprague-Dawley Rats. Chicago, IL: The Dynamac Corporation. IITRI Project No. L06183, Study No. 3.
*Gerhart JM. 1987. Ninety-day oral toxicity study of copper silver cyanide [KAg(CN)2] in Sprague-Dawley rats. Chicago, IL: The Dynamac Corporation. IITRI Project No. L06183, Study No. 4.
*Gettler AO, Baine JO. 1938. The toxicology of cyanide. Am J Med Sci 195:182–198.
*Gettler AO, St. George AV. 1934. Cyanide poisoning. Am J Clin Pathol 4:429–437.
*Gibson QH, Greenwood C. 1963. Reactions of cytochrome oxidase of oxygen and carbon monoxide. Biochem J 86:541–554.13947736
Gill JR, Marker E, Stajic M. 2004. Suicide by cyanide: 17 deaths. J Forensic Sci 49(4):826–828.15317203
*Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.7902273
*Goldfrank LR, Flomenbaum NE, Lewin NA, . 1998. Cyanide and hydrogen sulfide. In: Goldfrank’s toxicologic emergencies. 6th ed. Stamford, CT: Appleton & Lange, 1569–1585.
Gomez G, Aparicio MA, Willhite CC. 1988. Relationship between dietary cassava cyanide levels and broiler performance. Nutr Rep Int 37(1):103–107.
*Goodhart GL. 1994. Patient treated with antidote kit and hyperbaric oxygen survives cyanide poisoning. South Med J 87(8):814–816.8052890
Gosselin RE, Hodge HC, Smith RP, . 1976. Clinical toxicology of commercial products: Acute poisoning. 4th ed. Baltimore, MD: The Williams & Williams Co., 105–112.
*Gosselin RE, Smith RP, Hodge HC, . 1984. Cyanide. In: Tracy TM, ed. Clinical toxicology of commercial products. 5th ed. Baltimore: Williams & Wilkins, III123–III130.
Graeme KA, Curry SC, Bikin DS, . 1999. The lack of transplacental movement of the cyanide antidote thiosulfate in gravid ewes. Anesth Analg 89:1448–1452.10589625
*Grandas F, Artieda J, Obeso JA. 1989. Clinical and CT scan findings in a case of cyanide intoxication. Mov Disord 4:188–193.2733710
*Gray BH, Porvaznik M, Lee LH. 1986. Cyanide stimulation of tri-n-butyltin mediated hemolysis. J Appl Toxicol 6:263–269.3760452
*Great Lakes Water Quality Board. 1983. An inventory of chemical substances identified in the Great Lakes ecosystem. Vol. 1. Windsor, Ontario: Great Lakes Water Quality Board, 195.
*Greer JJ, Carter JE. 1995. Effects of cyanide on the neural mechanisms controlling breathing in the neonatal rat in vitro. Neurotoxicology 16(2):211–216.7566681
*Greim H. 1990. Toxicological evaluation of emission from modern municipal waste incinerators. Chemosphere 20:317–331.
*Grosse DW. 1986. Treatment technologies for hazardous wastes part IV. A review of alternative treatment processes for metal-bearing hazardous waste streams. J Air Pollut Control Assoc 36:603–614.
*Guerin MR, Higgins CE, Jenkins RA. 1987. Measuring environmental emissions from tobacco combustion: Sidestream cigarette smoke literature review. Atmos Environ 21(2):291–297.
*Gunasekar PG, Sun PW, Kanthasamy AG, . 1996. Cyanide-induced neurotoxicity involves nitric oxide and reactive oxygen species generation after N-methyl-D-aspartate receptor activation. J Pharmacol Exp Ther 277:150–155.8613912
*Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
*Hall AH, Doutre WH, Ludden T, . 1987. Nitrite/thiosulfate treated acute cyanide poisoning: Estimated kinetics after antidote. Clin Toxicol 25(1&2):121–133.
Hansch C, Leo A, Hoekman D. 1995. In: Heller SR, ed. Exploring QSAR: Hydrophobic, electronic, and steric constants. Washington DC: American Chemical Society, 3.
Hansen BA, Dekker EE. 1976. Inactivation of bovine liver 2-keto-4-hydroxyglutarate aldolase by cyanide in the presence of aldehydes. Biochemistry 15:2912–2917.985699
*Hantson P, N’Geye P, Laforge M, . 1996. Suicide attempt by ingestion of potassium ferricyanide. J Toxicol Clin Toxicol 34:471–473.8699565
*Hargis KM, Tillery MI, Ettinger HJ, . 1986. Industrial hygiene study of a true in-situ oil shale retorting facility. Am Ind Hyg Assoc J 47:455–464.
Hathway DE. 2000. Toxic action/toxicity. Biol Rev Cambridge Phil Soc 75(1):95–127.
*Hartung R. 1982. Cyanides and nitriles. In: Clayton GD, Clayton FE, eds. Patty’s industrial hygiene and toxicology. Vol. IIC, 3rd ed. New York, NY: John Wiley and Sons, 4845–4900.
*Hauth JC, Hauth J, Drawbaugh RB, . 1984. Passive smoking and thiocyanate concentrations in pregnant women and newborns. Obstet Gynecol 63(4):519–522 6700899
*Hawley GG. 1981. The condensed chemical dictionary. 10th ed. New York, NY: Van Nostrand Reinhold Co., 106, 180–181, 275, 294–295, 542, 847–848, 924, 937–938, 1108.
Haxhiu MA, Erokwu B, van Lunteren E, . 1993. Central and spinal effects of sodium cyanide on respiratory activity. J Appl Physiol 74(2):574–579.8458772
*Haymaker W, Ginzler AM, Ferguson RL. 1952. Residual neuropathological effects of cyanide poisoning: A study of the central nervous system of 23 dogs exposed to cyanide compounds. Mil Surg 3:231–246.
*HazDat. 2005. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry. www.atsdr.cdc.gov/hazdat.html. September 15, 2005.
HECS. 1991. Cyanide. Healthy environments and consumer safety. www.hc-sc.gc.ca/hecs-sesc/water/pdf/dwg/cyanide.pdf. June 3, 2004.
*Henderson L, Wolfreys A, Fedyk J, . 1998. The ability of the Comet assay to discriminate between genotoxins and cytotoxins. Mutagenesis 13:89–94.9491401
*Henny CJ, Hallock RJ, Hill EF. 1994. Cyanide and migratory birds at gold mines in Nevada, USA. Ecotoxicology 3(1):45–58.24201865
Henretig FM, Cieslak TJ, Eitzen EM. 2002. Biological and chemical terrorism. J Pediatr 141:311–326.12219050
*Hertting GO, Kraupp E, Schnetz E, . 1960. [Investigation about the consequences of a chronic administration of acutely toxic doses of sodium cyanide to dogs.] Acta Pharmacol Toxicol 17:27–43. (German)
*Heuser SG, Scudmore KA. 1969. Determination of fumigant residues in cereals and other foodstuffs: A multidetection scheme for gas chromatography of solvent extract. J Sci Food Agric 20:566–572.5347751
*Higgins TE, Desher DP. 1988. Metal finishing and processing. J Water Pollut Control Fed 60:904–909.
*Higgins EA, Fiorca V, Thomas AA, . 1972. Acute toxicity of brief exposures to HF, HCI, NO_2_ and HCN with and without CO. Fire Technol 8:120–130.
Him YH, Foo M, Terry R. 1982. Cyanide encephalopathy following therapy with sodium nitroprusside. Arch Pathol Lab Med 106:392–393.6896629
*Himwich WA, Saunders JP. 1948. Enzymatic conversion of cyanide to thiocyanate. Am J Physiol 153:348–354.18872649
*Hirano A, Levine S, Zimmerman HM. 1967. Experimental cyanide encephalopathy: Electron microscopic observations of early lesions in white matter. J Neuropathol Exp Neurol 26:200–213.6022168
*Hirano A, Levine S, Zimmerman HM. 1968. Remyelination in the central nervous system after cyanide intoxication. J Neuropathol Exp Neurol 27:234–245.5646195
*Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
*Homan ER. 1987. Reactions, processes, and materials with potential for cyanide exposure. In: Ballantyne B, Marrs TC, eds. Clinical and experimental toxicology of cyanides. Bristol: IOP Publishing Limited, 1–21.
*Honig DH, Hockridge ME, Gould RM, . 1983. Determination of cyanide in soybeans and soybean products. J Agric Food Chem 31:272–275.6682869
*Howard JW, Hanzal RF. 1955. Chronic toxicity for rats of food treated with hydrogen cyanide. Agric and Food Chem 3:325–329.
Howd RA, Brown JP, Morry DW, . 2000. Development of California public health goals (PHGs) for chemicals in drinking water. J Appl Toxicol 20:365–380.11139167
*Howlett WP, Brubaker GR, Mlingi N, . 1990. Konzo, an epidemic upper motor neuron disease studied in Tanzania. Brain 113:223–235.2302534
*HSDB. 2004. Cyanide. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. June 06, 2004.
Hshieh F. 1999. Predicting heats of combustion and lower flammability limits of organosilicon compounds. Fire Mater 23:79–89.
*Huang J, Niknahad H, Khan S, . 1998. Hepatocyte-catalysed detoxification of cyanide by L- and D-cysteine. Biochem Pharmacol 55:1983–1990.9714318
*Huiatt JL. 1985. Cyanide from mineral processing: Problems and research needs. In: Van Zyl D ed. Cyanide and Environment: Proceedings of a conference Tucson, Arizona December 11-14, 1984: Volume 1. Fort Collins, CO: Colorado State University, 65–81.
*Hume AS, Mozigo JR, McIntyre B, . 1995. Antidotal efficacy of alpha-ketoglutaric acid and sodium thiosulfate in cyanide poisoning. Clin Toxicol 33(6):721–724.
*IARC. 2004. Overall evaluations of carcinogenicity to humans: As evaluated in IARC Monographs volumes 1-82 (at total of 900 agents, mixtures and exposures). Lyon, France: International Agency for Research on Cancer. http://www-cie.iarc.fr/monoeval/crthall.html. February 15, 2005.
*Ibrahim MZ, Briscoe PB, Bayliss OB, . 1963. The relationship between enzyme activity and neuroglia in the prodromal and demyelinating stages of cyanide encephalopathy in the rat. J Neurol Neurosurg Psychiatry 26:479–486.14083218
*Ikegaya H, Iwase H, Hatanaka K, . 2001. Diagnosis of cyanide intoxication by measurement of cytochrome c oxidase activity. Toxicol Lett 119:117–123.11311573
Inoue M, Imanaga I. 1998. Activation of Ca^2+^-dependent K^+^ channels by cyanide in guinea pig adrenal chromaffin cells. Am J Physiol 274:C105–C111.9458718
Inoue M, Sakamoto Y, Yano A, . 1997. Cyanide suppression of inwardly rectifying K^+^ channels in guinea pig chromaffin cells involves dephosphorylation. Am J Physiol Cell Physiol 273:C137–C147.
IPCS. 2004. Poisons information monograph: Cyanides. International Programme Chemical Safety. www.inchem.org/documents/pims/chemical/pimg003.htm. May 24, 2004.
*IPCS/CEC. 1993. IPCS/CEC evaluation of antidotes series. Volume 2. Antidotes for poisoning by cyanide. International Program on Chemical Safety/Commission of the European Communities. http://www.inchem.org/documents/antidote/antidote/ant02.htm. June 16, 2004.
*IRIS. 2004. Cyanide compounds. Integrated risk information system. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/ June 06, 2004.
*IRPTC. 1985. Treatment and disposal methods for waste chemicals. International register of potentially toxic chemicals. Geneva, Switzerland: United Nations Environmental Programme.
Ishii A, Seno H, Watanabe-Suzuki K, . 1998. Determination of cyanide in whole blood by capillary gas chromatography with cryogenic oven trapping. Anal Chem 70:4873–4876.9844576
*Isom GE, Borowitz JL. 1995. Modification of cyanide toxicodynamics: Mechanistic based antidote development. Toxicol Lett 82/83:795–799.8597144
*Isom GE, Way JL. 1973. Cyanide intoxication: Protection with cobaltous chloride. Toxicol Appl Pharmacol 24:449–456.4704816
*Isom GE, Way JL. 1974. Effect of oxygen on cyanide intoxication. VI. Reactivation of cyanide-inhibited glucose metabolism. J Pharmacol Exp Ther 189:235–243.4823293
*Isom GE, Burrows GE, Way JL. 1982. Effect of oxygen on the antagonism of cyanide intoxication-cytochrome oxidase, in vivo. Toxicol Appl Pharmacol 65:250–256.6294919
*Isom GE, Liu DHW, Way JL. 1975. Effect of sublethal doses of cyanide on glucose catabolism. Biochem Pharmacol 24:871–875.1125087
Iwahashi H, Takahasi Y. 2000. Bioassay for chemical toxicity using yeast Saccharomyces cerevisiae. Water Sci Technol 42:269–276.
*Jacangelo JG, Patania NL, Reagan KM, . 1989. Ozonation: Assessing its role in the formation and control of disinfection by-products. J Am Water Works Assoc 81:74–84.
*Jackson LC. 1988. Behavioral effects of chronic sublethal dietary cyanide in an animal model: Implications for humans consuming cassava (Manihot esculenta). Hum Biol 60:597–614.3417281
Jackson LC, Chandler JP, Jackson RT. 1986. Inhibition and adaptation of red cell glucose-6-phosphate dehydrogenase (G6PD) in vivo to chronic sublethal dietary cyanide in an animal model. Hum Biol 58:67–77.3514426
*Jaramillo M, DeZafra RL, Barrett J, . 1989. Measurements of stratospheric hydrogen cyanide and McMurdo Station, Antarctica: Further evidence of winter stratospheric subsidence? J Geophys Res 94:16,773–16,777.
*Jarvis MJ. 1989. Application of biochemical intake markers to passive smoking measurement and risk estimation. Mutat Res 222:101–110.2645516
*Jenks WR. 1979. Cyanides. In: Grayson, M, ed. Kirk-Othmer encyclopedia of chemical technology. New York, NY: John Wiley and Sons, Inc., 307–334.
*Jensen JN, Tuan Y-J. 1993. Chemical oxidation of thiocyanate ion by ozone. Ozone Sci Eng 15(4):343–360.
*Jiang S, Liu Z, Zhuang X. 1998. Effect of procaine hydrochloride on cyanide intoxication and its effect on neuronal calcium in mice. Toxicol Appl Pharmacol 150(1):32–36.9630450
Johanning RJ, Zaske DE, Tschida SJ, . 1995. A retrospective study of sodium nitroprusside use and assessment of the potential risk of cyanide poisoning. Pharmacotherapy 15(6):773–777.8602386
*Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
Johnson JD, Isom GE. 1985. The oxidative disposition of potassium cyanide in mice. Toxicology 37:215–224.3000027
*Johnson JD, Conroy WG, Burris KD, . 1987a. Peroxidation of brain lipids following cyanide intoxication in mice. Toxicology 46:21–28.3660418
Johnson JD, Conroy WG, Isom GE. 1987b. Effect of pentobarbital on cyanide-induced tremors in mice and calcium accumulation in PC12 cells. Biochem Pharmacol 36:1747–1749.3593396
*Johnson JD, Meisenheimer TL, Isom GE. 1986. Cyanide-induced neurotoxicity: Role of neuronal calcium. Toxicol Appl Pharmacol 84:464–469.3726869
*Johnson CA, Leinz RW, Grimes DJ, . 2002. Photochemical changes in cyanide speciation in drainage from a precious metal ore heap. Environ Sci Technol 36:840–845.11918005
*Jones DA. 1998. Why are so many food plants cyanogenic? Phytochemistry 47:155–162.9431670
Jones DP. 1995. Mitochondrial dysfunction during anoxia and acute cell injury. Biochim Biophys Acta 1271:29–33.7599222
*Jones DC, Gunasekar PG, Borowitz JL, . 2000. Dopamine-induced apoptosis is mediated by oxidative stress and is enhanced by cyanide in differentiated PC12 cells. J Neurochem 74:2296–2304.10820189
*Jones DC, Prabhakaran K, Li L, . 2003. Cyanide enhancement of dopamine-induced apoptosis in mesencephalic cells involves mitochondrial dysfunction and oxidative stress. Neurotoxicology 24:333–342.12782099
Kadushin FS, Bronstein AC, Riddle MW, . 1988. Cyanide induced parkinsonism: Neuropsychological and radiological findings [Abstract]. Vet Hum Toxicol 30:359.
Kage S, Nagata T, Kudo K. 1996. Determination of cyanide and thiocyanate in blood by gas chromatography and gas chromatography - mass spectrometry. J Chromatogr B Biomed Appl 675:27–32.8634765
Kales SN, Christiani DC. 2004. Acute chemical emergencies. N Engl J Med 350:800–808.14973213
Kales SN, Dinklage D, Dickey J, . 1997. Paranoid psychosis after exposure to cyanide. Arch Environ Health 52(3):245–246.9169637
*Kamalu BP. 1993. Pathological changes in growing dogs fed on a balanced cassava (Manihot esculenta Crantz) diet. Br J Nutr 69(3):921–934.8329365
Kamendulis LM, Zhang H, Wang Y, . 2002. Morphological transformation and oxidative stress induced by cyanide in Syrian hamster embryo (SHE) cells. Toxicol Sci 68(2):437–443.12151639
*Kampe S, Iffland R, Korenkov M, . 2000. Survival from a lethal blood concentration of cyanide with associated alcohol intoxication. Anaesthesia 55:1189–1191.11121929
*Kanthasamy AG, Ardelt B, Malave A, . 1997. Reactive oxygen species generated by cyanide mediate toxicity in rat pheochromocytoma cells. Toxicol Lett 93:47–54.9381482
*Kanthasamy AG, Borowitz JL, Isom GE. 1991b. Cyanide-induced increases in plasma catecholamines: Relationship to acute toxicity. Neurotoxicology 12:777–784.1795901
*Kanthasamy AG, Borowitz JL, Pavlakovic G, . 1994. Dopaminergic neurotoxicity of cyanide: neurochemical, histological, and behavioral characterization. Toxicol Appl Pharmacol 126(1):156–163.7910421
*Kanthasamy AG, Maduh EU, Peoples RW, . 1991a. Calcium mediation of cyanide-induced catecholamine release: Implications for neurotoxicity. Toxicol Appl Pharmacol 110:275–282.1909818
*Kaplin AI, Snyder SH, Linden DJ. 1996. Reduced nicotinamide adenine dinucleotide-selective stimulation of inositol 1,4,5-trisphosphate receptors mediates hypoxic mobilization of calcium. J Neurosci 16(6):2002–2011.8604044
*Karmarkar S. 2002. Anion-exchange chromatography of metal cyanide complexes with gradient separation and direct UV detection. J Chromatogr A 956:229–235.12108655
*Karube I, Yano K, Sasaki S, . 1998. Biosensors for environmental monitoring. Ann NY Acad Sci 864:23–36.9928081
*Kasamo K, Okuhata Y, Satoh R, . 1993. Chronological changes of MRI findings on striatal damage after acute cyanide intoxication: Pathogenesis of the damage and its selectivity, and prevention for neurological sequelae: A case report. Eur Arch Psychiatry Clin Neurosci 243(2):71–74.8218429
*Katayama Y, Narahara Y, Inoue Y, . 1992. A thiocyanate hydrolase of Thiobacillus thioparus. A novel enzyme catalyzing the formation of carbonyl sulfide from thiocyanate. J Biol Chem 267(13):9170–9175.1577754
*Katayama Y, Kanagawa T, Kuraishi H. 1993. Emission of carbonyl sulfide by Thiobacillus thioparus grown with thiocyanate in pure and mixed cultures. FEMS Microbiol Lett 114 (2):223–228.
*Kato T, Kameyama M, Nakamura S, . 1985. Cyanide metabolism in motor neuron disease. Acta Neurol Scand 72:151–156.4050324
Katsumata Y, Sato K, Yada S, . 1983. Kinetic analysis of anaerobic metabolism in rats during acute cyanide poisoning. Life Sci 33:151–155.
Kazim R, Whittington RA, Sun LS. 1996. Sodium nitroprusside metabolism in children. Anesth Analg 82:1301–1302.
*Keith LH. 1991. Sampling water matrices. Environmental sampling and analysis: A practical guide. Chelsea, MI: Lewis Publishers, 31–40.
*Kelly DP, Harrison AP. 1989. Genus Thiobacillus. In: Staley JT, Bryant MP, Pfenning N, ., eds. Bergey’s manual of systemic bacteriology. Vol. 3. Baltimore, MD: Williams & Wilkins, 1842–1858.
*Keniston RC, Cabellon S, Yarbrouch KS. 1987. Pyridoxal 5’-phosphate as an antidote for cyanide, spermine, gentamicin, and dopamine toxicity: An in vivo rat study. Toxicol Appl Pharmacol 88:433–441.3576625
Kevan SD, Dixon DG. 1996. Effects of age and coion (K^+^ and Na^+^) on the toxicity of thiocyanate to rainbow trout (Oncorhychus mykiss) during pulse or continuous exposure. Ecotoxicol Environ Saf 35:288–293.9007007
*Khandekar JD, Edelman H. 1979. Studies of amygdalin (laetrile) toxicity in rodents. J Am Med Assoc 242:169–171.
Khot UN, Novaro GM, Popovic ZB, . 2003. Nitroprusside in critically ill patients with left ventricular dysfunction and aortic stenosis. N Engl J Med 348:1756–1763.12724481
Kiang JG, Smallridge RC. 1994. Sodium cyanide increases cytosolic free calcium: Evidence for activation of the reversed mode of the Na^+^/Ca^2+^ exchanger and Ca^2+^ mobilization from inositol trisphosphate-insensitive pools. Toxicol Appl Pharmacol 127(2):173–181.7519371
Kiang JG, Ding XZ, McClain DE. 1998. Overexpression of HSP-70 attenuates increases in [Ca^2+^]; and protects human epidermoid A-431 cells after chemical hypoxia. Toxicol Appl Pharmacol 149(2):185–194.9571987
*Kiang JG, Warke VG, Tsokos GC. 2003. NaCN-induced chemical hypoxia is associated with altered gene expression. Mol Cell Biochem 254:211–216.14674700
Kim E, Little JC, Chiu N, . 2001. Inhalation exposure to volatile chemicals in drinking water. Environ Carcinog Ecotoxicol C19(2):387–413.
Kim YM, Harrad S, Harrison RM. 2002. Levels and sources of personal inhalation exposure to volatile organic compounds. Environ Sci Technol 36:5405–5410.12521168
Kirk M, Kulig K, Rumack BH. 1989. Methemoglobin and cyanide kinetics in smoke inhalation [Abstract]. Vet Hum Toxicol 31:353.
*Kirk RL, Stenhouse NS. 1953. Ability to smell solutions of potassium cyanide. Nature 171:698–699.13054678
*Kiuchi Y, Inagaki M, Izumi J, . 1992. Effect of local cyanide perfusion on rat striatal extracellular dopamine and its metabolites as studied by in vivo brain mirodialysis. Neurosci Lett 147:193–196.1491807
*Klecka GM, Landi LP, Bodner KM. 1985. Evaluation of the OECD activated sludge, respiration inhibition test. Chemosphere 14:1239–1251.
*Klimmek R, Roddewig C, Fladerer H, . 1983. Effects of 4-dimethylaminophenol, Co_2_EDTA, or NaNO_2_ on cerebral blood flow and sinus blood homeostasis of dogs in connection with acute cyanide poisoning. Toxicology 26:143–154.6407153
*Knowles CJ. 1988. Cyanide utilisation and degradation by microorganisms. In: Cyanide compounds in biology. Chichester: John Wiley and Sons, 3–15.
*Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
Kong Z, Vanrolleghem P, Willems P, . 1996. Simultaneous determination of inhibition kinetics of carbon oxidation and nitrification with a respirometer. Water Res 30(4):825–836.
Konstantinou IK, Albanis TA. 2004. Worldwide occurrence and effects of antifouling paint booster biocides in the aquatic environment: A review. Environ Int 30:235–248.14749112
*Kopfler FC, Melton RG, Mullaney JL, . 1977. Human exposure to water pollutants. Adv Environ Sci Technol 8:419–433.
Kopp S, Kisling G, Paulson D, . 1989. Cardiac actions of cadmium, potassium cyanide and carbonyl cyanide m-chlorophenylhydrazone [Abstract]. FASEB J 3:A–251.
*Korte F, Coulston F. 1995. Comment: From single-substance evaluation to ecological process concept: The dilemma of processing gold with cyanide. Ecotoxicol Environ Saf 32:96–101.8565884
Korte F, Coulston F. 1998. Commentary: Some considerations on the impact on ecological chemical principles in practice with emphasis on gold mining and cyanide. Ecotoxicol Environ Saf 41:119–129.9756700
Korte F, Spiteller M, Coulston F. 2000. Commentary: The cyanide leaching gold recovery process is a nonsustainable technology with unacceptable impacts on ecosystems and humans: The disaster in Romania. Ecotoxicol Environ Saf 46(3):241–245.10903819
*Koyama K, Yoshida A, Takeda A, . 1997. Abnormal cyanide metabolism in uraemic patients. Nephrol Dial Transplant 12:1622–1628.9269639
*Krasner SW, McGuire MJ, Jacangelo JG, . 1989. The occurrence of disinfection by-products in U.S. drinking water. J Am Water Works Assoc 81:41–53.
*Krieble VK, McNally JG. 1929. The hydrolysis of hydrogen cyanide by acids. J Am Chem Soc 51:3368–3375.
*Krieble VK, Peiker AL. 1933. The hydrolysis of hydrogen cyanide by acids II. J Am Chem Soc 55:2326–2331.
*Kreutler PA, Varbanov V, Goodman W, . 1978. Interactions of protein deficiency, cyanide, and thiocyanate on thyroid function in neonatal and adult rats. Am J Clin Nutr 31:282–289.74949
*Krishnan K, Andersen ME. 1994. Physiologically-based pharmacokinetic modeling in toxicology. In: Hayes W, ed. Principles and methods of toxicology. 3rd edition. New York, NY: Raven Press, Ltd.
*Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
*Kruszyna R, Kruszyna H, Smith RP. 1982. Comparison of hydroxylamine, 4-dimethylaminophenol and nitrite protection against cyanide poisoning in mice. Arch Toxicol 49:191–202.7092558
*Kuban V. 1992. Gas permeation and preconcentration in the flow-injection determination of acid-available cyanide in waste water. Anal Chim Acta 259(1):45–52.
*Kubo T, Urano K, Utsumi H. 2002. Mutagenicity characteristics of 255 environmental chemicals. J Health Sci 48(6):545–554.
*Kumar P, Das M, Kumar A. 1992. Health status of workers engaged in heat treatment (case hardening) plant and electroplating at cyanide bath. Indian J Environ Prot 12(3):179–183.
*Kunz DA, Nagappan O, Silva-Avalos J, . 1992. Utilization of cyanide as a nitrogenous substrate by Pseudomonas fluorescens NCIMB 11764: Evidence for multiple pathways of metabolic conversion. Appl Environ Microbiol 58(6):2022–2029.1622281
*Kushi A, Matsumoto T, Yoshida D. 1983. Mutagen from the gaseous phase of protein pyrolyzate. Agric Biol Chem 47:1979–1982.
*Laforge M, Buneaux F, Houeto P, . 1994. A rapid spectrophotometric blood cyanide determination applicable to emergency toxicology. J Anal Toxicol 18:173–175.8065128
*Laforge M, Gourlain H, Fompeydie D, . 1999. Ferrocyanide ingestion may cause false positives in cyanide determination. J Toxicol Clin Toxicol 37(3):337–340.10384799
*Lam KK, Lau FL. 2000. An incident of hydrogen cyanide poisoning. Am J Emerg Med 18:172–175.10750924
*Lambat Z, Conrad N, Anoopkumar-Dukie S, . 2000. An investigation into the neuroprotective properties of ibuprofen. Metab Brain Dis 15(4):249–256.11383549
Lambert W, Meyer E, De Leenheer A. 1995. Cyanide and sodium azide intoxication. Ann Emerg Med 26:392.
*Landahl HD, Herrmann RG. 1950. Retention of vapors and gases in the human nose and lung. Arch Ind Hyg Occup Med 1:36–45.15419854
Lang CJG. 2000. The use of neuroimaging techniques for clinical detection of neurotoxicity: A review. Neurotoxicology 21:847–856.11130290
*Lasch EE, El Shawa R. 1981. Multiple cases of cyanide poisoning by apricot kernels in children from Gaza. Pediatrics 68:5–7.
*Leeder JS, Kearns GL. 1997. Pharmcogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Leng G, Lewalter J. 2002. Polymorphism of glutathione S-transferases and susceptibility to acrylonitrile and dimethylsulfate in cases of intoxication. Toxicol Lett 134:209–217.12191880
*Lessell S. 1971. Experimental cyanide optic neuropathy. Arch Ophthalmol 86:194–204.4328388
*Leung H. 1993. Physiologically-based pharmacokinetic modeling. In: Ballantine B, Marro T, Turner T, eds. General and applied toxicology. Vol. I. New York, NY: Stockton Press, 153–164.
*Levin BC, Paabo M, Gurman JL, . 1987. Effect of exposure to single or multiple combinations of the predominant toxic gases and low oxygen atmospheres produced in fires. Fundam Appl Toxicol 9:236–250.2820822
*Levin BC, Rechani PR, Gurman JL, . 1990. Analysis of carboxyhemoglobin and cyanide in blood from victims of the Dupont Plaza Hotel fire in Puerto Rico. J Forensic Sci 35(1):151–168.2155992
*Levine S. 1969. Experimental cyanide encephalopathy: Gradients of susceptibility in the corpus callosum. J Neuropathol Exp Neurol 26:214–222.
*Levine S, Stypulkowski W. 1959a. Experimental cyanide encephalopathy. Arch Pathol 67:306–323.
*Levine S, Stypulkowski W. 1959b. Effect of ischemia on cyanide encephalopathy. Neurology 9:407–411.13657302
*Lewis TR, Anger WK, Te Vault RK. 1984. Toxicity evaluation of sub-chronic exposures to cyanogen in monkeys and rats. J Environ Pathol Toxicol Oncol 5:151–163.6520722
Li W, Palmer G. 1993. Spectroscopic characterization of the interaction of azide and thiocyanate with the binuclear center of cytochrome oxidase: Evidence for multiple ligand sites. Biochemistry 32(7):1833–1843.8382524
*Li HZ, Bai G, Sun RM, . 1993. Determination of thiocyanate metabolite of sodium nitroprusside in serum by spectrophotometry. Yaoxue Xuebao 28(11):854–858.
*Li L, Prabhakaran K, Mills EM, . 2005. Enhancement of cyanide-induced mitochondrial dysfunction and cortical cell necrosis by uncoupling protein-2. Toxicol Sci 86(1):116–124.15800031
Li L, Prabhakaran K, Shou Y, . 2002. Oxidative stress and cyclooxygenase-2 induction mediate cyanide-induced apoptosis of cortical cells. Toxicol Appl Pharmacol 185:55–63.12460737
*Lide DR, ed. 1990. CRC handbook of chemistry and physics. 72nd ed. Boca Raton, FL: CRC Press, Inc.
Lide DR, ed. 2000. CRC handbook of chemistry and physics. 81st ed. Boca Raton, FL: CRC Press, Inc.
*Lide DR, ed. 2005. CRC handbook of chemistry and physics. 86th ed. Boca Raton, FL: CRC Press, Inc., 4–49.
*Liebowitz D, Schwartz H. 1948. Cyanide poisoning: Report of a case with recovery. Am J Clin Pathol 18:965–970.18105520
*Linden CH, Lovejoy Jr. FH. 1998. Poisoning and drug overdose. In: Fauci AS, Braunwald E, Isselbacher KJ, eds. Harrison’s principles of internal medicine. New York: McGraw-Hill Health Professions Division.
*Litovitz TL, Larkin RF, Myers RA. 1983. Cyanide poisoning treated with hyperbaric oxygen. Am J Emerg Med 1:94–101.6680611
*Liu X, Yun Z. 1993. High-performance liquid chromatographic determination of thiocyanate anions by derivatization with pentafluorobenzyl bromide. J Chromatogr A 653:348–353.
*Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
Lo SC, Agar NS. 1999. NADH-methemoglobin reductase activity in the erythrocytes of newborn and adult mammals. Experientia 42:1264–1265.
*Lobert JM, Warnatz J. 1993. Emission from the combustion process in vegetation. In: Crutzen PJ, Goldammer JG, eds. Fire in the environment: the ecological, atmospheric and climatic importance of vegetation fires. Chincherster, England: John Wiley and Sons, Ltd., 15–37.
*Logue BA, Kirschten NP, Petrikovics I, . 2005. Determination of the cyanide metabolite 2-aminothiazoline-4-carboxylic acid in urine and plasma by gas chromatography-mass spectrometry. J Chromatogr B Analyt Technol Biomed Life Sci 819(2):237–244.
*Lowe J, Sullivan JB, Jr. 1992. Fumigants. In: Sullivan JB, Krieger GR, eds. Hazardous materials toxicology, clinical principles of 1992. Baltimore: Williams and Wilkins, 1053–1062.
Lu Q, Collins GE, Evans T, . 2004. Vapor and liquid phase detection of cyanide on a microchip. Electrophoresis 25:116–122.14730575
*Lucas AD. 1992. Health hazards associated with the cyanotype printing process. J Environ Pathol Toxicol Oncol 11(1):18–20.1740763
*Lucas AD, Salisbury SA. 1992. Industrial hygiene survey in a university art department. J Environ Pathol Toxicol Oncol 11(1):21–27.1740764
*Ludzack FJ, Moore WA, Krieger HL, . 1951. Effect of cyanide on biochemical oxidation in sewage and polluted water. Sewage Ind Wastes 23:1298–1307.
Lundquist P. 1992. Determination of cyanide and thiocyanate in humans. Linkoping University Medical Dissertations no. 355.
*Lundquist P, Sorbo B. 1989. Rapid determination of toxic cyanide concentrations in blood. Clin Chem 35:617–619.2539272
Lundquist P, Rammer L, Sorbo B. 1989. The role of hydrogen cyanide and carbon monoxide in fire casualties: A prospective study. Forensic Sci Int 43:9–14.2556335
Lv J, Zhang Z, Li J, . 2005. A micro-chemiluminescence determination of cyanide in whole blood. Forensic Sci Int 148(1):15–19.15607585
*Lyman, W. 1982. Atmospheric residence time. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods: Environmental behavior of organic compounds. New York, NY: McGraw Hill Book Company, 10-2–10-33.
*Ma H, Liu J. 1992. Flow-injection determination of cyanide by detecting an intermediate of the pyridine-barbituric acid chromogenic reaction. Anal Chim Acta 261(1–2):247–252.
Macey PM, Richard CA, Rector DM, . 2000. State influences on ventral medullary surface and physiological responses to sodium cyanide challenges. J Appl Physiol 89:1919–1927.11053344
*Maduh EU, Baskin SI. 1994. Protein kinase C modulation of rhodanese catalyzed conversion of cyanide to thiocyanate. Res Comm Mol Pathol Pharmacol 86(2):155–173.
*Maduh EU, Borowitz JL, Isom GE. 1990a. Cyanide-induced alteration of cytosolic pH: Involvement of cellular hydrogen ion handling processes. Toxicol Appl Pharmacol 106:201–208.2256111
*Maduh EU, Johnson JD, Ardelt BK, . 1988. Cyanide-induced neurotoxicity: Mechanisms of attenuation by chlorpromazine. Toxicol Appl Pharmacol 96:60–67.3188027
*Maduh EU, Nealley EW, Song H, . 1995. A protein kinase C inhibitor attenuates cyanide toxicity in vivo. Toxicology 100:129–137.7624870
*Maduh EU, Turek JJ, Borowitz JL, . 1990b. Cyanide-induced neurotoxicity: Calcium mediation of morphological changes in neuronal cells. Toxicol Appl Pharmacol 103:214–221.2330585
*Madungwe L, Zaranyika MF, Gurira RC. 1991. Reversed-phase liquid chromatographic determination of cyanide as 1-benzoyl-1,2-dihydroquinaldonitrile. Anal Chim Acta 251:109–114.
*Maharaj DS, Walker RB, Glass BD, . 2003. 6-Hydroxymelatonin protects against cyanide induced oxidative stress in rat brain homogenates. J Chem Neuroanat 26:103–107.14599659
*Makene WJ, Wilson J. 1972. Biochemical studies in Tanzanian patients with ataxic tropical neuropathy. J Neurol Neurosurg Psychiatry 35:31–33.5026008
*Malaney GW, Sheets WD, Quillin R. 1959. Toxic effects of metallic ions on sewage microorganisms. Sewage Ind Wastes 31:1909–1915.
Malenfant A, Shirey T, Young CC. 1996. Thiocyanate interference in nova stat profile analyses. Clin Chem 42:483.
*Maliszewski TF, Bass DE. 1955. True and apparent thiocyanate in body fluids of smokers and nonsmokers. J Appl Physiol 8:289–291.13271257
Malone KE, Koepsell TD, Daling JR, . 1987. Chronic lymphocytic leukemia in relation to toxic substance exposure [Abstract]. Am J Epidemiol 126:763.
Manitoba Environment. 1996. Ambient air quality guidelines for hydrogen cyanide: CAS74-90-8. Manitoba Environment. MIC9701427.
*Mannaioni G, Vannacci A, Marzocca C, . 2002. Acute cyanide intoxication treated with a combination of hydroxycobalamin, sodium nitrite, and sodium thiosulfate. Clin Toxicol 40:181–183.
Maragos WF, Zhu J, Chesnut MD, . 2002. Mitochondrial toxin inhibition of [^3^H]dopamine uptake into rat striatal synaptosomes. Biochem Pharmacol 63(8):1499–1505.11996892
*Martin-Bermudez R, Maestre-Romero A, Goni-Belzunegui MV, . 1997. Venous blood arteriolization and multiple organ failure after cyanide poisoning. Intensive Care Med 23:1286.9470088
Maseda C, Matsubara K, Shiono H. 1989. Improved gas chromatography with electron-capture detection using a reaction pre-column for the determination of blood cyanide: A higher content in the left ventricle of fire victims. J Chromatogr 82:319–327.
Mathangi DC, Namasivayam A. 2000. Effect of chronic cyanide intoxication on memory in albino rats. Food Chem Toxicol 38:51–55.10685013
*Mathangi DC, Namasivayam A. 2004a. Calcium ions: Its role in cyanide neurotoxicity. Food Chem Toxicol 42:359–361.14871577
*Mathangi DC, Namasivayam A. 2004b. Protective effect of diltiazem on cyanide-induced neurotoxicity in Wistar strain rats. Food Chem Toxicol 42:605–608.15019184
*Matijak-Schaper M, Alarie Y. 1982. Toxicity of carbon monoxide, hydrogen cyanide and low oxygen. J Combust Toxicol 9:21–61.
*Matsumoto M, Inagaki M, Kiuchi Y, . 1993. Role of calcium ions in dopamine release induced by sodium cyanide perfusion in rat striatum. Neuropharmacol 32(7):681–688.
*Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
McElhatton PR, Garbis H, Schaefer C. 2001. Industrial and environmental chemicals. In: Schaefer C, ed. Drugs during pregnancy and lactation: Handbook of prescription drugs and comparative risk assessment: With undated information on recreational drugs. Amsterdam: Elsevier.
McGregor D, Anderson D. 1999. DNA damage and repair in mammalian cells in vitro and in vivo as indicators of exposure to carcinogens. IARC Sci Publ 146:309–313.
*McGuinn WD, Baxter L, Pei L, . 1994. Antagonism of the lethal effects of cyanide by a synthetic water-soluble cobalt(III) porphyrin compound. Fundam Appl Toxicol 23(1):76–80.7958566
McMahon T, Birnbaum L. 1990. Age-related changes in biotransformation and toxicity of potassium cyanide (KCN) in male C57BL/6N mice [Abstract]. In: Proceedings of the 29th Annual Meeting of the Society of Toxicology. Miami Beach, FL: Society of Toxicology.
*McMillan DE, Svoboda AC. 1982. The role of erythrocytes in cyanide detoxification. J Pharmacol Exp Ther 221:37–42.7062290
*McNerney JM, Schrenk HH. 1960. The acute toxicity of cyanogen. Am Ind Hyg Assoc J 21:121–124.
Meeussen JCL, Temminghoff EJM, Keizer MG, . 1989. Spectrophotometric determination of total cyanide, iron-cyanide complexes, free cyanide and thiocyanate in water by a continuous-flow system. Analyst (London) 114:959–963.
*Mengel K, Kramer W, Isert B, . 1989. Thiosulphate and hydroxocobalamin prophylaxis in progressive cyanide poisoning in guinea-pigs. Toxicology 54:335–342.2705197
*Menton RG, Reid FM, Niemuth NA, . 1996. Efficacy of p-aminopropiophenone in preventing cyanide intoxication. 1996 Medical defense bioscience review: Proceedings 12-16 May. Aberdeen Proving Ground, MD: United States Army Medical Research Institute of Chemical Defense.
*Menton RG, Reid FM, Olson CT, . 1997. Comparative efficacy of three methemoglobin formers in delaying effects of infused sodium cyanide. Int J Toxicol 16:151–164.
*Meranger JC, Lo B. 1992. Selected anions and trace elements in Canadian drinking water supplies. Prepr Pap Natl Meet Am Chem Soc Div Environ Chem 32(2):31–37.
*Meriläinen J, Lampinen J. 2004. EILATox-Oregon Workshop: Blind study evaluation of Vitotox test with genotoxic and cytotoxic sample library. J Appl Toxicol 24(5):327–332.15478175
Meyer S, Baghai A, Sailer N-L, . 2005. Lactic acidosis caused by sodium nitroprusside in a newborn with congenital heart disease. Eur J Pediatr 164(4):253–254.15666157
*Meyers PR, Rawlings DE, Woods DR, . 1993. Isolation and characterization of a cyanide dihydratase from Bacillus pumilus C1. J Bacteriol 175(19):6105–6112.8407782
*Michigami Y, Fujii K, Ueda K, . 1992. Determination of thiocyanate in human saliva and urine by ion chromatography. Analyst (U.K.) 117(12):1855–1858.
*Mills EM, Gunasekar PG, Li L, . 1999. Differential susceptibility of brain areas to cyanide involves different modes of cell death. Toxicol Appl Pharmacol 156(1):6–16.10101094
Mills EM, Gunasekar PG, Pavlakovic G, . 1996. Cyanide-induced apoptosis and oxidative stress in differentiated PC12 cells. J Neurochem 67:1039–1046.8752110
*Minami K. 1982. Volatilization of sulfur from paddy soils. Jpn Agric Res Q 15:167–171.
*Minami K, Fukushi S. 1981. Volatilization of carbonyl sulfide from paddy soils treated with sulfur-containing substances. Soil Sci Plant Nutr 27:339–345.
*Ministry of Health, Mozambique. 1984. Mantakassa: An epidemic of spastic paraparesis associated with chronic cyanide intoxication in a cassava staple area of Mozambique. 1. Epidemiology and clinical and laboratory findings in patients. Bull WHO 62:477–484.6331909
MIS. 1990. Management Information System. Atlanta, GA: Agency for Toxic Substances and Disease Registry (ATSDR), Office of External Affairs, Exposure and Disease Registry Branch. September 24, 1990.
*Miura Y, Koh T. 1991. Determination of thiocyanate in human urine samples by suppressed ion chromatography. Anal Sci 7(Suppl Proc Int Congr Anal Sci, 1991, Pt 1):167–170.
*Mlingi N, Poulter NH, Rosling H. 1992. An outbreak of acute intoxications from consumption of insufficiently processed cassava in Tanzania. Nutr Res 12(6):677–687.
*Mlingi N, Vassey VD, Swai A BM, . 1993. Determinants of cyanide exposure from cassava in a konzo-affected population in northern Tanzania. Int J Food Sci Nutr 44(2):137–144.
Mokhlesi B, Leikin JB, Murray P, . 2003. Adult toxicology in critical care. Part II: Specific poisonings. Chest 123:897–922.12628894
*Monekosso GL, Wilson J. 1966. Plasma thiocyanate and vitamin B12 in Nigerian patients with degenerative neurological disease. Lancet 14:1062–1064.
*Money GL. 1958. Endemic neuropathies in the Epe district of southern Nigeria. West Africa Med J 7:58–62.
*Moore SJ, Norris JD, Ho IK, . 1986. The efficacy of ketoglutaric acid in the antagonism of cyanide intoxication. Toxicol Appl Pharmacol 82:40–44.3945942
Morawetz JS. 2005. Tales of acute risk assessment: Health effects made out of whole cloth. Am J Ind Med 47(4):370–375.15776471
*Morgan RL, Way JL. 1980. Fluorometric determination of cyanide in biological fluids with pyridoxal. J Anal Toxicol 4:78–81.7421138
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
*Mudder TI, Botz M. 2000. A global perspective of cyanide. Minerals Resources Forum. United Nations Environment Programme. www.mineralresourcesforum.org/Initiatives/cyanides/docs/mudder.pdf. June 11, 2004.
*Mudder TI, Whitlock JL. 1984. Biological treatment of cyanidation waste waters. Minerals Metallurgical Processing 1:161–165.
Muehlbauer PA, Schuler MJ. 2003. Measuring the mitotic index in chemically-treated human lymphocyte cultures by flow cytometry. Mutat Res 537:117–130.12787817
*Munro NB, Talmage SS, Griffin GD, . 1999. The sources, fate, and toxicity of chemical warfare agent degradation products. Environ Health Perspect 107(12):933–974.10585900
*Mushett CW, Kelley KL, Boxer GE, . 1952. Antidotal efficacy of vitamin B12 (hydroxo-cobalamin) in experimental cyanide poisoning. Proc Soc Exp Biol Med 81:234–247.13047367
Musshoff F, Padosch S, Steinborn S, . 2004. Fatal blood and tissue concentrations of more than 200 drugs. Forensic Sci Int 142(2–3):161–210.15172079
Mutlu GM, Leikin JB, Oh K, . 2002. An unresponsive biochemistry professor in the bathtub. Chest 122:1073–1076.12226056
*Myers VB. 1983. Remedial activities at the Miami Drum site, Florida. In: National conference on management of uncontrolled hazardous waste sites. Silver Springs, MD: Hazardous Materials Control Research Institute, 354–357.
*Myers KM, Fiskum G, Liu Y, . 1995. Bcl-2 protects neural cells from cyanide/aglycemia-induced lipid oxidation, mitochondrial injury, and loss of viability. J Neurochem 65:2432–2440.7595537
Nakatani T, Kosugi Y, Mori A, . 1993. Changes in the parameters of oxygen metabolism in a clinical course recovering from potassium cyanide. Am J Emerg Med 11(3):213–217.8489660
NAS. 1980. Drinking water and health. Vol. 3. Washington, DC: National Academy of Science.
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
NATICH. 1992. National Air Toxics Information Clearinghouse, Office of Air Quality Planning and Standards, U.S. Environmental Protection Agency.
*Nielsen P, Dresow B, Fischer R, . 1990. Bioavailability of iron and cyanide from oral potassium ferric hexacyanoferrate (II) in humans. Arch Toxicol 64:420–422.2403291
*Niknahad H, Ghelichkhani E. 2002. Antagonism of cyanide poisoning by dihydroxyacetone. Toxicol Lett 132:95–100.12044542
Niknahad H, O’Brien PJ. 1996a. Antidotal effect of dihydroxyacetone against cyanide toxicity in vivo. Toxicol Appl Pharmacol 138:186–191.8658508
Niknahad H, O’Brien PJ. 1996b. Involvement of nitric oxide in nitroprusside-induced hepatocyte cytotoxicity. Biochem Pharmacol 51:1031–1039.8866825
*Niknahad H, Khan S, Sood C, . 1994. Prevention of cyanide induced cytotoxicity by nutrients in isolated rat hepatocytes. Toxicol Appl Pharmacol 128(128):271–279.7940542
*Nikolelis DP, Siontorou CG, Andreou VG. 1997. Biosensors based on bilayer lipid membranes for automated continuous monitoring or rapid screening of environmental pollutants. Laboratory Robotics and Automation 9:285–295.
*Nikolic SD, Millosavljevic EB, Nelson JH. 1992. Flow injection amperometric determination of cyanide on a modified silver electrode. Analyst (London) 117(1):47–50.
*NIOSH. 1976. Health hazard evaluation report. Cincinnati, OH: U.S. Department of Health, Education, and Welfare, Center for Disease Control, National Institute for Occupational Safety and Health. No. 74-129-268.
*NIOSH. 1978. Health hazard evaluation report. Cincinnati, OH: U.S. Department of Health, Education, and Welfare, Center for Disease Control, National Institute for Occupational Safety and Health. No. 77-88-457.
*NIOSH. 1982. In-depth survey report of American Airlines plating facility. Cincinnati, OH: National Institute for Occupational Safety and Health. PB83187799.
NIOSH. 1986a. National Institute for Occupational Safety and Health. Morbidity and Mortality Weekly Supplement 35:19S.
*NIOSH. 1986b. Progress toward developing a monitoring method for hydrogen cyanide in air. Cincinnati, OH: National Institute for Occupational Safety and Health, Division of Physical Sciences and Engineering, Method Research Branch. PB86236171.
*NIOSH. 1989a. HCN and salts. Manual of analytical methods. 3rd edition, third supplement. Cincinnati, OH: National Institute of Occupational Safety and Health. PB90162470, 7904-1–7904-4.
*NIOSH. 1989b. Hydrogen cyanide. Manual of analytical methods. 3rd edition, third supplement. Cincinnati, OH: National Institute of Occupational Safety and Health. PB90162470. 6010-1–6010-4.
NIOSH. 1990. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. U.S. Department of Health and Human Services. DHHS (NIOSH) publication No. 90-117.
*NIOSH. 1992. NIOSH recommendations for occupational safety and health. Compendium of policy documents and statements. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Services, Centers for Disease Control, National Institute for Occupational Safety and Health, Division of Standards Development and Technology Transfer.
NIOSH. 2004. Cyanide compounds. NIOSH pocket guide to chemical hazards. Washington, DC: National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/npg/npg.html. June 06, 2004.
*NIOSH. 2005. Cyanide compounds. NIOSH pocket guide to chemical hazards. Washington, DC: National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/npg/npg.html. September 07, 2005.
Nishizawa K, Inoue O, Saito Y, . 1994. Protective effects of Kamikihi-to, a traditional Chinese medicine against cerebral ischemia, hypoxia and anoxia in mice and gerbils. Jpn J Pharmacol 64:7171–177.
*Nolte KB, Dasgupta A. 1996. Prevention of occupational cyanide exposure in autopsy prosectors. J Forensic Sci 41(1):146–147.8934715
Nonomura M. 1987. Indirect determination of cyanide compounds by ion chromatography with conductivity measurement. Anal Chem 59:2073–2076.
*Norris JC, Moore SJ, Hume AS. 1986. Synergistic lethality induced by the combination of carbon monoxide and cyanide. Toxicology 40:121–129.3726889
*NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Academy Press. National Research Council.
NRC/NAS. 1993. Telecommunication regarding compilation of current EEGLs and CEGLs. Washington, DC: National Research Council/National Academy of Sciences.
NTP. 1990. Chemical status report produced from NTP chemtrack system. National Toxicology Program, Division of Toxicology Research and Testing.
*NTP. 1993. Technical Report on toxicity studies of sodium cyanide (CAS No. 143-33-9) administered in drinking water to F344/N rats and B6C3F_l_ mice. Research Triangle Park, NC: National Toxicology Program, U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. NIH Publication 94-3386. NTP TOX 37.
*NYSDOH. 2005. The facts about cyanides. Technical information. New York State Department of Health. http://www.health.state.ny.us/nysdoh/bt/chemical_terrorism/docs/cyanide_tech.pdf. September 05, 2005.
*Obidoa O, Obasi SC. 1991. Coumarin compounds in cassava diets: 2 health implications of scopoletin in gari. Plant Foods Hum Nutr 41:283–289.1924193
*O’Brien GM, Mbome L, Taylor AJ, . 1992. Variations in cyanogen content of cassava during village processing in Cameroon. Food Chem 44(2):131–136.
*Odoul M, Fouillet B, Nouri B, . 1994. Specific determination of cyanide in blood by headspace gas chromatography. J Anal Toxicol 18(4):205–207.7967540
Odunuga OO, Adenuga GA. 1997. Sodium nitrite alone protects the brain microsomal Ca^2+^-ATPase against potassium cyanide-induced neurotoxicity in rats. Biosci Rep 17(6):543–546.9561299
Oehmichen M, Ochs U, Meissner C. 2001. Regional potassium distribution in the brain in forensic relevant types of intoxication: Preliminary morphometric evaluation using a histochemical method. Neurotoxicology 22:99–107.11307856
*O’Flaherty EJ, Thomas WC. 1982. The cardiotoxicity of hydrogen cyanide as a component of polymer pyrolysis smokes. Toxicol Appl Pharmacol 63:373–381.6285553
*Ohio River Valley Water Sanitation Commission. 1982. Assessment of the water quality conditions: Ohio River mainstem 1980-81. Cincinnati, OH: Ohio River Valley Water Sanitation Commission.
Ohno T. 1989. Spectrophotometric determination of total cyanide in surface waters following ultraviolet-induced photodecomposition. Analyst (London) 114:857–858.
*Ohya T, Kanno S. 1987. Formation of cyanogen chloride during the chlorination of water containing aromatic compounds and ammonium ion. J Pharm Sci 76(11)S128.
*Ojo O, Deane R. 2002. Effects of cassava processing methods on antinutritional components and health status of children. J Sci Food Agric 82:252–257.
*Okafor PN, Okorowkwo CO, Maduagwu EN. 2002. Occupational and dietary exposures of humans to cyanide poisoning from large-scale cassava processing and ingestion of cassava foods. Food Chem Toxicol 40(7):1001–1005.12065222
*Okoh PN. 1983. Excretion of ^14^C-labeled cyanide in rats exposed to chronic intake of potassium cyanide. Toxicol Appl Pharmacol 70:335–339.6623474
Okolie NP. 2002. Hypocholesterolemic and hypertriglycerolemic effects of chronic cyanide intoxication in rabbits. Global Journal of Pure and Applied Sciences 8(4):489–493.
*Okolie NP, Iroanya CU. 2003. Some histological and biochemical evidence for mitigation of cyanide-induced tissue lesions by antioxidant vitamin administration in rabbits. Food Chem Toxicol 41:463–469.12615119
*Okolie NP, Osagie AU. 1999. Liver and kidney lesions and associated enzyme changes induced in rabbits by chronic cyanide exposure. Food Chem Toxicol 37:745–750.10496376
*Okolie NP, Osagie AU. 2000. Differential effects of chronic cyanide intoxication on heart, lung and pancreatic tissues. Food Chem Toxicol 38:543–548.10828506
*Olea F, Parras P. 1992. Determination of serum levels of dietary thiocyanate. J Anal Toxicol 16(4):258–260.1501479
*Olea-Serano MF, Ruiz-Lopez MD, Justica-Palomares H. 1988. Determination of SCN- in vegetables by gas-chromatography in relation to endemic goiter. J Anal Toxicol 12:307–309.3244270
Oluwole OSA, Onabolu AO, Sowunmi A. 2002. Exposure to cyanide following a meal of cassava food. Toxicol Lett 135:19–23.12243860
*Onabolu AO, Oluwole OSA, Rosling H, . 2002. Processing factors affecting the level of residual cyanohydrins in gari. J Sci Food Agric 82:966–969.
*Opresko DM, Young RA, Faust RA, . 1998. Chemical warfare agents: Estimating oral reference doses. Rev Environ Contam Toxicol 156:1–183.9597943
OSHA. 1974. U.S. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910. 119, App. A.
OSHA. 1989. Air contaminants: Final rule. Occupational Safety and Health Administration. Fed Regist 54:2332–2925.
*OSHA. 1992. Air contaminants. Occupational Safety and Health Administration, Department of Labor. Fed Regist 57:2602–2660.
*OSHA. 2004a. Air contaminants. Occupational safety and health standards for shipyard employment. Washington, DC: Occupational Safety and Health Administration. Code of Federal regulations. 29 CFR 1915.1000. http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10286. June 06, 2004.
*OSHA. 2004b. Appendix A. Occupational safety and health standards. List of highly hazardous chemicals, toxics, and reactives. Washington, DC: Occupational Safety and Health Administration. Code of Federal regulations. 29 CFR 1910.119, App A. http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=9761. June 06, 2004.
*OSHA. 2004c. Appendix A. Safety and health regulations for construction: Gases, vapors, fumes, dusts, and mists. Washington, DC: Occupational Safety and Health Administration. Code of Federal regulations. 29 CFR 1926.55, App A. http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10629. June 06, 2004.
*OSHA. 2004d. Table Z-1: Limits for air contaminants. Occupational safety and health standards. Washington, DC: Occupational Safety and Health Administration. Code of Federal regulations. 29 CFR 1910.1000. http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=9992. June 06, 2004.
Osterloh JD, Hall AH. 1997. Hydroxocobalamin analysis and pharmacokinetics. J Toxicol Clin Toxicol 35:409–415.9204103
*Osuntokun BO. 1968. An ataxic neuropathy in Nigeria: A clinical, biochemical and electrophysiological study. Brain 91:215–248.5721927
*Osuntokun BO. 1972. Chronic cyanide neurotoxicity and neuropathy in Nigerians. Plant Foods Hum Nutr 2:215–266.
*Osuntokun BO. 1973. Atoxic neuropathy associated with high cassava diets in West Africa. In: Nestel B, MacIntyre R, eds. Chronic cassava toxicity: Proceedings of an interdisciplinary workshop London, England, 29-30 January 1973. Ottawa, Canada: International Development Research Centre, 127–138.
*Osuntokun BO. 1980. A degenerative neuropathy with blindness and chronic cyanide intoxication of dietary origin: The evidence in the Nigerians. In: Smith RL, Bababunmi EA, eds. Toxicology in the tropics. London: Taylor and Francis, 16–52.
*Osuntokun BO, Monekosso GL, Wilson J. 1969. Relationship of a degenerative tropical neuropathy to diet report of a field survey. Br Med J 1:547–550.5764702
*OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment. OTABA438.
*Oudjehani K, Zagury GJ, Deschênes L. 2002. Natural attenuation potential of cyanide via microbial activity in mine tailings. Appl Microbiol Biotechnol 58:409–415.11935195
Owasoyo JO, Iramain CA. 1980. Acetylcholinesterase activity in rat brain: Effect of acute cyanide intoxication. Toxicol Lett 6:1–3.7423537
*Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
*Painter RB, Howard R. 1982. The HeLa DNA-synthesis inhibition test as a rapid screen for mutagenic carcinogens. Mutat Res 92:427–437.7088012
*Palmer IS, Olson OE. 1979. Partitial prevention by cyanide of selenium poisoning in rats. Biochem Biophys Res Comm 90:1379–1386.518604
Panda M, Robinson NC. 1995. Kinetics of mechanism for the binding of HCN to cytochrome c oxidase. Biochemistry 34:10009–10018.7632673
Park Y, Devlin TM, Jones DP. 1992. Protective effect of the dimer of 16,16-diMePGB1 against KCN-induced mitochondrial failure in hepatocytes. Am J Physiol 263(2 Pt 1):C405–C411.1514587
*Paruchuri YL, Shivaraman N, Kumaran P. 1990. Microbial transformation of thiocyanate. Environ Pollut 68:15–28.15092192
*Pastorino JG, Wilhelm TJ, Glascott PA Jr., . 1995. Dexamethasone induces resistance to the lethal consequences of electron transport inhibition in cultured hepatocytes. Arch Biochem Biophys 318(1):175–181.7726559
*Patel MN, Ardelt BK, Yim GKW, . 1991. Cyanide induces Ca^2+^-dependent and independent release of glutamate from mouse brain slices. Neurosci Lett 131:42–44.1686477
*Patel MN, Yim GKW, Isom GE. 1992. Blockade of N-methyl-D-aspartate receptors prevents cyanide-induced neuronal injury in primary hippocampal cultures. Toxicol Appl Pharmacol 115:124–129.1352919
*Patel MN, Yim GK, Isom GE. 1993. N-Methyl-D-aspartate receptors mediate cyanide-induced cytotoxicity in hippocampal cultures. Neurotoxicology 14(1):35–40.8103209
Pavlakovic G, Rathinavelu A, Isom GE. 1994. MK-801 prevents cyanide-induced changes of FOS levels in rat brain. Neurochem Res 19(10):1289–1294.7891846
*Pazdernik T, Cross R, Nelson S, . 1994. Is there an energy conservation system in brain that protects against the consequences of energy depletion? Neurochem Res 19(11):1393–1400.7898608
Pazdernik TL, Nelson SR, Cross R, . 1996. Chemical-induced seizures: Free radicals as a final common pathway. 1996 Medical Defense Bioscience Review: Proceedings 12-16 May. Aberdeen Proving Ground, MD: United States Army Medical Research Institute of Chemical Defense.
Pearce LL, Bominaar EL, Hill BC, . 2003. Reversal of cyanide inhibition of cytochrome c oxidase by the auxiliary substrate nitric oxide. An endogenous antidote to cyanide poisoning? J Biol Chem 278:52139–52145.14534303
*Peden NR, Taha A, McSorley PD, . 1986. Industrial exposure to hydrogen cyanide: Implications for treatment. Br Med J 293:538.
*Persson SA, Cassel G, Sellstrom A. 1985. Acute cyanide intoxication and central transmitter systems. Fund Appl Toxicol 5:5150–5159.
Pery-Man N, Houeto P, Coirault C, . 1996. Hydroxocobalamin vs cobalt toxicity on rat cardiac and diaphragmatic muscles. Intensive Care Med 22:108–115.8857117
*Pesce LD. 1993. Cyanides. Kirk-Othmer encyclopedia of chemical technology. New York, NY: John Wiley and Sons, Inc. http://www.mrw.interscience.wiley.com/kirk/articles/cyanpesc.a01/abstract.html. June 14, 2004.
*Petrikovics I, Cannon EP, McGuinn WD. 1995. Cyanide antagonism with carrier erythrocytes and organic thiosulfonates. Fundam Appl Toxicol 24:86–93.7713346
Petrikovics I, Pei L, McGuinn WD, . 1994. Encapsulation of Rhodanese and organic thiosulfonates by mouse erythrocytes. Fundam Appl Toxicol 23:70–75.7958565
*Pettersen JC, Cohen SD. 1993. The effects of cyanide on brain mitochondrial cytochrome oxidase and respiratory activities. J Appl Toxicol 13(1):9–14.8382715
*Pettet AEJ, Mills EV. 1954. Biological treatment of cyanides with and without sewage. J Appl Chem 4:434–444.
*Pettigrew AR, Fell GS. 1972. Simplified colorimetric determination of thiocyanate in biological fluid and its application of investigation of toxic amblyopias. Clin Chem 18:996–1000.5052105
*Pettigrew AR, Fell GS. 1973. Microdiffusion method for estimation of cyanide in whole blood and its application to the study of conversion of cyanide to thiocyanate. Clin Chem 19:466–471.4703653
*Philbrick DJ, Hopkins JB, Hill DC, . 1979. Effects of prolonged cyanide and thiocyanate feeding in rats. J Toxicol Environ Health 5:579–592.490674
*Poitrast BJ, Keller WC, Elves RG. 1988. Estimation of chemical hazards in breast milk. Aviat Space Environ Med 59:A87–A92.3202809
*Porter DW, Nealley EW, Baskin SI. 1996. In vivo detoxification of cyanide by cystathionase γ-lyase. Biochem Pharmacol 52:941–944.8781514
*Potter AL. 1950. The successful treatment of two recent cases of cyanide poisoning. Br J Ind Med 7:125–130.15434249
Potter J, Smith RL, Api AM. 2001. Urinary thiocyanate levels as a biomarker for the generation of inorganic cyanide from benzyl cyanide in the rat. Food Chem Toxicol 39:141–146.11267707
*Prabhakaran K, Li L, Borowitz JL, . 2002. Cyanide induces different modes of death in cortical and mesencephalon cells. J Pharmacol Exp Ther 303:510–519.12388630
Prabhakaran K, Li L, Borowitz JL, . 2004. Caspase inhibition switches the mode of cell death induced by cyanide by enhancing reactive oxygen species generation and PARP-1 activation. Toxicol Appl Pharmacol 195:194–202.14998685
*Prahhakaran K, Li L, Mills EM, . 2005. Up-regulation of uncoupling protein 2 by cyanide is linked with cytotoxicity in mesencephalic cells. J Pharmacol Exp Ther 314(3):1338–1345.15937145
*Pre J, Vassy R. 1992. Plasma thiocyanate and cigarette-smoking status. Med Sci Res 20(18):671–672.
*Pre J, Vassy R. 1993. Cigarette smoking and serum levels of alpha-1 fetoprotein carcinoembryonic antigen cancer antigens 125 and 19-9 neurone-specific enolase. Med Sci Res 21(12):445–446.
Prickaerts J, Blokland A, Bothmer J, . 1998. Acute effects of acetyl-L-carnitine on sodium cyanide-induced behavioral and biochemical deficits. Neurochem Int 33(5):435–443.9874094
*Pritsos CA. 1996. Mitochondrial dysfunction and energy depletion from subchronic peroral exposure to cyanide using the Wistar rat as a mammalian model. Toxic Subst Mech 15(3):219–229.
*Przybylo HJ, Stevenson GW, Schanbacher P, . 1995. Sodium nitroprusside metabolism in children during hypothermic cardiopulmonary bypass. Anesth Analg 81:952–956.7486083
*Purser DA. 1984. A bioassay model for testing the incapacitating effects of exposure to combustion product atmospheres using cynomolgus monkeys. J Fire Sci 2:20–36.
*Purser DA, Grimshaw P, Berrill KR. 1984. Intoxication by cyanide in fires: A study in monkeys using polyacrylonitrile. Arch Environ Health 39:394–400.6098227
*Rachinger J, Fellner FA, Stieglbauer K. 2002. MR changes after acute cyanide intoxication. AJNR Am J Neuroradiol 23:1398–1401.12223384
*Raef SF, Characklis WG, Kessick MA, . 1977a. Fate of cyanide and related compounds in aerobic microbial systems--II. Microbial degradation. Water Res 11:485–492.
*Raef SF, Characklis WG, Kessick MA, . 1977b. Fate of cyanide and related compounds in aerobic microbial systems. I. Chemical reaction with substrate and physical removal. Water Res 11:477–483.
*Randell EW, St. Louis P. 1996. Interference in glucose and other clinical chemistry assays by thiocyanate and cyanide in a patient treated with nitroprusside. Clin Chem 42:449–453.8598112
Rauws AG, Olling M, Timmerman A. 1982. The pharmacokinetics of amygdalin. Arch of Toxicol 49:311–319.7092570
Rauws AG, Olling M, Timmerman A. 1983. The pharmacokinetics of prunasin, a metabolite of amygdalin. J Toxicol Clin Toxicol 19(8):851–856.
*Rawlings GD, Samfield M. 1979. Textile plant waste water toxicity. Environ Sci Technol 13:160–164.
*Raybuck SA. 1992. Microbes and microbial enzymes for cyanide degradation. Biodegradation 3(1):3–18.1369135
*Richards DJ, Shieh WK. 1989. Anoxic-oxic activated-sludge treatment of cyanides and phenols. Biotechnol Bioeng 33:32–38.18587841
*Rieders F. 1971. Noxious gases and vapors. I: Carbon monoxide, cyanides, methemoglobin, and sulfhemoglobin. In: DePalma JR, ed. Drill’s pharmacology in medicine. 4th ed. New York, NY: McGraw-Hill Book Company, 1180–1205.
Riordan M, Rylance G, Berry K. 2002. Poisoning in children 5: Rare and dangerous poisons. Arch Dis Child 87(5):407–410.12390912
*Riudavets MA, Aronica-Pollak P, Troncoso JC. 2005. Pseudolaminar necrosis in cyanide intoxication: A neuropathology case report. Am J Forensic Med Pathol 26(2):189–191.15894858
*Robinson CP, Baskin SI, Franz DR. 1985a. The mechanisms of action of cyanide on the rabbit aorta. J Appl Toxicol 5:372–377.4078218
*Robinson CP, Baskin SI, Visnich N Jr., . 1985b. The effects of cyanide and its interactions with norepinephrine on isolated aorta strips from the rabbit, dog, and ferret. Toxicology 35:59–72.4002238
*Rocklin RD, Johnson DL. 1983. Determination of cyanide, sulfide, iodide, and bromide by ion chromatography with electrochemical detection. Anal Chem 55:4–7.
*Rockwood GA, Armstrong KR, Baskin SI. 2003. Species comparison of methemoglobin reductase. Exper Biol and Med 228(1):79–83.
Rodriguez M, Sanders CA, Greenbaum E. 2002. Biosensors for rapid monitoring of primary-source drinking water using naturally occurring photosynthesis. Biosensors Bioelectronics 17(10):843–849.12243902
*Rohmann SO, Miller RL, Scott EA, . 1985. Tracing a river’s toxic pollution: A case study of the Hudson. In: McCook AS, ed. New York, NY: Inform, Inc., Inform report no. 154.
*Rosenberg NL, Myers JA, Martin WRW. 1989. Cyanide-induced parkinsonism clinical MRI and 6 fluorodopa Fd positron emission tomography pet studies. Neurology 39:142–144.2491915
*Rosenow F, Herholz K, Lanfermann H, . 1995. Neurological sequelae of cyanide intoxication - the patterns of clinical, magnetic resonance imaging, and positron emission tomography findings. Ann Neurol 38:825–828.7486875
*Rosentreter JJ, Skogerboe RK. 1992. A method development for the routine analytical monitoring of aqueous cyanide species. Water Sci Technol 26(1–2):255–262.
*Rosling H. 1988. Cassava toxicity and food security. A report for UNICEF African household food security programme. 2nd ed. Uppsala, Sweden: Tryck kontakt, 1–40.
Roy P, Kulkarni AP. 1999. Co-oxidation of acrylonitrile by soybean lipoxygenase and partially purified human lung lipoxygenase. Xenobiotica 29(5):511–531.10379988
*Rubio R, Sanz J, Rauret G. 1987. Determination of cyanide using a microdiffusion technique and potentiometric measurement. Analyst 112:1705–1708.3445939
*Rutkowski JV, Roebuck BD, Smith RP. 1985. Effects of protein-free diet and food deprivation on hepatic rhodanese activity, serum proteins and acute cyanide lethality in mice. J Nutr 115:132–137.3855311
Sadun AA. 2002. Mitochondrial optic neuropathies. J Neurol Neurosurg Psychiatry 72:424–426.
*Saincher A, Swirsky N, Tenenbein M. 1994. Cyanide overdose: Survival with fatal blood concentration without antidotal therapy. J Emerg Med 12(4):555–557.7963405
*Saito S, Tsukamoto S, Kanegae T, . 2000. Influence of L-cysteine and hydroxocobalamin on cyanide distribution in rats. Nihon Univ J Med 42(4):215–228.
*Sakaida I, Thomas AP, Farber JL. 1992. Phospholipid metabolism and intracellular Ca^2+^ homeostasis in cultured rat hepatocytes intoxicated with cyanide. Am J Physiol 263(3 Pt 1):C684–C690.1415517
Salkowski AA, Penney DG. 1995. Metabolic, cardiovascular, and neurologic aspects of acute cyanide poisoning in the rat. Toxicol Lett 75:19–27.7863526
*Sandberg CG. 1967. A case of chronic poisoning with potassium cyanide? Acta Med Scand 181:233–236.6017819
Sandhu JK, Birnboim HC. 1997. Mutagenicity and cytotoxicity of reactive oxygen and nitrogen species in the MN-11 murine tumor cell line. Mutat Res 379:241–252.9357553
*Sano A, Takezawa M, Takitani S. 1989. Spectrofluorometric determination of cyanide in blood and urine with naphthalene-2,3-dialdehyde and taurine. Anal Chim Acta 225:351–358.
*Sano A, Takimoto N, Takitani S. 1992. High-performance liquid chromatographic determination of cyanide in human red blood cells by pre-column fluorescence derivitization. J Chromatogr 582:131–135.1491032
Sauer SW, Keim ME. 2001. Hydroxocobalamin: Improved public health readiness for cyanide disasters. Ann Emerg Med 37:635–641.11385334
Sax NI, ed. 1984. Dangerous properties of industrial materials. 6th ed. New York, NY: Van Nostrand Reinhold Co., 825.
*Sax NI, Lewis RD, eds. 1987. Hawley’s condensed chemical dictionary. 11th ed. New York, NY: Van Nostrand Reinhold Company, 203, 954, 1057.
*Scharf BA, Fricke RF, Baskin SI. 1992. Comparison of methemoglobin formers in protection against the toxic effects of cyanide. Gen Pharmacol 23(1):19–25.1592224
Scheers EM, Ekwall B, Dierickx PJ. 2001. In vitro long-term cytotoxicity testing of 27 MEIC chemicals on Hep G2 cells and comparison with acute human toxicity data. Toxicol in Vitro 15:153–161.11287174
*Schneider JF, Westley J. 1969. Metabolic interrelations of sulfur in proteins, thiosulfate, and cystine. J Biol Chem 244:5735–5744.5348607
*Schubert J, Brill WA. 1968. Antagonism of experimental cyanide toxicity in relation to the in vivo activity of cytochrome oxidase. J Pharmacol Exp Ther 162:352–359.4299107
*Schwartz C, Morgan RL, Way LM, . 1979. Antagonism of cyanide intoxication with sodium pyruvate. Toxicol Appl Pharmacol 50:437–441.516056
*Scott JS. 1985. An overview of cyanide treatment methods for gold mill effluents. In: Van Zyl D ed. Cyanide and Environment: Proceedings of a conference Tucson, Arizona December 11-14, 1984: Volume 1. Fort Collins, CO: Colorado State University, 307–330.
*Scrivner NC, Bennett KE, Pease RA, . 1986. Chemical fate of injected wastes. Ground Water Monit Rev 6:53–58.
*Seigler DS. 1991. Cyanide and cyanogenic glycosides. In: Rosenthal GA, Berenbaum MR, eds. Herbivores: Their interaction with secondary plant metabolites. New York, NY: Academic Press, 35–77.
Seigneur C, Constantinou E, Levin L. 1996. Multipathway health risk assessment of power plant water discharges. Water Air Soil Pollut 90:55–64.
Seltzer MD. 1998. Continuous air monitoring using inductively coupled plasma atomic emission spectrometry: Correction of spectral interferences arising from CN emission. Appl Spectrosc 52(2):195–199.
Senda T, Matsuno K, Mita S. 2000. The suppression of potassium cyanide-induced mortality by the increase of extracellular acetylcholine level in the brain. Can J Physiol Pharmacol 78:645–648.10958165
*Setchell BP, Waites GMH. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society.
Seto Y. 1995. Oxidative conversion of thiocyanate to cyanide by oxyhemoglobin during acid denaturation. Arch Biochem Biophys 321:245–254 7639528
Seto Y. 1996. Stability and spontaneous production of blood cyanide during heating. J Forensic Sci 41(3):465–468.8656188
*Seto Y, Tsunoda N, Ohta H, . 1993. Determination of blood cyanide by headspace gas chromatography with nitrogen phosphorus detection and using a megabore capillary column. Anal Chim Acta 276:247–259.
Sexton K, Adgate JL, Ramachandran G, . 2004. Comparison of personal, indoor, and outdoor exposures to hazardous air pollutants in three urban communities. Environ Sci Technol 38:423–430.14750716
Shan D, Mousty C, Cosnier S. 2004. Subnanomolar cyanide detection at polyphenol oxidase/clay biosensors. Anal Chem 76:178–183 14697048
*Sheehy M, Way JL. 1968. Effect of oxygen on cyanide intoxication. III. Mithridate. J Pharmacol Exp Ther 161:163–168.5648494
*Shifrin NS, Beck BD, Gauthier TD, . 1996. Chemistry, toxicology, and human health risk of cyanide compounds in soils at former manufactured gas plant sites. Regul Toxicol Pharmacol 23:106–116.8661329
*Shine NB. 1971. Fluohmic process for hydrogen cyanide. Chem Eng Prog 67(2):52–57.
*Shivaraman N, Kumaran P, Pandey RA, . 1985. Microbial degradation of thiocyanate, phenol and cyanide in a completely mixed aeration system. Environ Pollut Ser A 39:141–150.
Shou Y, Gunasekar PG, Borowitz JL, . 2000. Cyanide-induced apoptosis involves oxidative-stress-activated NF-kB in corticol neurons. Toxicol Appl Pharmacol 164:196–205.10764633
*Shou Y, Li N, Borowitz JL, . 2002. NF-κB-mediated up-regulation of Bcl-X_S_ and Bax contributes to cytochrome c release in cyanide-induced apoptosis. J Neurochem 81(4):842–852.12065643
*Shou Y, Li L, Prabhakaran K, . 2003. p38 Mitogen-activated protein kinase regulates Bax translocation in cyanide-induced apoptosis. Toxicol Sci 75(1):99–107.12805646
*Shou Y, Li L, Prabhakaran K, . 2004. Calcineurin-medicated Bad translocation regulates cyanide-induced neuronal apoptosis. Biochem J 379(Pt 3):805–813.14741051
Shvets-Teneta-Gurii TB, Dubinin AG, Alexandrov VI, . 1998. Fast glycolytic oscillations induced by potassium cyanide in the brain of behaving rats (potentiometric recording). Bioelectrochem Bioenerg 47:143–149.
*Silva-Avalos J, Richmond MG, Nagappan O, . 1990. Degradation of the metal-cyano complex tetracyanonickelate (II) by cyanide-utilizing bacterial isolates. Microbiol 56:3664–3670.
*Sine C, ed. 2004. Crop protection handbook 2004. Willoughby, OH: Meister Media Worldwide, C272.
*Singh JD. 1981. The teratogenic effects of dietary cassava on the pregnant albino rat: A preliminary report. Teratology 24:289–291.7330778
*Singh BM, Coles N, Lewis P, . 1989. The metabolic effects of fatal cyanide poisoning. Postgrad Med J 65:923–925.2616434
*Sipe EK, Trienski TL, Porter JM. 2001. Cyanide toxicity in the surgical intensive care unit: A case report. Am Surg 67:684–686.11450789
*Sittig, M, ed. 1980. Pesticide manufacturing and toxic materials control encyclopedia. Park Ridge, NJ: Noyes Data Corporation, 452.
Sittig, M. 1994. World-wide limits for toxic and hazardous chemicals in air, water and soil. Park Ridge, NJ: Noyes Publications. 43, 151, 225–229, 426–427, 629–630, 671–672.
Skelton LA, Ormerod MG, Titley J, . 1999. A novel class of lipophilic quinazoline-based folic acid analogues: Cytotoxic agents with a folate-independent locus. Br J Cancer 79:1692–1701.10206279
*Sklarew DS, Hayes DJ. 1984. Trace nitrogen-containing species in the offgas from 2 oil shale retorting processes. Environ Sci Technol 18:600–603.22300057
*Smith RP. 1996. Toxic responses of the blood. In: Wonsiezwicz MJ, Sheinis LA, eds. Casarett & Doull’s toxicology: The basic science of poisons. 5th ed. New York, NY: McGraw-Hill, 335–354.
*Smith RM, Martell AE. 1976. Critical stability constants: Volume 4: Inorganic complexes. New York, NY: Plenum Press, 26–27.
Smith ADM, Duckett S, Waters AH. 1963. Neuropathological changes in chronic cyanide intoxication. Nature 200:179–181.14073042
*Smyth HF, Carpenter CP, Weil CS, . 1969. Range-finding toxicity data: List VII. Am Ind Hyg Assoc J 30:470–476.5823428
*Snodgrass WR. 1996. Clinical toxicology. In: Wonsiezwicz MJ, Sheinis LA, eds. Casarett & Doull’s toxicology: The basic science of poisons. 5th ed. New York, NY: McGraw-Hill, 969–986.
Snyder JW, Pastorino JG, Thomas AP, . 1993. ATP synthase activity is required for fructose to protect cultured hepatocytes from the toxicity of cyanide. Am J Physiol Cell Physiol 264(3):C709–C714.
Sono M, Ledbetter AP, McMillan K, . 1999. Essential thiol requirement to restore pterin- or substrate-binding capability and to regenerate native enzyme-type high-spin heme spectra in the Escherichia coli-expressed tetrahydrobiopterin-free oxygenase domain of neuronal nitric oxide synthase. Biochemistry 38:15853–15862.10625450
*Soto-Blanco B, Gorniak SL. 2003. Milk transfer of cyanide and thiocyanate: Cyanide exposure by lactation in goats. Vet Res 34:213–220.12657213
*Soto-Blanco B, Gorniak SL, Kimura ET. 2001a. Physiopathological effects of the administration of chronic cyanide to growing goats - a model for ingestion of cyanogenic plants. Vet Res Commun 25:379–389.11469509
*Soto-Blanco B, Marioka PC, Górniak SL. 2002a. Effects of long term low-dose cyanide administration to rats. Ecotoxicol Environ Saf 53(1):37–41.12481854
*Soto-Blanco B, Maiorka PC, Górniak SL. 2002b. Neuorpathologic study of long term cyanide administration to goats. Food Chem Toxicol 40:1693–1698.12176095
Soto-Blanco B, Sousa AB, Manzano H, . 2001b. Controversies in toxicology: Does prolonged cyanide exposure have a diabetogenic effect? Vet Hum Toxicol 43(2):106–108.11308117
*Sousa AB, Manzano H, Soto-Blanco B, . 2003. Toxicokinetics of cyanide in rats, pigs and goats after oral dosing with potassium cyanide. Arch Toxicol 77:330–334.12799772
*Sousa AB, Soto-Blanco B, Guerra JL, . 2002. Does prolonged oral exposure to cyanide promote hepatotoxicity and nephrotoxicity? Toxicology 174:87–95.11985886
SRI. 1990. 1990 Directory of chemical producers. Menlo Park, CA: SRI International, 547, 924, 958.
SRI. 1994. 1994 Directory of chemical producers. Menlo Park, CA: SRI International, 463, 534, 684, 871, 873, 901.
*SRI. 1995. 1995 Directory of chemical producers. Menlo Park, CA: SRI International.
SRI. 2003. 2003 Directory of chemical producers. Menlo Park, CA: SRI International.
SRI. 2004. 2004 Directory of chemical producers. Menlo Park, CA: SRI Consulting, 862.
*SRI. 2005. 2005 Directory of chemical producers. Menlo Park, CA: SRI International.
*Stadelmann W. 1976. Content of hydrocyanic acid in stone fruit juices. Fluess Obst 43:45–47.
*Stafford DA, Callely AG. 1969. The utilization of thiocyanate by a heterotrophic bacterium. J Gen Microbiol 55:285–289.5764739
*Stannard JN, Horecker BL. 1948. The in vitro inhibition of cytochrome oxidase by azide and cyanide. J Biol Chem 172:599–608.18901179
*Storer RD, McKelvey TW, Kraynak AR, . 1996. Revalidation of the in vitro alkaline elution/rat hepatocyte assay for DNA damage: Improved criteria for assessment of cytotoxicity and genotoxicity and results for 81 compounds. Mutat Res 368:59–101.8684406
Streicher E. 1951. Toxicity of colchicine, di-isopropyl fluorophosphate, intocostrin, and potassium cyanide in mice at 4 degrees C. Proc Soc Exp Biol Med 76:536–538.14844264
Strugala GJ, Elbers R. 1984. Metabolism of amygdalin and prunasin in the isolated perfused rat liver. Naunyn-Schmiedeberg’s Arch Pharmacol. 325(Suppl.):R23.
*Sturm CD, Frisella WA, Yoon KW. 1993. Attenuation of potassium cyanide-mediated neuronal cell death by adenosine. J Neurosurg 79(1):111–115.8315447
*Stutz DR, Janusz SJ. 1988. Hazardous materials injuries: A handbook for pre-hospital care. 2nd ed. Beltsville, MD: Bradford Communications Corporation.
*Suchard JR, Wallace KL, Gerkin RD. 1998. Acute cyanide toxicity caused by apricot kernal ingestion. Ann Emerg Med 32(6):742–744.9832674
Sun P, Borowitz JL, Kanthasamy AG, . 1995. Antagonism of cyanide toxicity by isosorbide dinitrate: Possible role of nitric oxide. Toxicology 104:105–111.8560488
*Swain E, LI CP, Poulton JE. 1992. Development of the potential for cyanogenesis in maturing black cherry (Prunus serotina Ehrh.) fruits. Plant Physiol 98(4):1423–1428.16668810
*Sylvester DM, Hayton WL, Morgan RL, . 1983. Effects of thiosulfate on cyanide pharmacokinetics in dogs. Toxicol Appl Pharmacol 69:265–271.6868088
*Sylvester DM, Holmes RK, Sander C, . 1982. Interference of thiosulfate with potentiometric analysis of cyanide in blood and its elimination. Toxicol Appl Pharmacol 65:116–121.7147246
*Symington IS, Anderson RA, Oliver JS, . 1987. Cyanide exposure in fires. Lancet 2:91–92.
*Tadic V. 1992. The in vivo effects of cyanide and its antidotes on rat brain cytochrome oxidase activity. Toxicology 76(1):9–67.
ten Berge WF, Zwart A, Appelman LM. 1986. Concentration-time mortality response relationship of irritant and systemically acting vapours and gases. J Hazard Mater 13:301–309.
*Ternay AL Jr, Brzezinska E, Sorokin V, . 2000. Organosulfur compounds as pre-exposure therapy for threat agents. J Appl Toxicol 20(Suppl 1):S31–S34.11428640
*Tewe OO, Maner JH. 1980. Cyanide, protein and iodine interactions in the performance, metabolism and pathology of pigs. Res Vet Sci 29:271–276.7255888
*Tewe OO, Maner JH. 1981a. Long-term and carry-over effect of dietary inorganic cyanide (KCN) in the life cycle performance and metabolism of rats. Toxicol Appl Pharmacol 58:1–7.7233430
*Tewe OO, Maner JH. 1981b. Performance and pathophysiological changes in pregnant pigs fed cassava diets containing different levels of cyanide. Res Vet Sci 30:147–151.7255905
*Tewe OO, Maner JH. 1982. Cyanide, protein and iodine interactions in the performance and metabolism of rats. J Environ Pathol Toxicol Oncol 6:69–77.
Thier R, Lewalter J, Bolt HM. 2000. Species differences in acrylonitrile metabolism and toxicity between experimental animals and humans based on observations in human accidental poisonings. Arch Toxicol 74:184–189.10959790
Thilly CH, Swennen B, Bourdoux P, . 1993. The epidemiology of iodine-deficiency disorders in relation to goitrogenic factors and thyroid-stimulating-hormone regulation. Am J Clin Nutr 57(2 Suppl):267S–270S.8427202
Thomas RG. 1982. Volatilization from water. In: Lyman WJ, Reehl, WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods: Environmental behavior of organic compounds. New York, NY: McGraw-Hill Book Co., 15–16.
*Thomas AO, Lester JN. 1993. The microbial remediation of former gasworks sites. A review. Environ Technol 14(1):1–24.
*Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
*Thomas TA, Brooks JW. 1970. Accidental cyanide poisoning. Anaesthesia 25:110–114.4983953
*Thompson RW, Valentine HL, Valentine WM. 2003. Cytotoxic mechanisms of hydrosulfide anion and cyanide anion in primary rat hepatocyte cultures. Toxicology 188:149–159.12767687
Tiwary RK. 2001. Environmental impact of coal mining on water regime and its management. Water Air Soil Pollut 132(1–2):185–199.
Toida T, Togawa T, Tanabe S, . 1984. Determination of cyanide and thiocyanate in blood plasma and red cells by high-performance liquid chromatography with fluorometric detection. J Chromatogr 308:133–141.6746810
*Tominaga MY, Midio AF. 1991. Modified method for the determination of thiocyanate in urine by ion-exchange chromatography and spectrophotometry. Rev Farm Bioquim Univ Sao Paulo 27(1):100–105.
Tomoda A, Hashimoto K. 1991. The determination of cyanide in water and biological tissues by methemoglobin. J Hazard Mater 28:241–249.
*Tomoda A, Nagai K, Hashimoto K. 1992. A simple and convenient method for the determination of cyanide in bloods and water by methemoglobin. Int Congr Ser - Excerpta Med 991:789–791.
Tor-Agbidye J, Palmer VS, Lasarev MR, . 1999. Bioactivation of cyanide to cyanate in sulfur amino acid deficiency: Relevance to neurological disease in humans subsisting on cassava. Toxicol Sci 50(2):228–235.10478859
Tor-Agbidye J, Palmer VS, Sabri M, . 1998. Dietary deficiency of cystine and methionine in rats alters thiol homeostasis required for cyanide detoxification. J Toxicol Environ Health A 55:583–595.9885999
*Tracqui A, Raul JS, Geraut A, . 2002. Determination of blood cyanide by HPLC-MS. J Anal Toxicol 26(3):144–148.11991530
*Trapp WG. 1970. Massive cyanide poisoning with recovery: A boxing-day story. Can Med Assoc J 102:517.5438769
Trenholm A. 1998. Identification of PICs in hazardous waste combustion emissions. Waste Manage 18:485–492.
*TRI88. 1990. Toxic Chemical Release Inventory 1988. Bethesda, MD: National Library of Medicine, National Toxicology Information Program.
*TRI03. 2005. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access, Offices of Environmental Information, U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. September 14, 2005.
Troup CM, Ballantyne B. 1987. Analysis of cyanide in biological fluids and tissues. In: Ballantyne B, Marrs TC, eds. Clinical and experimental toxicology of cyanides. Bristol, UK: IOP Publishing Limited, 22–40.
*Tsuge K, Kataoka M, Seto Y. 2000. Cyanide and thiocyanate levels in blood and saliva of health adult volunteers. J Health Sci 46(5):343–350.
Tsuge K, Kataoka M, Seto Y. 2001. Rapid determination of cyanide and azide in beverages by microdiffusion spectrophotometric method. J Anal Toxicol 25(4):228–236.11386635
*Tucker SP, Carson GA. 1985. Deactivation of hazardous chemical wastes. Environ Sci Technol 19:215–220.22296006
Tung A, Lynch J, McDade WA. 1997. A new biological assay for measuring cyanide in blood. Anesth Analg 85:1045–1051.9356097
Twerdok LE, Burton DT, Gardner HS, . 1997. The use of nontraditional assays in an integrated environmental assessment of contaminated ground water. Environ Toxicol Chem 16(9):1816–1820.
*Tylleskar T, Banea M, Bikangi N, . 1992. Cassava cyanogens and konzo, an upper motoneuron disease found in Africa [erratum in Lancet 1992 Feb 15;339(8790):440]. Lancet 339(8787):208–211.1346173
*Tylleskar T, Legue FD, Peterson S, . 1994. Konzo in the Central African Republic. Neurology 44(5):959–61.8190305
*Uitti RJ, Rajput AH, Ashenhurst EM, . 1985. Cyanide-induced parkinsonism: A clinicopathologic report. Neurology 35:921–925.4000494
*Ukhun ME, Dibie EN. 1989. Cyanide content of cassava mash and gari flour and influence of water activity (a_w_) during storage. Bull Environ Contam Toxicol 42:548–552.2713530
UN. 1985. Treatment and disposal methods for waste chemicals. International Register of Potentially Toxic Chemicals. Geneva, Switzerland: United Nations Environment Programme, 118–122.
*USAMRICD. 1994. A comparison of the treatment of cyanide poisoning in the Cynomolgus monkey with sodium nitrite or 4-dimethylaminophenol (4-DMAP), with and without sodium thiosulfate. Aberdeen Proving Ground, MD: U.S. Army Medical Research Institute of Chemical Defense. USAMRICDTR9401. ADA284920.
*U.S. Army. 1989. Review of reactions of chemical agents in water. Final report. Fort Detrick, MD: U.S. Army Medical Research and Development Command. ADA213287, 51–52.
*USDOC. 2003. U.S. Trade quick-reference tables: December 2003. Office of Trade and Economic Analysis, International Trade Administration. U.S. Department of Commerce. http://www.ita.doc.gov/td/industry/otea/Trade-Detail/Latest-December. June 2004.
*USDOC. 2004. U.S. imports for consumption: 2004 and 2004 year-to-date. Office of Trade and Economic Analysis, International Trade Administration. U.S. Department of Commerce. http://www.ita.doc.gov/td/industry/otea/Trade-Detail/. September 5, 2005.
*USGS. 1985. Cyanide, colorimetric, barbituric acid, automated-segmented flow. Denver, CO: U.S. Geological Survey. http://reports.er.usgs.gov/reports. June 16, 2004.
*Valade MP. 1952. [Central nervous system lesions in chronic experimental poisoning with gaseous hydrocyanic acid]. Bull Acad Natl Med (Paris) 136:280–285. (French)
*Valenzuela R, Court J, Godoy J. 1992. Delayed cyanide induced dystonia. J Neurol Neurosurg Psychiatry 55(3):198–199.1564480
*Van Buuren JH, Zuurendonk PF, Van Gelder BF, . 1972. Biochemical and biophysical studies on Cytochrome aa_3_ V. binding of cyanide to cytochrome aa_3_. Biochim Biophys Acta 256 (2):243–257.4335836
*VanderLaan WP, Bissell A. 1946. Effects of propylthiouracil and of potassium thiocyanate on the uptake of iodine by the thyroid gland of the rat. Endocrinology 39:157–160.20996892
*van Heijst AN, Maes RA, Mtanda AT, . 1994. Chronic cyanide poisoning in relation to blindness and tropical neuropathy. Clin Toxicol 32(5):549–556.
*Van Middlesworth L. 1986. Potential metabolic significance of blood thiocyanate. Endocrinol Exp 20:17–22.3486109
*Venkataramani ES, Ahlert RC, Corbo P. 1984. Biological treatment of landfill leachates. CRC Crit Rev Environ Control 14:333–376.
Vesey CJ. 1987. Nitroprusside cyanogenesis. In: Ballantyne B, Marrs TC, eds. Clinical and experimental toxicology of cyanides. Bristol, UK: IOP Publishing Limited, 184–208.
*Vesey CJ, Cole PV, Simpson PJ. 1976. Cyanide and thiocyanate concentrations following sodium nitroprusside infusion in man. Br J Anaesth 48(7):651–660.797397
Vick JA, Froehlich HL. 1985. Studies of cyanide poisoning. Arch Int Pharmacodyn 273:314–322.2860882
*Vick JA, Von Bredow JD. 1996. Effectiveness of intramuscularly administered cyanide antidotes on methemoglobin formation and survival. J Appl Toxicol 16(6):509–516.8956097
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
*Vock EH, Lutz WK, Hormes P, . 1998. Discrimination between genotoxicity and cytotoxicity in the induction of DNA double-strand breaks in cells treated with etoposide, melphalan, cisplatin, potassium cyanide, Triton X-100, and gamma-irradiation. Mutat Res 413:83–94.9602861
*Vogel SN, Sultan TR, Ten Eyck RP. 1981. Cyanide poisoning. Clin Toxicol 18:367–383.7016420
*Voldrich M, Kyzlink V. 1992. Cyanogenesis in canned stone fruits. J Food Sci 57(1):161–162, 189.
*Waage H, Silsand T, Urdal P, . 1992. Discrimination of smoking status by thiocyanate and cotinine in serum, and carbon monoxide in expired air. Int J Epidemiol 21(3):488–493.1634310
*Walton DC, Witherspoon MG. 1926. Skin absorption of certain gases. J Pharmacol Exp Ther 26:315–324.
*Watanabe-Suzuki K, Ishii A, Suzuki O. 2002. Cryogenic oven-trapping gas chromatography for analysis of volatile organic compounds in body fluids. Anal Bioanal Chem 373:75–80.12012175
*Way JL. 1984. Cyanide intoxication and its mechanism of antagonism. Ann Rev Pharmacol Toxicol 24:451–481.6428300
*Way JL, Burrows G. 1976. Cyanide intoxication: Protection with chlorpromazine. Toxicol Appl Pharmacol 36:93–97.1273841
*Way JL, End E, Sheehy MH, . 1972. Effect of oxygen on cyanide intoxication IV. Hyperbaric oxygen. Toxicol App Pharmacol 22:415–421.
*Way JL, Gibbon SL, Sheehy M. 1966. Cyanide intoxication: Protection with oxygen. Science 152:210–211.12325348
Weast RC, ed. 1985. CRC handbook of chemistry and physics. 66^th^ ed. Boca Raton, FL: CRC Press, Inc., B-82, B-93, B-95, B-100, B-127, B-142.
*Weil ED, Sandler SR. 1997. Sulfur compounds. Kirk-Othmer encyclopedia of chemical technology. http://www.mrw.interscience.wiley.com/kirk/articles/sulfweil.a01/sect1_11-fs.html. June 15, 2004.
*Weinberg HS, Cook SJ. 2002. Segmented flow injection, UV digestion, and amperometric detection for the determination of total cyanide in wastewater treatment plant effluents. Anal Chem 74:6055–6063.12498202
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
Westley AM, Westley J. 1989. Voltammetric determination of cyanide and thiocyanate in small biological samples. Anal Biochem 181:190–194.2817378
*Weuffen W, Franzke C, Thurkow B. 1984. Forschrittsbericht: Zur alimentären aufnahme, analytic und biologischen bedeutung des thiocyanats. Die Nahrung 28:341–355.6382017
*Wexler J, Whittenberger JL, Dumke PR. 1947. The effect of cyanide on the electrocardiogram of man. Am Heart J 34:163–173.20255260
*White JM, Jones DD, Huang D, . 1988. Conversion of cyanide to formate and ammonia by a pseudomonad obtained from industrial wastewater. J Indust Microbiol 3:263–272.
WHO. 1984. Guidelines for drinking-water quality. Geneva, Switzerland: World Health Organization.
*WHO. 1992. Technical Report Series 828. Evaluation of certain food additives and naturally occurring toxicants. Thirty-ninth report of the Joint FAO/WHO Expert Committee on food additives. Geneva, Switzerland: World Health Organization.
*WHO. 1996. Cyanide. Guidelines for drinking-water quality. Volume 2. Health criteria and other supporting information. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/dwq/en/2edvol2p2b.pdf. June 06, 2004.
*WHO. 2000. Air quality guidelines. 2nd ed. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/Document/AIQ/AirQualRepMtg.pdf. February 15, 2005.
*WHO. 2004a. Guidelines for drinking-water quality. 3rd ed. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/index.html. August 31, 2005.
*WHO. 2004b. Hydrogen cyanide and cyanides: Human health aspects. Geneva, Switzerland: World Heath Organization, 1–67.
*Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York, NY: Academic Press.
*Wiegand GH, Tremelling M. 1972. The kinetics and mechanism of the decomposition of potassium cyanide in aqueous alkaline medium. Hydrolysis of the simplest nitrile. J Org Chem 37(6):914–916.
Willhite CC. 1981. Malformations induced by inhalation of acetonitrile vapors in the Golden hamster [Abstract]. Teratology 23:69A.
*Willhite CC. 1982. Congenital malformations induced by laetrile. Science 215:1513–1515.7063858
*Willhite CC, Smith RP. 1981. The role of cyanide liberation in the acute toxicity of aliphatic nitriles. Toxicol Appl Pharmacol 59:589–602.6267734
*Wilson J. 1965. Leber’s hereditary optic atrophy: A possible defect of cyanide metabolism. Clin Sci 29:505–515.5848703
*Wilson J. 1983. Cyanide in human disease: A review of clinical and laboratory evidence. Fundam Appl Toxicol 3:397–399.6357925
*Wilson MT, Antonini G, Malatesta F, . 1994. Probing the oxygen binding site of cytochrome c oxidase by cyanide. J Biol Chem 269(39):24114–24119.7929065
*Windholz M, ed. 1983. The Merck index. 10th ed. Rahway, NJ: Merck and Co. Inc., 229, 385, 696, 1100, 1104, 1233.
Wing DA, Patel HC, Baskin SI. 1992. The effect of picrylsulphonic acid on in vitro conversion of cyanide to thiocyanate by 3-mercaptopyruvate sulphurtransferase and rhodanese. Toxicol In Vitro 6(6):597–603.20732163
Wolterink AFWM, Jonker AB, Kengen SWM, . 2002. Pseudomonas chloritidismutans sp. nov., a non-denitrifying, chlorate-reducing bacterium. Int J Syst Evol Microbiol 52:2183–2190.12508887
*Wood JL, Cooley SL. 1956. Detoxication of cyanide by cystine. J Biol Chem 218:449–457.13278352
*Worthing CR, ed. 1987. The pesticide manual. 8th ed. Thornton Heath, UK: British Crop Protection Council, 467.
Wurzburg H. 1996. Treatment of cyanide poisoning in an industrial setting. Vet Hum Toxicol 38(1):44–47.8825751
Xia Z, Jin S, Zhou Y, . 1999. Analysis of 541 cases of occupational acute chemical injuries in a large petrochemical company in china. Int J Occup Environ Health 5(4):262–266.10633242
*Xie Y, Reckhow DA. 1993. A rapid and simple analytical method for cyanogen chloride and cyanogen bromide in drinking water. Water Res 27(3):507–511.
*Xu J, Xin M, Takeuchi T, . 1993. Determination of oxidizable inorganic anions by reversed-phase ion-pair chromatography with amperometric detection. Anal Chim Acta 276(2):261–264.
*Yamamoto H. 1989. Hyperammonemia, increased brain neutral and aromatic amino acid levels, and encephalopathy induced by cyanide in mice. Toxicol Appl Pharmacol 99:415–420.2749730
*Yamamoto H. 1995a. A hypothesis for cyanide-induced tonic seizures with supporting evidence. Toxicology 95:19–26.7825186
Yamamoto H. 1995b. Effect of atropine on cyanide-induced acute lethality in mice. Toxicol Lett 80:29–33.7482588
*Yamamoto H, Mohanan PV. 2002. Melatonin attenuates brain mitochondria DNA damage induced by potassium cyanide in vivo and in vitro. Toxicology 179:29–36.12204540
*Yamamoto H, Tang H. 1996a. Effect of carbetapentane or melatonin on cyanide-induced neurotoxicity in mice. J Hyg Chem 42(6):487–491.
*Yamamoto H, Tang H. 1996b. Preventive effect of melatonin against cyanide-induced seizures and lipid peroxidation in mice. Neurosci Lett 207:89–92.8731428
*Yamamoto H, Tang H. 1996c. Antagonistic effect of melatonin against cyanide-induced seizures and acute lethality in mice. Toxicol Lett 87:19–24.8701440
*Yamamoto H, Tang H. 1998. Effects of 2-amino-7-phosphonoheptanoic acid, melatonin or N^G^-nitro-L-arginine on cyanide or N-methyl-D-aspartate-induced neurotoxicity in rat cortical cells. Toxicol Lett 94:13–18.9544694
*Yamamoto K, Yamamoto Y, Hattori H, . 1982. Effects of routes of administration on the cyanide concentration distribution in the various organs of cyanide-intoxicated rats. Tohoku J Exp Med 137:73–78.7101288
*Yamanaka S, Takaku S, Takaesu Y, . 1991. Validity of salivary thiocyanate as an indicator of cyanide exposure from smoking. Bull Tokyo Dental Coll 32(4):157–163.
*Yang X, Shang C. 2005. Quantification of aqueous cyanogen chloride and cyanogen bromide in environmental samples by MIMS. Water Res 39(9):1709–1718.15899269
Yang A, Cardona DL, Barile FA. 2002. Subacute cytotoxicity testing with cultured human lung cells. Toxicol in Vitro 16:33–39.11812637
*Yen D, Tsai J, Wang LM, . 1995. The clinical experience of acute cyanide poisoning. Am J Emerg Med 13(5):524–528.7662055
Yeoh MJ, Braitberg G. 2002. Carbon monoxide, ethanol and cyanide poisoning in smoke inhalation fatalities. J Toxicol Clin Toxicol 40:659–660.
Yi Y, Theis TL, Young TC. 2002. The effect of chlorination on organocyanide compounds. Water Environ Res 74(1):51–56.11995867
*Yoo KP, Lee SY, Lee WH. 1986. Ionization and Henry’s law constants for volatile, weak electrolyte water pollutants. Korean J Chem Eng 3:67–72.
*Youatt JB. 1954. Studies on the metabolism of Thiobacillus thiocyanoxidans. J Gen Microbiol 11:139–149.13211968
*Young DR. 1978. Priority pollutants in municipal wastewaters. In: Annual Report South California Coastal Water Research Project. LA Jolla, CA: University of California, 103–112.
Yu X, Trapp S, Zhou P, . 2004. Metabolism of cyanide by Chinese vegetation. Chemosphere 56:121–126.15120557
*Zagury GJ, Oudjehani K, Deschenes L. 2004. Characterization and availability of cyanide in solid mine tailings from gold extraction plants. Sci Total Environ 320:211–224.15016508
*Zaknun JJ, Stieglbauer K, Trenkler J, . 2005. Cyanide-induced akinetic rigid syndrome: Clinical, MRI, FDG-PET, β-CIT and HMPAO SPECT findings. Parkinsonism Relat Disord 11(25):125–129.15734673
*Zhang C, Zheng H, Ouyang J, . 2005. Cyanide distribution in human tissue, determined by GC/ECD/HS. Anal Lett 38:247–256.
Zhang J, Tan Z, Tran ND. 2000. Chemical hypoxia-ischemia induces apoptosis in cerebromicrovascular endothelial cells. Brain Res 877:134–140.10986325
Zhang JG, Tirmenstein MA, Nicholls-Grzemski FA, . 2001. Mitochondrial electron transport inhibitors cause lipid peroxidation-dependent and -independent cell death: Protective role of antioxidants. Arch Biochem Biophys 393:87–96.11516165
Zhu Z, Fang Z. 1987. Spectrophotometric determination of total cyanide in waste waters in a flow-injection system with gas-diffusion separation and pre-concentration. Anal Chim Acta 198:25–36.
*Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372