# 8 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding cyanide in air, water, and other media are summarized in Table 8-1.

ATSDR has derived an intermediate oral MRL of 0.05 mg/kg/day for cyanide based on a NOAEL of 4.5 mg/kg/day and a LOAEL of 12.5 mg/kg/day from a study in which 10 male and 10 female rats were given 0.2–12.5 mg/kg/day cyanide, as sodium cyanide, in the drinking water for 13 weeks (NTP 1993).

EPA reference doses (RfDs) have been established for chronic oral exposure to cyanide and its compounds. These RfDs range from 2x10^−1^ mg/kg/day for potassium silver cyanide to 5x10^−3^ mg/kg/day for copper cyanide. The RfD for potassium silver cyanide was based on weight loss and thyroid effects in several rat studies (Howard and Hanzel 1955; Philbrick et al. 1979), while the RfD for copper cyanide was based on decreased body and organ weights and liver and kidney effects in an intermediate-duration rat study (Gerhart 1987). An EPA reference concentration (RfC) exists only for chronic inhalation exposure to hydrogen cyanide; this RfC is 3x10^−3^ mg/m^3^. The RfC was based on central nervous system and thyroid effects in a human occupational study (El Ghawabi et al. 1975).

The EPA has determined that cyanide is not classifiable as to its human carcinogenicity (Group D). No cancer classifications exist for the National Toxicology Program, IRIS, or IARC (no available data).

Several cyanide compounds are on the list of chemicals regulated under “The Emergency Planning and Community Right-to-Know Act of 1986” (EPCRA) (EPA 2004d). Section 313 of Title III of EPCRA requires owners and operators of certain facilities that manufacture, import, process, or otherwise use the chemicals on this list to report annually their release of those chemicals to any environmental media.

OSHA requires employers of workers who are occupationally exposed to cyanide to institute engineering controls and work practices to reduce and maintain employee exposure at or below permissible exposure limits (PELs). The employer must use engineering and work practice controls, if feasible, to reduce exposure to or below an 8-hour time-weighted average (TWA) of 10 ppm (11 mg/m^3^) as cyanide. Respirators must be provided and used during the time period necessary to install or implement feasible engineering and work practice controls (OSHA 2004d). NIOSH (2004) recommends a 10-minute ceiling of 5 mg/m^3^ for cyanide in compounds such as sodium cyanide or potassium cyanide.

Table 8-1 Regulations and Guidelines Applicable to Cyanide and Cyanide Compounds

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | No data | IARC 2004
WHO | Air quality guideline value | No data | WHO 2000
WHO | Drinking water guideline value | | WHO 2004
WHO | Cyanide | 0.07 mg/L | WHO 2004
WHO | Cyanogen chloride (for cyanide as total cyanogenic compounds) | 0.07 mg/L | WHO 2004
NATIONAL
Regulations and Guidelines:
a. Air
ACGIH | TLV (8-hour TWA) | | ACGIH 2003
ACGIH | Cyanogen | 10 ppm | ACGIH 2003
ACGIH | Cyanogen chloride (ceiling limit) | 0.3 ppm | ACGIH 2003
ACGIH | Hydrogen cyanide (ceiling limit)^a^ | 4.7 ppm | ACGIH 2003
EPA | Hazardous air pollutant | | EPA 2004j; 42USC7412
EPA | Cyanide compounds | | EPA 2004j; 42USC7412
EPA | Regulated toxic and flammable substances and threshold quantities for accidental release prevention | | EPA 2005a; 40CFR68.130
EPA | Cyanogen (toxic) | 10,000 pounds | EPA 2005a; 40CFR68.130
EPA | Cyanogen chloride (flammable) | 10,000 pounds | EPA 2005a; 40CFR68.130
NIOSH | REL (10-hour TWA) | | NIOSH 2005
NIOSH | Cyanogen | 10 ppm | NIOSH 2005
NIOSH | Cyanogen chloride (10-minute ceiling limit) | 0.3 ppm | NIOSH 2005
NIOSH | Hydrogen cyanide (short-term limit)^a^ | 4.7 ppm | NIOSH 2005
NIOSH | Potassium cyanide (10-minute ceiling limit) | 4.7 ppm | NIOSH 2005
NIOSH | Sodium cyanide (10-minute ceiling limit) | 4.7 ppm | NIOSH 2005
NIOSH | IDLH | | NIOSH 2005
NIOSH | Cyanogen | No data | NIOSH 2005
NIOSH | Cyanogen chloride | No data | NIOSH 2005
NIOSH | Hydrogen cyanide | 50 ppm | NIOSH 2005
NIOSH | Potassium cyanide (as cyanide) | 25 mg/m^3^ | NIOSH 2005
NIOSH | Sodium cyanide (as cyanide) | 25 mg/m^3^ | NIOSH 2005
OSHA | PEL (8-hour TWA) for general industry | | OSHA 2004d; 29CFR1910.1000, Table Z-1
OSHA | Hydrogen cyanide^a^ | 10 ppm | OSHA 2004d; 29CFR1910.1000, Table Z-1
OSHA | PEL (8-hour TWA) for construction industry | 10 ppm | OSHA 2004c; 29CFR1926.55, Appendix A
OSHA | Cyanogen | 10 ppm | OSHA 2004c; 29CFR1926.55, Appendix A
OSHA | Hydrogen cyanide^a^ | 10 ppm | OSHA 2004c; 29CFR1926.55, Appendix A
OSHA | PEL (8-hour TWA) for shipyard industry | | OSHA 2004a; 29CFR1915.1000, Table Z
OSHA | Cyanogen | 10 ppm | OSHA 2004a; 29CFR1915.1000, Table Z
OSHA | Hydrogen cyanide^a^ | 10 ppm | OSHA 2004a; 29CFR1915.1000, Table Z
OSHA | Highly hazardous chemicals which present a potential for a catastrophic event at or above the threshold quantity listed | | OSHA 2004b; 29CFR1910.119, Appendix A
OSHA | Cyanogen | 2,500 pounds | OSHA 2004b; 29CFR1910.119, Appendix A
OSHA | Cyanogen chloride | 500 pounds | OSHA 2004b; 29CFR1910.119, Appendix A
OSHA | Hydrogen cyanide, anhydrous | 1,000 pounds | OSHA 2004b; 29CFR1910.119, Appendix A
b. Water
EPA | Drinking water standards and health advisories | | EPA 2004a
EPA | Cyanide | | EPA 2004a
EPA | 1-day HA for a 10-kg child | 0.2 mg/L | EPA 2004a
EPA | 10-day HA for a 10-kg child | 0.2 mg/L | EPA 2004a
EPA | DWEL | 0.8 mg/L | EPA 2004a
EPA | Lifetime HA (70-kg adult) | 0.2 mg/L | EPA 2004a
EPA | Cyanogen chloride | | EPA 2004a
EPA | 1-day HA for a 10-kg child | 0.05 mg/L | EPA 2004a
EPA | 10-day HA for a 10-kg child | 0.05 mg/L | EPA 2004a
EPA | DWEL | 2.0 mg/L | EPA 2004a
EPA | Designated as a hazardous substances pursuant to Section 311(b) of the Clean Water Act | | EPA 2004t; 40CFR116.4
EPA | Ammonium thiocyanate | Yes | EPA 2004t; 40CFR116.4
EPA | Calcium cyanide | | EPA 2004t; 40CFR116.4
EPA | Cyanogen chloride | | EPA 2004t; 40CFR116.4
EPA | Hydrogen cyanide | | EPA 2004t; 40CFR116.4
EPA | Potassium cyanide | | EPA 2004t; 40CFR116.4
EPA | Sodium cyanide | | EPA 2004t; 40CFR116.4
EPA | National primary drinking water standards and public notification | | EPA 2004h; 40CFR141.32
EPA | Cyanide^b^ | 0.2 ppm | EPA 2004h; 40CFR141.32
EPA | Reportable quantities of hazardous substances designated pursuant to Section 311(b) of the Clean Water Act | | EPA 2004k; 40CFR117.3
EPA | Ammonium thiocyanate | 5,000 pounds | EPA 2004k; 40CFR117.3
EPA | Calcium cyanide | 10 pounds | EPA 2004k; 40CFR117.3
EPA | Cyanogen chloride | 10 pounds | EPA 2004k; 40CFR117.3
EPA | Hydrogen cyanide | 10 pounds | EPA 2004k; 40CFR117.3
EPA | Potassium cyanide | 10 pounds | EPA 2004k; 40CFR117.3
EPA | Sodium cyanide | 10 pounds | EPA 2004k; 40CFR117.3
EPA | National primary drinking water regulations (MCL) | | EPA 2004g; 40CFR141.62
EPA | Cyanide | 0.2 mg/L | EPA 2004g; 40CFR141.62
FDA | Bottled water | | FDA 2003; 21CFR165.110
FDA | Cyanide | 0.2 mg/L | FDA 2003; 21CFR165.110
c. Food
EPA | Tolerance for residues of hydrogen cyanide from postharvest fumigation as a result of application of sodium cyanide on citrus fruits | 50 ppm | EPA 2004m; 40CFR180.130
EPA | Exemptions from the requirement of a tolerance when used in accordance with good agricultural practices in pesticide formulations applied to growing crops; and when used as an adjuvant or intensifier for defoliation and weed control on cotton and soybeans | Ammonium thiocyanate | EPA 2004n; 40CFR180.920
FDA | Indirect food additive for use only as a component of adhesives | Ammonium thiocyanate | FDA 2003; 21CFR175.105
d. Other
EPA | Carcinogenicity classification | | IRIS 2004
EPA | Calcium cyanide | No data | IRIS 2004
EPA | Chlorine cyanide | No data | IRIS 2004
EPA | Copper(I) cyanide | No data | IRIS 2004
EPA | Cyanide | Group D^c^ | IRIS 2004
EPA | Cyanogen | No data | IRIS 2004
EPA | Hydrogen cyanide | No data | IRIS 2004
EPA | Potassium cyanide | No data | IRIS 2004
EPA | Potassium silver cyanide | No data | IRIS 2004
EPA | Sodium cyanide | No data | IRIS 2004
EPA | Rfc^d^ | | IRIS 2004
EPA | Calcium cyanide | No data | IRIS 2004
EPA | Chlorine cyanide | No data | IRIS 2004
EPA | Copper(I) cyanide | No data | IRIS 2004
EPA | Cyanide | No data | IRIS 2004
EPA | Cyanogen | No data | IRIS 2004
EPA | Hydrogen cyanide | 3x10^−3^ mg/m^3^ | IRIS 2004
EPA | Potassium cyanide | No data | IRIS 2004
EPA | Potassium silver cyanide | No data | IRIS 2004
EPA | Sodium cyanide | No data | IRIS 2004
EPA | RfD^e^ | | IRIS 2004
EPA | Calcium cyanide | 4x10^−2^ mg/kg/day | IRIS 2004
EPA | Chlorine cyanide | 5x10^−2^ mg/kg/day | IRIS 2004
EPA | Copper(I) cyanide | 5x10^−3^ mg/kg/day | IRIS 2004
EPA | Cyanide | 2x10^−2^ mg/kg/day | IRIS 2004
EPA | Cyanogen | 4x10^−2^ mg/kg/day | IRIS 2004
EPA | Hydrogen cyanide | 2x10^−2^ mg/kg/day | IRIS 2004
EPA | Potassium cyanide | 5x10^−2^ mg/kg/day | IRIS 2004
EPA | Potassium silver cyanide | 2x10^−1^ mg/kg/day | IRIS 2004
EPA | Sodium cyanide | 4x10^−2^ mg/kg/day | IRIS 2004
EPA | Hazardous waste identification | | EPA 2004f; 40CFR261, Appendix VIII
EPA | Calcium cyanide | P021 | EPA 2004f; 40CFR261, Appendix VIII
EPA | Copper(I) cyanide | P029 | EPA 2004f; 40CFR261, Appendix VIII
EPA | Cyanides (soluble salts and complexes) | P030 | EPA 2004f; 40CFR261, Appendix VIII
EPA | Cyanogen | P031 | EPA 2004f; 40CFR261, Appendix VIII
EPA | Cyanogen chloride | P033 | EPA 2004f; 40CFR261, Appendix VIII
EPA | Hydrogen cyanide | P063 | EPA 2004f; 40CFR261, Appendix VIII
EPA | Potassium cyanide | P098 | EPA 2004f; 40CFR261, Appendix VIII
EPA | Potassium silver cyanide | P099 | EPA 2004f; 40CFR261, Appendix VIII
EPA | Sodium cyanide | P106 | EPA 2004f; 40CFR261, Appendix VIII
EPA | Pesticide (sodium cyanide) classified as restricted use and limited to use by or under the direct supervision of a certified applicator | All capsules and all ball formulations for all uses^f^ | EPA 2004i; 40CFR152.175
EPA | Superfund; emergency planning and notification of extremely hazardous substances and their threshold quantities | | EPA 2004e; 40CFR355, Appendix A
EPA | Hydrogen cyanide | 100 pounds | EPA 2004e; 40CFR355, Appendix A
EPA | Potassium cyanide | 100 pounds | EPA 2004e; 40CFR355, Appendix A
EPA | Potassium silver cyanide | 500 pounds | EPA 2004e; 40CFR355, Appendix A
EPA | Sodium cyanide | 100 pounds | EPA 2004e; 40CFR355, Appendix A
EPA | Superfund; designation of hazardous substances and their reportable quantities | | EPA 2004d; 40CFR302.4
EPA | Ammonium thiocyanate^g^ | 5,000 pounds | EPA 2004d; 40CFR302.4
EPA | Calcium cyanide^h^ | 10 pounds | EPA 2004d; 40CFR302.4
EPA | Copper cyanide^i^ | 10 pounds | EPA 2004d; 40CFR302.4
EPA | Cyanides (soluble salts and complexes) | 10 pounds | EPA 2004d; 40CFR302.4
EPA | Cyanogen^i^ | 100 pounds | EPA 2004d; 40CFR302.4
EPA | Cyanogen chloride^h^ | 10 pounds | EPA 2004d; 40CFR302.4
EPA | Hydrogen cyanide^h^ | 10 pounds | EPA 2004d; 40CFR302.4
EPA | Potassium cyanide^h^ | 10 pounds | EPA 2004d; 40CFR302.4
EPA | Potassium silver cyanide^i^ | 1 pound | EPA 2004d; 40CFR302.4
EPA | Sodium cyanide^h^ | 10 pounds | EPA 2004d; 40CFR302.4
EPA | Tolerances for pesticide chemicals in food; when calcium cyanide and hydrogen cyanide are on the same agricultural commodity, the total amount shall not yield more residue than the larger of the two tolerances, calculated as hydrogen cyanide | | EPA 2004o; 40CFR180.3
EPA | Toxic chemical release reporting; community right-to-know; effective date for hydrogen cyanide | 01/01/1987 | EPA 2004p; 40CFR372.65
EPA | TSCA chemical information rules; manufacturers reporting period for sodium cyanide | | EPA 2004r; 40CFR712.30
EPA | Effective date | 10/29/1990 | EPA 2004r; 40CFR712.30
EPA | Reporting date | 12/27/1990 | EPA 2004r; 40CFR712.30
EPA | TSCA health and safety data reporting for sodium cyanide | | EPA 2004s; 40CFR716.120
EPA | Effective date | 10/29/1990 | EPA 2004s; 40CFR716.120
EPA | Sunset date | 12/19/1995 | EPA 2004s; 40CFR716.120
[underlined: STATE]
a. Air
| No data
b. Water
| Drinking water standards and guidelines | | HSDB 2004
Arizona | Calcium cyanide | 220 μg/L | HSDB 2004
Arizona | Copper(I) cyanide | 1,300 μg/L | HSDB 2004
Arizona | Potassium cyanide | 220 μg/L | HSDB 2004
Arizona | Potassium silver cyanide | 50 μg/L | HSDB 2004
Arizona | Sodium cyanide | 220 μg/L | HSDB 2004
Connecticut | Potassium silver cyanide | 50 μg/L | HSDB 2004
Florida | Cyanogen | 10,000 μg/L | HSDB 2004
Florida | Cyanogen chloride | 350 μg/L | HSDB 2004
Florida | Hydrogen cyanide | 10,000 μg/L | HSDB 2004
Maine | Potassium cyanide | 154 μg/L | HSDB 2004
Maine | Potassium silver cyanide | 50 μg/L | HSDB 2004
Maine | Sodium cyanide | 154 μg/L | HSDB 2004
Minnesota | Potassium cyanide | 100 μg/L | HSDB 2004
Minnesota | Potassium silver cyanide | 30 μg/L | HSDB 2004
Minnesota | Sodium cyanide | 100 μg/L | HSDB 2004
Wisconsin | Potassium silver cyanide | 50 μg/L | HSDB 2004
c. Food
| No data
d. Other
| No data

a Skin designation: Potential significant contribution to the overall exposure by the cutaneous route, including mucous membranes and the eyes, either by contact with vapors, or of probable greater significance, by direct skin contact with the substance.

b EPA sets drinking water standards and has determined that cyanide is a health concern at certain levels of exposure. This inorganic chemical is used in electroplating, steel processing, plastics, synthetic fabrics, and fertilizer products; it usually gets into water as a result of improper waste disposal. This chemical has been shown to damage the spleen, brain, and liver of humans fatally poisoned with cyanide. EPA has set the drinking water standard for cyanide at 0.2 ppm to protect against the risk of these adverse health effects. Drinking water that meets the EPA standard is associated with little to none of this risk and should be considered safe with respect to cyanide (EPA 2004h).

c Group D: Not classifiable as a human carcinogen.

d An estimate (with uncertainty spanning an order of magnitude) of a daily inhalation exposure concentration that is likely to be without significant risk of adverse effects during a lifetime (chronic exposure).

e An estimate (with uncertainty spanning an order of magnitude) of a daily oral exposure dose that is likely to be without significant risk of adverse effects during a lifetime (chronic exposure).

f The criteria influencing the restriction of sodium cyanide is based on the inhalation hazard to humans. Also, sodium cyanide capsules may only be used by certified applicators who have also taken the required additional training.

g Designated as a hazardous substance pursuant to Section 311(b)(2) of the Clean Water Act.

h Designated as a hazardous substance pursuant to Section 311(b)(2) of the Clean Water Act and Section 3001 of RCRA.

i Designated as a hazardous substance pursuant to Section 3001 of RCRA.

ACGIH = American Conference of Governmental Industrial Hygienists; CFR = Code of Federal Regulations; DWEL = drinking water equivalent level; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; HA = health advisory; HSDB = Hazardous Substances Data Bank; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; NIOSH = National Institute for Occupational Safety and Health; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; RCRA = Resource Conservation and Recovery Act; REL = recommended exposure limit; RfC = reference concentration; RfD = reference dose; TLV = threshold limit values; TSCA = Toxic Substances Control Act; TWA = time-weighted average; USC = United States Codes; WHO = World Health Organization

Cyanide is regulated by the Clean Water Effluent Guidelines as stated in Title 40, Sections 400–475, of the Code of Federal Regulations. For each point source category, cyanide may be regulated as amenable or total cyanide. The point source categories for which cyanide is controlled include electroplating; metal finishing; organic chemicals; plastics and synthetic fibers; hydrogen peroxide manufacturing; iron and steel; nonferrous metals; steam electri-power; ferroalloy manufacturing; pharmaceuticals; battery manufacturing; aluminum forming; nonferrous metal forming; and coil coating.

Under the Federal Insecticide, Fungicide, and Rodenticide Act (FIFRA), food tolerance restrictions (see Table 8-1) apply to various cyanide compounds when applied to growing crops (EPA 2004m, 2004n, 2004o).

Under the Resource Conservation and Recovery Act (RCRA), cyanide is listed as a hazardous waste when it is a discarded commercial chemical product, off-specification species, container residue, or spill residue (EPA 1980c); a waste from non-specific sources (EPA 1981c); or a waste from specific sources (EPA 1981c).