# 7 ANALYTICAL METHODS

The purpose of this chapter is to describe the analytical methods that are available for detecting, measuring, and/or monitoring cyanide, its metabolites, and other biomarkers of exposure and effect to cyanide. The intent is not to provide an exhaustive list of analytical methods. Rather, the intention is to identify well-established methods that are used as the standard methods of analysis. Many of the analytical methods used for environmental samples are the methods approved by federal agencies and organizations such as EPA and the National Institute for Occupational Safety and Health (NIOSH). Other methods presented in this chapter are those that are approved by groups such as the Association of Official Analytical Chemists (AOAC) and the American Public Health Association (APHA). Additionally, analytical methods are included that modify previously used methods to obtain lower detection limits and/or to improve accuracy and precision.

## 7.1 BIOLOGICAL MATERIALS

Humans may be exposed to cyanide from dietary, industrial, environmental, and other sources. Inhalation of tobacco smoke is an important source of cyanide, and exposure may occur from smoke due to fires. After absorption, cyanide is rapidly distributed in the body through blood. Some of the common methods available for determining cyanide in biological media are reported in Table 7-1. Since cyanide forms volatile hydrogen cyanide gas, tissue sampling techniques, storage, and cyanide analysis must be done with caution. The choice of tissues and the factors influencing measured cyanide concentrations are also important (Ballantyne 1983c, 1987a).

The determination of cyanide in body fluids requires the separation of cyanide from thiocyanate, usually by distillation of cyanides or microdiffusion into an absorber solution. The cyanide is measured spectrophotometrically after a colorimetric reaction involving the cyanide ion and chloramines-T plus pyridine-pyrazolone, p-benzoquinone, or p-phenylene diamine (see Table 7-1). Detection limits are in the low to mid ppb range (μg/L) (Cruz-Landeira et al. 2000; Ganjeloo et al. 1980; Laforge et al. 1994). Most of these techniques are time-consuming, and some lack specificity or sensitivity. Cyanide in blood is almost exclusively localized to the erythrocytes, whereas thiocyanate is confined to plasma (Lundquist and Sorbo 1989); thus, some researchers recommend analysis of erythrocytes (McMillan and Svoboda 1982; Sano et al. 1992). Some interferences can be mitigated. For example, sodium thiosulfate, a common cyanide antagonist that acts as an interference, can be eliminated by using a buffered solution at pH 5.2 as the acidifying agent for cyanide microdiffusion (Sylvester et al. 1982; Way 1984).

Table 7-1 Analytical Methods for Determining Cyanide in Biological Samples

Sample matrix | Preparation method | Analytical method | Sample detection limit | Percent recovery | Reference
Blood | Separation in a microdiffusion cell; treatment of absorber solution with chloramine T-phosphate and pyridine-pyrazolone reagent | Spectrophotometry (total cyanide) | 0.1 ppm | No data | Morgan and Way 1980
Blood | Separation in a microdiffusion cell; treatment of absorber solution with p-benzoquinone | Spectrofluorometry (total cyanide) | 0.025 ppm | No data | Ganjeloo et al. 1980
Plasma | Deproteinization with trichloroacetic acid; bromination of supernatant and treatment with pyridine-p-phenylene diamine | Spectrophotometry (thiocyanate-cyanide determination) | 0.07 ppm | 96 (thiocyanate) | Pettigrew and Fell 1972
Erythrocyte suspension | Sample purged; absorption of hydrogen cyanide in sodium hydroxide; conversion of thiocyanate to cyanide by potassium permanganate oxidation | Spectrophotometry (thiocyanate-cyanide determination) | No data | 93–97 | McMillan and Svoboda 1982
Blood cells | Separation of cells by centrifugation; extraction; derivitization | HPLC with fluorescence detection | 2 ng/mL | 83 | Sano et al. 1992
Blood | Lysis of blood; extraction; derivatization NDA and taurine | Capillary electrophoresis with fluorescence detection | 0.1 ng/mL | No data | Chinaka et al. 2001
Blood | Acidification of sample in a sealed vial | Headspace GC/NPD | 0.3 μg/mL | No data | Levin et al. 1990
Blood | Acidification of sample; incubation with chloramine-T in sealed vial | Headspace GC/ECD | 100 μg/L | No data | Odoul et al. 1994
Blood | Acidification of sample containing K^13^C^15^N in a sealed vial; microdiffusion to NDA derivatization solution | HPLC-MS | 5 ng/mL | 88.0 (100 ng/mL); 85.7 (500 ng/mL) | Tracqui et al. 2002
Blood | Separation by diffusion; color development | Spectrophotometry | 0.07 μg/mL | No data | Laforge et al. 1994
Blood | Incubation of acidified sample | GC/NPD | 1 ng/mL | No data | Seto et al. 1993
Blood | Separation in a microdiffusion cell; absorption in methemoglobin solution | Spectrophotometric (free cyanide determination) | 0.4 μg/mL | 80 | Tomoda and Hashimoto 1991
Blood | Add K^13^C^15^N to blood sample; acidify with phosphoric acid and incubate at 60 °C for 15 minutes | GC/MS | 0.008 μg/mL | 98 | Dumas et al. 2005
Blood and liver | Treatment of HCN released from sample digestion with lead acetate and absorption with NaOH | Specific ion electrode (total cyanide) | 5 μg/L | 100–109 (whole blood, 0.3–130 ppb) | Egekeze and Oehme 1979
Blood and urine | Separation in a Conway microdiffusion cell; treatment of absorber solution with naphthalene-2,3-dialdehyde and taurine | Spectrophotofluorometric | 0.8 ppb | 66–82.6 at 0.0013–0.13 ppm (blood); 75.6–82 at 0.0013–0.13 ppm (urine) | Sano et al. 1989
Plasma and urine | Sample is acidified with HCl and extracted on a mixed cation exchange column; analyte is eluted from column, lyophilized, and derivatized by reaction with 30% MSTFA in hexane | GC/MS (2-aminothiazoline-4-carboxylic acid) | 25 ng/mL | 100% (plasma); 84% (urine) | Logue et al. 2005
Urine | Dilution of sample; bromination and treatment with pyridine-p-phenylenediamine | Spectrophotometric (thiocyanate-cyanide determination) | 0.07 ppm | 88 (thiocyanate at 0.6 ppm) | Pettigrew and Fell 1972
Urine | Sample acidified and purged; absorbed and reacted in hydroxycobalamine solution | Spectrophotometry (total cyanide) | 28 ng/mL | 50 | Cruz-Landeira et al. 2000
Saliva | Derivatization | HPLC/UV (thiocyanate) | 2 ng (instrumental) | 95–99 | Liu and Yun 1993

ECD = electron capture detector; GC = gas chromatography; GC/MS = gas chromatography/mass spectrometry; HCN = hydrogen cyanide; HPLC = high performance liquid chromatography; HPLC-MS = high performance liquid chromatography coupled with mass spectrometric detector; MSTFA = N-methyl-N-trimethylsilyltrifluoroacetamide; NaOH = sodium hydroxide; NDA = naphthalenedialdehyde; NPD = nitrogen-phosphorus detector; UV = ultraviolet detector

Low detection limits (low ng/mL) have been achieved using a headspace/gas chromatographic (GC) technique (Dumas et al. 2005; Seto et al. 1993) with good precision in the measurements reported (Dumas et al. 2005; Levin et al. 1990; Seto et al. 1993). The sample is acidified and incubated, and the headspace analyzed by GC with a nitrogen-specific detector (NPD) (Levin et al. 1990; Seto et al. 1993) or mass spectrometer (Dumas et al. 2005). Cryogenic oven-trapping techniques have been used to trap volatiles from blood, such as cyanide, at the head of the GC column before analysis, thus eliminating problems of sample foaming that are encountered in traditional head-space analysis methods. Detection limits of 2 ng/mL (2 μg/L) have been reported with extraction efficiencies of 3.22% from blood (Watanabe-Suzuki et al. 2002). Blood samples may be treated with chloramine-T prior to incubation to produce a derivative which can be determined by GC with electron capture detection (ECD). Cyanate and thiocyanate do not interfere with the detection of cyanide in this method (Odoul et al. 1994). The detection limit is 5 μg/L (ppb); precision is good (<15% relative standard deviation [RSD]) (Odoul et al. 1994).

Trace amounts of cyanide in blood cells may be determined using a liquid chromatographic technique with fluorescence detection (Felscher and Wulfmeyer 1998; Sano et al. 1992). The blood cells are extracted and the cyanide derivatized prior to chromatography. The detection limit is 2 ng/mL. Recovery is acceptable (>80%), and precision is good (<15% RSD) (Felscher and Wulfmeyer 1998; Sano et al. 1992). Coupling the liquid chromatography technique to a mass spectrometric detector also provides good detection sensitivities (limit of detection=5 ng/mL) and recoveries (>85%) (Tracqui et al. 2002). Using an ion liquid chromatography method coupled with fluorescence detection, Chinaka et al. (1998) were able to achieve detection limits down to 3.8 pmoles/mL (0.10 ng/mL) of cyanide and 86 pmoles/mL (5.1 ng/mL) of thiocyanate in blood.

Cyanide in biological tissue and fluids can be measured spectrophotometrically after reaction with methemoglobin (Tomoda and Hashimoto 1991). The detection limit is 0.4 μg/mL. Other performance data were not reported (Tomoda and Hashimoto 1991). Cyanide in urine has been determined using microdiffusion separation and fluorimetric determination (Sano et al. 1989). The detection limit of the assay is reported to be 30 ng/L with recoveries of 75.6–82.6% (Sano et al. 1989).

Cyanide in the body is biotransformed to thiocyanate quickly. People may also be exposed to thiocyanate from dietary, industrial, and medical sources. The plasma concentration of thiocyanate has also been used as an index of long-term exposure to cigarette smoke (Liu and Yun 1993). Some authors have determined thiocyanate in body fluids as a measure of cyanide exposure, while others measure cyanide concentrations in body fluids directly.

Serum levels of thiocyanate are usually determined spectrophotometrically after a colorimetric reaction of thiocyanate with ferric nitrate or barbituric acid and pyridine (Li et al. 1993; Olea et al. 1992). Ion exchange resin chromatography has been used to isolate thiocyanate from serum (Olea et al. 1992). Detection limits are in the ppb range (Li et al. 1993; Olea et al. 1992). Recovery and precision, where reported, are good (recovery >90%; precision <15% RSD) (Li et al. 1993). Methods are available for measuring thiocyanate in saliva by high performance liquid chromatography (HPLC) (Liu and Yun 1993) and in saliva and blood spectrophotometrically (Tominaga et al. 1991; Yamanaka et al. 1991). Table 7-2 lists representative analytical methods for determining thiocyanides in biological matrices.

In addition to thiocyanate, another cyanide metabolite, 2-aminothiazoline-4-carboxylic acid (ATCA), is being used as a biomarker of cyanide exposures. This biomarker is formed through the reaction of cyanide with l-cystine and accounts for 20% of cyanide metabolism in the human body (Logue et al. 2005). Unlike cyanide, ATCA is stable for months in biological samples stored at freezing or ambient temperatures. ATCA is readily recovered from plasma or urine by first acidifying the sample and then extracting the compound on to a mixed, cation exchange column. The ACTA is eluted from the column and coverted to the trimethylsilyl derivative through reaction with 30% N-methyl-N-trimethylsilyl-trifluoroacetamide (MSTFA) in hexane before analysis by gas chromatography/mass spectrometry (GC/MS). The assay method provides for good detection limits (25 ng/mL) and recoveries (100% from plasma and 84% from urine).

## 7.2 ENVIRONMENTAL SAMPLES

Hydrogen cyanide and cyanide salts are important environmental contaminants, and there are numerous reports dealing with the identification and quantification of cyanide in air, water, and other environmental media. Representative examples of monitoring methods for cyanide are included in Table 7-3.

Hydrogen cyanide in environmental or workplace air is usually collected in sodium hydroxide solution, then measured spectrophotometrically after color development (Agrawal et al. 1991; NIOSH 1989b). One of the most significant problems in cyanide monitoring is the instability of the collected samples (NIOSH 1986b). The collection solution is pH ≥11 to avoid volatilization loss of molecular hydrogen cyanide. However, carbon dioxide from air may react with the solution during storage, thereby lowering the pH and releasing hydrogen cyanide gas, making the reading for cyanide lower than actually presented. Oxidizing agents in solution may transform cyanide during storage and handling. Ferrocyanide and ferricyanide complexes of cyanide undergo photodecomposition with ultraviolet light. Particulate cyanides are known to decompose in moist air with the liberation of hydrogen cyanide and cyanic acid (HOCN). The recommended method for the storage of cyanide samples is to collect the samples at pH 12–12.5 in closed, dark bottles and store them in a cool, dark place. It is also recommended that the samples be analyzed immediately upon collection. The sample handling and preservation methods have been discussed (NIOSH 1986b; Egekeze and Oehme 1979). Cyanide determination in air usually distinguishes between two forms of cyanides: hydrogen cyanide gas and particulate cyanides. Filters are usually used to collect particulate cyanides, and the hydrogen cyanide gas that passes through the membrane is trapped in sodium hydroxide. The collected particulate cyanides can be quantified separately after acid distillation. Detection limits are in the ppm range for occupational air (Dolzine et al. 1982; NIOSH 1989a, 1989b) and sub-ppm range for ambient air (NIOSH 1986b). Reported recovery is good (>90%) (Dolzine et al. 1982; NIOSH 1986b, 1989a, 1989b).

Table 7-2 Analytical Methods for Determining Biomarkers for Cyanide

Analyte | Sample matrix | Preparation method | Analytical method | Sample detection limit | Percent recovery | Reference
Thiocyanate | Human serum, urine, saliva | Extraction of buffered (pH 7) 2-benzoyl pyridine thiosemicarbazone and sample with isoamyl acetate | Flame atomic absorption spectrometry | 4 ng/mL | 96–102 | Chattaraj and Das 1992
Thiocyanate | Serum | Addition of acetonitrile, centrifugation, separation | Spectrophotometry | 0.3 μg/mL | 94 | Li et al. 1993
Thiocyanate | Human urine, saliva | Derivatization of basic pH sample with pentafluorobenzyl bromide in the presence of Kryptofix 222 B polymer and extraction into methylene chloride then back extraction into isooctane | GC with ECD | 0.0115 nmol (in 0.2 mL) | 83–106 | Chen et al. 1994
Thiocyanate | Human urine, saliva | Dilution with water then filtration (0.45 μm) | Ion chromatography utilizing ODS column coated with cetyldimethylamine and with UV absorbance (210 nm) detection | 20 ng/mL | 95–101 | Michigami et al. 1992
Thiocyanate | Urine | Ion chromatography using weakly basic resin; acidification of eluate with HCl; addition of bromine water, arseneous oxide and pyridine-p-phenylene diamine | Spectrophotometry | 2.5 μmol/L (lowest reported) | No data | Tominaga and Midio 1991
Thiocyanate | Human urine | Dilution with water then passage through disposable Toyo pack ODS and IC-SP columns | Suppressed ion chromatography with conductivity detection | 200 nM | No data | Miura and Koh 1991

ECD = electron capture detector; GC = gas chromatography; IC/SP = ion chromatography/sulfopropyl type column; ODS = octadecyl silane; nM = nanomolar

Table 7-3 Analytical Methods for Determining Cyanide in Environmental Samples

Sample matrix | Preparation method | Analytical method | Sample detection limit | Percent recovery | Reference
Occupational air (NIOSH Method 7904) | Filtered air collected in midget impinger containing NaOH; extraction of filter with NaOH; sulfide removed | Specific ion electrode (HCN cyanide salts) | 2.5 μg CN^−a^ | 96.7 at 5–21 mg/m^3^ | NIOSH 1989a
Occupational air (NIOSH Method 6010) | Collection of breathing zone air samples on adsorbent; extraction with water; treatment with barbituric acid/pyridine reagent | Spectrophotometry (HCN) | 1 μg CN^−b^ | ~100 | NIOSH 1989b
Occupational air | Passage of filtered air through midget impinger containing NaOH; conversion of NaCN to sodium formate; optional ion exchange clean-up | Ion-chromatography/amperometric detector (HCN) | 5–10 ppm | 100–109 at 5–20 ppm | Dolzine et al. 1982
Air | Filtered air collected in midget impinger | Ion-chromatography/amperometric detection (HCN only) | 0.04 ppm (for 2.6 L of air) | 91 at air flow rate of 0.171 L/minute | NIOSH 1986b
Water (drinking, surface, saline, domestic, and industrial waste) (EPA Method 335.1) | Chlorination of sample at pH 11–12 and ClCN driven off; reflux-distillation of residual sample; absorption of released HCN in NaOH; treatment with chloramine-T and pyridine-pyrazolone or pyridine-barbituric acid | Spectrophotometry (cyanide amenable to chlorination) | No data | No data | EPA 1983a
Water (drinking, surface, saline, domestic, and industrial waste) (EPA Method 335.2) | Reflux-distillation of sample; absorption of released HCN in NaOH scrubber; treatment of absorbing solution with chloramine-T and pyridine-pyrazolone or pyridine barbituric acid | Spectrophotometry (total cyanide) | 0.02 ppm | 85–102 at 0.28–0.62 ppm | EPA 1983a
Water (drinking, surface, saline, domestic, and industrial waste) (EPA Method 335.2) (EPA Method 335.3) | Reflux-distillation of sample; absorption of released HCN in NaOH; titration of absorbing solution with AgNO_3_ in presence of p-dimethylamino-benzalrhodanine indicator | Titrimetric (total cyanide) | 1 ppm | No data | EPA 1983a
Water (drinking, surface, saline, domestic, and industrial waste) (EPA Method 335.4) | Reflux-distillation of sample; absorption of released HCN in NaOH; treatment with chloramine-T, pyridine barbituric acid | Semi-automated spectrophotometry (total cyanide) | ~0.02 ppm | 95 (ave.) | EPA 1993h
Water | None | Ion-chromatography/amperometric detection (free and a few complexed cyanides) | 2 ppb | 100–112 | Rocklin and Johnson 1983
Water | Separation of acidified sample in a microdiffusion cell; absorption in NaOH | Potentiometric (free cyanide) | 0.018 mg/L CN^−^ | 96.5–103.9 at 0.037–3.49 mg/L | Rubio et al. 1987
Water (ASTM Method D2036A) | Separation of acidified sample in a microdiffusion cell; absorption in NaOH | Potentiometric (total cyanides) | 0.03 mg/L | 99.0–111 | ASTM 1999
Water | None | FIA; spectrophotometric detection (free cyanide) | 20 ng/mL | 88–107 | Ma and Liu 1992
Water | None | FIA; amperometric detection (free cyanide) | 2.6 ng/mL | 99–103 | Nikolić et al. 1992
Water | Sample shaken in presence of quinoline and benzoyl chloride at pH 7 | HPLC with spectrophotometric detection (free CN^−^) | 26 pg/mL | No data | Madungwe et al. 1991
Water | None | Ion chromatography with postcolumn derivatization and fluorimetric detection (free cyanide) | 0.1 ng/mL | 94–96 | Gamoh and Imamichi 1991
Water | Treatment of sample with NaOH and hypophosphite; passage through silver filter (free cyanide); treatment in photo cell prior to filter for total cyanide and selective oxidation for cyanides not amenable to chlorination (CNATC) | Flame AAS or graphite furnace AAS | 2 ng/mL (flame AAS); 0.06 ng/mL (graphite furnace AAS | 107 (free cyanide), 90.4 (CNATC), 98.1 (total cyanide) | Rosentreter and Skogerboe 1992
Water | Samples sealed in vials with nitrogen | Headspace GC/ECD (cyanogen chloride) | 0.04 ng/mL | 91 average | Xie and Reckhow 1993
Water | Absorption on to SPME fiber; thermal desorption in GC | GC/ECD (cyanogen chloride or bromide) | 77 ng/L (cyanogen chloride) 41 ng/L (cyanogen bromide) | No data | Cancho et al. 2000
Water (APHA Method 4500-CN^−^ J) | Adjustment of sample pH to 8.0–8.5 using phosphate buffer; addition of pyridine-barbituric acid | Spectrophotometry (cyanogen chloride) | 0.02 μg/mL (as CN^−^) (lowest calibration) | No data | APHA 1992
Water and waste water (APHA Method 4500-CN^−^ M) | Filtration of sample; optional treatment with resin; treatment with ferric nitrate solution | Colorimetric detection (thiocyanate) | No data | 71–99, 0.07–1.42 mg/L | APHA 1992
Waste or leachate (EPA Method 9012A) | Reflux-distillation of acidified sample; absorption of released HCN in NaOH; treatment with AgNO_3_ and an indicator (titrimetric) or chloramine-T/pyridine-barbituric acid (colorimetric) | Titrimetric or colorimetric detection (total and amenable cyanide) | 0.1–0.2 mg/L (titrimetric); 0.02 mg/L (colorimetric) | (titrimetric) 94–99 (total cyanide), 87–97 (amenable cyanide) | EPA 1996
Waste water | Addition of sample to buffered methemoglobin | Spectrophotometry (free cyanide) | 0.2 μg/mL | No data | Tomoda and Hashimoto 1991
Waste water | None | FIA with spectrophotometric detection | 3 ng/mL | 98 | Kubáň 1992
Waste water | Sample acidified and irradiated with UV; microdiffusion and absorption in NaOH solution | FIA with amperiometric detection (total cyanide) | 0.5 μg/L | 99.5 (2 μg/L); 99 (30 μg/L) | Weinberg and Cook 2002
Waste water | Complexation of sample with 2-benzoyl-pyridine thiosemicarbazone; solvent extraction | Flame AAS (free cyanide) | 4.8 ng/mL | 97–101 | Chattaraj and Das 1991
Solid waste or oil waste (EPA Method 9013) | Extraction of solid component with water at pH 10 and hexane | Titrimetric or colorimetric detection (soluble cyanides) | No data | 60–90 (solid); 88–92 (oil) | EPA 1992e
Soils/sediments (USGS Method I6302) | Reflux-distillation of sample; absorption of released HCN in NaOH; treatment with chloramine-T, pyridine barbituric acid | Colorimetric detection (recoverable simple cyanides) | 0.5 mg/kg | No data | USGS 1985
Food (cereal and other foodstuffs) | Extraction of sample with water/ acetonitrile, dried | GC/ECD at low detection voltage (free cyanide) | 0.1 ppm | 90 | Heuser and Scudmore 1969
Food (soybean and soybean products) | Sample mixed with water, lead nitrate, tartaric acid, and anti-forming agent; acidification and distillation; treatment of distillate with pyridine-barbituric acid | Spectrophotometry (total cyanide) | No data | 32–80 | Honig et al. 1983

a Method detection limits depend upon the volume of air sampled; the working range is 5–20 mg/m^3^ for a 10-L air sample.

b Method detection limits depend upon the volume of air sampled; the working range is 1–333 mg/m^3^ for a 3-L sample.

AAS = atomic absorption spectroscopy; AgNO_3_ = silver nitrate; ASTM = American Society for Testing and Materials; ClCN = cyanogen chloride; CN^−^ = cyanide ion; CNATC = cyanides not amenable to chlorination (Rosentreter and Skogerboe 1992); EPA = Environmental Protection Agency; FIA = flow injection analysis; GC/ECD = gas chromatograph/electron capture detector; HCN = hydrogen cyanide; NaOH = sodium hydroxide; NIOSH = National Institute for Occupational Safety and Health; USGS = United States Geological Survey; UV = ultraviolet

Inorganic cyanides in water can be present both as complexed and free cyanide. Cyanide in water is usually determined in three different forms: free cyanide, cyanide amenable to chlorination, and total cyanide. Free cyanides such as sodium cyanide, potassium cyanide, and hydrogen cyanide are readily ionized to the cyanide ion under the conditions used in most common analytical techniques. Methods for determining cyanide amenable to chlorination measure simple metal cyanides and most complex cyanides with the exception of iron cyanides. Total cyanide is a measure of all cyanides including iron cyanide complexes. Table 7-3 lists representative analytical methods for determining cyanides that may be present in various forms. A number of standard methods are available (APHA 1992; ASTM 1999; EPA 1983a, 1996; NIOSH 1989a, 1989b). An ion-exchange chromatography method has been developed to separate and quantify cyano complexes of gold, silver, iron, nickel, cobalt, and copper using a UV detection technique (Karmarkar 2002). Minimum detection limits of 0.07–0.83 mg/L and recoveries of 99.8–118.8% were reported, both of which varied considerably depending on the cyano metal complex.

Procedures for extracting cyanide from aqueous matrices usually involve acidifying the sample followed by heating and refluxing to evolve hydrogen cyanide, which is then trapped in an impinger containing absorption media. Complex cyanides and metal cyanide complexes can be degraded to free cyanide through UV irradiation (314 nm) of an acidified sample (Weinberg and Cook 2002). Cyanide is usually measured by colorimetric, titrimetric, or electrochemical methods (for example, APHA 1992). All are subject to interference problems. Sulfide, certain oxidizing agents, nitrate or nitrite, thiocyanate, aldehydes, and ketones may interfere under acid distillation conditions, thus producing erroneous results from both colorimetric and titrimetric methods. In addition, fatty acids in samples may distill over and form soaps under alkaline titration conditions, thus causing interference in the titrimetric method (EPA 1983a, 1996). Colorimetric methods may be based on pyridine with chloramine-T as the oxidizing agent and barbituric acid as the coupling component (EPA 1996) or pyrazolone as the coupling agent (EPA 1983a). Low detection limits are attained (10–20 μg/L), but sulfide and thiocyanate are common interferents (Csikal and Barnard 1983; Drikas and Routley 1988). Titrimetric methods usually employ silver nitrate (EPA 1983a, 1996); however, the detection limits are in the low mg/L range. Methods using specific ion electrodes (electrochemical) respond to numerous interferences (sulfur, chlorine, iodine, bromine, cadmium, silver, zinc, copper, nickel, and mercury) (NIOSH 1986b).

Continuous monitoring methods based on amperometric (Nikolić et al. 1992) or spectrophotometric (Kubáň 1992; Ma and Liu 1992) techniques for the quantification of free cyanide are also available. Ion chromatography with amperometric determination provides good sensitivity (2 ppb) and selectivity for free cyanide and for the weak complexes of cadmium and zinc (Rocklin and Johnson 1983). Postcolumn derivatization and fluorescence detection provides low detection limits as well (0.1 ppb) (Gamoh and Imamichi 1991).

Methods were identified in the available literature for the determination of the concentrations of cyanides and thiocyanates present in soils at low levels. A colorimetric method (USGS 1985) is used to quantify simple cyanides in soils and sediments (see Table 7-3). A reflux-distillation of soil or sediment samples converts CN^−^ to hydrogen cyanide, which is released from the sample and then absorbed in a 1 M NaOH solution. The absorbed cyanide is chlorinated with Chloramine-T and then reacted with pyridine-barbituric acid to form the chromophore. Detection limits of >0.5 mg/kg are reported; no recovery data were given. The method will decompose thiocyanate in the samples to cyanide and sulfide, resulting in a concentration of cyanide that is higher than was originally present in the sample. Sulfide concentrations of >10 mg/kg will greatly interfere with the quantification of cyanide in the assay. In addition to simple cyanides, complex cyanides can also be measured in soil and sediment samples utilizing a modified sample preparation procedure that uses an ultraviolet digestion-distillation method to break down the complex cyanides to the cyanide ion. Brown and Morra (1991) extracted simple cyanides from soils using a calcium chloride solution followed by analysis by ion-chromatography (see Table 7-4). The assay provided a detection limit of 0.02 μg/L with a recovery averaging 94%, depending on soil type.

Table 7-4 Analytical Methods for Determining Environmental Degradation Products of Cyanide

Analyte | Sample matrix | Preparation method | Analytical method | Sample detection limit | Percent recovery | Reference
SCN^−^ | Water | Filtration (0.45 μm) | Reversed-phase ion-pair chromatography with amperometric detection | 104 ng/mL | No data | Xu et al. 1993
SCN^−^ | Water/waste water | Filtration; acidification; reaction with ferric chloride | Colorimetric | 0.1 mg/L | No data | ASTM 1994a
SCN^−^ | Soil | Extraction of soil with calcium chloride solution | Ion chromatography with conductivity detection | 0.02 μg/g | 83; avg. 94, depending on soil type | Brown and Morra 1991

SCN^−^ = thiocyanate ion

Recent method development strategies for quantifying cyanide in water are using biological sensing elements (i.e., organisms, enzyme, receptor, antibody, etc.) coupled to an electronic signal-transducing element. With respect to organisms, the assay takes advantage of the effect that cyanide has on respiration and metabolism. For example, Karube et al. (1998) use yeast in a flow-through reactor setup where river water containing cyanide is pumped through the reactor and the oxygen concentration in the effluent stream is measured using an oxygen electrode. When cyanide passes through the reactor, it inhibits yeast respiration and therefore decreases oxygen consumption, resulting in an increase in the current at the oxygen electrode. A detection limit of 0.2 ppm (3μM) was reported for the assay with a linear response to 1 ppm. In another approach, Nikolelis et al. (1997) use a lipid bilayer embedded with methemoglobin to detect and quantify cyanide in water samples. The binding of cyanide to the methemoglobin causes a change in the electrochemical potential across the membrane that is measured with an electrometer. A detection limit of 4.9 nM (0.0032 ppm) was reported with a relative standard deviation (RSD) of 5.2% at cyanide concentration of 150 nM.

Few methods are available for the determination of cyanogen and cyanogen chloride in environmental matrices. Methods available include gas chromatographic-flame ionization detection of cyanogen chloride and cyanogen (Brown et al. 1986), headspace gas chromatography with electron capture detection (GC/ECD) (Cancho et al. 2000; Xie and Reckhow 1993) and colorimetric detection (APHA 1992). Detection limits are in the low ppb range for the colorimetric method (APHA 1992) and in the sub-ppb range for the GC/ECD method (Xie and Reckhow 1993).

Recent work by Yang and Shang (2005) reports the development of a membrane introduction mass spectrometry (MIMS) technique for quantifying cyanogens chloride in environmental samples. Non-polar, low molecular weight, volatile and semi-volatile organics in aqueous samples are introduced direct to a mass spectrometer through pervaporation as the sample passes through a permeable silicone membrane. Linear responses over three orders of magnitude of concentrations of cyanogens chloride were obtained with a detection limit of 1.7 μg/L and a recovery of 98.5%. The presence of organics, such as dichloroethene, acetophenone, benzaldehyde, and benzyl alcohol, can interfere with the quantification of cyanogen chloride. However, these compounds are generally industrial chemicals that are typically not detected in drinking water, most surface waters, or domestic waste water.

Standard methods are available for measuring thiocyanate in aqueous matrices (APHA 1992; ASTM 1994a). These are colorimetric methods and are subject to interferences. In addition, thiocyanate is biodegradable; thus, care must be exercised in sample collection, preservation, and storage. The detection limit is 100 ppb (ASTM 1994a). An automated method with good sensitivity (0.5 ppb) is available for determining thiocyanate in water and waste water (ASTM 1994b). Various methods have been reported for determination of thiocyanate in soils; however, ion chromatographic determination provides good selectivity and sensitivity (20 ppb) (Brown and Morra 1991). Representative examples of monitoring methods for thiocyanate are included in Table 7-4.

## 7.3 ADEQUACY OF THE DATABASE

Section 104(i)(5) of CERCLA, as amended, directs the Administrator of ATSDR (in consultation with the Administrator of EPA and agencies and programs of the Public Health Service) to assess whether adequate information on the health effects of cyanide is available. Where adequate information is not available, ATSDR, in conjunction with NTP, is required to assure the initiation of a program of research designed to determine the health effects (and techniques for developing methods to determine such health effects) of cyanide.

The following categories of possible data needs have been identified by a joint team of scientists from ATSDR, NTP, and EPA. They are defined as substance-specific informational needs that if met would reduce the uncertainties of human health assessment. This definition should not be interpreted to mean that all data needs discussed in this section must be filled. In the future, the identified data needs will be evaluated and prioritized, and a substance-specific research agenda will be proposed.

### 7.3.1 Identification of Data Needs

Methods for Determining Biomarkers of Exposure and Effect.

Exposure. Besides environmental exposure, exposure to cyanide can also occur from consumption of cyanide-containing food and smoking cigarettes. Since so many factors can influence cyanide exposure, the exact correlation between cyanide concentrations in the body and its level in the environment has not been made. Therefore, measuring cyanide and/or thiocyanate levels in blood and urine cannot be used as a biomarker for exposure to low cyanide concentrations. Reliable analytical methods are available for the detection of cyanide and thiocyanate in blood, plasma, and urine of both unexposed and exposed persons are available, as summarized in Tables 7-1 and 7-2. Further studies determining biomarkers for exposure to low cyanide concentrations would be useful since current methods that are used to measure cyanide and/or thiocyanate in blood and urine are not effective at assessing exposures to low concentrations of cyanide.

The International Programme on Chemical Safety, in its document regarding the antidotes for poisoning by cyanide, has identified several analytical data needs related to the detection of cyanide in biological matrices (IPCS/CEC 1993). Analytical techniques available for the measurement of methemoglobin do not permit accurate estimation of the amount of free hemoglobin available for oxygen transport because cyanmethemoglobin cannot be quantified. A rapid and accurate technique for measuring methemoglobin and cyanmethemoglobin concentrations in conjunction is therefore needed to monitor the use of methemoglobin-generating cyanide antidotes. Reliable quantitative analytical methods for cyanide in whole blood in the presence of one or more antidotes are also needed.

Effect. Although certain effects, such as cyanosis and endemic goiter, have been associated with cyanide exposure (see Section 3.8.2), a positive correlation between cyanide exposure and one of its effects has not yet been established. Additional studies establishing a correlation between cyanide exposure and one of its effects will be useful in diagnosing cyanide exposure.

Methods for Determining Parent Compounds and Degradation Products in Environmental Media. The concentration of hydrogen cyanide in most ambient air is so low that it is beyond the detection limit of the standard analytical methods. An infrared absorption method of a large vertical tropospheric column was used to measure the hydrogen cyanide concentration in the troposphere (Cicerone and Zellner 1983). Similarly, ground-based millimeter wave emission spectroscopy was used to measure stratospheric concentration of hydrogen cyanide (Jaramillo et al. 1989). Also, the level of cyanogen chloride in drinking water ranges from 0.45 to 0.80 ppb (Krasner et al. 1989), which is beyond the detection limit of the standard analytical methods without concentration and trapping procedures. Cyanogen chloride in water was determined by a purge and trap GC/MS method (Krasner et al. 1989) and an MIMS-based method (Yang and Shang 2005), methods that are not available to many laboratories. There is, therefore, a need to develop standard analytical methods capable of quantifying hydrogen cyanide in air and cyanogen chloride in water at levels that are generally found in these media.

Cyanide metabolizes in the human body to thiocyanate, and its biodegradation products include ammonia, carbon dioxide, nitrate, or nitrogen (Richards and Shieh 1989). The detection of thiocyanate or 2-aminothiazoline-4-carboxylic acid in body fluids may indicate cyanide exposure (Logue et al. 2005). Similarly, the amounts of cyanide degradation products formed in an environmental medium could be used to measure cyanide’s biodegradation rate. A summary of methods for determining environmental degradation products is shown in Table 7-4. Suitable analytical methods are available to detect all of these compounds (Pettigrew and Fell 1973; Richards and Shieh 1989). No additional information is needed at this time.

### 7.3.2 Ongoing Studies

The Federal Research in Progress (FEDRIP 2005) database provides additional information obtainable from a few ongoing studies that may fill in some of the data needs identified in Section 7.3.1 and provides examples of new methods used in the detection and quantification of cyanide or thiocyanide. Only one study was identified. Dr. Fennell at Research Triangle Institute is developing liquid-chromatography/mass spectrometry based analytical methods for the detection and quantification of adducts formed between hemoglobin and reactive chemicals such as cyanide.