# 6 POTENTIAL FOR HUMAN EXPOSURE

## 6.1 OVERVIEW

The term cyanide in this Toxicological Profile means a compound that contains the cyanogen (CN) radical. Since the CN portion of the compound is of concern in poisons, any reference to the amount present in air, water, soil, sediments, or other media refers only to this part of the compound. The term free cyanide refers to hydrogen cyanide and cyanide ion (CN^−^) (EPA 1981e; Oudjehani et al. 2002; Shifrin et al. 1996; WHO 2004b).

Cyanide (reported as cyanide, hydrogen cyanide, sodium cyanide, potassium cyanide, or copper (I) cyanide) has been identified in at least 464 of the 1,662 hazardous waste sites that have been proposed for inclusion on the EPA National Priorities List (NPL) (HazDat 2005). However, the number of sites evaluated for cyanide is not known. The frequency of these sites can be seen in Figure 6-1. Of these sites, 462 are located within the United States, 1 is located in Guam (not shown), and 1 is located in the Commonwealth of Puerto Rico (not shown).

Anthropogenic (of human origin) sources are responsible for much of the cyanide in the environment. Cyanide-containing substances also occur naturally in the fruits, seeds, roots, and leaves of numerous plants, and are released to the environment from natural biogenic processes from higher plants, bacteria, and fungi (Cicerone and Zellner 1983; Crutzen and Carmichael 1993; EPA 1981e; Jones 1998; Knowles 1988; Mudder and Botz 2000). However, an estimate of the amount of cyanide released to the environment from natural biogenic processes is not available. The major cyanide releases to water are discharges from metal-finishing industries, iron and steel mills, and organic chemical industries (EPA 1981e). Effluents from the cyanidation process used in precious metal extraction contain high amounts of cyanide (EPA 1994c; Huiatt 1985; Scott 1985). The contribution of this source to the total cyanide discharge in water is insignificant on average (EPA 1981e). However, large, short-term releases can occur from the failure of tailing ponds resulting in the introduction of high concentrations of cyanide into local surface waters and subsoils (Fields 2001; Mudder and Botz 2000). Vehicle exhaust (EPA 1981e) and biomass burning (Crutzen and Carmichael 1993; Lobert and Warnatz 1993) are major sources of cyanide released into the air. The major sources of simple and complex cyanide releases to soil appear to be from the disposal of cyanide wastes in landfills and the use of cyanide-containing road salts (EPA 1981e; Gaffney et al. 1987). Cyanogen chloride is formed in drinking water from reaction of humic substances with chloramine produced during chlorination (Jacangelo et al. 1989; Ohya and Kanno 1987). Thiocyanate is released to water primarily from discharges of industrial waste waters from coal processing and extraction of gold and silver (Boucabeille et al. 1994a); the thiocyanate is formed from the reaction of sulfur donors that are present in coal and crushed rock with the cyanide that is used in the processing of these materials. Thiocyanate is also found in mining waste waters where it results from the interaction of the cyanide anion (CN^−^) with sulphur (Boucabeille et al. 1994b). Releases of thiocyanate to soil result from anthropogenic and natural sources. Anthropogenic releases occur primarily from direct application in herbicidal formulations and from disposal as byproducts from industrial processes. Nonanthropogenic sources include damaged or decaying tissues of plants from the family Brassica (e.g., cabbage, mustard, kale) (Brown and Morra 1993).

Figure 6-1 Frequency of NPL Sites with Cyanide Contamination

Derived from HazDat 2005

Cyanide is released into air mainly as hydrogen cyanide gas and, to a lesser extent, as particulate cyanides. Hydrogen cyanide can potentially be transported over long distances before reacting with photochemically generated hydroxyl radicals. The residence time of hydrogen cyanide in the atmosphere has been estimated to be approximately 2.5 years, with a range of 1.3–5.0 years, depending on the hydroxyl radical concentration (Cicerone and Zellner 1983). Neither photolysis nor deposition by rainwater is expected to be a significant removal mechanism. Only 2% of the tropospheric hydrogen cyanide is expected to be transported to the stratosphere (Cicerone and Zellner 1983). In water, cyanide occurs most commonly as hydrogen cyanide. Hydrogen cyanide is expected to be removed from water primarily by volatilization. Cyanide may also be removed by aerobic or anaerobic biodegradation (Akcil and Mudder 2003; EPA 1979, 1994c). At soil surfaces, volatilization of hydrogen cyanide is a significant loss mechanism for cyanides. In subsurface soil, cyanide at low concentrations would probably biodegrade under both aerobic and anaerobic conditions. In cases where cyanide levels are toxic to microorganisms (i.e., landfills, spills), the concentrations of water-soluble cyanides may be sufficiently high to leach into groundwater.

The environmental fate of thiocyanate has not been thoroughly investigated. Aerobic and anaerobic biodegradation are significant transformation processes for thiocyanates in water (Boucabeille et al. 1994a, 1994b; Shivaraman et al. 1985) and soil (Brown and Morra 1993). At near-ambient temperatures, sorption and volatilization are not significant partitioning processes for thiocyanate in soil (Brown and Morra 1993).

Despite the various ways cyanide is thought to be released into the environment, available monitoring data are limited. The available data indicate that the general population is exposed to cyanide primarily by ingestion of foods that contain substances that release cyanides when ingested and through smoking, and to a lesser extent, by consumption of contaminated drinking water and inhalation of contaminated air. Dermal absorption is not a significant exposure route for the general population. The concentration of cyanide in the northern hemisphere’s non-urban troposphere ranges from 160 to 166 ppt (ppt = parts per trillion) (Cicerone and Zellner 1983; Jaramillo et al. 1989). The mean cyanide concentration in most surface waters is not greater than 3.5 μg/L (EPA 1981e). The cyanide content in certain varieties of lima beans can be as high as 3 mg/g (Honig et al. 1983), although values between 0.10 and 0.17 mg/g are common in U.S. lima beans (EPA 1978c). Much lower cyanide concentrations in various cereal grains and cereal products have been reported, ranging from 0.001 to 0.45 μg/g (Honig et al. 1983). Mean cyanide concentrations in soybean products have been found to range from 0.07 to 0.3 μg/g, whereas the mean cyanide concentration in soybean hulls was 1.24 μg/g (Honig et al. 1983). Due to the lack of data on cyanide content in total diet samples, the average daily intake could not be estimated.

Cyanogen chloride has been measured in drinking water with a concentration ranging between 0.45 and 0.80 μg/L (Krasner et al. 1989).

Available monitoring data on thiocyanate are also very limited. No information was found in the available literature on major routes of exposure among the general population or on estimates of exposure. Because thiocyanate is a major metabolite of cyanide in the body, exposure to cyanide is a source of thiocyanate exposure. Thiocyanate occurs naturally in many edible plants. Vegetables in the family Brassica contain high levels of thiocyanate with concentrations ranging up to 660 μg/g, whereas other commonly consumed vegetables (e.g., spinach, radishes, celery) generally contain thiocyanates at concentrations <2 μg/g. Thiocyanate concentrations in milk and other dairy products and in meat have been reported to be <1–9.0 and 0.5–0.7 μg/g, respectively (Weuffen et al. 1984). Thiocyanate concentrations in coal plant waste waters (Jensen and Tuan 1993) and mining waste waters (Boucabeille et al. 1994b) have been found to be 100–1,500 and 300–450 mg/L, respectively. No data were found in the available literature on thiocyanate concentrations in surface, ground, or drinking waters. Soils treated with rapeseed meal (from the family Brassica) contained thiocyanate at concentrations on the order of 6 μg/g (Brown et al. 1991).

It should be noted that the amounts of cyanide or thiocyanate found by chemical analysis are not necessarily the amounts that are bioavailable.

Among the general population, subpopulations with the most likely potential of exposure to cyanide at concentrations higher than background levels include active and passive tobacco smokers (EPA 1981e) and individuals who are exposed to house fires or other types of building fires (Andrews et al. 1989; Bolstad-Johnson 2000). Subpopulations with potential for exposure to cyanides or thiocyanates are residents who live near industrial sites releasing these compounds to the environment, residents who live near cyanide- or thiocyanate-containing hazardous waste sites, and people who consume foods high in cyanogenic glycosides. Fetuses of smoking mothers or mothers exposed to high levels of environmental smoke may also be at risk of exposure to relatively high concentrations of cyanide and thiocyanate (Bottoms et al. 1982; EPA 1992f; Hauth et al. 1984). For example, mean thiocyanate concentrations of 88.6 and 32.0 μg/L have been measured in fetal blood of mothers who smoked or were exposed to passive smoke, as compared to a mean thiocyanate concentration of 24.3 μg/L in unexposed mothers (Bottoms et al. 1982).

Occupational exposures to cyanide occur primarily through inhalation and, less frequently, through dermal absorption. Estimates from the National Occupational Exposure Survey (NOES) conducted by the National Institute for Occupational Safety and Health (NIOSH) indicate that over 250,000 workers are potentially exposed to cyanide compounds, including cyanogen chloride (NIOSH 1989a). Workers may be exposed to cyanides in various occupations, including electroplating, metallurgy, pesticide application, firefighting, steel manufacturing, gas works operations, and metal cleaning (EPA 1981e; WHO 2004b). The manufacture of industrial inorganic chemicals may be a potential source of occupational exposure to cyanogen chloride (NIOSH 1989a). Potential sources of occupational exposure to ammonium thiocyanate include the manufacture of electronic computing equipment, research and development laboratories, newspaper and other commercial printing, general medical and surgical hospitals, production of adhesives and sealants, and the construction and furniture industries (NIOSH 1989a). Potential occupational exposures may also occur during the direct application of herbicidal formulations (e.g., amitrol-T, a mixture of ammonium thiocyanate and amino-1,2,4-triazole) and from handling, treatment, or disposal of thiocyanate-containing wastes from industrial processes (Brown and Morra 1993).

## 6.2 RELEASES TO THE ENVIRONMENT

The Toxics Release Inventory (TRI) data should be used with caution because only certain types of facilities are required to report (EPA 2005b). This is not an exhaustive list. Manufacturing and processing facilities are required to report information to the TRI only if they employ 10 or more full-time employees; if their facility is included in Standard Industrial Classification (SIC) Codes 10 (except 1011, 1081, and 1094), 12 (except 1241), 20–39, 4911 (limited to facilities that combust coal and/or oil for the purpose of generating electricity for distribution in commerce), 4931 (limited to facilities that combust coal and/or oil for the purpose of generating electricity for distribution in commerce), 4939 (limited to facilities that combust coal and/or oil for the purpose of generating electricity for distribution in commerce), 4953 (limited to facilities regulated under RCRA Subtitle C, 42 U.S.C. section 6921 et seq.), 5169, 5171, and 7389 (limited S.C. section 6921 et seq.), 5169, 5171, and 7389 (limited to facilities primarily engaged in solvents recovery services on a contract or fee basis); and if their facility produces, imports, or processes ≥25,000 pounds of any TRI chemical or otherwise uses >10,000 pounds of a TRI chemical in a calendar year (EPA 2005b).

### 6.2.1 Air

Cyanide emissions into the air have been conservatively estimated at 44 million pounds/year based on data obtained during the mid-to-late 1970s. Over 90% of these emissions were attributed to releases from automobile exhaust. The second largest source of cyanide emission to the air was reported to be from the manufacture of methyl methacrylate, acrylonitrile, and hydrogen cyanide (EPA 1981e). From data acquired from the California Air Resources Board (ARB), it is estimated that 1.2 million pounds of hydrogen cyanide were released into air from industrial sources (CEPA 1997). Other smaller sources of cyanide release include emissions from iron and steel production, coal combustion (EPA 1981e), petroleum refineries (EPA 1981e), oil shale retorting processes (Hargis et al. 1986; Sklarew and Hayes 1984), municipal solid waste incinerators (Carotti and Kaiser 1972; Greim 1990), the combustion of acrylonitriles or other nitrogen-containing plastics (Brandt-Rauf et al. 1988; EPA 1981e), cigarette smoke (Baker and Proctor 1990; EPA 1981e; Guerin et al. 1987), volatilization from cyanide waste disposed of in landfills, and direct release to the atmosphere from certain agricultural pest control activities (EPA 1981e). In 1976, an estimated 137,000 pounds of cyanide was released in the air from agricultural pest control, 18,000–180,000 pounds from incineration, and 13,000–750,000 pounds from cigarette smoke (EPA 1981e). The production of coke or other coal carbonization processes also release hydrogen cyanide into the atmosphere (Cicerone and Zellner 1983). Release of hydrogen cyanide from cyanidation processes used in the extraction of precious metals from their ores was estimated to be 22 tons/year in the United States in 1992, or 20,000 tons worldwide (Korte and Coulston 1995). Hydrogen cyanide is also released into the atmosphere from natural biogenic processes from higher plants, bacteria, and fungi (Cicerone and Zellner 1983; Crutzen and Carmichael 1993; EPA 1981e; Knowles 1988; Mudder and Botz 2000; WHO 2004b). However, an estimate of the amount of hydrogen cyanide released from natural biogenic sources is not available (Cicerone and Zellner 1983; WHO 2004b). Crutzen and Carmichael (1993) have recently suggested that biomass burning represents an important source of atmospheric hydrogen cyanide. The combined worldwide emissions of hydrogen cyanide and acetonitrile due to biomass burning have been estimated to range from 0.5 to 1.7x10^12^ g of N/year (≈1.1–3.7 billion pounds per year) (Crutzen and Andreae 1990). These estimates were based in part on highly uncertain global estimates of worldwide amounts of burned fuel and area and, consequently, have a high degree of uncertainty. Lobert and Warnatz (1993) have estimated that low molecular weight nitriles, primarily hydrogen cyanide and acetonitrile, represent about 4% of the nitrogen balance of biomass fires and contribute a major amount to their global atmospheric source.

The amount of hydrogen cyanide released to the atmosphere in 2003 by U.S. industrial facilities sorted by state is given in Table 6-1 (TRI03 2005). According to TRI03 (2005), an estimated total of 1.14 million pounds (approximately 517 metric tons) of hydrogen cyanide was discharged into air, amounting to approximately 42.2% of the total amount of hydrogen cyanide released into the environment from manufacturing and processing facilities in the United States in 2003. The release of cyanide compounds (as X^+^CN^−^, where X^+^=H^+^ or any group where formal dissociation can occur; for example, KCN or Ca(CN)_2_) into air by U.S. industrial facilities is given in Table 6-2 and sorted by state (TRI03 2005). According to the data given in Table 6-2, it is estimated that 0.313 million pounds (approximately 142 metric tons) of cyanide compounds were released into air in 2003, which amounts to approximately 4.97% of the total environmental release. The TRI data should be used with caution since only certain types of facilities are required to report. This is not an exhaustive list. No information is available in the TRI database for other cyanide and thiocyanate compounds in this profile because these compounds are not included under SARA, Title III, and therefore, are not among the chemicals that facilities are required to report (EPA 1993g, 2001).

### 6.2.2 Water

There are numerous sources that release cyanide into water. Cyanide is released into water from both point and nonpoint sources. The major point sources of cyanide released to water are discharges from publicly owned treatment works (POTWs), iron and steel production, and organic chemical industries (EPA 1981e). Estimates based on data from the mid-to-late 1970s indicate that these sources account for ≈89% of the estimated 31 million pounds of total cyanide discharged annually to surface waters. Since metal finishing and organic chemical industries are estimated to account for 90% of the influent to POTWs, they are the dominant sources of both direct and indirect discharge of cyanide to water (EPA 1981e). The amount of cyanide released to surface water by U.S. industrial facilities that manufactured or processed cyanide compounds ranged from approximately 0 to 150,000 and 1,100 to 1,090,000 pounds, respectively (TRI88 1990). These data indicate that the industrial discharge of cyanides into surface water and POTWs decreased substantially in 1988 in comparison to the estimated discharge during the 1970s.

Table 6-1 Releases to the Environment from Facilities that Produce, Process, or Use Hydrogen Cyanide^a^

State^c^ | RF^d^ | Reported amounts released in pounds per year^b^
State^c^ | RF^d^ | Air^e^ | Water^f^ | UI^g^ | Land^h^ | Total release
State^c^ | RF^d^ | Air^e^ | Water^f^ | UI^g^ | Land^h^ | On-site^i^ | Off-site^j^ | On- and off-site
AK | 1 | 12,477 | 0 | 0 | 0 | 12,477 | 0 | 12,477
AL | 2 | 5,735 | 0 | 0 | 0 | 5,735 | 0 | 5,735
AR | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0
CA | 6 | 20,719 | 0 | 0 | 0 | 20,719 | 0 | 20,719
CO | 2 | 8,119 | 0 | 0 | 1 | 8,120 | 0 | 8,120
DE | 1 | 7,100 | 960 | 0 | 0 | 8,060 | 0 | 8,060
ID | 1 | 15,000 | 0 | 0 | 0 | 15,000 | 0 | 15,000
IL | 2 | 8,178 | 0 | 0 | 842 | 8,178 | 842 | 9,020
IN | 2 | 2,963 | 0 | 0 | 0 | 2,963 | 0 | 2,963
KY | 1 | 250 | 0 | 0 | 0 | 250 | 0 | 250
LA | 9 | 64,664 | 59 | 0 | 0 | 64,723 | 0 | 64,723
MA | 1 | 4,241 | 0 | 0 | 0 | 4,241 | 0 | 4,241
MI | 1 | 1,155 | 0 | 0 | 0 | 1,155 | 0 | 1,155
MS | 1 | 28,000 | 0 | 0 | 0 | 28,000 | 0 | 28,000
MT | 2 | 720 | 0 | 0 | 510 | 1,230 | 0 | 1,230
NC | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0
NH | 1 | 74 | 0 | 0 | 0 | 74 | 0 | 74
NJ | 1 | 290 | 0 | 0 | 0 | 290 | 0 | 290
NV | 13 | 154,182 | 0 | 0 | 320 | 154,502 | 0 | 154,502
OH | 2 | 20,910 | 0 | 1,219 | 0 | 20,910 | 1,219 | 22,129
OK | 1 | 3,409 | 0 | 0 | 0 | 3,409 | 0 | 3,409
PA | 1 | 5,402 | 0 | 0 | 0 | 5,402 | 0 | 5,402
SC | 3 | 31,005 | 136 | 0 | 0 | 31,141 | 0 | 31,141
TN | 4 | 146,700 | 0 | 0 | 0 | 146,700 | 0 | 146,700
TX | 23 | 531,144 | 452 | 1,554,533 | 573 | 2,086,507 | 195 | 2,086,702
UT | 1 | 26,342 | 0 | 0 | 0 | 26,342 | 0 | 26,342
WA | 1 | 440 | 110 | 0 | 0 | 550 | 0 | 550
WV | 2 | 40,496 | 0 | 0 | 0 | 40,496 | 0 | 40,496
Total | 87 | 1,139,715 | 1,717 | 1,555,752 | 2,246 | 2,697,174 | 2,256 | 2,699,430

a The TRI data should be used with caution since only certain types of facilities are required to report. This is not an exhaustive list. Data are rounded to nearest whole number.

b Data in TRI are maximum amounts released by each facility.

c Post office state abbreviations are used.

d Number of reporting facilities.

e The sum of fugitive and point source releases are included in releases to air by a given facility.

f Surface water discharges, waste water treatment-(metals only), and publicly owned treatment works (POTWs) (metal and metal compounds).

g Class I wells, Class II-V wells, and underground injection.

h Resource Conservation and Recovery Act (RCRA) subtitle C landfills; other on-site landfills, land treatment, surface impoundments, other land disposal, other landfills.

i The sum of all releases of the chemical to air, land, water, and underground injection wells.

j Total amount of chemical transferred off-site, including to POTWs.

RF = reporting facilities; UI = underground injection

Source: TRI03 2005 (Data are from 2003)

Table 6-2 Releases to the Environment from Facilities that Produce, Process, or Use Cyanide Compounds^a^

State^c^ | RF^d^ | Reported amounts released in pounds per year^b^
State^c^ | RF^d^ | Air^e^ | Water^f^ | UI^g^ | Land^h^ | Other^i^ | Total release
State^c^ | RF^d^ | Air^e^ | Water^f^ | UI^g^ | Land^h^ | Other^i^ | On-site^j^ | Off-site^k^ | On- and off-site
AK | 4 | 0 | 0 | 0 | 540,718 | 0 | 540,718 | 0 | 540,718
AL | 6 | 930 | 1,569 | 65 | 23,000 | 0 | 25,499 | 65 | 25,564
AR | 3 | 746 | 0 | 0 | 21,955 | 0 | 22,701 | 0 | 22,701
AZ | 3 | 20 | 0 | 0 | 0 | 119 | 20 | 119 | 139
CA | 15 | 1,288 | 533 | 560 | 16,501 | 11 | 1,821 | 17,072 | 18,893
CO | 1 | 10 | 0 | 0 | 3 | 0 | 13 | 0 | 13
CT | 6 | 945 | 149 | 0 | 0 | 297 | 1,094 | 297 | 1,391
DE | 1 | 7,100 | 960 | 0 | 0 | 0 | 8,060 | 0 | 8,060
FL | 4 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
GA | 4 | 36 | 9 | 0 | 261 | 0 | 45 | 261 | 306
IA | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
ID | 1 | 255 | 5 | 0 | 0 | 0 | 260 | 0 | 260
IL | 28 | 5,521 | 422 | 0 | 35 | 3,587 | 5,944 | 3,621 | 9,565
IN | 14 | 6,442 | 13,585 | 39,006 | 430,760 | 0 | 489,787 | 6 | 489,793
KY | 7 | 1,189 | 337 | 0 | 5 | 0 | 1,526 | 5 | 1,531
LA | 3 | 4 | 65 | 605,383 | 4 | 0 | 605,456 | 0 | 605,456
MA | 4 | 255 | 0 | 0 | 18 | 355 | 255 | 373 | 628
MD | 1 | 168 | 0 | 0 | 0 | 0 | 168 | 0 | 168
ME | 2 | 736 | 0 | 0 | 0 | 0 | 736 | 0 | 736
MI | 15 | 3,189 | 6 | 11,953 | 12,667 | 1,325 | 25,398 | 3,742 | 29,140
MN | 5 | 1,841 | 0 | 0 | 0 | 0 | 1,841 | 0 | 1,841
MO | 5 | 487 | 5 | 0 | 5 | 0 | 497 | 0 | 497
MS | 2 | 28,000 | 0 | 0 | 0 | 0 | 28,000 | 0 | 28,000
MT | 2 | 0 | 0 | 0 | 71,000 | 0 | 71,000 | 0 | 71,000
NC | 3 | 250 | 0 | 0 | 0 | 250 | 250 | 250 | 500
NH | 1 | 0 | 47 | 0 | 0 | 0 | 47 | 0 | 47
NJ | 5 | 11,922 | 1,312 | 0 | 20,400 | 4 | 14,220 | 19,418 | 33,638
NV | 21 | 37,473 | 0 | 0 | 1,416,272 | 1,025 | 1,453,745 | 1,025 | 1,454,770
NY | 10 | 2,475 | 270 | 0 | 0 | 0 | 2,745 | 0 | 2,745
OH | 22 | 14,709 | 168 | 450,025 | 1,133 | 26,900 | 464,877 | 28,058 | 492,936
OK | 2 | 500 | 5 | 0 | 5 | 250 | 510 | 250 | 760
OR | 3 | 162 | 5 | 0 | 150 | 0 | 167 | 150 | 317
PA | 8 | 80,089 | 17,519 | 0 | 4,350 | 0 | 97,608 | 4,350 | 101,958
PR | 1 | 250 | 0 | 0 | 0 | 0 | 250 | 0 | 250
RI | 6 | 250 | 250 | 0 | 0 | 746 | 500 | 746 | 1,246
SC | 4 | 512 | 0 | 0 | 0 | 7,938 | 512 | 7,938 | 8,450
SD | 2 | 255 | 500 | 0 | 500 | 0 | 1,005 | 250 | 1,255
TN | 7 | 2,091 | 1,135 | 0 | 15 | 0 | 3,226 | 15 | 3,241
TX | 18 | 80,533 | 1,725 | 1,829,872 | 936 | 0 | 1,912,143 | 923 | 1,913,066
UT | 4 | 16,304 | 1,300 | 0 | 177,278 | 117 | 194,882 | 117 | 194,999
VA | 3 | 232 | 190 | 0 | 0 | 8 | 422 | 8 | 430
WA | 3 | 892 | 110 | 0 | 281 | 0 | 1,283 | 0 | 1,283
WI | 6 | 272 | 0 | 0 | 0 | 0 | 272 | 0 | 272
WV | 2 | 5,120 | 9,061 | 0 | 221,163 | 0 | 14,181 | 221,163 | 235,344
Total | 268 | 313,453 | 51,243 | 2,936,864 | 2,959,415 | 42,931 | 5,993,686 | 310,222 | 6,303,907

a The TRI data should be used with caution since only certain types of facilities are required to report. This is not an exhaustive list. Data are rounded to nearest whole number.

b Data in TRI are maximum amounts released by each facility.

c Post office state abbreviations are used.

d Number of reporting facilities.

e The sum of fugitive and point source releases are included in releases to air by a given facility.

f Surface water discharges, waste water treatment-(metals only), and publicly owned treatment works (POTWs) (metal and metal compounds).

g Class I wells, Class II-V wells, and underground injection.

h Resource Conservation and Recovery Act (RCRA) subtitle C landfills; other on-site landfills, land treatment, surface impoundments, other land disposal, other landfills.

i Storage only, solidification/stabilization (metals only), other off-site management, transfers to waste broker for disposal, unknown

j The sum of all releases of the chemical to air, land, water, and underground injection wells.

k Total amount of chemical transferred off-site, including to POTWs.

RF = reporting facilities; UI = underground injection

Source: TRI03 2005 (Data are from 2003)

The amount of hydrogen cyanide and cyanide compounds released to surface water in 2003 by U.S. industrial facilities sorted by state is shown in Tables 6-1 and 6-2 (TRI03 2005). According to TRI03 (2005), estimated totals of 1,717 and 51,200 pounds of hydrogen cyanide and cyanide compounds, respectively, were discharged to surface water in 2003. These releases amount to approximately 0.064 and 0.81% of the total environmental release of hydrogen cyanide and cyanide compounds, respectively. Hydrogen cyanide and cyanide compounds were also released through underground injection wells at estimated totals of 1,560,000 and 2,940,000 pounds, respectively. These releases amount to 57.7 and 46.6% of the total environmental release of hydrogen cyanide and cyanide compounds, respectively. The TRI data should be used with caution since only certain facilities are required to report. This is not an exhaustive list. No information is available in the TRI database for other cyanide and thiocyanate compounds in this profile because these compounds are not included under SARA, Title III, and therefore, are not among the chemicals that facilities are required to report (EPA 1993g, 2001).

The effluents from the cyanidation process used in the extraction of precious metals from their ores may contain high levels of cyanide (Huiatt 1985; Korte and Coulston 1995; Mudder and Botz 2000; Scott 1985). The total cyanide content of typical tailing pond effluents from gold mill tailing ponds has been reported to range from 0.3 to 310 mg/L (EPA 1994c; Scott 1985). Although the contribution from this source to the total discharge of cyanide into the environment has been estimated to be negligible on average (EPA 1981e), large, short-term releases can occur from the failure of tailing ponds, resulting in the introduction of high concentrations of cyanide into local surface waters and subsoils (Fields 2001; Mudder and Botz 2000). Normally, these cyanide wastes undergo decontamination through the conversion of cyanide to the less toxic cyanate in a chemical oxidation methods commonly referred to as alkaline chlorination. In the method, the cyanide wastes are treated with sodium hydroxide or sodium hypochlorite. Alkaline chlorination is the most widely used commercial method for treating cyanide-containing wastes. Depending on the cyanides present, the product will be a sludge or solution, which, when sufficient reaction time has been allowed, will, in time, largely be devoid of free cyanide (IRPTC 1985). Leachates from solid waste disposal sites are point sources of cyanide release to groundwater (Myers 1983; Venkataramani et al. 1984). No quantitative estimate of the amount of cyanide entering the groundwater from this point source was located. The nonpoint sources of cyanide released to water are comprised of agricultural and road runoff and atmospheric fallout and washout. The predominant sources of cyanides found in urban runoff samples were reported to be products of gasoline combustion and anticaking ingredients in road salts (Cole et al. 1984). It has been estimated that a maximum of ≈2 million pounds of sodium ferrocyanide, which is used as an anticaking agent in road salts during the winter in the northeastern United States, are washed off from roads into streams and storm sewers (EPA 1981e; Gaffney et al. 1987).

Thiocyanate is released to water primarily from discharges of industrial waste waters from coal processing and extraction of gold and silver (Boucabeille et al. 1994a). Thiocyanate is also found in mining waste waters where it results from the reaction of the cyanide anion (CN^−^) with sulphur (Boucabeille et al. 1994b). Thiocyanate has been detected in surface water samples at one of eight hazardous waste sites, and in groundwater samples at five of eight hazardous waste sites where thiocyanate has been detected in some environmental medium (HazDat 2005). The HazDat information used includes data from both NPL and other Superfund sites.

### 6.2.3 Soil

Estimates of amounts of cyanide released to soil from anthropogenic sources are limited. The largest anthropogenic sources of cyanide releases to soil probably result from the disposal of cyanide wastes in landfills and the use of cyanide-containing road salts (EPA 1981e; Gaffney et al. 1987). In 77 of 124 hazardous waste sites in the United States, the median cyanide concentration in subsoil samples was 0.8 mg/kg (HazDat 2005; WHO 2004b). In the same study, topsoil samples taken from 51 of 91 had median cyanide concentrations of 0.4 mg/kg. In the soils of former manufactured gas plant sites, the concentrations of cyanide compounds in the United States are below 2,000 mg/kg (Shifrin et al. 1996; WHO 2004b). The cyanides in these soils are predominately (97%) in the form of ferrocyanides.

The amount of hydrogen cyanide and cyanide compounds released to land in 2003 by U.S. industrial facilities sorted by state is shown in Tables 6-1 and 6-2 (TRI03 2005). According to TRI03 (2005), an estimated total of only 2,250 pounds of hydrogen cyanide was discharged to land from U.S. manufacturing or processing facilities in 2003. Conversely, an estimated 2.96 million pounds of cyanide compounds were discharged to land in 2003, which amounts to 46.9% of the total release to the environment. An estimated 2,260 and 310,000 pounds of hydrogen cyanide and cyanide compound wastes were transferred off-site (see Tables 6-1 and 6-2) and may be ultimately disposed of on land. The TRI data should be used with caution since only certain facilities are required to report. This is not an exhaustive list. No information is available in the TRI database for other cyanide and thiocyanate compounds in this profile because these compounds are not included under SARA, Title III, and therefore, are not among the chemicals that facilities are required to report (EPA 1993g, 2001).

Natural biogenic processes of bacteria, fungi, and cyanogenic plants such as sorghum, soybeans, and cassava, also release cyanide into the soil (EPA 1978c; Knowles 1988; WHO 1992, 2004).

Releases of thiocyanate to soil result from anthropogenic and natural sources. Anthropogenic releases occur primarily from direct application in herbicidal formulations (e.g., amitrol-T, a mixture of ammonium thiocyanate and amino-1,2,4-triazole) and from disposal as byproducts from industrial processes. Nonanthropogenic sources include damaged or decaying tissues of plants from the family Brassica (e.g., mustard, rape) (Brown and Morra 1993).

## 6.3 ENVIRONMENTAL FATE

### 6.3.1 Transport and Partitioning

Because hydrogen cyanide is a gas and has a relatively slow degradation rate in air (see Section 6.3.2), the atmosphere will be the ultimate sink for this compound. Almost all of the hydrogen cyanide released to the atmosphere remains in the lower altitudes (troposphere); only 2% of tropospheric hydrogen cyanide is transferred to the stratosphere (Cicerone and Zellner 1983). Cyanide has the potential to be transported over long distances from its emission source. Despite higher water solubility at saturated pressure, the removal of hydrogen cyanide by rainwater appears to be a negligible partitioning pathway (Cicerone and Zellner 1983). Because hydrogen cyanide is a gas, its removal from air by dry deposition is also likely to be negligible. However, metal cyanide particles, particularly water-soluble cyanide particles, are expected to be removed from the air by both wet and dry deposition.

Volatilization and sorption are the two physical processes that contribute to the loss of cyanide from water. At pH <9.2, most of the free cyanide in solution should exist as hydrogen cyanide, a volatile cyanide form (EPA 1978c). On the basis of Henry’s law constant (see Table 4-2) and the volatility characteristics associated with various ranges of Henry’s law constant (Thomas 1982), volatilization is a significant and probably dominant fate process for hydrogen cyanide in surface water (EPA 1992f). The most common alkali metal cyanides (e.g., sodium and potassium cyanide) may also be lost from surface water primarily through volatilization; whereas, the sparingly soluble metal cyanides such as copper (I) cyanide are removed from water predominantly by sedimentation and biodegradation (see Section 6.3.2.2) (EPA 1992f). Variations in the volatilization rate are expected because this process is affected by several parameters including temperature, pH, wind speed, and cyanide concentration (EPA 1979). EPA (1979) summarized the unpublished results of a laboratory study that indicated that the volatilization half-life of hydrogen cyanide from solutions at concentrations of 25–200 μg/L ranged from 22 to 110 hours. First-order kinetics were observed. In outdoor experiments with moderate winds, the rate of hydrogen cyanide loss increased by a factor of 2–2.5. In a study to evaluate the effect of cyanide on biochemical oxidation, there was a 50% loss of 6 ppm (mg/L) cyanide in river water kept in open biochemical oxygen demand bottles (without aeration) at pH 7.4 within ≈10 days (Ludzack et al. 1951). When the bottles were aerated (rate of aeration not given), 50% loss occurred in only ≈10 hours. The kinetics of the rate of loss due to volatilization were not rigorously investigated. The volatilization rate was pH-dependent, with the rate faster at a lower pH. Data indicated that cyanide volatilization is a more important fate process than cyanide loss due to chemical and biodegradation reactions (see Section 6.3.2.2) (Ludzack et al. 1951; Raef et al. 1977a). Because volatilization is not an important fate process for cyanide in groundwater, cyanide would be expected to persist for considerably longer periods of time in underground aquifers than in surface water.

Cyanides are sorbed by various natural media, including clays (Cruz et al. 1974), biological solids (Raef et al. 1977b), and sediments (EPA. 1979). However, additional data are necessary to assess the significance of cyanide sorption to suspended solids and sediments in water. Hydrogen cyanide and the alkali metal cyanides are not likely to be strongly sorbed onto sediments and suspended solids because of their high water solubilities (see Table 4-2). Soluble metal cyanides may show somewhat stronger sorption than hydrogen cyanide, with the extent of sorption increasing with decreasing pH and increasing iron oxide, clay, and organic material contents of sediment and suspended solids (EPA 1979). However, sorption is probably insignificant even for metal cyanides when compared to volatilization and biodegradation (EPA 1979, 1992f).

There are no data available to indicate that simple metal cyanides and hydrogen cyanide bioconcentrate in aquatic organisms (EPA 1979, 1980a, 1985a, 1992f). Bioconcentration factors (BCFs) of 0.73 and 1.62 can be calculated for hydrogen cyanide, using the equation of Veith et al. (1979) for the BCF of a chemical in whole fish (log BCF, 0.85; log K_ow_, −0.70) and the log K_ow_ values in Table 4-2. Similarly, the calculated BCF for sodium cyanide is 0.47. There is some evidence that certain metal cyanide complexes bioaccumulate in aquatic organisms. Fish from water with soluble silver and copper cyanide complexes were found to have metal cyanides in their tissues at concentrations ranging up to 168 and 304 μg/g, respectively (wet or dry weight not specified) (EPA 1979). It is difficult to evaluate the toxicologic significance of bioaccumulation of metal cyanide complexes because these compounds are much less toxic than soluble hydrogen cyanide, sodium cyanide, or potassium cyanide (EPA 1992f). There is no evidence of biomagnification of cyanides in the food chain (EPA 1978c). Accumulation of cyanide in food webs is not expected, considering the rapid detoxification of cyanide by most species and the lethal effects of large doses of cyanide (EPA 1978c).

Volatilization of hydrogen cyanide would be a significant loss mechanism for cyanides from soil surfaces at a pH <9.2. Cyanides are fairly mobile in soil. Mobility is lowest in soils with low pH and high concentrations of free iron oxides, positively charged particles, and clays (e.g., chlorite, kaolin, gibbsite), and highest in soils with high pH, high concentrations of free CaCO_3_ and negatively charged particles, and low clay content (EPA 1979). Although cyanide has a low soil sorption capability, it is usually not detected in groundwater, probably because of fixation by trace metals through complexation or transformation by soil microorganisms (see Section 6.3.2.3) (EPA 1978c). In soils where cyanide levels are high enough to be toxic to microorganisms (i.e., landfills, spills), this compound may leach into groundwater (EPA 1984a). Also, leaching of cyanide into a shallow aquifer can occur, as demonstrated by the high concentration of cyanide (1,200 μg/L) in groundwater sampled from the Biscayne Aquifer in Dade County, Florida, which lies below a solid waste site (Myers 1983).

No information could be found in the available literature on the transport and partitioning of cyanogen chloride in the environment, or its partitioning coefficients (K_oc_, K_ow_) or Henry’s law constants (see Table 4-2). Like cyanogen, cyanogen chloride is a highly volatile gas (see Table 4-2). Therefore, it would be expected that volatilization from water and soil would be a primary route of environmental partitioning for both cyanogen and cyanogen chloride.

Similarly, little information could be found in the available literature on the environmental transport and partitioning of thiocyanate in the environment. At near ambient temperatures (≈30 °C), it appears that sorption and volatilization are not significant partitioning processes for thiocyanate in soil, with thiocyanate losses due primarily to microbial degradation (see Section 6.3.2.3) (Brown and Morra 1993).

### 6.3.2 Transformation and Degradation

The various cyanide compounds included in this profile undergo a number of different transformation and degradation reactions in the environment as discussed in the following sections. The resulting environmental transformation products within different media are shown in Table 6-3.

#### 6.3.2.1 Air

Most cyanide in the atmosphere exists almost entirely as hydrogen cyanide gas, although small amounts of metal cyanides may be present as particulate matter in the air (EPA 1984a). Hydrogen cyanide is very resistant to photolysis at wavelengths of normal sunlight (EPA 1979). The most important reaction of hydrogen cyanide in air is the reaction with photochemically-generated hydroxyl radicals and subsequent rapid oxidation to carbon monoxide (CO) and nitric oxide (NO); photolysis and reaction with ozone are not important transformation processes, and reaction with singlet oxygen (O ^1^D) is not a significant transformation process except at stratospheric altitudes where singlet oxygen is present in significant concentrations (Cicerone and Zellner 1983). The rate of hydroxyl radical reaction with hydrogen cyanide in the atmosphere depends on the altitude, and the rate of the reaction is at least an order of magnitude faster at lower tropospheric altitudes (0–8 km) than at upper tropospheric altitudes (10–12 km) (Cicerone and Zellner 1983). Based on a reaction rate constant of 3x10^−14^ cm^3^/(molecule-sec) at 25 °C (Fritz et al. 1982) and assuming an average hydroxyl radical concentration of 5x10^5^ molecules/cm^3^, the residence time for the reaction of hydrogen cyanide vapor with hydroxyl radicals in the atmosphere is ≈2 years. This value compares well with the atmospheric residence time derived by Cicerone and Zellner (1983) of approximately 2.5 years, with a range of 1.3–5.0 years, depending on the hydroxyl radical concentrations assumed. Using the equation t_½_ = 0.693τ for converting residence time (τ) to half-life (t_½_) (Lyman 1982) and an estimated atmospheric residence time for hydrogen cyanide of 2–3 years, and assuming first-order kinetics for the reaction of hydrogen cyanide with hydroxyl radicals, an atmospheric half-life of 1.4–2.9 years can be calculated for hydrogen cyanide.

Cyanogen is reactive and does not persist in the environment unchanged (EPA 1978c). Cyanogen reacts slowly with water to yield hydrogen cyanide and cyanic acid (HOCN) among other products (EPA 1979) and this hydrolysis reaction may be a possible atmospheric degradation pathway. Cyanogen has also been shown to react with hydroxyl radicals in the gas phase (Atkinson 1989). Based on a rate constant of 2.5x10^−15^ cm^3^/(molecule-sec) at 27 °C and assuming an average hydroxyl radical concentration of 5x10^5^ molecules/cm^3^, the residence time for the reaction of hydrogen cyanide vapor with hydroxyl radicals in the atmosphere is ≈25 years. Therefore, the reaction of cyanogen with photochemically-induced hydroxyl radicals will not play a significant role in the degradation of this compound in air.

Table 6-3 Environmental Transformation Products of Cyanide Compounds by Medium

Parent compound | Product(s) | Comments | Reference
Air
HCN | HOCN + HO_2_ (unlikely) NO + CHO^−^ (formed in minutes) | HNC-OH intermediate | Cicerone and Zellner 1983
HCN | NO + CHO^−^ (formed in minutes) | HCN-OH intermediate | Cicerone and Zellner 1983
Cyanogen | HCN, cyanic acid (NCOH), and other compounds | In the presence of water; slow reaction | EPA 1979
Water
HCN | NH_4_^+^ + HCOO^−^ in equilibrium with H_2_NCHO + H_2_ | pH dependent (pH <1, t_1/2_=10−1,000 hours) | EPA 1979
HCN | NH_4_^+^ + HCOO^−^ | Alkaline hydrolysis; very slow reaction
CN^−^ | Metal cyanides | In the presence of excess metals; alkali metal cyanides very soluble; alkaline earth metal cyanides not very soluble | EPA 1979, 1992f
CN^−^ | Complex metallocyanides | Excess CN^−^ in the presence of metals; solubilities of metallocyanides vary | EPA 1979, 1992f
CN^−^ | >99% HCN | pH<7 | EPA 1978c
CN^−^ | NH_3_ + CO_2_ (NH_3_ converted to nitrite and nitrate in presence of nitrifying bacteria) | Aerobic biotransformation | Richards and Shieh 1989
CN^−^ | N_2_ + CO_2_ | Anaerobic biotransformation under denitrification conditions | Richards and Shieh 1989
HCN/CN^−^ salts | Thiocyanate (SCN^−^), NH_3_ + CO_2_, CHOO^−^ | Biotransformation | EPA 1978c
Cyanogen | HCN, cyanic acid (NCOh), and other compounds | Slow reaction at pH 7; 5.25 hours at pH 8.5 | EPA 1979; Munro et al. 1999; U.S. Army 1989
Metallocyanides | CN^−^ (possibly) | Photolysis | EPA 1979
Metallocyanides | Isocyanate (OCN^−^) | Oxidation | EPA 1992f
Metallocyanides | CO_2_ + N_2_ | In the presence of strong oxidizing agents | EPA 1992f
SCN^−^ | HCN | In acidic media | EPA 1979
Sediment and Soil
CN^−^ | Metallocomplexes | Abiotic transformation in the presence of metals | EPA 1978c
CN^−^ | NH_3_ + CO_2_ (NH_3_ converted to nitrite and nitrate in presence of nitrifying bacteria) | Aerobic biotransformation (predicted from fate in waste water) | Richards and Shieh 1989
CN^−^ | N_2_ + CO_2_ | Aerobic biotransformation under denitrification conditions (predicted from fate in waste water) | Richards and Shieh 1989
SCN^−^ | COS (possibly; microbial degradation pathway not known) | Microbial degradation | Brown and Morra 1993
Waste water/sludge
CN^−^ | NH_3_ + CO_2_ (NH_3_ converted to nitrite and nitrate in presence of nitrifying bacteria) | Aerobic biotransformation | Richards and Shieh 1989
CN^−^ | N_2_ + CO_2_ | Anaerobic biotransformation under denitrification conditions | Richards and Shieh 1989
CN^−^/metallocyanides (including cuprocyanide) | NH_3_ + CO_2_ | Microbial degradation in mining waste waters | Boucabeille et al. 1994b
SCN^−^ | NH_3_ + CO_2_ + SO_4_^=^ | Microbial degradation in mining waste waters | Boucabeille et al. 1994a
SCN^−^ | COS + NH_3_ | Microbial degradation in activated sludge | Katayama et al. 1993

No specific information was found in the available literature on the transformation and degradation of cyanogen chloride or thiocyanates in air. However, cyanogen chloride has been shown to undergo slow hydrolysis in neutral aqueous solution (rate constant at pH 7 of 6.45x10^−5^ mol^−1^sec^−1^) (U.S. Army 1989). Therefore, hydrolysis of this compound may be a possible atmospheric degradation pathway in air.

#### 6.3.2.2 Water

Cyanide occurs most commonly as hydrogen cyanide in water, although it can also occur as the cyanide ion, alkali and alkaline earth metal cyanides (potassium cyanide, sodium cyanide, calcium cyanide), relatively stable metallocyanide complexes (ferricyanide complex [Fe(CN)_6_]^−3^), moderately stable metallocyanide complexes (complex nickel and copper cyanide), or easily decomposable metallocyanide complexes (zinc cyanide [Zn(CN)_2_], cadmium cyanide [Cd(CN)_2_]). The environmental fate of these cyanide compounds varies widely (EPA 1979).

Oxidation, hydrolysis, and photolysis are the three predominant chemical processes that may cause loss of simple cyanides in aquatic media. Certain cyanides are oxidized to isocyanates by strong oxidizing agents; the isocyanates may be further hydrolyzed to ammonia and carbon dioxide (EPA 1978c). However, it has not yet been determined whether such oxidation and subsequent hydrolysis of isocyanate is a significant fate process in natural waters known to contain peroxy radicals (EPA 1992f).

In water, hydrogen cyanide and cyanide ion exist in equilibrium with their relative concentrations primarily dependent on pH and temperature. At pH <8, >93% of the free cyanide in water will exist as undissociated hydrogen cyanide (EPA 1978c). Hydrogen cyanide can be hydrolyzed to formamide, which is subsequently hydrolyzed to ammonium and formate ions (EPA 1979). However, the relatively slow rates of hydrolysis reported for hydrogen cyanide in acidic solution (Krieble and McNally 1929; Krieble and Peiker 1933) and of cyanides under alkaline conditions (Wiegand and Tremelling 1972) indicate that hydrolysis is not competitive with volatilization and biodegradation for removal of free cyanide from ambient waters (EPA 1979).

The alkali metal cyanides are very soluble in water. As a result, they readily dissociate into their respective anions and cations when released into water. Depending on the pH of the water, the resulting cyanide ion may then form hydrogen cyanide or react with various metals in natural water. The proportion of hydrogen cyanide formed from soluble cyanides increases as the water pH decreases. At pH <7, >99% of the cyanide ions in water are converted to hydrogen cyanide (EPA 1978c). As the pH increases, cyanide ions in the water may form complex metallocyanides in the presence of excess cyanides; however, if metals are prevalent, simple metal cyanides are formed. Unlike water-soluble alkali metal cyanides, insoluble metal cyanides are not expected to degrade to hydrogen cyanide (EPA 1979).

The significance of photolysis in the fate of cyanides in water has not been fully investigated. Hydrogen cyanide and cyanide ions in aqueous solution have been found to be very resistant to photolysis by natural sunlight, except under heterogeneous photocatalytic conditions (EPA 1979; Frank and Bard 1977). Photocatalytic oxidation may not be significant in natural waters, however, because of significant light reduction at increasingly greater depths (EPA 1992f). In clear water or at water surfaces, some metallocyanides, such as ferrocyanides and ferricyanides, may decompose to the cyanide ion by photodissociation and subsequently form hydrogen cyanide. For example, diurnal changes in free cyanide concentrations in the drainage from spent precious metal ore heaps were found to maximize around mid-day due to the photodissociation of iron and cobalt cyanocomplexes (Johnson et al. 2002). Because of adsorption of ferrocyanide onto soil surfaces and sediment of surface waters, and light scattering in turbid waters in the field, the rate of free cyanide formation from the photolysis of ferrocyanide in runoff and surface water from washout of ferrocyanide in de-icing salt will be slower than from laboratory photolysis with clean water (EPA 1979).

Biodegradation is an important transformation process for cyanide in natural surface waters, and is dependent on such factors as cyanide concentrations, pH, temperature, availability of nutrients, and acclimation of microbes. However, additional data are needed to assess the relative significance of this process in determining the fate of aquatic cyanides (EPA 1979). Although the cyanide ion is toxic to microorganisms at concentrations as low as 5–10 mg/L (Klecka et al. 1985; Malaney et al. 1959), acclimation increases tolerance to this compound (Raef et al. 1977a). A number of pure cultures of microorganisms degrade low concentrations of cyanide under both aerobic and anaerobic conditions (EPA 1978c, 1979, 1992f). However, biodegradation data derived from use of a pure culture are not strictly relevant to natural waters that contain mixed cultures. Mixed microorganisms in sewage sludge or activated sludge acclimated to cyanide also significantly biodegrade concentrations ≤100 mg/L of most simple and complex cyanides (Gaudy et al. 1982; Pettet and Mills 1954; Richards and Shieh 1989; Shivaraman et al. 1985). In a study to evaluate the effect of the cyanide ion on biochemical oxidation conducted in sealed vessels, a 50% loss of cyanide at concentrations ≤6 mg/L in two natural river waters occurred at times estimated to range from <10 to 24 days (Ludzack et al. 1951). The rate of loss appeared to be linear within this time frame. These data may represent a biodegradation half-life; however, the possibility of loss by chemical reaction was not addressed in this study.

Most of the available information on the mechanisms of biodegradation of cyanides in water comes from studies on the evaluation and use of this process as a means of detoxicifying cyanide-containing wastes (Akcil and Mudder 2003; EPA 1994c; Raybuck 1992). It is known that there is a natural attentuation of the cyanide ion and thiocyanide concentrations in waste waters, for example those obtained gold mill tails, that is due the acclimation of indigenous microflora in the tailings (Akcil and Mudder 2003; Oudjehani et al. 2002; Zagury et al. 2004). A number of microorganisms have been identified that are capable of uptake, conversion, sorption, and/or precipitation of the cyanide ion, cyanate, and thiocyanate, including species of the genera, Actinomyces, Alcaligenes, Arthrobacter, Bacillus, Micrococcus, Neisseria, Paracoccus, Pseudomonas, and Thiobacillus (Akcil and Mudder 2003). Some of these species, for example Pseudomonas, are capable of using the cyanide ion and thiocyanate as the sole source of carbon and nitrogen and therefore, are particularly effective at cyanide degradation. In fact, Pseudomonas is the basis of commercial applications for degrading the cyanide ion to ammonia and carbonate in waste waters generated in mining operations that use the cyanide ion to leach gold and other precious metals for low-grade ores (Akcil and Mudder 2003).

Raybuck (1992) has recently reviewed the role of microbes in cyanide degradation and has categorized the microbial enzymes that use the cyanide ion as a substrate according to the following types of reactions: substitution/addition, hydrolysis, oxidation, and reduction. Sulfur transferases such as rhodanese are involved in substitution reactions that result in the conversion of the cyanide ion to the less toxic thiocyanate, whereas pyridoxal phosphate enzymes are involved in substitution/addition reactions that result in production of nitrile derivatives of α-amino acids. These organic nitriles may then be ultimately degraded via enzyme catalyzed hydrolysis to either the corresponding amino acid and ammonia (without formation of the free amide) or the carboxylic acid and ammonia (via formation of the free amide). The cyanide hydratase and cyanidase enzymes catalyze the hydrolysis of the cyanide ion to formamide or formic acid and ammonia, respectively. A strain of Alcaligenes xylosoxidans subsp. denitrificans has been found to effectively hydrolyze the cyanide ion concentrations up to 300 mg/L down to very low levels (0.01–0.02 mg/L) and to be resistant to inactivation by chloride, sulfate, iodide, Fe^+2^, Zn^+2^, or Ni^+2^ at concentrations of 70 mg/L (Basheer et al. 1992). Thus, these hydrolytic systems are some of the most promising for detoxification of cyanide-containing waste waters (Raybuck 1992). A number of microbial systems have been identified that are capable of direct oxidation or reduction of the cyanide ion. Bacillus pumulus, Pseudomonas fluorescens, and Pseudomonas paucimobili have all been found to oxidize the cyanide ion to ammonia and carbon dioxide (Meyers et al. 1993). In an aerobic batch bioreactor experiment, Pseudomonas putida was found to significantly degrade 4 mM sodium cyanide (cyanide concentration approximately 100 mg/L) to ammonia and carbon dioxide (Chapatwala et al. 1993). Other evidence indicates that formamide and formate are additional transformation products in microbial oxidation of the cyanide ion by this species, inferring that there may be more than one pathway of cyanide biotransformation involved (Kunz et al. 1992; White et al. 1988). Several bacterial species have been identified that are capable of oxidative degradation of metallocyanides (Silva-Avalos et al. 1990). The cyanide oxygenase system involved in this process offers a new technology for the treatment of metal cyanide wastes (Raybuck 1992).

The ferrocyanide complex is not easily biodegradable (Belly and Goodhue 1976; Pettet and Mills 1954). However, when an aqueous solution of potassium ferrocyanide was seeded with pure culture of Pseudomona aeruginosa, or E. coli, or a mixture of the two bacteria, formation of free cyanide was observed after a delay period of ≈2 days (Cherryholmes et al. 1985). The rate of free cyanide formation, when measured as CN^−^, increased with addition of nutrient in water, and a free cyanide concentration ≤4,000 μg/L was detected at the end of 25 days. It was shown that the free cyanide formation was due to biodegradation and not to either photolysis or hydrolysis. The relevance of this study to the fate of ferrocyanide complexes in natural water or industrial effluents is difficult to assess because ferrocyanide concentrations used in these experiments (3,300 mg/L) are rarely encountered in these media.

Biodegradation is also a significant transformation process for thiocyanates in natural waters; however, additional data are needed to assess the relative importance of this process. Like the cyanide ion, thiocyanate is toxic to microorganisms at high concentrations and acclimated cultures have increased tolerance to this compound (Boucabeille et al. 1994a). Laboratory studies have shown that at concentrations up to at least 1.42 g/L, thiocyanate was completely degraded within 4 days to ammonia and sulfate ion (SO_4_^−2^) by an acclimatized co-culture of two bacteria (Acinetobacter johnsonii and Pseudomonas diminuta) isolated from sludge from an urban sewage treatment plant (Boucabeille et al. 1994a). Thiosulfate ion (S_2_O_3_^−2^) was identified as the intermediate in this degradation pathway.

Several studies document the biodegradation of mixtures of cyanides and thiocyanate in waste waters (e.g., Akcil and Mudder 2003; Boucabeille et al. 1994b; EPA 1994c; Mudder and Whitlock 1984; Paruchuri et al. 1990; Shivaraman et al. 1985). Under aerobic conditions, the biodegradation of the cyanide ion and thiocyanate initially produces ammonia, which is converted to nitrite and nitrate in the presence of nitrifying bacteria, whereas anaerobic biodegradation under denitrification conditions may produce nitrogen (Richards and Shieh 1989). Complete biodegradation of simple and metal complexed cyanides and thiocyanate from mining waste waters by various bacteria belonging to the families Pseudomonadaceae, Vibrioniaceae, and Enterobacteriaceae has recently been reported (Boucabeille et al. 1994b). Biodegradation of cyanide and thiocyanate resulted in the formation of ammonia, with or without accumulation of nitrite and/or nitrate, depending on whether a batch, fed-batch, or continuous treatment process was used. Sulphate ions were produced from thiocyanate degradation. Shivaraman et al. (1985) reported the uninhibited microbial degradation of thiocyanate and the cyanide ion to ammonia by acclimatized mixed cultures at cyanide concentrations up to 22.40±1.34 mg/L, whereas Paruchuri et al. (1990) have reported the complete inhibition of microbial degradation of thiocyanate in the presence of 10 mg/L cyanide ion.

Cyanogen reacts slowly with water to produce hydrogen cyanide, cyanic acid, and other compounds (EPA 1979). Cyanogen chloride also hydrolyzes slowly to cyanic acid and hydrochloric acid in water at pH 7, with a rate constant of 6.45x10^−5^ mol^−1^sec^−1^ (U.S. Army 1989). Hydrolysis of cyanogen chloride is more rapid under acidic and basic conditions, with rate constants of 2x10^−2^ and 6–8x10^2^ mol^−1^sec^−1^ (pH 10), respectively (U.S. Army 1989). The half-life of cyanogen chloride at neutral pH ranges between 1 minute at 45 °C and 10 hours at 5 °C (Opresko et al. 1998). However, volatilization would be expected to be the predominant fate process for both cyanogen chloride and cyanogen in water and, therefore, these compounds are not expected to persist in water.

#### 6.3.2.3 Sediment and Soil

Analogous to the fate of cyanides in water, it is predicted that the fate of cyanides in soil would be dependent on cyanide concentrations, pH, temperature, metal content, concentration of microbes, availability of nutrients, and acclimation of microbes. Cyanide may occur as hydrogen cyanide, alkali metal salts, or as immobile metallocyanide complexes. In soil, cyanide present at low concentrations would biodegrade under aerobic conditions with the initial formation of ammonia, which would be converted to nitrite and nitrate in the presence of nitrifying bacteria. Under anaerobic conditions, the cyanides ion will denitrify to gaseous nitrogen (Richards and Shieh 1989). Upper limits of 200 and 2 ppm (mg/kg CN^−^), respectively, have been reported for uninhibited aerobic and anaerobic biodegradation of cyanide in soil (Fueller 1985); however, these limits have not been confirmed in other studies (Thomas and Lester 1993). Cyanide ions in soil are not involved in oxidation-reduction reactions but may undergo complexation reactions with metal ions in soil (EPA 1978c).

No information could be found in the available literature on the transformation of cyanogen or cyanogen chloride in soil or sediment. However, because these compounds are highly volatile gases they are not expected to persist in soils. Additionally, biotic or abiotic degradation would not be expected to be significant fate processes compared to volatilization.

Although the fate of thiocyanate in soil is largely uncharacterized, there is evidence to suggest that thiocyanate is not persistent in soils. Early studies have shown that thiocyanate can undergo both aerobic (Betts et al. 1979) and anaerobic microbial degradation (Betts et al. 1979; Stafford and Callely 1969; Youatt 1954); however, the degradation pathway has not been defined (Brown and Morra 1993). Saturated soils treated with thiocyanate were found to emit carbonyl sulfide (COS) (Minami 1982; Minami and Fukushi 1981). Katayama et al. (1992, 1993) have reported the formation of carbonyl sulfide from the biodegradation of thiocyanate by pure and mixed cultures of Thiobacillus thioparus. These species are ubiquitous in soil (Kelly and Harrison 1989). In a recent laboratory investigation of the fate of ionic thiocyanate in six different soils, Brown and Morra (1993) concluded that microbial degradation is the primary mechanism for thiocyanate disappearance at or below 30 °C, with carbonyl sulfide proposed as a possible hydrolysis product. Loss of thiocyanate at higher temperatures (50–60 °C) did not appear to result from microbial degradation; the observed decreases in thiocyanate concentrations of soil extracts with incubation time at elevated temperatures were postulated to result primarily from increased sorption or increased sorption kinetics, but abiotic catalysis of thiocyanate degradation was also noted as a possible cause.

## 6.4 LEVELS MONITORED OR ESTIMATED IN THE ENVIRONMENT

Reliable evaluation of the potential for human exposure to cyanide depends in part on the reliability of supporting analytical data from environmental samples and biological specimens. Concentrations of cyanide in unpolluted atmospheres and in pristine surface waters are often so low as to be near the limits of current analytical methods. Where levels have been measured in the environment, the values reported for cyanide and thiocyanate must be interpreted with caution. Methods for the analysis of cyanide and thiocyanate have many interferences (EPA 1978d, 1980e, 1996). In addition, samples containing cyanide and/or thiocyanate may not be stable if the samples are not carefully preserved (EPA 1978d, 1980e, 1996; Keith 1991; WHO 2004b). In reviewing data on cyanide levels monitored or estimated in the environment, it should also be noted that the amount of chemical identified analytically is not necessarily equivalent to the amount that is bioavailable (Oudjehani et al. 2002; Zagury et al. 2004). The analytical methods available for monitoring cyanide in a variety of environmental media are detailed in Chapter 7.

### 6.4.1 Air

The concentration of hydrogen cyanide in the northern hemisphere’s non-urban troposphere ranges from 160 to 166 ppt (Cicerone and Zellner 1983; Jaramillo et al. 1989). Although ambient monitoring data regarding cyanide in air near source areas (e.g., hydrogen cyanide manufacturing industries, coke production industries, waste disposal sites) were not located in the available literature, the hydrogen cyanide concentration in the vicinity of the source areas would be expected to be higher than the non-urban tropospheric concentration. The semiquantitatively measured hydrogen cyanide concentrations in the offgas from shale oil retorting processes ranged from 6 to 39 ppm in one retort at one site; however, hydrogen cyanide was not detected in retorts at another site (Sklarew and Hayes 1984).

Cyanides (reported as cyanide, hydrogen cyanide, sodium cyanide, potassium cyanide, calcium cyanide, or copper(I) cyanide) have been detected at concentrations (measured as cyanide) between 0.00797 and 0.032 mg/m^3^ in 6 air samples collected at 5 of 464 hazardous waste sites where cyanides have been detected in some environmental medium (HazDat 2005). The HazDat information used includes data from both NPL and other Superfund sites. No information was found on the detection of cyanogen, cyanogen chloride, or thiocyanates in air at any NPL or other Superfund hazardous waste sites (HazDat 2005). No information could be found in the available literature on the concentrations of cyanogen, cyanogen chloride, or thiocyanates in air at other locations in the United States.

### 6.4.2 Water

Cyanide has been detected in waste waters from plating industries at concentrations up to 100 g/L (Chen et al. 1994; Grosse 1986); from a textile industry at a maximum concentration of 0.2 mg/L (Rawlings and Samfield 1979); in the primary and secondary effluents from a Los Angeles City waste water treatment plant at mean concentrations of 29±4 and 10±6 μg/L (0.03 and 0.01 mg/L), respectively (Young 1978); and in the final effluent from a Los Angeles County waste water treatment plant at a mean concentration of 240 μg/L (0.24 mg/L) (Young 1978). Waste waters from a mining site storage basin were found to contain cyanide at concentrations of >10 mg/L as simple cyanides; 20–80 mg/L as combined simple cyanides and copper(I) cyanide; 20–190 mg/L as combined simple cyanides, copper(I) cyanide, and ferrocyanide; and 300–450 mg/L as thiocyanate (Boucabeille et al. 1994b). Waste waters from gold mines have been reported to contain total cyanide and thiocyanate concentrations ranging from 0.5 to 10 mg/L and from 45 to 75 mg/L, respectively (Mudder and Whitlock 1984). Weak acid dissociable (WAD) cyanide was measured in tailing ponds at several Nevada gold mines in 1990; the concentrations ranged from 8.4 to 216 mg/L at the discharge pipe and from 7.8 to 11.3 mg/L at the reclaim area (Henny et al. 1994). In New York State alone, 47 industries discharged 3,877 pounds of cyanide into streams in 1982 (Rohmann et al. 1985). Cyanide has also been found in groundwater below landfills and disposal sites (Agency for Toxic Substances and Disease Registry 1989a; Myers 1983; Venkataramani et al. 1984). A maximum cyanide concentration of 1,200 μg/L (1.2 mg/L) was found in shallow groundwater ≤3 meters below an inactive drum recycling facility in Miami, Florida (Myers 1983). In another example, a maximum cyanide concentration of 52,000 μg/L (52 mg/L) in shallow groundwater (≈3 meters) was measured below an inactive detinning plant near Tampa, Florida (Agency for Toxic Substances and Disease Registry 1998). Cyanide concentrations were found to range from 0.005 to 14.0 mg/L in the leachates from 14 of 43 U.S. landfills with industrial wastes; the “typical” cyanide concentration was reported to be 0.008 mg/L (Venkataramani et al. 1984). Data from the Nationwide Urban Runoff Program as of 1982 indicate that cyanide was found in urban runoff samples collected in 4 of 15 urban areas across the United States: Denver, Colorado; Long Island, New York; Austin Texas; and Bellevue, Washington. Overall, cyanide was detected in 16% of the urban runoff samples collected, at concentrations ranging from 2 to 33 μg/L (Cole et al. 1984).

Cyanide concentrations in run-off obtained from an area that had been burned in a 2000 wildfire that occurred in Tennessee and North Carolina near the Smokey Mountains National Park averaged 49 μg/L (Barber et al. 2003). This is equal to the LC_50_ for cyanide in rainbow trout and is more than an order magnitude greater than the cyanide concentration measured in run-off obtained from unburned areas surrounding the wildfire site. Higher cyanide concentrations were reported in run-off from the Cerro Grande fire that occurred near Los Alamos, New Mexico in 2000 with an average value of 80 μg/L.

Based on data obtained from the EPA STORET database, the mean cyanide concentration in 61% of surface waters tested in the United States is ≤3.5 μg/L and 35 % of surface waters contained cyanide (as CN^−^) at concentrations of 3.5–52 μg/L (EPA 1981e). The data also show that 37 of 50 states (74%) have locales where cyanide concentrations in ambient water are >3.5 μg/L. Areas with levels >200 μg/L include portions of southern California, North Dakota, South Dakota, Iowa, northwest Georgia, western New York, and western Pennsylvania (EPA 1981e). It should be noted that these results are applicable only to the period from the late 1970s to the early 1980s. Furthermore, the reliability of some of these early STORET data may be questionable. Analyses of more recent STORET cyanide data could not be found. Cyanide at a concentration >1 μg/L was detected in water from the Great Lakes (Great Lakes Water Quality Board 1983). The concentration of cyanide in 104 samples collected during 1980 and 1981 at various points on the Ohio River and its tributaries was reported to range from <5 to 80 μg/L (Ohio River Valley Sanitation Commission 1982). The highest concentration was detected in water from Beaver Falls, Pennsylvania.

A survey of 969 water supply systems in the United States in 1970 found the concentration of cyanide to be at or below 0.008 mg/L (EPA 1981e). In 1975, a survey of interstate water supply systems found that in 21 of 297 analyses (7.1%), the concentration of cyanide exceeded the maximum concentration limit (MCL) of 0.2 mg/L (EPA 1981e). In more recent data from the EPA taken from 1993–1998, only 0.2% of public water systems using groundwater exceeded the MCL of 0.2 mg/L (EPA 1999). For public water systems using surface water, there were no reported cyanide concentrations in excess of the MCL. In a nationwide survey of Canadian water supplies, it was found that in 70 cities, the concentration of cyanide was <0.001 mg/L, whereas water samples taken from two cities had a cyanide concentration of 0.011 mg/L (Meranger and Lo 1992).

Cyanides (reported as cyanide, hydrogen cyanide, sodium cyanide, potassium cyanide, calcium cyanide, or copper(I) cyanide) have been detected in surface water samples at 243 of 464 hazardous waste sites (HazDat 2005). Cyanide concentrations in 70 surface water (lake, streams, ponds, etc.) samples ranged between 0.0012 and 120 mg/L with mean and median values of 2.67 and 0.0385 mg/L, respectively. Cyanides have also been detected in groundwater samples at 120 of the 464 hazardous waste sites. Cyanide concentrations in 19 groundwater samples taken from private and public wells ranged between 0.00002 and 300 mg/L with mean and median values of 16.0 and 0.0292 mg/L, respectively (HazDat 2005). Cyanides have also been identified in leachate samples at 43 of 406 hazardous waste sites at concentrations ranging from 0.0017 to 400 mg/L (HazDat 1996). The HazDat information used includes data from both NPL and other Superfund sites.

Cyanogen chloride is formed in drinking water from the reaction of humic substances with chloramine used during chlorination (Jacangelo et al. 1989; Ohya and Kanno 1987). In a mid-1970s EPA survey, cyanogen chloride was detected in drinking water from 8 of 10 U.S. cities (Fielding and Packham 1977). No information could be found in the available literature on the release of cyanogen to water. No information was found on detections of cyanogen or cyanogen chloride in surface water or groundwater at any NPL or other Superfund hazardous waste sites (HazDat 2005).

Cyanogen chloride is formed in drinking water due to reaction of humic substances with chloramine formed during chlorination (Ohya and Kanno 1987). It has been reported that the concentration of cyanogen chloride in drinking water is most influenced by the final disinfectant. The use of chloramine as a final disinfectant produces levels of cyanogen chloride that are 4–15 times higher than levels produced when chlorine is used (Jacangelo et al. 1989; Krasner et al. 1989). Cyanogen chloride was qualitatively detected during a 1975 survey of Cincinnati, Ohio drinking water (Kopfler et al. 1977). A 10-city survey that was conducted as part of the 1974 EPA National Organics Reconnaissance Survey revealed that cyanogen chloride was present in 8 of 10 drinking water supplies analyzed (no quantitative concentration values given) (Bedding et al. 1982). In a 1988 survey of 35 water utilities, the quarterly median cyanogen chloride concentrations in drinking water ranged from 0.45 to 0.80 μg/L (Krasner et al. 1989).

No information could be found in the available literature on the levels of thiocyanate in ground, surface, or drinking water. Thiocyanate is found in concentrations ranging from 100 to 1,500 mg/L in coal plant waste waters (Ganczarczyk 1979; Jensen and Tuan 1993), and from 300 to 450 mg/L in mining (gold extraction) waste waters (Boucabeille et al. 1994b).

### 6.4.3 Sediment and Soil

Limited information was found in the available literature on concentrations of cyanides in soil or sediments at several hazardous waste sites; however, no information could be found for cyanogen or cyanogen chloride. Maximum total cyanide concentrations in soil, subsoil, and sediments at an inactive detinning plant located near Tampa, Florida, were measured at 1.5, 19, and 0.87 μg/L, respectively (Agency for Toxic Substances and Disease Registry 1998). At the Greenwood Chemical Site in Albemarle, Virginia, a maximum concentration of total cyanides of 2,870 mg/kg soil was measured in 1989 along with a maximum concentration of 84.0 mg/kg in sediments obtained from abandoned waste lagoons (Agency for Toxic Substances and Disease Registry 1999a). The maximum total cyanide concentrations in soil samples taken from the Byron Salvage Yard NPL site and neighboring Dirk Farm waste disposal site were measured at 133 ppm and between 1 and 835 ppm, respectively (Agency for Toxic Substances and Disease Registry 1999b). In general, though, the highly volatile gases hydrogen cyanide, cyanogen, and cyanogen chloride (see Table 4-2) would not be expected to be present in sediment or soil in any appreciable amounts. Also, degradation by microorganisms in soil can convert cyanide to carbon dioxide, ammonia, and other nitrogen compounds that will rapidly volatilize from soils (CEPA 1997).

Cyanides (reported as cyanide, hydrogen cyanide, sodium cyanide, potassium cyanide, calcium cyanide, or copper(I) cyanide) have been detected at 225 of 464 hazardous waste sites (HazDat 2005). Cyanide concentrations in 60 topsoil (<3 inches depth) samples ranged between 0.0022 and 18,000 mg/kg, with mean and median values of 1,017 and 4.02 mg/kg, respectively. Cyanide concentrations in 91 subsurface soil (>3 inches depth) samples ranged between 0.00024 to 32,300 mg/kg, with mean and median values of 813 and 15.4 mg/kg, respectively. Cyanides were also detected at 118 of 464 hazardous waste sites where cyanides have been detected in some environmental medium (HazDat 2005). Cyanide concentrations in 40 sediment samples (lakes, streams, ponds, etc.) ranged between 0.00006 and 30,700 mg/kg, with mean and median values of 777 and 1.15 mg/kg, respectively. The HazDat information used includes data from both NPL and other Superfund sites.

Cyanogen has been detected in soil samples taken from one hazardous waste site at a concentration of 0.063 ppm (HazDat 2005). Measurements of cyanogen chloride in soil samples at two hazardous waste sites have been conducted; however, concentrations of cyanogens chloride were not reported (HazDat 2005). The HazDat information used includes data from both NPL and other Superfund sites. No other information could be found in the available literature on the concentration of cyanogen or cyanogen chloride in soil.

Monitoring data on thiocyanate concentrations in soils are scarce. Concentrations of thiocyanate in soils amended with defatted seed meal of Brassica napus L. (rapeseed) were reported to be on the order of 6 μg/g (Brown et al. 1991). Thiocyanate has been detected in soil samples collected at three of eight hazardous waste sites, and in sediment samples at three of eight hazardous waste sites where thiocyanate has been detected in some medium (HazDat 2005). The HazDat information used includes data from both NPL and other Superfund sites. No information could be found in the available literature on thiocyanate concentrations in sediments.

### 6.4.4 Other Environmental Media

The primary cyanide source in food is cyanogenic glycosides. Plants containing cyanogenic glycosides can produce hydrogen cyanide by acid hydrolysis or by the action of the enzyme β-glucosidase (EPA 1980a, 1981e; Jones 1998; Seigler 1991). Hydrogen cyanide release can occur either during maceration, which activates the intracellular β-glucosidase, or in the gut by the action of β-glucosidase produced by microflora. The level of activity of β-glucosidase in the gut depends on the bacterial composition and the pH level (WHO 1992, 2004). There are approximately 60 known cyanogenic glycosides, which differ in their bioavailability (Seigler 1991). For example, cyanide production from the ingestion of seeds containing prunasin does not occur unless the seeds have been crushed. The potential toxicity of cyanogenic plants depends on their ability to release hydrogen cyanide during preparation or digestion at concentrations high enough to be of concern for human health (WHO 1992, 2004).

Over 2,650 plant species can produce hydrogen cyanide (Seigler 1991; Swain et al. 1992). These include edible plants such as almonds, pits from stone fruits (e.g., apricots, peaches, plums, cherries), sorghum, cassava, soybeans, spinach, lima beans, sweet potatoes, maize, millet, sugarcane, and bamboo shoots (EPA 1981e). The cyanogenic glycoside content of a foodstuff is usually expressed as the amount of cyanide released by acid hydrolysis; glycoside concentrations are rarely reported (WHO 1992).

Cyanide levels measured in some foods are as follows: cereal grains and their products, 0.001–0.45 μg/g; soy protein products, 0.07–0.3 μg/g; and lima beans, 0.1–3 mg/g (EPA 1978c; Honig et al. 1983). The cyanide equivalent of total cyanogenic content (i.e., cyanogenic glycosides, cyanohydrins, and hydrogen cyanide) of cassava root has been reported to range from 91 to 1,515 mg/kg hydrogen cyanide (86–1,458 μg/g CN^−^) dry weight (d/w) (O’Brien et al. 1992). Cassava is the major starchy food for more than 300 million people in many tropical countries of the world, and many cultivars are toxic (Seigler 1991). Effective processing can reduce the amount of total cyanogen in fresh cassava roots to significantly lower levels in foods ready for consumption (Mlingi et al. 1993; O’Brien et al. 1992). For example, the mean cyanide content in garri (a flour product of grated, pressed, and fermented cassava root pulp) from a city market in Nigeria ranged from 10.6 to 22.1 μg/g dry weight (d/w) (Ukhun and Dibie 1989). A somewhat wider distribution of results was obtained in another recent evaluation of commercial garri from three main garri-producing Nigerian communities (Aletor 1993). The mean total cyanide content (glucosidic plus non-glucosidic) of 38.8% of all samples (n=108) ranged from 0 to 10 mg/kg hydrogen cyanide (0–9.6 μg/g CN^−^), whereas 40.7, 12.9, and 7.4% of the samples had mean total cyanide contents of 10–20, 20–30, and 30–40 mg/kg hydrogen cyanide (9.6–19, 19–29, and 29–39 μg/g CN^−^), respectively. The mean cyanide content of domestic samples of “sweet” to “bitter” cassava food products in Cameroon was reported to range from 18.6 to 94.9 mg/kg hydrogen cyanide (17.9–91.4 μg/g CN^−^) d/w for a dried cassava flour, and from 0.0 to 0.9 mg/kg hydrogen cyanide (0.0–0.9 μg/g CN^−^) d/w for a cassava paste (O’Brien et al. 1992). Improper processing of cassava roots may result in maintenance of cyanogenic content of cassava food products at levels that are toxic (Mlingi et al. 1992, 1993; O’Brien et al. 1992).

Cassava is a starch staple, but it is low in protein (Gomez et al. 1988). Low protein intake results in a decrease in available sulfur for conversion of cyanide to thiocyanate (Mlingi et al. 1993; Tylleskar et al. 1992). Hydrogen cyanide concentrations in sorghum leaves have been reported to range from approximately 200 to 1,300 ppm (192–1,250 μg/g CN^−^) wet weight (w/w), with higher concentrations observed in early growth stages and at lower levels of phosphorus fertilization (Chand et al. 1992).

In apricot pits, the cyanide concentration may vary from 8.9 to 217 mg/100 g (89–2,170 μg/g) w/w, depending on the type of cultivar, season, and geographic area (Lasch and El Shawa 1981). Swain et al. (1992) reported a mean cyanide concentration in black cherry (Prunus serotina Ehrh.) fruits somewhat greater than 3 μmol/seed at maturity, which is equivalent to a mean cyanide content of 78 μg/seed; insufficient information was provided to allow conversion of these results to weight per weight (w:w) units. In a recent laboratory study, Voldrich and Kyzlink (1992) reported cyanide concentrations in canned unpitted fruits (peaches, apricots, plums, and cherries) ranging from 0 to 4 mg/kg (μg/g) w/w, depending on the glycoside content of the raw fruits and the conditions of heat processing. These authors noted that the observed cyanide levels were not negligible relative to an allowable daily intake (ADI) value for cyanide of 0.05 mg/kg body weight. An adult (70 kg body weight) could consume approximately 1 kg of canned fruits with a cyanide content of 4 mg/kg without exceeding this ADI value; however, a safe portion for a child (15 kg body weight) would be only about 180 grams (12 mg/kg). The analysis of 233 samples of commercially available and homemade stone-fruit juices showed that pitted fruit juices had lower cyanide concentrations than unpitted or partially pitted fruit juices, indicating that the pits are the primary sources of cyanides in these juices (Stadelmann 1976). For example, the hydrogen cyanide content of a home-made mixed cherry juice from pitted fruits was 5.3 mg/L, compared to 23.5 mg/L in a cherry juice containing 100% crushed pits. This study also reported the following levels (median concentrations in mg/L) of hydrogen cyanide in commercial fruit juices: cherry, 4.6; apricot, 2.2; prune, 1.9; and peach, 2.9. Stadelmann (1976) recommended that the maximum hydrogen cyanide content allowed in fruit juices should be set at a level of 5 mg/L.

Cyanide can also be present in foodstuffs as residues from cyanide fumigation (EPA 1981e). Human exposure to naturally occurring cyanide in foods in the United States is expected to be low compared to certain populations in the Third World that subsist on cassava and similar crops (EPA 1981e).

Edible plants such as kale, cabbage, radishes, broccoli, brussels sprouts, cauliflower, collards, mustard greens, turnips, and kohlrabi contain glucosinolates, are hydrolysed by the endogenous enzyme myrosinase to produce toxic products, including thiocyanate (Abukutsa et al. 1993; Bible and Chong 1975; Bible et al. 1980; Carlson et al. 1985, 1987; Olea and Parras 1992; Olea-Serano et al. 1988). Vegetables from the Brassica family (e.g., cabbages, kohlrabi, kale) contain high levels of thiocyanate ranging from 5 to 660 μg/g w/w (Weuffen et al. 1984). Kale leaves have been reported to contain concentrations of potassium thiocyanate at harvest ranging from 447 to 5,067 ppm (μg/g) d/w (equivalent to thiocyanate concentrations of 267–3,035 μg/g d/w) depending on the fertilizer nitrogen source (Abukutsa et al. 1993). Other commonly consumed vegetables (e.g., lettuce, spinach, radishes) have been found to contain thiocyanate at concentrations ranging from approximately 0.1–5.0 μg/g w/w, with concentrations usually <2.0 μg/g w/w (Weuffen et al. 1984). Milk and other dairy products have been reported to contain thiocyanate at concentrations ranging from <1 to 9.0 μg/g, whereas concentrations in meat products have been reported to range from only 0.5 to 0.7 μg/g (Weuffen et al. 1984).

Laetrile (amygdalin), a drug formerly used in clinical trials for the treatment of cancer (Khandekar and Edelman 1979); sodium nitroprusside, a drug used to reduce high blood pressure (Aitken et al. 1977; Vesey et al. 1976); and a series of commercially important, simple, aliphatic nitriles (e.g., acetonitrile, propionitrile, acrylonitrile, n-butyronitrile, maleonitrile, succinonitrile) (Willhite and Smith 1981) release cyanide upon metabolism. These drugs and industrial chemicals have been associated with human exposure to cyanide and have caused serious poisoning and, in some cases, death.

Reported levels of cyanide in tobacco smoke are quite variable. Cyanide levels in mainstream (inhaled) smoke from U.S. commercial cigarettes have been reported to range from 10 to 400 μg per cigarette, with the ratio of cyanide concentration in sidestream smoke to mainstream smoke ranging from 0.006 to 0.27 per cigarette (Chepiga et al. 2000; EPA 1981e). In studies that have included non-U.S. commercial cigarettes, hydrogen cyanide concentrations in mainstream and sidestream smoke ranging from 280 to 550 μg/cigarette and from 53 to 111 μg/cigarette, respectively, have been reported; sidestream/mainstream ratios of hydrogen cyanide concentrations ranged from 0.06 to 0.50 (Baker and Proctor 1990; Guerin et al. 1987).

Cyanides have been detected in automobile exhaust. The average emission rate was 11–14 mg/mile for cars not equipped with catalytic converters and 1 mg/mile for cars with catalytic converters operating under optimum conditions. Cars with malfunctioning catalytic converters may emit as much or more hydrogen cyanide than cars without such equipment (EPA 1981e).

## 6.5 GENERAL POPULATION AND OCCUPATIONAL EXPOSURE

The general population may be exposed to cyanide from inhaling air and ingesting food and drinking water contaminated with it. Since most of the cyanide in the air will be present as hydrogen cyanide (see Section 6.3.2.1), the primary inhalation exposure to cyanide will occur from hydrogen cyanide. The concentration of hydrogen cyanide in the air of non-urban areas is ≈160–166 ppt (see Section 6.4.1). Based on an atmospheric hydrogen cyanide concentration of 170 ppt (0.191 mg/m^3^) and an average daily inhalation volume of 20 m^3^, the inhalation exposure of the general U.S. non-urban, nonsmoking population to hydrogen cyanide is estimated to be 3.8 μg/day. In drinking water, cyanide may be present as cyanogen chloride (see Section 6.4.2). In 1988, the quarterly median cyanogen chloride concentration in drinking water from 35 U.S. water utilities ranged from 0.45 to 0.8 μg/L (0.19–0.3 μg/L cyanide) (Krasner et al. 1989). Based on a daily drinking water consumption of 2 L for a 70-kg adult, the daily intake of cyanogen chloride is estimated to be 0.9–1.6 μg, which is equivalent to 0.4–0.7 μg of hydrogen cyanide. The concentration of cyanide in drinking water in the United States in 1970 was <0.008 mg/L (EPA 1981e). In more recent data obtained from water supply systems in Canada, the concentration of cyanide was below 0.001 mg/L in 70 cities with two cities reporting concentrations of 0.011 mg/L (Meranger and Lo 1992). Using the range of cyanide concentrations given in the Canadian study (0.001–0.011 mg/L) as representative of the general population in the United States and assuming a daily water consumption of 2 L for a 70-kg adult, the daily intake of cyanide is estimated to be 0.002–0.22 mg. EPA has established an MCL of 0.2 mg/L for cyanide in drinking water (see Chapter 8), which is equivalent to a daily intake of 0.4 mg, based on a daily drinking water consumption rate of 2 L for a 70-kg adult (EPA 1991a). Estimates of the cyanide concentration in the total diet of a U.S. adult were not located in the available literature. Therefore, no estimate of daily cyanide intake from food can be made. In the United States, human exposure to cyanide from foods in which it occurs naturally is expected to be low, but is likely to exceed cyanide intake from inhalation of air and ingestion of drinking water (CEPA 1997; EPA 1981e). The EPA has established tolerances for hydrogen cyanide in various foods ranging from 25 to 250 ppm (EPA 1975b) and from 5 to 25 ppm (see Chapter 8). Poitrast et al. (1988) have estimated an overall allowable daily intake of 0.6 mg for cyanide, incorporating an uncertainty factor of 100–1,000 to ensure that the potential for an infant receiving a toxic dose of cyanide from breast milk is quite low.

The dietary cyanide intake of Tukanoan Indians in northwest Amazonia who rely heavily on high (>70% of all foods) cyanide-containing varieties of cassava was estimated to be >20 mg/day (Dufour 1988). Yet, Dufour (1988) did not find physical disorders in Tukanoan Indians attributable to high cassava diets, in contrast to observations related to cassava-consuming populations in Africa. One reason that has been suggested is that the cassava processing techniques of the Tukanoans are very sophisticated and very effective in reducing the cyanide concentration in the crop. Indeed, it has been shown in several studies of cassava processing techniques used in Africa that the level of hydrogen cyanide can be effectively and reliably reduced by allowing sufficient time for the hydrolysis of cyanogenic glucosides and evaporation of hydrogen cyanide (Ojo and Dean 2002; Onabolu et al. 2002). Another reason that may account for the observed differences in toxicity among different populations is that the variety of cassava may differ between geographical areas (Rosling 1988). When outbreaks of acute cyanide intoxications do occur in African populations that have been found to result from incomplete processing of cassava, resulting in highly elevated cyanide levels in combination with chronic dietary protein malnutrition (WHO 2004b). This occurred when, due to a food shortage, the lengthy sun drying normally used to remove cyanogenic glucosides was replaced by repeated pounding and drying to obtain flour for consumption in 1 day (Mlingi et al. 1992, 1993; Tylleskar et al. 1992).

The primary route of exposure to thiocyanates for the general population appears to be from ingestion of foods in which thiocyanate occurs naturally (e.g., cabbage, kale, spinach, kohlrabi). Estimates of the thiocyanate concentration in the total diet of an adult in the United States were not located in the available literature; however, these would be expected to be quite low. Exposure to cyanide also is a source of thiocyanate exposure because thiocyanate is a major metabolite of cyanide in the human body.

Occupational exposures to cyanide are expected to occur primarily through inhalation and, less frequently, through skin absorption. Preliminary data from the NOES conducted by NIOSH from 1980 to 1983 estimated that the number of workers potentially exposed to cyanide compounds in the United States in 1981–1983 are as follows (NIOSH 1989a): cyanide, 367; hydrogen cyanide, 4,005; sodium cyanide, 66,493; potassium cyanide, 64,244; potassium silver cyanide, 3,215; calcium cyanide, 3,606; copper (I) cyanide, 22,339; ammonium thiocyanate, 90,599; and cyanogen chloride, 1,393. Thiocyanate and cyanogen were not included in the NOES (NIOSH 1989a). These numbers do not include workers potentially exposed to trade-name compounds that contain cyanides or thiocyanates. Workers in various occupations may be exposed to cyanide compounds. People possibly exposed to cyanide include workers involved in electroplating, metallurgy, cyanotype printing, pesticide application, firefighting, steel manufacturing, and gas works operations; workers involved in the manufacture of cyanides, adiponitrile and other simple, aliphatic nitriles, methyl methacrylate, cyanuric acid, dyes, pharmaceuticals, or chelating agents; and people who work in tanneries, blacksmithing, metal cleaning, and photoengraving or photography industries (EPA 1981e; Lucas 1992; WHO 2004b; Willhite and Smith 1981). Workers in the oil shale retorting industry may be exposed to cyanide because the offgas from the retorting process contains hydrogen cyanide (see Section 6.2.1). There is a reported case of the fatal poisoning of three trawler crew members as they entered a refrigerated compartment containing spoiled fish in which cyanide, in addition to methane and hydrogen sulfide, have been implicated in their deaths (Cherian and Richmond 2000). Medical and emergency personnel (e.g., police and firefighters) who may be involved in resuscitation efforts or removal of gastric contents of postmortem victims of cyanide poisoning are potentially exposed to higher levels of cyanide (Andrews et al. 1989; Bolstad-Johnson et al. 2000; Nolte and Dasgupta 1996). Workers involved in large-scale processing of cassava have been shown to have thiocyanate levels in urine that are 2.2–2.6 times the levels found in individuals who regularly consume cassava products (Okafor et al. 2002). The increased thiocyanate levels in cassava processors are due to inhalation of hydrogen cyanide that is discharged to air during the processing of cassava. The manufacture of industrial inorganic chemicals may be a significant potential source of occupational exposure to cyanogen chloride (NIOSH 1989a). Potential sources of occupational exposure to ammonium thiocyanate include the manufacture of electronic computing equipment, research and development laboratories, newspaper and other commercial printing, general medical and surgical hospitals, production of adhesives and sealants, and the construction and furniture industries (NIOSH 1989a).

In a survey of the plating facility of a national airline conducted by NIOSH in December 1981, the concentrations of hydrogen cyanide in three work areas ranged from 0.001 to 0.004 mg/m^3^ (0.0009–0.004 ppm) (NIOSH 1982). The cyanide concentrations in four work areas in a plating facility of an electrical and electronic company in Waynesboro, Virginia, ranged from 0.07 mg/m^3^ (0.07 ppm hydrogen cyanide) in a salt pot room to 4.3 mg/m^3^ (4.0 ppm hydrogen cyanide) beside a stripping tank (NIOSH 1976). Similarly, the concentration of cyanide in the breathing zone air of workers in a plating facility in Galion, Ohio, was 1.7 mg/m^3^ (1.6 ppm hydrogen cyanide) (NIOSH 1978). In a NIOSH survey of a university art department foundry, hydrogen cyanide was detected in the smoke produced during pouring and knockout of castings at a concentration of approximately 4 ppm; hydrogen cyanide was not detected in personal breathing zone samples taken during knockout of castings (Lucas and Salisbury 1992). These levels are all below the NIOSH recommended ceiling limit of 4.7 ppm (NIOSH 1992).

Levels of cyanide and its metabolite thiocyanate in blood serum and plasma, urine, and saliva have been used as indicators of cyanide exposure in humans, particularly in workers at risk of occupational exposures, in smokers or nonsmokers exposed to sidestream or environmental tobacco smoke, in populations exposed to high dietary levels of cyanide, and in other populations with potentially high exposures (see Section 6.7). The correlation between increased cyanide exposure and urinary thiocyanate levels was demonstrated in workers exposed to 6.4–10.3 ppm cyanide in air (El Ghawabi et al. 1975). In another study, blood cyanide concentrations were found to vary from 0.54 to 28.4 μg/100 mL in workers exposed to approximately 0.2–0.8 ppm cyanide in air, and from 0.0 to 14.0 μg/100 mL in control workers (Chandra et al. 1988). Similar elevations in urinary thiocyanate levels were observed, with concentrations for exposed workers and controls ranging from 0.05 to 2.80 and from 0.02 to 0.88 mg/mL, respectively.

A study of tissue distributions of cyanide in five victims of acute cyanide poisoning found that cyanide concentrations are highest in blood (Zhang et al. 2005). Blood had the highest concentration of cyanide in all the victims, ranging between 0.65 and 30.6 μg/mL. Normalizing cyanide concentrations in liver, kidney, brain, and urine samples to cyanide concentrations in blood, it was found that liver had the next highest concentrations of cyanide, with S/B ratios ranging from 0.24 to 0.35.

The results of several studies that have shown elevated cyanide or thiocyanate concentrations in body fluids of smokers are summarized in Table 6-4. In general, these results indicate that serum cyanide levels (Cardeal et al. 1993; Symington et al. 1987; Tsuge et al. 2000) and plasma, serum, and saliva thiocyanate levels (Banerjee and Muthu 1994; Jarvis 1989; Maliszewski and Bass 1955; Pre and Vassy 1992, 1993; Tsuge et al. 2000; Waage et al. 1992; Yamanaka et al. 1991) could distinguish smokers from nonsmokers and/or light smokers. Pre and Vassy (1992) found that plasma thiocyanate was an indicator of smoking status that was not sensitive to light or passive smoking. However, inhaling smokers were easily distinguished from noninhaling smokers. The authors concluded that a plasma thiocyanate concentration below 20 μmol/L (1,200 μg/L) indicated that passive smoking was very unlikely, whereas concentrations above 80–85 μmol/L (4,600–4,900 μg/L) were a reliable indication of an active inhalation of smoke. Yamanaka et al. (1991) found a correlation between the number of cigarettes smoked per day and the thiocyanate levels in plasma and saliva; however, in apparent contrast to results obtained by Maliszewski and Bass (1955), thiocyanate concentrations in urine of smokers and nonsmokers were not found to be significantly different.

Data on elevated levels of thiocyanate in body fluids resulting from consumption of cyanide-containing foods come primarily from populations in tropical regions that may consume large quantities of improperly processed cyanogenic plants such as cassava (WHO 2004b). Among four populations in Africa known to be exposed to high levels of dietary cyanide because of incomplete processing of cassava during drought periods, urinary thiocyanate concentrations (mean±SE) ranged from 350±39 to 1,120±75 μmol/L (20±2–65±4 mg/L), compared to urinary thiocyanate levels in the normal population of <100 μmol/L (5.8 μg/L) (Mlingi et al. 1992, 1993; Tylleskar et al. 1992). The mean plasma thiocyanate concentration in one of these populations was 335±12 μmol/L (19±1 μg/L), compared to 28±4 μmol/L (1.6±0.2 μg/L) in a control population (Mlingi et al. 1992). Elevated mean serum thiocyanate concentrations (11±3 μg/L compared to reference values of 0.5–4 μg/L) were observed in only one of two populations in which this biomarker was measured (Tylleskar et al. 1992, 1994). There was no apparent explanation for this difference.

Table 6-4 Cyanide and Thiocyanate Concentrations (μg/mL)^a^ in Smokers and Nonsmokers

Compound | Plasma/Blood | | Serum | | Saliva | | Urine | | Reference
Compound | S^b^ | NS^b^ | S | NS | S | NS | S | NS | Reference
Cyanide
| | | 2.11; (1.42–3.67) | 0.78; (0.44–1.15) | | | | | Cardeal et al. 1993 ^c^
| | | 6.8; (1.3–19.4) | 2.9; (0.0–11.7) | | | | | Symington et al. 1987 ^c^ ^,^ ^d^
| 0.27; (0.14–0.41)^e^ | 0.17; (0.11–0.25)^e^ | | | 0.66; (0.13–2.07)^e^ | 0.38; (0.05–1.20)^e^ | | | Tsuge et al. 2000
Thiocyanate
| | | 232; (10) | 92; (9) | | | | | Banerjee and Muthu 1994 ^f^
| 7.1 | 2.9 | | | 142 | 76 | 9.0 | 5.8 | Jarvis 1989 ^g^
| 7.1; (6.2–8.6) | 2.0; (1.2–2.8) | | | 75.7; (48.4–112.2) | 20.3; (9.71–28.7) | 12.3; (7.8–17.2) | 2.1; (1.1–3.9) | Maliszewski and Bass 1955 ^c^
| 8.7^h^; (4.4–21.5) | 1.8^i^; (0.5–4.4) | | | | | | | Pré and Vassy 1992 ^f^
| 3.3^j^; (1.0–4.6)
| | | 6.6; (1.5) | 1.2; (0.3) | | | | | Pré and Vassy 1993 ^f^
| 111.2; (17–290)^e^ | 33.5; (6.3–94)^e^ | | | 1,655; (270–2,940)^e^ | 542; (13–1,630)^e^ | | | Tsuge et al. 2000
| | | (<0.05–0.35) | (<0.05–0.08) | | | | | Waage et al. 1992 ^f^ ^,^ ^k^
| 2.1 | 3.7 | | | 88 | 33 | 18 | 19 | Yamanaka et al. 1991 ^k^ ^,^ ^l^

a Values are means; values in parentheses are ranges or standard deviations

b S = smoker; NS = nonsmoker

c No statistics reported

d As cited in Cardeal et al. 1993

e Values are expressed as μM; values in parentheses are ranges.

f Results significantly different

g Results not significantly different

h Inhaling smokers

i Nonsmokers including passive smokers

j Noninhaling smokers

k Values estimated from graphical presentation of data

l All results, except urine, are significantly different.

High serum thiocyanate concentrations (>180 μmol/L) have been found in Tukanoan Indians on traditional diets. However, the levels of residual cyanide appear to be tolerated well (Dufour 1988).

## 6.6 EXPOSURES OF CHILDREN

This section focuses on exposures from conception to maturity at 18 years in humans. Differences from adults in susceptibility to hazardous substances are discussed in Section 3.7, Children’s Susceptibility.

Children are not small adults. A child’s exposure may differ from an adult’s exposure in many ways. Children drink more fluids, eat more food, breathe more air per kilogram of body weight, and have a larger skin surface in proportion to their body volume. A child’s diet often differs from that of adults. The developing human’s source of nutrition changes with age: from placental nourishment to breast milk or formula to the diet of older children who eat more of certain types of foods than adults. A child’s behavior and lifestyle also influence exposure. Children crawl on the floor, put things in their mouths, sometimes eat inappropriate things (such as dirt or paint chips), and spend more time outdoors. Children also are closer to the ground, and they do not use the judgment of adults to avoid hazards (NRC 1993).

Information on exposures of cyanide to children living in the United States is mainly limited to studies on side-stream smoke. These studies show that this is an important route of exposure to cyanide for children in households with a resident smoker. Chen et al. (1990) found that serum thiocyanate concentrations of 18-month-old infants heavily exposed to environmental tobacco smoke (>20 cigarettes a day smoked in the home) were significantly higher than those of unexposed infants (p<0.05). Mean concentrations (±standard deviation [SD]) in these respective groups were 36.2±14.88 μmol/L (2.1±0.9 μg/mL) and 27.7±10.7 μmol/L (1.6±0.6 μg/mL). Positive correlations between fetal umbilical serum thiocyanate levels and serum thiocyanate levels of smoking mothers (Bottoms et al. 1982; Hauth et al. 1984) and mothers exposed to environmental tobacco smoke in the home (Bottoms et al. 1982) have been reported. Hauth et al. (1984) found that the mean serum thiocyanate concentration (95 μmol/L; 5.5 μg/mL) was significantly higher (p<0.001) in smokers than in passive smokers (35.9 μmol/L; 2.1 μg/mL) or nonsmokers (32.3 μmol/L; 1.9 μg/mL). Similarly, the mean umbilical thiocyanate concentration in the newborn infants of smoking mothers (72 μmol/L; 4.8 μg/mL) was significantly higher than those in newborn infants of passive smokers (26 μmol/L; 1.5 μg/mL) and nonsmokers (23 μmol/L; 1.3 μg/mL). In contrast, Bottoms et al. (1982) found that among newborn infants of nonsmoking mothers, fetal umbilical thiocyanate concentrations increased with passive smoking in the home (p<0.05).

For children without exposures to side-steam smoke, their main cyanide exposures are expected to be similar to those noted for the general population in Section 6.5 in air and water. Estimates of the cyanide concentration in the total diet of children in the United States were not located in the available literature. Therefore, no estimate of daily cyanide intake from food can be made. However, in the United States, exposure of children to cyanide from foods in which it occurs naturally is expected to be low, but, as noted for Section 6.5 for the general population, it is likely to exceed cyanide intake from inhalation of air and ingestion of drinking water (EPA 1981e). Based on a concentration of cyanide in U.S. and Canadian drinking water of 0.001–0.011 mg/L, the daily intake of cyanide in children is estimated to be 0.001–0.011 mg, assuming a daily consumption of 1 L of water (EPA 1981e; Meranger and Lo 1992). For cyanide as cyanogen chloride, the daily intake is estimated to be 0.5–0.8 μg, which is equivalent to 0.2–0.4 μg of hydrogen cyanide. This estimate is based on the quarterly median cyanogen chloride concentration in drinking water from 35 U.S. water utilities ranged from 0.45 to 0.8 μg/L (0.19–0.3 μg/L cyanide) (Krasner et al. 1989) and the daily consumption of 1 L of drinking water.

Accidental cyanide poisonings in children are rare and are usually associated with exposures to combustion products in smoke (Riordan et al. 2002). Poisonings have been reported for ingestion of apricot kernels or seeds or candy made from apricot kernels. Because of their lower body weight, children tend to be more susceptible to consumption of apricot kernels than adults, with 10 or more seeds being fatal to a child (WHO 2004b).

## 6.7 POPULATIONS WITH POTENTIALLY HIGH EXPOSURES

Among the general population, subpopulations with the most likely potential for exposure to cyanide and thiocyanate include active and passive smokers (EPA 1981e) and people who are exposed to house or other building fires (Andrews et al. 1989; Ballantyne 1987a; Bolstad-Johnson et al. 2000). Other subpopulations with potentially high cyanide or thiocyanate exposures are residents who live near industrial sites releasing cyanides or thiocyanates into the environment, residents who live near cyanide- or thiocyanate-containing hazardous waste sites, and people who consume foods high in cyanogenic glycosides. The fetuses of pregnant women who smoke or who are exposed to high levels of environmental smoke (i.e., passive smokers) may be subjected to potentially high exposures of cyanide and thiocyanate (Bottoms et al. 1982; EPA 1992f; Hauth et al. 1984). Workers involved in electroplating, metallurgy, pesticide application, firefighting, gas works operations, tanning, blacksmithing, metal cleaning, photoengraving, photography, cyanotype printing, the manufacture of steel, cyanides, adiponitrile and other nitriles, methyl methacrylate, cyanuric acid, dyes, pharmaceuticals, or chelating agents have the potential to be occupationally exposed to higher concentrations of cyanide than the general population (EPA 1981e; NIOSH 1989a). Workers in the following industries may also be exposed to higher concentrations of thiocyanate than the general population: manufacture of electronic computing equipment, research and development laboratories, newspaper and other commercial printing, general medical or surgical hospitals, production of adhesives and sealants, pesticide application, building and furniture construction, and handling, treatment, or disposal of thiocyanate-containing wastes from industrial processes (Brown and Morra 1993; NIOSH 1989a; WHO 2004b). Two additional groups of people who may be at greater risk for cyanide exposure are those who are exposed to cyanide but are unable to smell the chemical (EPA 1987a) and patients with motor neuron disease (see Section 3.10).

Data related to the levels of cyanide or thiocyanate exposure in several of these population groups have been presented in Section 6.5. No data were found related to the levels of cyanide or thiocyanate exposure in cassava eaters in the United States. Also, no data were located in the available literature related to the levels of cyanide and thiocyanate exposure of people who live near industrial sites releasing cyanides or thiocyanates to the environment, or near hazardous waste sites. Cyanides (reported as cyanide, hydrogen cyanide, sodium cyanide, potassium cyanide, calcium cyanide, or copper (I) cyanide) have been detected in air, surface and groundwater, and soil samples at NPL hazardous waste sites; cyanogen and cyanogen chloride have been detected in soil samples at NPL hazardous waste sites; and thiocyanates have been detected in surface and groundwater, and soil samples at NPL sites (see Section 6.2) (HazDat 2005). There is a need for reliable data on the levels at which these substances are found in various media at these sites in order to estimate potential exposures of people living near hazardous waste sites.

## 6.8 ADEQUACY OF THE DATABASE

Section 104(i)(5) of CERCLA, as amended, directs the Administrator of ATSDR (in consultation with the Administrator of EPA and agencies and programs of the Public Health Service) to assess whether adequate information on the health effects of cyanide is available. Where adequate information is not available, ATSDR, in conjunction with NTP, is required to assure the initiation of a program of research designed to determine the health effects (and techniques for developing methods to determine such health effects) of cyanide.

The following categories of possible data needs have been identified by a joint team of scientists from ATSDR, NTP, and EPA. They are defined as substance-specific informational needs that if met would reduce the uncertainties of human health assessment. This definition should not be interpreted to mean that all data needs discussed in this section must be filled. In the future, the identified data needs will be evaluated and prioritized, and a substance-specific research agenda will be proposed.

### 6.8.1 Identification of Data Needs

Physical and Chemical Properties. As reported in Section 4.2, most of the relevant physical and chemical properties of cyanide compounds are known. Except for soil partition (K_oc_) coefficient, data for the physical and chemical properties of hydrogen cyanide are available to estimate its environmental fate. Additional data are needed to estimate the environmental fate of the other cyanides covered in this profile. Although qualitative information is available, quantitative data are needed for the solubility of calcium cyanide in water. Octanol/water partition coefficient (K_ow_) data are needed for cyanogen chloride. Certain physical parameters, such as K_ow_ and K_oc_, are not available nor are they useful for predicting the environmental fate and transport of the ionic cyanide compounds. These partition coefficients are generally used to assess the partitioning of neutral organic compounds between organic matter and water and are not good at describing the varying ionic or complexation interactions of ionic compounds, such as the simple and metal complexed cyanides and thiocyanate, with water, aquatic biota, soil, or sediments.

Production, Import/Export, Use, Release, and Disposal. According to the Emergency Planning and Community Right-to-Know Act of 1986, 42 U.S.C. Section 11023, industries are required to submit substance release and off-site transfer information to the EPA. The TRI, which contains this information for 2003, became available in May of 2005. This database is updated yearly and should provide a list of industrial production facilities and emissions.

Knowledge of a chemical’s production volume is important because it may indicate the magnitude of environmental contamination and human exposure. Data regarding the production, trend, use pattern, and disposal of commercially significant cyanide compounds are available (CMR 2001; Curry 1992; Homan 1987; HSDB 2004; Sittig 1980; SRI 2005; TRI03 2005). It is known that the import and export of hydrogen cyanide is insignificant compared to its production; however, except for potassium, sodium and calcium cyanide salts, recent import and export data for other individual cyanide compounds are difficult to obtain (USDOC 2004). There are some less recent data regarding the release of cyanides in air (EPA 1981e; TRI88 1990) but, except for hydrogen cyanide (TRI03 2005), more recent quantitative data regarding the release of individual cyanide compounds in air, water, and particularly soil and sediment are unavailable and would be useful for assessing current human exposures to cyanides.

Cyanide is naturally present in many foods high in cyanogenic glycosides (EPA 1978c, 1981e; Honig et al. 1983; Jones 1998). No information was located in the available literature to indicate that cyanide enters foods during processing or that elevated cyanide concentrations are present in any consumer products. The two most likely sources of general population exposure to cyanide include people who inhale cigarette smoke (EPA 1981e) or individuals who are exposed to a house or other type of building fire (Andrews et al. 1989; Ballantyne 1987a; Bolstad-Johnson et al. 2000). There are EPA regulations regarding the disposal of cyanide wastes or OSHA and NIOSH regulations regarding the levels of hydrogen cyanide in workplaces (see Chapter 8). Data is available on chemical and biological processes for degrading cyanide in leachate and waste water generated during the extraction of gold and other precious metals from low grade ore (Akcil and Mudder 2003; EPA 1994c). Additional research is needed on improved methods of pollution prevention and biodegradation to reduce or eliminate releases of cyanide compounds to the environment from industrial processes.

Environmental Fate. The environmental fate of hydrogen cyanide gas in air is well studied (Cicerone and Zellner 1983; Fritz et al. 1982); however, it would be useful if the role of particulate cyanides (e.g., sodium cyanide, potassium cyanide) in determining the fate of total cyanides in the air was known. Given that hydrogen cyanide occurs in the atmosphere from both natural and anthropogenic processes (Cicerone and Zellner 1983; Crutzen and Andreae 1990; Crutzen and Carmichael 1993; EPA 1981e; Knowles 1988; Lobert and Warnatz 1993), it would be useful if an estimate were available for the contribution of anthropogenic processes to the overall hydrogen cyanide burden in the atmosphere. It is generally known that volatilization and biodegradation will be important processes for the loss of cyanides in water (EPA 1978c, 1979; Ludzack et al. 1951; Raef et al. 1977a), but no experimental or estimated values for the half-life of cyanides in ambient water are available. No comprehensive data regarding the role of sorption in determining the fate of cyanides in water are available. It is generally known that volatilization from soil surfaces and biodegradation play significant roles in the loss of cyanides in soil (EPA 1978c), but no quantitative data regarding the half-life of cyanides in ambient soil are available. Additional data on the relative importance of volatilization and biodegradation in determining the fate of cyanides in soils are needed. The elucidation of the role of cyanide complexation by metals in soil and sediment in controlling the fate of cyanide would be useful.

Both cyanogen and cyanogen chloride are highly volatile gases, indicating that volatilization would be the major transport pathway for these compounds from surface water and soils. Cyanogen is reactive and does not persist in the environment unchanged (EPA 1979). It also has been reported to react slowly with water to yield hydrogen cyanide and cyanic acid, among other products (EPA 1979), and this hydrolysis reaction may be a possible degradation pathway. Likewise, cyanogen chloride has also been shown undergo slow hydrolysis at neutral pH to form cyanic acid and hydrogen chloride (U.S. Army 1989). Additional information on the environmental fate of cyanogen and cyanogen chloride is needed. There is almost no available information on the environmental transport and partitioning of thiocyanate in the environment. At ambient temperatures, it appears that sorption and volatilization are not significant partitioning processes for thiocyanate in soil, with thiocyanate losses due primarily to microbial degradation (Brown and Morra 1993); however, additional research is needed in this area. Although biodegradation is a significant transformation process for thiocyanate in water, additional data are needed on the relative importance of this process in determining the fate of thiocyanates in natural water systems.

Bioavailability from Environmental Media. Cyanide is known to be absorbed following inhalation, oral, and dermal contact (Gosselin et al. 1984; Rieders 1971). The environmental factors that may influence the bioavailability of cyanide from contaminated air, water, soil, or plant material have not been studied. Since cyanides are not strongly sorbed to soil and sediments (EPA 1979), the role of sorption may not be significant in determining the bioavailability of cyanides from different soils or waters. The bioavailability of cyanide from an environmental medium is expected to increase if the cyanide is present in water-soluble forms, such as ions or soluble complexes. The pH of a medium may also be significant in determining the bioavailability because hydrogen cyanide gas may be released as the pH of the medium decreases (EPA 1978c, 1979). Data delineating the factors affecting the bioavailability of cyanide compounds from soil and other environmental media need further development, since the absorption studies discussed in Section 3.4.1 have been performed with the pure chemical.

The factors that may influence the bioavailability of thiocyanate from various foods and other environmental media have not been investigated. There is no data need at this time because exposure to thiocyanate from environmental media is expected to be low.

Food Chain Bioaccumulation. Simple cyanide compounds do not bioconcentrate in fish (EPA 1979, 1985a). There is evidence suggesting that the bioconcentration of cyanide metal complexes in fish (EPA 1979). Therefore, it would be useful to determine the bioconcentration potential for cyanide in fish from water exposed to less toxic and water-soluble cyanide complexes. There is no indication of biomagnification of cyanides in aquatic and terrestrial food chains (EPA 1978c). Because of the high toxicity of cyanides at high doses and rapid metabolism at low doses, biomagnification of cyanide in animals seems unlikely.

No information could be found in the available literature on the potential of thiocyanates for bioconcentration or biomagnification in the food web. In the absence of this information, data would be useful to determine the potential for thiocyanate to bioconcentrate and/or biomagnify in a food chain.

Exposure Levels in Environmental Media. Reliable monitoring data for the levels of cyanide in contaminated media at hazardous waste sites are needed so that the information obtained on levels of cyanide in the environment can be used in combination with the known body burden of cyanide to assess the potential risk of adverse health effects in populations living in the vicinity of hazardous waste sites.

Data exist regarding the levels of cyanide in air and drinking water, and these data have been used to estimate human exposure. The concentration of hydrogen cyanide in the air of non-urban areas is ≈160–166 ppt (Cicerone and Zellner 1983; Jaramillo et al. 1989) and the inhalation exposure of the general U.S. non-urban, nonsmoking population to hydrogen cyanide was estimated to be 3.8 μg/day. The chlorination of public drinking water supplies may result in the formation of cyanogen chloride (Jacangelo et al. 1989; Ohya and Kanno 1987). In 1988, the quarterly median cyanogen chloride concentration in drinking water from 35 U.S. water utilities ranged from 0.45 to 0.8 μg/L (Krasner et al. 1989). Based on a daily drinking water consumption of 2 L for a 70-kg adult, the daily intake of cyanogen chloride is estimated to be 0.9–1.6 μg. These data are sufficient to estimate human exposure from air and drinking water, although continued monitoring data in these environmental media would be useful. Cyanide and thiocyanate concentrations in certain foods are known (Abukutsa et al. 1993; EPA 1978c, 1981e; Honig et al. 1983; Pre and Vassy 1992); however, a data need exists to estimate the dietary exposures for the general population to cyanide and thiocyanate from food sources. It will also be useful to develop data that would clearly establish whether cyanides or thiocyanates pose acute or chronic exposure hazards for residents in the vicinity of hazardous waste sites. This information should include data on background concentrations in all media to which a resident might be exposed.

Information on the consumption of cassava in the United States could not be located in the available literature. Therefore, an assessment of cassava consumption in the United States would be needed before recommending a need for data relating to exposure levels of cyanide in cassava consumers.

Exposure Levels in Humans. The levels of cyanide and thiocyanate in various human tissues and body fluids of both control and occupationally exposed groups and of smokers and nonsmokers are available (see Sections 3.4.4, 3.8.1, and 6.5). Although no specific data need exists regarding levels of cyanide and thiocyanate in human biological samples, continued monitoring data are recommended in order to assess current human exposure. Data are available that describe the levels of these chemicals in humans consuming foods containing cyanogenic materials (WHO 2004b). These data are mainly limited to cyanide exposures that result from the consumption of cassava (Dufour 1988; Mlingi et al. 1992; Ojo and Dean 2002; Okafor et al. 2002; Onabolu et al. 2002; Tylleskar et al. 1992, 1994).

This information is necessary for assessing the need to conduct health studies on these populations.

Exposures of Children. Data regarding the exposure of children to side-stream (second-hand) cigarette smoke are available (Bottoms et al. 1982; Chen et al. 1990; Hauth et al. 1984). There are no comprehensive data on the cyanide or thiocyanate content of total diet samples in the United States, so it is not possible to estimate the average daily intake from foods. This is a data need for both children and adult exposures.

Data on exposures of children to cyanides and thiocyanates in the vicinity of hazardous waste sites would be useful to clearly establish whether cyanides or thiocyanates pose acute or chronic exposure hazards to children living near these sites. This information should include data on background concentrations in all media.

Child health data needs relating to susceptibility are discussed in Section 3.12.2, Identification of Data Needs: Children’s Susceptibility.

Exposure Registries. No exposure registries for cyanide were located. This substance is not currently one of the compounds for which a sub-registry has been established in the National Exposure Registry. The substance will be considered in the future when chemical selection is made for sub-registries to be established. The information that is amassed in the National Exposure Registry facilitates the epidemiological research needed to assess adverse health outcomes that may be related to exposure to this substance.

### 6.8.2 Ongoing Studies

No new or ongoing studies of release, environmental fate and transport, levels monitored in the environment, or human exposures were identified for cyanide or cyanide compounds in the Federal Research in Progress (FEDRIP 2005) database.