# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of the most common cyanides is located in Table 4-1. Hydrogen cyanide is a toxic gas that may enter the environment from both natural processes and human industrial activities. It may exist in polymeric forms. The cyanide compounds in which cyanide can be obtained as CN^−^ are classified as simple and complex cyanides. Some simple cyanides are soluble in water (sodium cyanide, NaCN; potassium cyanide, KCN; and calcium cyanide, Ca(CN)_2_), while others are sparingly soluble or almost insoluble (copper (I) cyanide, CuCN). Cyanogen (NC-CN) and cyanogen chloride (CNCl) are highly toxic gases that are soluble in water. At neutral pH, cyanogen undergoes a slow hydrolysis to form hydrogen cyanide, cyanic acid (HOCN), and other products. At alkaline pH, CNCl hydrolyzes to CNO^−^, which has only limited toxicity. Alkaline chlorination of water containing cyanide produces cyanogen chloride. Thiocyanate (SCN^−^) is an oxidation product of the cyanide anion (CN^−^), produced in the presence of a sulfur donor.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of cyanide is located in Table 4-2. Cyanides form strong complexes with many metals, particularly those of the transition series. One example of such complex formation is the reaction of cyanide with iron in the formation of ferrocyanide and ferricyanide complexes. Solutions of ferrocyanides and ferricyanides can form hydrogen cyanide and cyanide ions when exposed to sunlight or ultraviolet radiation. Cyanogenic glycosides are cyanide compounds produced naturally in many plants (Jones 1998). These glycosides produce hydrogen cyanide when hydrolyzed (EPA 1978c) or digested (Ellenhorn and Barceloux 1997; WHO 2004b). For example, in the human gut, the cyanogenic glycoside amygdalin, which is found in bitter almonds and in apricot pits and is the active ingredient in the drug Laetrile, undergoes two enzymatically catalyzed hydrolysis steps (Ellenhorn and Barceloux 1997). The first step involves the removal of one of the two β-D-gluco-pyranosyl groups from amygdalin through the action of beta-glucosidase to form the cyanogenic glycoside, prunasin. The enzyme, emulsion, then hydrolyzes prunasin to form hydrogen cyanide, glucose, and benzaldehyde.

Table 4-1 Chemical Identity of Cyanide and Compounds^a^

Characteristic | Hydrogen cyanide | Sodium cyanide | Potassium cyanide | Calcium cyanide | Copper(l) cyanide | Potassium silver cyanide | Cyanogen | Cyanogen chloride | Ammonium thiocyanate
Synonym(s) | Formonitrile; hydrocyanic acid; prussic acid | Cyanide of sodium; hydrocyanic acid; sodium salt | Cyanide of potassium; hydrocyanic acid; potassium salt | Calcid; calcyan; cyanide of calcium | Cuprous cyanide^c^; cupricin^c^ | Potassium argentocyanide; potassium dicyanoargentate | Carbon nitride; dicyanogen; ethanedinitrile | Chlorine cyanide; chlorocyan | Thiocyanic acid, ammonium salt; ammonium rhodanide; ammonium sulfocyanate^c^
Registered trade name(s) | Cyclone B; Cyclon^b^ | Cyanogran^c^ | Carswell No. 688A | Caswell No. 142; Cyanogas^c^ | AI3-28745 | No data | No data | Caswell No. 267 | Trans-Aid^b^
Chemical formula | HCN | NaCN | KCN | Ca(CN)_2_ | CuCN | KAg(CN)_2_ | (CN)_2_ | CNCl | NH_4_SCN
Chemical structure | H^+^ C ≡ N^−^ | Na^+^ C ≡ N^−^ | K^+^ C ≡ N^−^ | ^−^N ≡ C Ca^+ 2^ C ≡ N^−^ | Cu^+^ C ≡ N^−^ | K^+^ [ Ag ( CN )_2_ ]^−^ | N ≡ C − C ≡ N | Cl − C ≡ N | NH_4_^+^ S − C ≡ N^−^
Identification numbers:
CAS registry | 74-90-8 | 143-33-9 | 151-50-8 | 592-01-8 | 544-92-3 | 506-61-6 | 460-19-5 | 506-77-4 | 1762-95-4
NIOSH RTECS | MW6825000 | VZ7530000 | TS8750000 | EW0700000 | GL7150000 | TT5775000 | GT1925000 | GT2275000 | XK7875000
EPA hazardous waste | P063; D003 | P106; D003 | P098; D003 | P021; D003 | P029; D003 | P099; D003; D011 | P031; D003 | P033; D003 | No data
OHM/TADS | 7216749 | 7216892 | 7216862 | 7216626 | No data | No data | 7216656 | 7216658 | 721218
DOT/UN/NA/IMCO shipping | UN1051; IMO 6.1 UN1614; NA 1051 | UN1689; IMO 6.1 | UN1680; IMO 6.1 | UN1575; IMO 6.1 | UN1587; IMO 6.1 | No data | UN1026; IMO 2.3 | UN1589; IMO 2.3 | NA9092
HSDB | 165 | 734 | 1245 | 242 | 1438 | 6053 | 2130 | 917 | 701
NCI | No data | No data | No data | No data | No data | No data | No data | No data | No data

a All data are from HSDB 2004 unless otherwise noted.

b Crop Protection Handbook 2004

c Budavari 1989

CAS = Chemical Abstracts Service; DOT/UN/NA/IMO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Cyanide and Compounds

Property | Hydrogen cyanide | Sodium cyanide | Potassium cyanide | Calcium cyanide | Potassium silver cyanide | Cyanogen | Cyanogen chloride | Copper(l) cyanide | Ammonium thiocyanate
Molecular weight | 27.03^a^ | 49.01^a^ | 65.12^a^ | 92.12^a^ | 199.01^b^ | 52.04^a^ | 61.47^a^ | 89.56^a^ | 76.12^a^
Color | Colorless^b^ | White^b^; colorless^a^ | White^b^; colorless^a^ | White^a^ | White^b^ | Colorless^a^ | Colorless^d^ | White to cream-colored^b^ | Colorless^a^
Physical state | Gas or liquid^b^ | Solid^b^ | Solid^b^ | Solid^a^ | Solid^b^ | Gas^a^ | Gas^d^ | Solid^a^ | Solid^a^
Melting point, °C | −13.4^b^ | 563.7^a^ | 634.5^a^ | Decomposes at >350 °C^a^ | No data | −27.9^a^ | −6^a^ | 473 (in N_2_)^a^ | 149.6^a^
Boiling point, °C | 25.70^c^ | 1496^a^ | No data | No data | No data | −20.7^a^ | 13.8^b^;12.7^a^ | Decomposes^a^ | 170 decomposes^a^
Density, g/cm^3^ | 0.6884 (liquid at 20 °C)^c^ | 1.60 (for cubic form)^c^ | 1.553 (for cubic form)^c^ | 1.8–1.9 (commercial product)^c^ | 2.36^a^ | 0.9577 at −21.17 °C^a^ | 1.186^b^ | 2.92^a^ | 1.305^a^
Odor | Faint bitter almond odor^d^ | Odorless when dry, emits slight odor of HCN in damp air^b^ | Faint bitter almond odor^b^ | Faint bitter almond odor^b^ | No data | Almond-like odor^b^ | Highly irritating^h^ | No data | Odorless^b^
Odor threshold:
Water | 0.17 ppm (w/v)^e^ | No data | No data | No data | No data | No data | No data | No data | No data
Air | 0.58 ppm (v/v)^e^; 0.8–4.4 ppm^f^ | No data | No data | No data | No data | 230 ppm; irritating at 15 ppm^f^ | 1 ppm^f^ | No data | No data
Solubility:
Water | Miscible^a^ | 48 g/100 mL at 10 °C^c^ | 71.6 g/100 mL at 25 °C^c^ | Soluble in water with gradual liberation of HCN^b^ | Soluble^b^; 250 g/L (25 °C)^m^ | 450 cc/100 cc (20 °C)^a^ | Soluble^b^; 27.5 mg/L (25 °C)^m^ | 2.6 mg/L (25°C)^m^ | 128 g/100 cc at 0 °C^a^; Very soluble in hot water^a^; 181 g/100 cc at 25 °C^p^
Organic solvent(s) | Soluble in ethanol, ether^a^ | Slightly soluble in ethanol^a^ and formamide^c^ | Slightly soluble in ethanol^c^ and methanol^b^ | | Slightly soluble in ethanol^a^ | Soluble in ethanol and ethyl ether^a^ | Soluble in ethanol and ethyl ether^b^ | Insoluble in alcohol^f^ | Very soluble in ethanol; soluble in acetone and methanol; insoluble in ethyl acetate and chloroform^b^
Partition coefficients:
Log K_ow_ | 0.66^g^; 1.07 (calc.)^h^ | 0.44^g^ | No data | No data | No data | 0.07^n^ | No data | No data | No data
Log K_oc_ | No data | No data | 3.0 (calculated)^l^ | No data | No data | No data | No data | No data | No data
Vapor pressure, mm Hg | 630 (at 20 °C)^f^ | 0.76 at 800 °C^c^ | No data | No data | No data | 3,800 at 20 °C^o^ | 760 at 13.8 °C | No data | No data
Henry’s law constant | 5.1×10^−2^ atm-m^3^/mol^i^ | No data | No data | No data | No data | No data | 3.2×10^−3^ atm-m^3^/mol^m^ | No data | No data
Autoignition temperature | 538^c^ | No data | No data | No data | No data | No data | No data | No data | No data
Flashpoint, °C | −17.8 (closed cup)^c^ | No data | No data | No data | No data | No data | No data | No data | No data
Flammability limits | 5.6–40%^j^ | Not combustible^j^ | Not combustible^j^ | Not combustible^j^ | No data | 6.6–32% in air^j^ | Not combustible^f^ | Does not readily ignite^f^ | May be combustible^f^
Conversion factors:
mg/m^3^ to ppm in air, 20 °C | 1 mg/m^3^ = 0.890 ppm | NA^k^ | NA^k^ | NA^k^ | NA^k^ | 1 mg/m^3^ = 0.462 ppm | 1 mg/m^3^ = 2.5 ppm | NA^k^ | NA^k^
ppm to mg/L in water | ppm (w/v) = mg/L = μg/mL | ppm (w/v) = mg/L = μg/mL | ppm (w/v) = mg/L = μg/mL | ppm (w/v) = mg/L = μg/mL | ppm (w/v) = mg/L = μg/mL | ppm (w/v) = mg/L = μg/mL | ppm (w/v) = mg/L = μg/mL | ppm (w/v) = mg/L = μg/mL | ppm (w/v) = mg/L = μg/mL
ppm to mg/kg in soluble samples | ppm (w/w) = mg/kg = μg/g | ppm (w/w) = mg/kg = μg/g | ppm (w/w) = mg/kg = μg/g | | ppm (w/w) = mg/kg = μg/g | ppm (w/w) = mg/kg = μg/g | ppm (w/w) = mg/kg = μg/g | ppm (w/w) = mg/kg = μg/g | ppm (w/w) = mg/kg = μg/g
Explosive limits | Upper, 40%; lower, 5.6%^f^ | No data | No data | No data | No data | No data | No data | No data | No data

a Lide 1990

b Budavari 1989

c Jenks 1979

d Hawley 1981

e Amoore and Hautala 1983

f HSDB 2004

g EPA 1984a

h Verschueren 1983

i Yoo et al. 1986; value at 25 °C and saturation pressure

j NFPA 1994

k Since these compounds do not exist in the atmosphere in the vapor phase, their concentrations are always expressed in weight by volume unit (e.g., mg/m^3^).

l Kenaga 1980

m EPA 1985f

n Hansch et al. 1995

o EPA 1978c

p Lide 2005

EPA = Environmental Protection Agency; HCN = hydrogen cyanide; HSDB = Hazardous Substances Data Bank; NA = not applicable

Hydrogen cyanide has a pK_a_ of 9.2 (Smith and Martell 1989); therefore, solutions of cyanide compounds in water (such as from sodium cyanide and potassium cyanide) can form hydrogen cyanide at acid and neutral pHs. Alkaline solutions with pH >12 are practical for preventing significant outgassing of hydrogen cyanide.

Hydrogen cyanide is a fire hazard and may be explosive when an excess of a strong acid is added to confined hydrogen cyanide. Solutions of some cyanide compounds are not stable and may decompose upon exposure to air or light.