# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Environmental Medicine, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Environmental Medicine, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-32, Atlanta, Georgia 30333.

## Cyanide and compounds Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Cyanide and compounds
CAS Numbers:
Date: | March 2006
Profile Status: | Post Public, Final
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 21
Species: | Rat

[underlined: Minimal Risk Level]: 0.05 [X] mg/kg/day [ ] ppm

[underlined: Reference]: NTP. 1993. NTP technical report on toxicity studies of sodium cyanide administered in drinking water to F344/N rats and B6C3F1 mice. Toxicity Report No. 37. National Toxicology Program, U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. NIH Publication 94-3386.

[underlined: Experimental design]: For the main study, 10 male and 10 female rats were given drinking water containing sodium cyanide at concentrations of 0, 3, 10, 30, 100, or 300 ppm for 13 weeks. A supplemental set of 10 males/group was assigned for interim examinations of hematology, clinical chemistry, and urinalysis examinations. The intakes of cyanide during that period averaged 0, 0.2, 0.5, 1.4 (males) or 1.7 (females), 4.5 (males) or 4.9 (females), or 12.5 mg/kg/day, respectively. Rats in the base study were observed twice daily. Body weights were recorded at the start of the study, weekly thereafter, and at necropsy. Clinical observation were recorded weekly. Water consumption by cage was measured weekly. Blood from the base study rats was collected on days 86 (males) and 93 (females), and from the supplemental study rats on days 5, 25, 45, and 92 for hematology and clinical chemistry. Urinalysis samples were collected from the supplemental rats on days 8, 22, 43, and 88. Complete necropsies were performed for all rats in the base study. The heart, kidneys, liver, lung, testes, and thymus were weighed. Complete histopathologic examinations of all gross lesions, tissue masses, and more than 35 tissues were performed on all animals in the 0 and 12.5 mg/kg/day dose groups. In the other exposed groups, all gross lesions, the liver (males only), spleen, and urinary bladder were examined for histopathology. Functional reproductive parameters were evaluated in main study rats in the 0, 30, 100, and 300 ppm groups. Vaginal cytology and sperm motility evaluations were performed for 12 days prior to sacrifice. Numbers of leukocytes, nucleated epithelial cells, and large squamous epithelial cells were determined from vaginal swabs to ascertain estrous cycle stage and the percentage of cycle spent in the various stages; the vagina in these rats was examined for histopathology. At necropsy, reproductive tissue weights were recorded for males, and data were recorded for epididymal sperm motility, density, and spermatogenesis.

[underlined: Effects noted in study and corresponding doses]: Exposure to cyanide had no significant effect on survival, body weight gain, the incidence of clinical signs, nonreproductive organ weights (absolute or relative to body weight), hematology, or clinical chemistry parameters. Water consumption was about 10% lower in the two highest exposure groups, and concomitantly, urine volume was decreased and urine specific density was increased; the authors suggested that these findings indicated a palatability problem at the two highest doses. Urinary thiocyanate levels were increased in most exposed groups, indicative of biotransformation of ingested cyanide. No treatment-related gross or histopathologic lesions were observed in rats, including potential target tissues such as the corpus callosum of the brain and the follicular epithelium of the thyroid gland (susceptible to the anti-thyroid effects of the metabolite thiocyanate).

Some cyanide-related effects were observed in the study of reproductive parameters. Statistically significant decreases compared to controls were observed in the absolute weights of the left epididymis (−7%), left cauda epididymis (−13%), and left testis (−7.6%) of rats treated at 12.5 mg/kg-day. In addition, 13.6% reductions compared to controls were observed in spermatid heads per testis and and spermatid counts per mL suspension in rats treated at 12.5 mg/kg/day. The authors considered these to be evidence of a mild adverse effect of cyanide on the male reproductive system. The statistically significant reductions (7.4–8.6% lower than controls) in left cauda epididymis weights observed at 1.4 and 4.5 mg/kg/day were not considered biologically significant in the absence of any other significant effect. The small (<4%), statistically significant, but not dose-related, reductions observed in spermatozoa motility in the 1.4, 4.5, and 12.5 mg/kg/day groups were within the range of normal values and were not considered biologically significant by the authors. For females, significantly (p=0.03, Wilk’s Criterion) more time was spent in proestrus and diestrus stages and less time in estrus and metestrus stages in the 4.9 and 12.5 mg/kg/day dose groups than in controls, but a dose-relationship was not observed. For this reason, the authors did not consider these results unequivocal proof that cyanide adversely affects the female reproductive system.

[underlined: Dose and end point used for MRL derivation]: 4.5 mg/kg/day, based on the NOAEL for no reproductive effects in male rats.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]: 100

- [ ] 00 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

MRL = 4.5 mg/kg/day/100 = 0.05 mg/kg/day

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] Yes. [underlined: If so, explain:] The doses based on water consumption as reported by NTP (1993) were 0, 0.3, 0.9, 1.0, 2.7, 3.2, 8.5, 9.2, 23.5, and 23.6 mg NaCN/kg/day. These doses were converted from sodium cyanide to cyanide by multiplying each dose by 0.53 (CN^−^/NaCN); resulting in dose levels of 0, 0.2, 0.5, 1.4 (males), 1.7 (females), 4.5 (males), 4.9 (females), or 12.5 mg/kg/day cyanide.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:] NA

[underlined: Was a conversion used from intermittent to continuous exposure?] NA

[underlined: Other additional studies or pertinent information that lend support to this MRL:] No studies are available for the intermediate-duration oral toxicity of humans exposed to known quantities of cyanide, but there are a number of studies in animals exposed to sodium or potassium cyanide (as discussed in Section 3.2.2). However, not all studies are suitable for establishing dose-response relationships. Several studies (Gerhart 1986, 1987; Jackson 1988: Soto-Blanco et al. 2002a) in rats and pigs report neurological, thyroid, and gastrointestinal effects following gavage administration of cyanide; however, their usefulness for dose-response assessment is limited because the bolus dosing may overwhelm the detoxification process and is not characteristic of typical general population exposures to cyanide in drinking water. Similarly, although a toxicity study in dogs receiving sodium cyanide reported effects in the male reproductive system, adrenal gland, and kidney, the lower levels of the detoxifying enzyme rhodanese in this species both increases the sensitivity to cyanide and prevents the production of the metabolite thiosulfate to levels that would be toxic to the thyroid as seen in humans and other animals (Kamalu 1993). Additionally, studies involving exposure to cyanide via a cassava diet (Tewe and Maner 1981a, 1981b) were not considered as the basis of an MRL because there is evidence suggesting that other toxic compounds, such as scopoletin, may contribute to the observed toxic effects (Kamalu 1993).

In rat and mice exposed to sodium cyanide in drinking water for 13 weeks (NTP 1993), reproductive effects in males were the only adverse effects observed. Effects on male reproduction included reductions in epididymal weights (−13%), testicular weights (−8%), and spermatid counts (−13.6%) in F344 rats exposed to 12.5 mg CN^−^/kg/day, and 10–18% reductions in epididymal/caudal epididymal weights in B6C3F1 mice exposed to 24.3 mg CN^−^/kg/day. In rabbits exposed to sodium cyanide in the diet at doses of 15 mg CN^−^/kg/day for 4 weeks or 20 mg CN^−^/kg/day for 40 weeks, hepatic toxicity (fatty degeneration and necrosis of the liver, increased serum levels of succinate dehydrogenase, alanine aminotransferase, and alkaline phosphatase) and renal toxicity (tubular necrosis) were observed (Okolie and Iroanya 2003; Okolie and Osagie 1999). Neurotoxicity (myelin degeneration in the spinal cord) was observed in rats exposed at 30 mg CN^−^/kg/day as potassium cyanide in food for 11.5 months (Philbrick et al. 1979). Effects on male reproduction were severe in dogs (germ cell sloughing and degeneration, reduced spermatogenesis cycle) (Kamalu 1993) and also observed in rats and mice in studies in which no other systemic effects were observed. Hepatic, renal, and body weight effects were reported in Wistar rats that received doses of 3.6 mg CN^−^/kg/day as potassium cyanide in drinking water for 15 days (Sousa et al. 2002a). However, the reliability of these findings is questionable because of the lack of incidence data for the histopathological lesions and because no body weight effects were noted in other rat studies with exposures for longer durations and at higher doses. On the basis of these considerations, reproductive toxicity in males is selected as the critical effect of cyanide toxicity. The NTP (1993) bioassay in rats is selected as the principal study because it provided the lowest LOAEL and a NOAEL for the critical effect and examined the full range of tissues with extensive interim hematological, clinical chemistry, and urinalyses.

[underlined: Agency Contacts (Chemical Managers)]: Jessilynn Taylor, Nickolette Roney, Carolyn Harper