# 9 REFERENCES

*Not cited in text

ACGIH. 2005. Cresols. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 24.
Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Fed Regist 54(174):37618–37634.
AIChE. 1989. o-, p-Cresols. C7H8O. In: Physical and thermodynamic properties of pure chemicals. American Institute of Chemical Engineers, Design Institute for Physical Property Data. Philadelphia, PA: Taylor and Francis.
AIChE. 2000. m-Cresols. C7H8O. In: Physical and thermodynamic properties of pure chemicals. American Institute of Chemical Engineers, Design Institute for Physical Property Data. Philadelphia, PA: Taylor and Francis.
Alexander M, Lustigman BK. 1966. Effect of chemical structure on microbial degradation of substituted benzenes. J Agric Food Chem 14:410–413.
Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
Altmann HJ, Grunow W, Mohr U, . 1986. Effects of BHA and related phenols on the forestomach of rats. Food Chem Toxicol 24(10/11):1183–1188.3804120
Amoore JE, Hautala E. 1983. Odor as an aid to chemical safety: Odor thresholds compared with threshold limit values and volatilities for 214 industrial chemicals in air and water dilution. J Appl Toxicol 3(6):272–290.6376602
Andelman JB, Wachter JK, Nolle S, . 1984. Organic water quality and other factors in poultry plant wastewater renovation and reuse. Water Res 18(7):843–854.
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ III, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
Angerer J, Kramer A. 1997. Occupational chronic exposure to organic solvents. XVI. Ambient and biological monitoring of workers exposed to toluene. Int Arch Occup Environ Health 69:91–96.9001914
Angerer J, Wulf H. 1985. Occupational chronic exposure to organic solvents. XI. Alkylbenzene exposure of varnish workers: Effects on hematopoietic system. Int Arch Occup Environ Health 56:307–321.4066054
Araki N, Ohno K, Nakai M, . 2005. Screening for androgen receptor activities in 253 industrial chemicals by in vitro reporter gene assays using AR-EcoScreen cells. Toxicol In Vitro 19(6):831–842.15950433
Arrendale RF, Severson RF, Chortyk OT, . 1982. Analyses of mono- and dihydroxybenzenes in tobacco smoke and pyrolyzates by glass capillary gas chromatography. J Chromatogr Sci 20(3):136–143.
Artiola-Fortuny J, Fuller WH. 1982. Adsorption of some monohydroxybenzene derivatives by soils. Soil Sci 133:18–26.
*Arvin E, Jensen B, Aamand J, . 1988. The potential of free-living ground water bacteria to degrade aromatic hydrocarbons and heterocyclic compounds. Water Sci Technol 20(3):109–118.
Assmuth T, Kalevi K. 1992. Concentrations and toxicological significance of trace organic compounds in municipal solid waste landfill gas. Chemosphere 24(9):1207–1216.
Atkinson R. 1985. Kinetics and mechanisms of the gas-phase reactions of the hydroxyl radical with organic compounds under atmospheric conditions. Chem Rev 85:69–201.
Atkinson R, Carter WPL. 1984. Kinetics and mechanisms of the gas-phase reactions of ozone with organic compounds under atmospheric conditions. Chem Rev 84:437–470.
Atkinson R, Carter WPL, Darnall KR, . 1980. A smog chamber and modeling study of the gas phase NO_x_ air photo-oxidation of toluene and the cresols. Int J Chem Kinet 12:779–836.
Atkinson R, Carter WPL, Plum CN, . 1984. Kinetics of the gas-phase reactions of NO_3_ radicals with a series of aromatics at 2962 K. Int J Chem Kinet 16:887–898.
Babeu L, Vaishnav DD. 1987. Prediction of biodegradability for selected organic chemicals. J Ind Microb 2:107–115.
Baird RB, Kuo CL, Shapiro JS, . 1974. The fate of phenolics in wastewater—determination by direct-injection GLC and Warburg respirometry. Arch Environ Contam Toxicol 2:165–178.4854833
Bammens B, Evenepoel P, Keuleers H, . 2006. Free serum concentrations of the protein-bound retention solute p-cresol predict mortality in hemodialysis patients. Kidney Int 69(6):1081–1087.16421516
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Bartholomew GW, Pfaender FK. 1983. Influence of spatial and temporal variations on organic pollutant biodegradation rates in an estuarine environment. Appl Environ Microbiol 45(1):103–109.6824312
Bassler BJ, Hartwick RA. 1989. The application of porous graphitic carbon as an HPLC stationary phase. J Chromatogr Sci 27(4):162–165.
Battersby NS, Wilson V. 1988. Evaluation of a serum bottle technique for assessing the anaerobic biodegradability of organic chemicals under methanogenic conditions. Chemosphere 17:2441–2460.
Battersby NS, Wilson V. 1989. Survey of the anaerobic biodegradation potential of organic chemicals in digesting sludge. Appl Environ Microbiol 55:433–439.16347851
Bayly RC, Wigmore GJ. 1973. Metabolism of phenol and cresols by mutants of Pseudomonas putida. J Bacteriol 113:1112–1120.4347965
Bedient PB, Springer NK, Baca E, . 1983. Ground-water transport from wastewater infiltration. J Environ Eng 109(2):485–501.
Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag, 3–7.
Bethune DN, Farvolden RN, Ryan MC, . 1996. Industrial contamination of a municipal water-supply lake by induced reversal of ground-water flow, Managua, Nicaragua. Ground Water 34(4):699–708.
Bieniek G. 1994. Concentrations of phenol, o-cresol, and 2,5-xylenol in the urine of workers employed in the distillation of the phenolic fraction of tar. Occup Environ Med 51(5):354–356.8199688
Bieniek G. 1997. Urinary excretion of phenols as an indicator of occupational exposure in the coke-plant industry. Int Arch Occup Environ Health 70(5):334–340.9352337
Bieniek G, Wilczok T. 1986. Separation and determination of phenol, α-naphthol, m-, p- and o-cresols, 2,5-xylenol, and catechol in the urine after mixed exposure to phenol, naphthalene, cresols, and xylenols. Br J Ind Med 43(8):570–571.3730312
Boatto G, Nieddu M, Carta A, . 2004. Determination of phenol and o-cresol by GC/MS in a fatal poisoning case. Forensic Sci Int 139(2–3):191–194.15040915
Boutwell RK, Bosch DK. 1959. The tumor-promoting action of phenol and related compounds for mouse skin. Cancer Res 19:413–424.13652126
Boyd SA. 1982. Adsorption of substituted phenols by soil. Soil Sci 134:337–343.
Boyd SA, Shelton DR, Berry D, . 1983. Anaerobic biodegradation of phenolic compounds in digested sludge. Appl Environ Microbiol 46:50–54.6614908
Bray HG, Thrope WV, White K. 1950. Metabolism of derivatives of toluene. Biochem J 46:275–278.16748675
Bronstein AC, Currance PL. 1988. Emergency care for hazardous materials exposure. Washington, DC: The C.V. Mosby Company, 201–202.
Bruce AM, Smith H, Watson AA. 1976. Cresol poisoning. Med Sci Law 16:171–176.950908
Brusick DJ. 1988a. Mutagenicity tests on o-cresol in the in vitro transformation of BALB/C-3T3 cells assay in the presence of rat liver cell activation system. Chemical Manufacturers Association. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0517697.
Brusick DJ. 1988b. Mutagenicity tests on meta-cresol and para-cresol in the in vitro transformation of BALB/C-3T3 cells assay. Chemical Manufacturers Association. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0517694.
Brusick DJ. 1988c. Mutagenicity tests on m-cresol in the in vitro transformation of BALB/C-3T3 cells assay. Chemical Manufacturers Association. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0517698.
Calderón-Guzmán D, Hernandez-Islas J, Vazquez IRE, . 2005. Effect of toluene and cresols on Na,K-ATPase, and serotonin in rat brain. Regul Toxicol Pharmacol 41(1):1–5.15649823
Campbell I. 1941. Petroleum cresylic acids. A study of their toxicity and the toxicity of cresylic disinfectants. Soap Sanit Chem 17(4):103.
Canter LW, Sabatini DA. 1994. Contamination of public ground water supplies by Superfund sites. Int J Environ Stud 46:35–57.
Cardwell TJ, Hamilton IC, McCormick MJ, . 1986. Determination of alkylphenols in refinery effluents by liquid chromatography using electrochemical detection. Environ Anal Chem 24:23–35
Carter WPL, Winer AM, Pitts JN Jr. 1981. Major atmospheric sink for phenol and the cresols: Reaction with the nitrate radical. Environ Sci Technol 15(7):829–831.
Cason JS. 1959. Report on three extensive industrial chemical burns. Br Med J 1:827–829.13629134
Cautreels W, Van Cauwenberghe K. 1978. Experiments on the distribution of organic pollutants between airborne particulate matter and the corresponding gas phase. Atmos Environ 12:1133–1141.
Cha YJ, Cadwallader KR. 1995. Volatile components in salt-fermented fish and shrimp pastes. J Food Sci 60:19–24.
Chambers CW, Tabak HH, Kabler PW. 1963. Degradation of aromatic compounds by phenol-adapted bacteria. J Water Pollut Contr Fed 35:1517–1528.
Chan TK, Mak LW, Ng RP. 1971. Methemoglobinemia, Heinz bodies and acute massive intravascular hemolysis in Lysol poisoning. Blood 38:739–744.4256663
Chao J, Lin CT, Chung TH. 1983. Vapor pressure of coal chemicals. J Phys Chem Ref Data 12(4):1033–1063.
ChemID. 2006. Cresols. ChemIDplus. National Library of Medicine. http://chem.sis.nlm.nih.gov/chemidplus/cmplxqry.html. July 24, 2008.
Cheng M, Kligerman AD. 1984. Evaluation of the genotoxicity of cresols using sister-chromatid exchange (SCE). Mutat Res 137(1):51–55.6749167
Chung HY. 1999. Volatile components in fermented soybean (glycine max) curds. J Agric Food Chem 47:2690–2696.10552546
Cifone MA. 1988a. Mutagenicity tests of p-cresol and m-cresol in a mouse lymphoma mutation assay. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0517693.
Cifone MA. 1988b. Mutagenicity tests on meta-cresol in a rat primary hepatocyte unscheduled DNA synthesis assay. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0517692
CIIT. 1983. Preliminary result of in vivo and in vitro sister chromatid exchange assays on cresol isomers and of an immunological evaluation of o-cresol. Memorandum to Office of Pesticides and Toxic Substances. Research Triangle Park, NC: Chemical Industry Institute of Toxicology. CIIT Docket no. 12283.
Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
CLPSD. 1988. Contract Laboratory Program Statistical Database. Alexandria, VA: Viar and Company, August 16, 1988.
CMR. 2004. Chemical profile: Cresylics. Chem Market Rep March 22, 2004:31.
Conoco. 1975. Acute toxicity studies of ortho-cresol in rats and rabbits. Conoco Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS206095.
Conoco. 1976. Skin corrosiveness test in rabbits. Conoco Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS206095.
Cote MA, Lyonnais J, Leblond PF. 1984. Acute Heinz-body anemia due to severe cresol poisoning: Successful treatment with erythrocytapheresis. Can Med Assoc J 130(10):1319–1322.6722696
Czuczwa J, Levenberger C, Tremp J, . 1987. Determination of trace levels of phenol and cresols in rain by continuous liquid-liquid extraction and high-performance liquid chromatography. J Chromatogr 403:233–241.3680411
Daugherty JP, Franks H. 1986. Effect of monocyclic derivatives on DNA repair in human lymphocytes. Res Commun Chem Pathol Pharmacol 54(1):133–136.3797804
Deichmann WB, Witherup S. 1944. Phenolic studies VI: The acute and comparative toxicity of phenol and o-, m-, and p-cresols for experimental animals. J Pharmacol Exp Ther 80:233–240.
Dellal V. 1931. Acute pancreatitis following Lysol poisoning. Lancet 1:407.
Demirjian YA, Joshi AM, Westman TR. 1987. Fate of organic compounds in land application of contaminated municipal sludge. J Water Pollut Control Fed 59:32–38.
Demirjian YA, Westman TR, Joshi AM, . 1984. Land treatment of contaminated sludge with wastewater irrigation. J Water Pollut Control Fed 56:370–377.
DeRosa E, Bartolucci GB, Sigon M, . 1987. Hippuric acid and ortho-cresol as biological indicators of occupational exposure to toluene. Am J Ind Med 11(5):529–537.3591803
De Smet R, David F, Sandra P, . 1998. A sensitive HPLC method for the quantification of free and total p-cresol in patients with chronic renal failure. Clin Chim Acta 278(1):1–21.9877120
De Smet R, Glorieux G, Hsu C, . 1997. p-Cresol and uric acid: Two old uremic toxins revisited. Kidney Int 52(62):S8–S11.
De Smet R, Van Kaer J, Van Vlem B, . 2003. Toxicity of free p-cresol: A prospective and cross-sectional analysis. Clin Chem 49(3):470–478.12600960
DeWolf WE, Carr SA, Varrichio A, . 1988. Inactivation of dopamine β-hydroxylase by p-cresol: Isolation and characterization of covalently modified active site peptides. Biochemistry 27:9093–9101.3242615
Dietrich AM, Chesnutt SA, Stone LA, . 1993. Determination of organic pollutants in land applied municipal wastewater sludges by toxicity characteristic leaching procedure (TCLP) and extraction procedure toxicity test (EP). Water Environ Res 65:612–619.
Dobbins DC, Pfaender FK. 1988. Methodology for assessing respiration and cellular incorporation of radiolabeled substrates by soil microbial communities. Microb Ecol 15:257–273.24201405
Dobson KR, Stephenson M, Greenfield PF, . 1985. Identification and treatability of organics in oil shale retort water. Water Res J 19:849–856.
DOE. 1985. Detection of organic acids in atmosphere precipitation. Granville, OH: U.S. Department of Energy. DE8005294.
DOE. 1997a. Method OH100R-2: Direct analysis of TCLP acidic semivolatile compounds in radioactive liquid wastes or leachates using HPLC with ultraviolet absorbance detection. U.S. Department of Energy. http://web1.er.usgs.gov/nemi/method_pdf/4773.pdf. May 23, 2006.
DOE. 1997b. Method OM100R: Semivolatile organic compounds in multimedia samples by capillary column ion trap MS. U.S. Department of Energy. http://web1.er.usgs.gov/nemi/method_pdf/4795.pdf. May 23, 2006.
Dou L, Bertrand E, Cerini C, . 2004. The uremic solutes p-cresol and indoxyl sulfate inhibit endothelial proliferation and wound repair. Kidney Int 65(2):442–451.14717914
Dou L, Cerini C, Brunet P, . 2002. p-Cresol, a uremic toxin, decreases endothelial cell response to inflammatory cytokines. Kidney Int 62(6):1999–2009.12427124
Douglas GR, Nestmann ER, Betts JL, . 1980. Mutagenic activity in pulp mill effluents. Water Chlorin Environ Impact Health Eff 3:865–880.
Dow. 1978. Acute toxicological properties and industrial handling hazards of cresol (ortho, meta, para isomers). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS206146.
Dreibelbis WG, Ealy JA, Porter WE. 1985. Industrial hygiene monitoring for evaluation of employee exposure and control measures in coal conversion program at Oak Ridge National Laboratory. In: Cooke M, Dennis AJ, eds. Polynuclear aromatic hydrocarbons: Mechanisms, methods and metabolism. Columbus, OH: Battelle Press, 351–363.
Drinkwater LA, Zoltek J Jr, Delfino JJ. 1986. Bench scale treatability of leachate from an abandoned phenolic waste site. J Water Pollut Control Fed 58(11):1057–1065, 644A.
Eastman Kodak. 1978. Toxicity and health hazard summary for o-, m-, and p-cresol. Eastman Kodak Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS206539.
EI du Pont. 1969. Toxicity data sheets for o-, p-, and m-cresol. EI du Pont Denemours & Co. Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS205862.
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15:30–38.
Ellenhorn MJ, Schonwald S, Ordog G, . 1997. Cresols. Ellenhorn’s medical toxicology: Diagnosis and treatment of human poisoning. 2nd ed. Baltimore, MD: Williams and Wilkins, 1210–1211.
EPA. 1978. Environmental pathways of selected chemicals in freshwater systems. Part II: Laboratory studies. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600778074.
EPA. 1979. Treatability and assessment of coal conversion wastewaters: Phase I. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600779248.
EPA. 1981. Development of test for determining anaerobic biodegradation potential. Washington, DC: U.S. Environmental Protection Agency. EPA560581013.
EPA. 1988a. Protection of the environment. Washington,DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136.3.
EPA. 1988b. Subchronic toxicity of ortho-cresol in Sprague Dawley rats. Washington, DC: U.S. Environmental Protection Agency. PB88197496.
EPA. 1988c. Subchronic toxicity of para-cresol in Sprague Dawley rats. Washington, DC: U.S. Environmental Protection Agency. PB88195292.
EPA. 1988d. Subchronic toxicity of meta-cresol in Sprague Dawley rats. Washington, DC: U.S. Environmental Protection Agency. PB88195292.
EPA. 1988e. National ambient volatile organic compound (VOCs) data base update. Washington, DC: U.S. Environmental Protection Agency. EPA600388010a.
EPA. 1990a. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066A.
*EPA. 1990b. Characterization of municipal waste combustion ash, ash extracts, and leachates. Philadelphia, PA: Environmental Protection Agency. EPA530SW90029A.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
EPA. 1998. Method 8270D: Semivolatile organic compounds by GC/MS. In: Draft update IVA of SW-846 on-line. U.S. Environmental Protection Agency. http://www.epa.gov/epaoswer/hazwaste/test/up4a.htm. April 1, 2006.
EPA. 2000a. Benchmark dose technical guidance document. Washington, DC: U.S. Environmental Protection Agency. EPA630R00001.
EPA. 2000b. Method 528: Determination of phenols in drinking water by solid phase extraction and capillary column gas chromatography/mass spectrometry (GC/MS). In: Methods for the determination of organic and inorganic compounds in drinking water, volume 1. Washington, DC: U.S. Environmental Protection Agency.
EPA. 2000c. Method 8041A: Phenols in aqueous and non-aqueous samples by capillary GC/FID or GC/ECD and single or dual columns. In: Draft update IVB of SW-846 on-line. U.S. Environmental Protection Agency. http://www.epa.gov/epaoswer/hazwaste/test/pdfs/8041a.pdf. May 23, 2006.
EPA. 2000d. National air pollutant emission trends, 1900-1998. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. EPA454R00002.
EPA. 2001. Method 1625: Semivolatile organic compounds by isotope dilution GCMS. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR Part 136, Appendix A. http://web1.er.usgs.gov/nemi/method_pdf/4686.pdf. May 23, 2006.
EPA. 2004. Drinking water standards and health advisories. Washington, DC: Office of water, U.S. Environmental Protection Agency. http://epa.gov/waterscience/criteria/drinking/. March 7, 2006.
EPA. 2005a. Analytical method for the analysis of semivolatile organic compounds. Multi-media, multi-concentration organics analysis, SOM01.1. U.S. Environmental Protection Agency, Superfund Analytical Services, Contract Laboratory Program. http://www.epa.gov/superfund/programs/clp/download/som/som11d-svoa.pdf. April 12, 2006.
EPA. 2005b. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. Office of Environmental Information. EPA260B05001.
EPA. 2005c. Guidelines for carcinogen risk assessment. Washington, DC: U.S. Environmental Protection Agency. EPA630P03001F.
EPA. 2006a. Acute Exposure Guideline Levels (AEGLs). Washington, DC: Office of Pollution Prevention and Toxics. U.S. Environmental Protection Agency. http://epa.gov/oppt/aegl/chemlist.htm. March 14, 2006.
EPA. 2006b. Designated as hazardous substances in accordance with section 311(b)(2)(A) of the Clean Water Act. Washington, DC: U.S. Environmental Protection Agency. http://epa.gov/epacfr40/chapt-I.info/chi-toc.htm. March 7, 2006.
EPA. 2006c. Hazardous air pollutants. Clean Air Act. U.S. Environmental Protection Agency. United States Code. 42 USC 7412. http://www.epa.gov/ttn/atw/orig189.html. March 7, 2006.
EPA. 2006d. Identification and listing of hazardous waste. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, Appendix VIII. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. March 8, 2006.
EPA. 2006e. National recommended water quality criteria. Washington, DC: Office of Water, Office of Science and Technology, U.S. Environmental Protection Agency. http://www.epa.gov/waterscience/criteria/nrwqc-2006.pdf. January 8, 2008.
EPA. 2006f. Table 117.3. Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3. http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/40cfr117.3.pdf. January 8, 2008.
EPA. 2006g. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/40cfr302.4.pdf. January 8, 2008.
EPA. 2006h. Superfund, emergency planning, and community right-to-know programs. Extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355, Appendix A. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. March 8, 2006.
EPA. 2006i. Toxic chemical release reporting: Community right-to-know. Chemicals and chemical categories to which this part applies. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/40cfr372.65.pdf. January 8, 2008.
*EPA. 2006j. Cresols. Modernized STORET system: Regular results by project (stormodb): Characteristic search by CAS number. U.S. Environmental Protection Agency. http://www.epa.gov/storet/dbtop.html. April 12, 2006.
Evers J, Aboudan F, Lewalter J, . 1994. Hemodialysis in metacresol poisoning. Clin Invest 72(6):472.
Faust BC, Holgné J. 1987. Sensitized photooxidation of phenols by fulvic acid in natural waters. Environ Sci Technol 21:957–964.19994993
FDA. 2005. Beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. http://a257.g.akamaitech.net/7/257/2422/01apr20051500/edocket.access.gpo.gov/cfr_2005/aprqtr/pdf/21cfr165.110.pdf. January 8, 2008.
Fedorak PM, Hrudey SE. 1984. The effects of phenol and some alkyl phenolics on batch anaerobic methanogenesis. Water Res 18:361–367.
Fedorak PM, Hrudey SE. 1986. Nutrient requirements for the methanogenic degradation of phenol and p-cresol in anaerobic draw and feed cultures. Water Res 20(7):929–933.
FEDRIP. 2006. Cresols. Federal Research in Progress database. Springfield, VA: National Technical Information Service.
Ferro Corp. 1974. Skin irritation in albino rabbits after application of o-, m-, and p-cresol. Ferro Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0517499.
Fiege H, Bayer AG. 1987. Cresols and xylenols. In: Ullman’s encyclopedia of industrial chemistry. Leverkusen, Federal Republic of Germany, 25–29.
Fischer B. 1955. Significance of Heinz bodies in anemia of obscure etiology. Am J Med Sci 230:143–146.14398692
Finzer KH. 1961. Lower nephron nephrosis due to concentrated Lysol vaginal douches: A report of two cases. Can Med Assoc J 84:549.13699712
Florin I, Rutberg L, Curvall M, . 1980. Screening of tobacco smoke constituents for mutagenicity using the Ames’ test. Toxicol 15(3):219–232.
Fomon SJ. 1966. Body composition of the infant: Part I: The male reference infant. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Fraser MP, Cass GR, Simoneit BRT, . 1998. Air quality model evaluation data for organics C6-C22 nonpolar and semipolar aromatic compounds. Environ Sci Technol 32:1760–1770.
Freitag D, Ballhorn L, Geyer H, . 1985. Environmental hazard profile of organic chemicals: An experimental method for the assessment of the behaviour of organic chemicals in the ecosphere by means of simple laboratory tests with 14C labeled chemicals. Chemosphere 14(10):1589–1616.
Freitag D, Geyer H, Kraus A, . 1982. Ecotoxicological profile analysis: VII. Screening chemicals for their environmental behavior by comparative evaluation. Ecotoxicol Environ Safety 60:60–81.
Fuke C, Sakai Y, Yagita K, . 1998. The quantitative analysis of cresols in a case of cresol poisoning following percutaneous absorption. Chudoku Kenkyu 11(1):55–60.
Fustinoni S, Mercadante R, Campo L, . 2007. Comparison between urinary o-cresol and toluene as biomarkers of toluene exposure. J Occup Environ Hyg 4(1):1–9.17162475
Gaffney JS, Streit GE, Spall WD, . 1987. Beyond acid rain: Do soluble oxidants toxins interact with SO_2_ and NO_x_ to increase ecosystem effects? Environ Sci Technol 21(6):519–523.19994967
Gaikwad NW, Bodell WJ. 2001. Formation of DNA adducts by microsomal and peroxidase activation of p-cresol: Role of quinone methide in DNA adduct formation. Chem Biol Interact 138(3):217–229.11714480
Gaikwad NW, Bodell WJ. 2003. Formation of DNA adducts in HL-60 cells treated with the toluene metabolite p-cresol: A potential biomarker for toluene exposure. Chem Biol Interact 145(2):149–158.12686491
Giabbai MF, Cross WH, Chian ESK, . 1985. Characterization of major and minor organic pollutants in wastewaters from coal gasification processes. Int J Environ Anal Chem 20:113–129.
Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Goerlitz DF, Troutman DE, Godsy EM, . 1985. Migration of wood-preserving chemicals in contaminated groundwater in a sand aquifer at Pensacola, Florida. Environ Sci Tech 19:955–961.
Goncharuk VV, Milyukin MV. 1999. Evaluation of contamination level of Dnieper River Basin by organic and inorganic toxicants. In: Baveye P, Block JC, Goncharuk VV, eds. Bioavailability of organic xenobiotics in the environment. Boston, MA: Kluwer Academic Publishers, 35–56.
Goodley PC, Gordon M. 1976. Characterization of industrial organic compounds in water. Trans Ky Acad Sci 37:11–15.
Gordon M, Goodley PC. 1971. Isolation and characterization of industrial organic pollutants in water. Presented before the division of water, air, and waste chemistry. Los Angeles, CA: American Chemical Society, 11:91–94.
Great Lakes Water Quality Board. 1983. An inventory of chemical substances identified in the Great Lakes ecosystem. Volume 1—summary. Report to the Great Lakes Water Quality Board, Windsor Ontario, Canada, 1–195.
Green MA. 1975. A household remedy misused - fatal cresol poisoning following cutaneous absorption (a case report). Med Sci Law 15:65–66.1219312
Grosjean D. 1984. Atmospheric reactions of ortho cresol: Gas phase and aerosol products. Atmos Environ 18:1641–1652.
Grosjean D. 1985. Reactions of o-cresol and nitrocresol with NO_x_ in sunlight and with ozone-nitrogen dioxide mixtures in the dark. Environ Sci Technol 19(10):968–974.
Grosjean D. 1991. Atmospheric fate of toxic aromatic compounds. Sci Total Environ 100:367–414.
Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Haddad LM, Shannon MW, Winchester JF. 1998. Phenol and related agents. Clinical management of poisoning and drug overdose. Philadelphia, PA: W.B. Saunders Company, 956–960.
Hall RR, Esbenshade KL. 1984. Depression of glucuronyltransferase activity by glucocorticoids in adult female mice. J Anim Sci 58(6):1412–1417.6430857
Hamaguchi F, Tsutsui T. 2000. Assessment of genotoxicity of dental antiseptics: Ability of phenol, guaiacol, p-phenolsulfonic acid, sodium hypochlorite, p-chlorophenol, m-cresol, or formaldehyde to induce unscheduled DNA synthesis in cultured Syrian hamster embryo cells. Jpn J Pharmacol 83:273–276.10952079
Hampton CV, Pierson WR, Harvey TM, . 1982. Hydrocarbon gases emitted from vehicles on the road. I. A qualitative gas chromatography/mass spectrometry survey. Environ Sci Technol 16:287–298.22257255
Hansch C, Leo AJ. 1985. Medchem Project. Claremont, CA: Pomona College, Issue 26.
Harley RA, Cass GR. 1994. Modeling the concentrations of gas-phase toxic organic air pollutants: Direct emissions and atmospheric formation. Environ Sci Technol 28:88–98.22175837
Hashimoto T, Iida H, Dohi S. 1998. Marked increases of aminotransferase levels after cresol ingestion. Am J Emerg Med 16(7):667–668.9827743
Haworth S, Lawlor T, Mortelmans K, . 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen Suppl 1:3–142.
Hawthorne SB, Sievers RE. 1984. Emission of organic air pollutants from shale oil wastewaters. Environ Sci Technol 18:483–490.22247953
Hawthorne SB, Krieger MS, Miller DJ, . 1989. Collection and quantitation of methoxylated phenol tracers for atmospheric pollution from residential wood stoves. Environ Sci Technol 23(4):470–475.
Hawthorne SB, Miller DJ, Barkley RM, . 1988. Identification of methoxylated phenols as candidate tracers for atmospheric wood smoke pollution. Environ Sci Technol 22(10):1191–1196.22148614
Hayakawa M. 2002. Severe hepatic dysfunction following cresol poisoning. Intensive Care Med 28(8):1190–1191.12400519
HazDat. 2006. Cresols. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/hazdat.html. July 5, 2006.
Heikkila PR, Hameila M, Pyy L, . 1987. Exposure to creosote in the impregnation and handling of impregnated wood. Scand J Work Environ Health 13:431–437.3433045
Herwick RP, Treweek DN. 1933. Burns from anesthesia mask sterilized in compound solution of cresol. J Am Med Assoc 100:407–408.
Heukelekian H, Rand MC. 1955. Biochemical oxygen demand of pure organic compounds. J Water Pollut Contr Assoc 29:1040–1053.
Hikiba H, Watanabe E, Barrett JC, . 2005. Ability of fourteen chemical agents used in dental practice to induce chromosome aberrations in Syrian hamster embryo cells. J Pharm Sci 97:146–152.
Hine J, Mookerjee PK. 1975. The intrinsic hydrophilic character of organic compounds. Correlations in terms of structural contributions. J Org Chem 40:292–298.
Hirose M, Inoue T, Asamoto M, . 1986. Comparison of the effects of 13 phenolic compounds in induction of proliferative lesions of the forestomach and increase in the labeling indices of the glandular stomach and urinary bladder epithelium of Syrian golden hamsters. Carcinogenesis 7(8):1285–1289.3731382
Hites RA. 1979. Sources and fates of industrial organic chemicals; a case study. Proceedings of the 8th National Conference on Municipal Sludge Management, 107–119.
Hites RA, Lopez-Avila V. 1980. Sedimentary accumulation of industrial organic compounds discharged into a river system. In: Baker RA, ed. Contaminants and sediments. Vol. 1. Fate and transport case studies, modeling, toxicity. Ann Arbor, MI: Ann Arbor Sci., 53–66.
Ho CT, Lee KN, Jin QZ. 1983. Isolation and identification of volatile flavor compounds in fried bacon. J Agric Food Chem 31:336–342.
Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
Hohenegger M, Vermes M, Esposito R, . 1988. Effect of some uremic toxins on oxygen consumption of rats in vivo and in vitro. Nephron 48(2):154–158.3344056
Hornshaw TC, Aulerich RJ, Ringer RK. 1986. Toxicity of o-cresol to mink and European ferrets. Environ Toxicol Chem 5(8):713–720.
Horowitz A, Shelton DR, Cornell CP, . 1982. Anaerobic degradation of aromatic compounds in sediments and digested sludge. Dev Ind Microbiol 23:435–444.
HSDB. 2008. Cresols. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. July 24, 2008.
Hutchins SR, Tomson MB, Wilson JT, . 1984. Fate of trace organics during rapid infiltration of primary waste water at Fort Devens, Massachusetts (USA). Water Res 18(8):1025–1036.
IARC. 2004. Overall evaluations of carcinogenicity to humans: As evaluated in IARC Monographs volumes 1–82 (at total of 900 agents, mixtures and exposures). Lyon, France: International Agency for Research on Cancer. http://www-cie.iarc.fr/monoeval/crthall.html. March 8, 2006.
IRIS. 2008. Cresol. Washington, DC: Integrated Risk Information System. U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/. July 24, 2008.
Isaacs R. 1922. Phenol and cresol poisoning. Ohio State Med J 18:558–561.
Ivett JL. 1989a. Dominant lethal assay in mice: Ortho cresol CRE-9.1-DL-HLA. Final report. Chemical Manufacturers Association. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0529223.
Ivett JL. 1989b. Dominant lethal assay in mice: Para cresol CRE945. Final report. Chemical Manufacturers Association. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0529223.
Ivett JL. 1989c. Mutagenicity test on meta-cresol in the mouse bone marrow cytogenetic assay (final report) with attachments and cover letter dated 020289. Chemical Manufacturers Association. Submitted to U.S. Environmental Protection Agency under TSCA Section 4. OTS529219.
James RH, Adams RE, Finkel JM, . 1984. Evaluation of analytical methods for the determination of POHC in combustion products. In: Johnson LD, eds. Proceedings: 77th APCA annual meeting; June 24-29, 1984, San Francisco, CA. Pittsburgh, PA: Air Pollution Control Association. Paper 84-18.5, 1-25.
Jay K, Stieglitz L. 1995. Identification and quantification of volatile organic components in emissions of waste incineration plants. Chemosphere 30(7):1249–1260.
Jin H, Yang X, Yu H, . 1999. Identification of ammonia and volatile phenols as primary toxicants in a coal gasification effluent. Bull Environ Contam Toxicol 63(3):399–406.10475920
Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
Johansen SS, Hansen AB, Mosboek H, . 1997. Identification of heteroaromatic and other organic compounds in ground water at creosote-contaminated sites in Denmark. Ground Water Monit Rev 17:106–115.
Johnson LD, Midgett MR, James RH, . 1989. Screening approach for principal organic hazardous constituents and products of incomplete combustion. J Air Pollut Control Assoc 39(5):709–713.
Jouglard J, Aquaron R, Gatua-Pelanchon J, . 1971. [Acute poisoning with a household antiseptic: “Cresyl”.] Mars Med 108:425–431. (French)5116733
Junk GA, Ford CS. 1980. A review of organic emissions from selected combustion processes. Chemosphere 9:187–230.
Kamijo Y, Soma K, Kokuto M, . 2003. Hepatocellular injury with hyperaminotransferasemia after cresol ingestion. Arch Pathol Lab Med 127(3):364–366.12653586
Kavlock RJ. 1990. Structure-activity relationships in the developmental toxicity of substituted phenols: In vitro effects. Teratology 41:43–59.2305374
Kawamura K, Kaplan IR. 1986. Compositional change of organic matter in rainwater during precipitation events. Atmos Environ 20(3):527–536.
Kelly TJ, Muklund R, Spicer CW, . 1994. Concentrations and transformations of hazardous air pollutants. Environ Sci Technol 28:378–387.
Kitagawa A. 2001. Effects of cresols (o-,m-, and p-isomers) on the bioenergetic system in isolated rat liver mitochondria. Drug Chem Toxicol 24(1):39–47.11307633
Klinger ME, Norton JF. 1945. Toxicity of cresylic acid-containing solvent. US Nav Med Bull 44(2):438–439.
Koch R, Nagel M. 1988. Quantitative structure activity relationships in soil ecotoxicology. Sci Total Environ 77(2–3):269–276.
Koizumi M, Noda A, Furukawa M, . 2003. Higher susceptibility of newborn than young rats to 3-methylphenol. J Toxicol Sci 28(2):59–70.12820538
Kolber A, Wolff T, Hughes T, . 1981. Collection, chemical fractionation, and mutagenicity bioassay of ambient air particulate. In: Waters MD, Sandhu SS, Huisingh JL, ., eds. Short-term bioassays in the analysis of complex environmental mixtures II. New York, NY: Pleman Publishing Corporation, 21–43.
Kolpin DW, Furlong ET, Meyer MT, . 2002. Pharmaceuticals, hormones, and other organic wastewater contaminants in US streams, 1999-2000: A national reconnaissance. Environ Sci Technol 36:1202–1211.11944670
Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
Koymans L, Donne-Op Den Kelder GM, Te Koppele JM. 1993. Generalized cytochrome P450-mediated oxidation and oxygenation reactions in aromatic substrates with activated N-H, O-H, C-H, or S-H substituents. Xenobiotica 23(6):633–648.8212737
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Krotoszynski BK, O’Neill HJ. 1982. Involuntary bioaccumulation of environmental pollutants in nonsmoking heterogeneous human population. J Environ Sci Health Part A Environ Sci Eng 17(6):855–883.
Kubo T, Urano K, Utsumi H. 2002. Mutagenicity characteristics of 255 environmental chemicals. J. Health Sci 48(6):545–554.
Kuhn EP, Zeyer J, Eicher P, . 1988. Anaerobic degradation of alkylated benzenes in denitrifying laboratory aquifer columns. Appl Environ Microbiol 54:490–496.3355134
Kurlyandskiy BA, Partsef DP, Chernomorskiy AR. 1975. [A procedure for determining the mean daily maximum permissible concentration of tricresol in atmospheric air.] Gig Sanit 5:85–87. (Russian)
Kuwata K, Tanaka S. 1988. Liquid chromatographic determination of traces of phenols in air. J Chromatogr 442:407–411.3417830
Labram C, Gervais P. 1968. [A case of massive cresol poisoning.] Sem Hop Paris 44:3029–3031. (French)4308753
Larcan A, Lambert H, Laprevote-Heully MC. 1974. [A case of acute cresol poisoning with massive acute hemolysis, methemoglobinemia, and Heinz bodies.] Eur J Toxicol 7:5–8. (French)
Leach J, Blanch A, Bianchi AC. 1999. Volatile organic compounds in an urban airborne environment adjacent to a municipal incinerator, waste collection centre and sewage treatment plant. Atmos Environ 33:4309–4325.
Lebedev AT, Poliakova OV, Karakhanova NK, . 1998. The contamination of birds with organic pollutants in the Lake Baikal region. Sci Total Environ 212:153–162.9573629
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Lehtonen M. 1983. Gas-liquid chromatographic determination of volatile phenols in matured distilled alcoholic beverages. J Assoc Off Anal Chem 66(1):62–70.
Leikin JB, Paloucek FP, eds. 2002. Poisoning and toxicology handbook. Hudson, OH: Lexi-Comp, Inc., 420–421.
Leone JA, Flagan RC, Grosjean D, . 1985. An outdoor smog chamber and modeling study of toluene-NO_x_ photooxidation. Int J Chem Kinet 17(2):177–216.
Lesaffer G, De Smet R, Belpaire FM, . 2003a. Urinary excretion of the uraemic toxin p-cresol in the rat: Contribution of glucuronidation to its metabolization. Nephrol Dial Transplant 18(7):1299–1306.12808165
Lesaffer G, De Smet R, D’Heuvaert T, . 2001. Kinetics of the protein-bound, lipophilic, uremic toxin p-cresol in healthy rats. Life Sci 69(19):2237–2248.11669466
Lesaffer G, De Smet R, D’Heuvarert T, . 2003b. Comparative kinetics of the uremic toxin p-cresol versus creatinine in rats with and without renal failure. Kidney Int 64(4):1365–1373.12969155
Leuenberger C, Ligocki MP, Pankow JF. 1985. Trace organic compounds in rain. 4. Identities, concentrations, and scavenging mechanisms for phenols in urban air and rain. Environ Sci Technol 19(11):1053–1058.22288749
Leung H-W. 1993. Physiologically-based pharmacokinetic modeling. In: Ballentyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Levsen K, Behnert S, Mussmann P, . 1993. Organic compounds in cloud and rain water. Int J Environ Anal Chem 52:87–97.
Lewis RJ, ed. 2001. Cresols. Hawley’s condensed chemical dictionary, 14th ed. New York: John Wiley & Sons, 306–307.
Li Y, Qu M, Sun L, . 2005. Genotoxicity study of phenol and o-cresol using the micronucleus test and the comet assay. Toxicol Environ Chem 87(3):365–372.
Liberti A, Goretti G, Russo MV. 1983. PCDD and PCDF formation in the combustion of vegetable wastes. Chemosphere 12:661–663.
Lide DR. 2005. Cresols. CRC handbook of chemistry and physics. 86th ed. Boca, FL: CRC Press. Taylor and Francis Group, 3–122.
Liu YY, Lu CC, Perng RP. 1999. Acute respiratory distress syndrome following cutaneous exposure to Lysol: A case report. Zhonghua Yi Xue Za Zhi 62(12):901–906.10634006
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
Lopes TJ, Furlong ET. 2001. Occurrence and potential adverse effects of semivolatile organic compounds in streambed sediment, United States, 1992-1995. Environ Toxicol Chem 20(4):727–737.11345447
Ludzack FJ, Ettinger MB. 1960. Chemical structures resistant to aerobic biochemical stabilization. J Water Pollut Control Fed 32:1173–2000.
Luh MD, Baker RA. 1970. Organic sorption from aqueous solution by two clays. Proceedings of the 25th Industrial Waste Conference, Purdue University, Eng Bull Ext Series. 25:534–542.
Lumanta IG Jr. 1987. The effects of tyrosine, p-hydroxyphenylacetic acid, p-cresol and bacitracin methylene disalicylate on the growth of weanling pigs. Diss Abstr Int 49/04-B:959.
Lund FA, Rodriguez DS. 1984. Acclimation of activated sludge to mono-substituted derivatives of phenol and benzoic acids. J Gen Appl Microbiol 30:53–61.
Luttke J, Levsen K, Acker K, . 1999. Phenols and nitrated phenols in clouds at Mount Brocken. Int J Environ Anal Chem 74:69–89.
Mabuchi H, Nakahashi H. 1988. Displacement by anionic drugs of endogenous ligands bound to albumin in uremic serum. Ther Drug Monit 10:261–264.3140432
Malaney GW. 1960. Oxidative abilities of aniline-acclimated activated sludge. J Water Pollut Control Fed 32:1300–1311.
Malaney GW, McKinney RE. 1966. Oxidative abilities of benzene-acclimated activated sludge. Water Sewage Works 113:302–309.
Masunaga S, Urushigawa Y, Yonezawa Y. 1983. Microbial transformation of o-cresol to dihydroxytoluenes by phenol acclimated activated sludge. Chemosphere 12:1075–1082.
Masunaga S, Urishigawa Y, Yonezawa Y. 1986. Biodegradation pathway of o-cresol by heterogeneous culture. Phenol activated sludge. Water Res 20:477–484.
Mattsson JL, Albee RR, Gorzinski SJ. 1989. Similarities of toluene and o-cresol neuroexcitation in rats. Neurotoxicol Teratol 11(1):71–75.2818714
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
McCreary JJ, Jackson JG, Zoltek J. 1983. Toxic chemicals in an abandoned phenolic waste site. Chemosphere 12:1619–1632.
McKinney RE, Tomlinson HD, Wilcox RL. 1956. Metabolism of aromatic compounds by activated sludge. Sew Indust Wastes 28:547–557.
McKnight DM, Pereira WE, Ceazan ML, . 1982. Characterization of dissolved organic materials in surface waters within the blast zone of Mount St. Helens, Washington. Org Geochem 4:85–92.
Medvedev VA, Davidov VD. 1981a. The influence of isomers on the transformation rate of phenols in Chernozem soil. In: Overcash MR, ed. Decomposition of toxic and nontoxic organic compounds in soil. Ann Arbor, MI: Ann Arbor Sci Publ., 175–181.
Medvedev VA, Davidov VD. 1981b. The transformation of various coke industry products in Chernozem soil. In: Overcash MR, ed. Decomposition of toxic and nontoxic organic compounds in soil. Ann Arbor, MI: Ann Arbor Sci Publ., 245–254.
Mellon Institute. 1949. The acute toxicity of m-cresol. Mellon Institute of Industrial Research. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0517523.
Middaugh DP, Mueller JG, Thomas RL, . 1991. Detoxification of pentachlorophenol and creosote contaminated groundwater by physical extraction: Chemical and biological assessment. Arch Environ Contam Toxicol 21:233–244.1958078
Minami M, Katsumata M, Tomoda A. 1990. Methemoglobinemia with oxidized hemoglobins and modified hemoglobins found in blood of workers handling aromatic compounds and those in a man who drank cresol solution. Biomed Biochim Acta 49(2–3):S327–S333.2386523
Miyachi T, Tsutsui T. 2005. Ability of 13 chemical agents used in dental practice to induce sister-chromatid exchanges in Syrian hamster embryo cells. Odontology 93(1):24–29.16170472
Mizutani T, Ishida I, Yamaoto K, . 1982. Pulmonary toxicity of butylated hydroxytoluene and related alkylphenols: Structural requirements for toxic potency in mice. Toxicol Appl Pharmacol 62(2):273–281.7058530
Mohammadi B, Haeseler G, Leuwer M, . 2001. Structural requirements of phenol derivatives for direct activation of chloride currents via GABA receptors. Eur J Pharmacol 421(2):85–91.11399263
Monma-Ohtaki J, Maeno Y, Nagao M, . 2002. An autopsy case of poisoning by massive absorption of cresol a short time before death. Forensic Sci Int 126(1):77–81.11955837
Moore SP, Coohill TP. 1983. An SV40 mammalian inductest for putative carcinogens. Prog Nucleic Acid Res Mol Biol 29:149–153.6320282
Morinaga Y, Fuke C, Arao T, . 2004. Quantitative analysis of cresol and its metabolites in biological materials and distribution in rats after oral administration. Leg Med 6(1):32–40.
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
Murli H. 1988. Mutagenicity tests on o-, m-, and p-cresol in an in vitro cytogenetic assay measuring chromosomal aberration frequencies in CHO cells. Chemical Manufacturers Association. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0517691.
Namkoong W, Loehr RC, Malina JF Jr. 1988. Kinetics of phenolic compounds removal in soil. Hazard Waste Hazard Mater 5(4):321–328.
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35
Nazaroff WW, Singer BC. 2004. Inhalation of hazardous air pollutants from environmental tobacco smoke in US residences. J Expo Anal Environ Epidemiol 14:S71–S77.15118748
Needham LL, Head SL, Cline RE. 1984. Determination of phenols and cresols in urine by gas chromatography. Anal Lett 17(B14):1555–1565.
Neeper-Bradley TL, Tyl RW. 1989a. Two-generation reproduction study of p-cresol (CAS No. 106-44-5) administered by gavage to Sprague-Dawley (CD^®^) rats. Project report 52-512. Union Carbide Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0529224.
Neeper-Bradley TL, Tyl RW. 1989b. Two-generation reproduction study of m-cresol (CAS No. 108-39-4) administered by gavage to Sprague-Dawley (CD^®^) rats. Project report 51-634. Union Carbide Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0529224.
Nelson PR, Kelly SP, Conrad FW. 1998. Studies of environmental tobacco smoke generated by different cigarettes. J Air Waste Manage Assoc 48:336–344.
Neufeld RD, Debes MR, Moretti C, . 1985. Cooling tower evaporation of treated coal gasification wastewaters. J Water Pollut Control Fed 57(9):955–964.
Nieminen E, Heikkila P. 1986. Simultaneous determination of phenol, cresols and xylenols in workplace air, using a polystyrene-divinylbenzene column and electrochemical detection. J Chromatogr 360(1):271–278.3733946
NIOSH. 1989. National occupational exposure survey as a March 29, 1989. Washington, DC: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health.
NIOSH. 1994a. Method 2546. Cresol (all isomers) and phenol. In: NIOSH manual of analytical methods. 4th ed. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/nmam/. March 8, 2006.
NIOSH. 1994b. Method 8305: Phenol and p-cresol in urine. NIOSH manual of analytical methods (NMAM) 4th ed. National Institute of Occupational Safety and Health. http://www.cdc.gov/niosh/nmam/pdfs/8305.pdf. May 25, 2006.
NIOSH. 2005. Cresol. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/. March 8, 2006.
Nise G. 1992. Urinary excretion of o-cresol and hippuric acid after toluene exposure in rotogravure printing. Int Arch Occup Environ Health 63:377–381.1544684
Nishihara T, Nishikawa J, Kanayama T, . 2000. Estrogenic activities of 517 chemicals by yeast two-hybrid assay. J Health Sci 46(4):282–298.
Novotny M, Merli F, Wiesler D, . 1982. Fractionation and capillary gas chromatographic-mass spectrometric characterization of the neutral components in marijuana and tobacco smoke condensates. J Chromatogr 238(1):141–150.
NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Academy Press, National Research Council.
NTP. 1992a. Final report on the reproductive toxicity of ortho-cresol (OCRE) in CD-1 Swiss mice II. Research Triangle Park, NC: National Toxicology Program. PB92176890.
NTP. 1992b. NTP report on the toxicity studies of cresols (CAS Nos. 95-48-7, 108-39-4, 106-44-5) in F344/N rats and B6C3F1 mice (feed studies). Research Triangle Park, NC: National Toxicology Program. NIH Publication No. 92-3128. NTP Tox 9.
NTP. 1992c. Final report on the reproductive toxicity of meta-/para-cresol (MPCREE) (CAS No. 1319-77-3) in Swiss mice. Research Triangle Park, NC: National Toxicology Program. PB92191741.
NTP. 2004. Report on carcinogens. 11th ed. Research Triangle Park, NC: National Toxicology Program, Department of Health and Human Services. http://ntp-server.niehs.nih.gov/ntp/roc/toc11.html. January 11, 2008.
NTP. 2008. Toxicology and carcinogenesis studies of cresols (CAS No. 1319-77-3) in male F344/N rats and female B6C3F1 mice (feed studies). Research Triangle Park, NC: National Toxicology Program. TR-550. Draft technical report.
Oglesby LA, Ebron-McCoy MT, Logsdon TR, . 1992. In vitro embryotoxicity of a series of para-substituted phenols: Structure, activity, and correlation with in vivo data. Teratology 45:11–33.1731394
Oliveira DP, Sitar N. 1985. Ground water contamination from underground solvent storage tanks, Santa Clara, California. In: Proceedings of the Fifth National Symposium on Aquifer Restoration and Ground Water Monitoring, 691–708.
Oman C, Hynning P-A. 1993. Identification of organic compounds in municipal landfill leachates. Environ Pollut 80:265–271.15091846
O’Neil MJ, Smith A, Heckelman PE, ., eds. 2001. Cresols. The Merck Index. An encyclopedia of chemicals, drugs, and biologicals. 13th ed. Whitehouse Station, NJ: Merck & Co.,451.
OSHA. 2005a. Air contaminants. Occupational safety and health standards for shipyard employment. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. http://www.osha.gov/comp-links.html. March 8, 2006.
OSHA. 2005b. Gases, vapors, fumes, dusts, and mists. Safety and health regulations for construction. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55, Appendix A. http://www.osha.gov/comp-links.html. March 8, 2006.
OSHA. 2005c. Limits for air contaminants. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. http://www.osha.gov/comp-links.html. March 8, 2006.
OSHA. 2006. Limits for air contaminants. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. http://www.osha.gov/comp-links.html. June 13, 2006.
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Palumbo AV, Pfaender FK, Paerl HW. 1988. Biodegradation of NTA and m-cresol in coastal environments. Environ Toxicol Chem 7:573–585.
Pauli O, Franke G. 1972. Behaviour and degradation of technical preservatives in the biological purification of sewage. In: Walters AH, Hueck-Van Der Plas EH, eds. Biodeterioration of materials. New York, NY: Halsted Press Division, Wiley, 52–60.
Pegg SP, Campbell DC. 1985. Children’s burns due to cresol. Burns Incl Therm Inj 11(4):294–296.4005649
Pellizzari ED, Castillo NP, Willis S, . 1979. Identification of organic components in aqueous effluents from energy-related processes. ASTM Spec Tech Publ STP 686:256–274.
Pepper, Hamilton, & Scheetz. 1980. Sister chromatid exchange assay, Ames assay, mouse lymphoma forward mutation assay, and transformation assay for o-, m-, and p-cresol with cover letter dated 071180. Pepper, Hamilton, & Scheetz, Attorneys at Law. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0517528.
Pepper, Hamilton, & Scheetz. 1981. Sister chromatid exchange assay, Ames assay, mouse lymphoma forward mutation assay, cell transformation on o-cresol. Pepper, Hamilton, & Scheetz, Attorneys at Law. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0517531.
Pfaender FK, Bartholomew GW. 1982a. Measurement of aquatic biodegradation rates by determining heterotrophic uptake of radiolabeled pollutants. Appl Environ Microbiol 44:159–164.7125647
Pfaender FK, Bartholomew GW. 1982b. Measurement of aquatic biodegradation rates by determining heterotrophic uptake of radiolabeled pollutants. Appl Environ Microbiol 44:1482.
Pitter P. 1976. Determination of biological degradability of organic substances. Water Res 10:231–235.
Platt UF, Winer AM, Biermann HW, . 1984. Measurement of nitrate radical concentrations in continental air. Environ Sci Technol 18:365–369.22280086
Poliakova OV, Lebedev AT, Hanninen O. 2000. Organic pollutants in snow of urban and rural Russia and Finland. Toxicol Environ Chem 75:181–194.
Pool BL, Lin PZ. 1982. Mutagenicity testing in the Salmonella typhimurium assay of phenolic compounds and phenolic fractions obtained from smokehouse smoke condensates. Food Chem Toxicol 20(4):383–391.6751955
Presley JA, Brown WE. 1956. Lysol-induced criminal abortion. Obstet Gynecol 8:368–370.13359011
*Purvis CR, McCrillis RC, Kariher PH. 2000. Fine particulate matter (PM) and organic speciation of fireplace emissions. Environ Sci Technol 34:1653–1658.
Reimann SP. 1933. “Sensitivity” to sulphydryl. Am J Clin Pathol 3(2):167–170.
Riddick JA, Bunger WB, Sakano TK. 1986. Organic solvents. New York, NY: John Wiley and Sons, Inc., 244–249.
Roberts MS, Anderson RA, Swabrick J. 1977. Permeability of human epidermis to the phenolic compounds. J Pharm Pharmacol 29:677–683.22602
Rustemeier K, Stabbert R, Haussmann H-J, . 2002. Evaluation of the potential effects of ingredients added to cigarettes. Part 2: Chemical composition of mainstream smoke. Food Chem Toxicol 40(1):93–104.11731039
Sabljic A. 1987. [The prediction of fish bioconcentration factors of organic pollutants from the molecular connectivity model.] Z Gesamte Hyg Ihre Grenzgeb 33:493–496. (Yugoslavic)
Sadtler. 1960a. m-Cresol (622). Ultra violet sprectra. Philadelphia, PA: Sadtler Research Laboratories.
Sadtler. 1960b. o-Cresol (259). Ultra violet sprectra. Philadelphia, PA: Sadtler Research Laboratories.
Sadtler. 1966. p-Cresol (15). Ultra violet sprectra. Philadelphia, PA: Sadtler Research Laboratories.
Satoh K, Nonaka R, Ohyama K, . 2005. Androgenic and antiandrogenic effects of alkylphenols and parabens assessed using the reporter gene assay with stably transfected CHO-K1 cells (AR-EcoScreen System). J Health Sci 51(5):557–568.
Savolainen H. 1979. Toxic effects of peroral o-cresol intake on rat brain. Res Commun Chem Pathol Pharmacol 25(2):357–364.493719
Sawhney BL, Kozloski RP. 1984. Organic pollutants in leachates from landfill sites. J Environ Qual 13:349–352.
Schauer JJ, Kleeman MJ, Cass GR, . 2001. Measurement of emissions from air pollution sources. 3. C1-C29 organic compounds for fireplace combustion of wood. Environ Sci Technol 35:1716–1728.11355184
Schwarzbauer J, Littke R, Weigelt V. 2000. Identification of specific organic contaminants for estimating the contribution of the Elbe River to the pollution of the German Bight. Org Geochem 31:1713–1731.
Scully FE Jr., Hoigne J. 1987. Rate constants for reactions of singlet oxygen with phenols and other compounds in water. Chemosphere 16:681–694.
Seizinger DE, Dimitriades B. 1972. Oxygenates in exhaust from simple hydrocarbon fuels. J Air Pollut Control Assoc 22:47–51.
Sernav RC. 1989a. Mutagenicity test on ortho-cresol (lot number RC645A) Drosophila melanogaster sex-linked recessive lethal test. Chemical Manufacturers Association. Submitted to U.S. Environmental Protection Agency under TSCA Section 4. OTS0529221.
Sernav RC. 1989b. Mutagenicity test on para-cresol lot number 1206 Drosophila melanogaster sex-linked recessive lethal test. Chemical Manufacturers Association. Submitted to U.S. Environmental Protection Agency under TSCA Section 4. OTS0529221.
Setchell BP, Waites GMH. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society, 143–172.
Sheldon LS, Hites RA. 1978. Organic compounds in the Delaware River. Environ Sci Technol 12:1188–1194.
Sheldon LS, Hites RA. 1979. Sources and movement of organic chemicals in the Delaware River. Environ Sci Technol 13:574–579.
Shelley WB. 1974. p-Cresol: Cause of ink-induced hair depigmentation in mice. Br J Dermatol 90:169–174.4819134
Singer BC, Hodgson AT, Guevarra KS, . 2002. Gas phase organics in environmental tobacco smoke. 1. Effects of smoking rate, ventilation, and furnishing level on emission factors. Environ Sci Technol 36:846–853.11918006
Singer BC, Hodgson AT, Nazaroff WW. 2003. Gas-phase organics in environmental tobacco smoke: 2. Exposure-relevant emission factors and indirect exposures from habitual smoking. Atmos Environ 37(39–4):5551–5561.
Smolenski WJ, Suflita JM. 1987. Biodegradation of cresol isomers in anoxic aquifers. Appl Environ Microbiol 58:710–716.
Snider EH, Manning FS. 1982. A survey of pollutant emission levels in waste waters and residuals from the petroleum refining industry. Environ Int 7:237–258.
Southworth GR, Keller JL. 1986. Hydrophobic sorption of polar organics by low organic carbon soils. Water Air Soil Pollut 28(3–4):239–248.
Spain JC, Van Veld PA. 1983. Adaptation of natural microbial communities to degradation of xenobiotic compounds: Effects of concentration, exposure time, inoculum, and chemical structure. Appl Environ Microbiol 45:428–435.16346193
SRI. 2005. 2005 Directory of chemical producers. Menlo Park, California: SRI Consulting, 317, 368–369, 546.
Stone AT. 1987. Reductive dissolution of manganese (III/IV) oxides by substituted phenols. Environ Sci Technol 979–988.19994996
Stuermer DH, Ng DJ, Morris CJ. 1982. Organic contaminants in groundwater near an underground coal gasification site in northeastern Wyoming. Environ Sci Technol. 16:582–587.22284199
Stutz DR, Janusz SJ. 1988. Hazardous materials injuries: A handbook for pre-hospital care. 2nd ed. Beltsville, MD: Bradford Communications Corporation, 362–363.
Suflita JM, Gibson SA, Beeman RE. 1988. Anaerobic biotransformations of pollutant chemicals in aquifers. J Ind Microbiol 3(3):179–194.
Suflita JM, Liang LN, Saxena A. 1989. The anaerobic biodegradation of o-, m-, and p-cresol by sulfatereducing bacterial enrichment cultures obtained from a shallow anoxic aquifer. J Ind Microbiol 4(4):255–266.
Swann RL, Laskowski DA, McCall PJ, . 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Res Rev 85:17–28.
Tabak HH, Chambers CW, Kabler PW. 1964. Microbial metabolism of aromatic compounds. I. Decomposition of phenolic compounds and aromatic hydrocarbons by phenol-adapted bacteria. J Bacteriol 87:910–919.14137630
Takemoto S, Kuge Y, Nakamoto M. 1981. Measurement of BOD in seawater. Suishitsu Odaku Kenkyu 4:80–90.
Thomas RG. 1982. Volatilization from water. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. New York, NY: McGraw-Hill, Inc., 15-1 to 15-15-34.
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
Thomas JM, Lee MD, Scott MJ, . 1989. Microbial ecology of the subsurface at an abandoned creosote waste site. J Indust Microbiol 4:109–120.
Thompson DC, Perera K, Fisher R, . 1994. Cresol isomers: Comparison of toxic potency in rat liver slices. Toxicol Appl Pharmacol 125(1):51–58.8128495
Thompson DC, Perera K, London R. 1995. Quinone methide formation from para isomers of methylphenol (cresol), ethylphenol, and isopropylphenol: Relationship to toxicity. Chem Res Toxicol 8(1):55–60.7703367
Thompson DC, Perera K, London R. 1996. Studies on the mechanism of hepatotoxicity of 4-methylphenol (p-cresol): Effects of deuterium labeling and ring substitution. Chem Biol Interact 101(1):1–11.8665615
TRL. 1986. Subchronic neurotoxicity study in rats of ortho-, meta-, and para-cresol. Unpublished data submitted by Toxicity Research Laboratories to EPA.
TRI05. 2007. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. December 26, 2007.
Turney GL, Goerlitz DF. 1990. Organic contamination of ground water at Gas Works Park, Seattle, Washington. Ground Water Monit Rev 10(3):187–198.
Tyl RW. 1988a. Developmental toxicity evaluation of o-, m-, or p-cresol administered by gavage to Sprague Dawley (CD) rats. Chemical Manufacturers Association. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0517695.
Tyl RW. 1988b. Developmental toxicity evaluation of o-, m-, or p-cresol administered by gavage to New Zealand white rabbits. Chemical Manufacturers Association. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0517695.
Tyl RW, Neeper-Bradley TL. 1989. Two-generation reproduction study of o-cresol (CAS No. 95-48-7) administered by gavage to Sprague-Dawley (CD^®^) rats. Project report 51-614. Chemical Manufacturers Association. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0529224.
USGS. 1995. Method O-5130-95: Determination of semivolatile organic compounds in bottom sediment by solvent extraction, gel permeation chromatographic fractionation, and capillary-column gas chromatography/mass spectrometry. U.S. Geological Survey. OFR 95-719. http://web1.er.usgs.gov/nemi/method_pdf/8963.pdf. May 23, 2006.
USGS. 2002. Method O-1433-01: Pesticides and degradates, filtered water, gas chromatography/mass spectrometry. In: Methods of analysis by the U.S. Geological Survey National Water Quality Laboratory--Determination of wastewater compounds by polystyrene-divinylbenzene solid-phase extraction and capillary-column gas chromatography/mass spectrometry. U.S. Geological Survey. WRI 01-4186. http://nwql.usgs.gov/Public/pubs/WRIR01-4186.pdf. May 23, 2006.
USITC. 2006. Synthetic organic chemicals. United States production and sales, 2005. HTS - 2907120000: Cresols and their salts. U.S. International Trade Commission. http://dataweb.usitc.gov/scripts/REPORT.asp. March 30, 2006.
USITC. 2008. Cresols and cresol salts. United States International Trade Commission. http://dataweb.usitc.gov/. July 24, 2008
Uzhdavini ER, Astaf’yeva IK, Mamayeva AA, . 1972. [Inhalation toxicity of o-cresol.] Tr Uzb Nauchno Issled Inst Sanit Gig Profzabol. 7:115–119. (Russian)
Vance BM. 1945. Intrauterine injection of lysol as an abortifacient. Report of a fatal case complicated by oil embolism and Lysol poisoning. Arch Pathol 40:395–398
Vanholder R, De Smet R, Lesaffer G. 1999. p-Cresol: A toxin revealing many neglected but relevant aspects of uraemic toxicity. Nephrol Dial Transplant 14(12):2813–2815.10570076
van Veld PA, Spain JC. 1983. Degradation of selected xenobiotic compounds in three types of aquatic test systems. Chemosphere 12:1291–1305.
Vecera Z, Janák J. 1987. Continuous aerodispersive enrichment unit for trace determination of pollutants in air. Anal Chem 59 (11):1494–1498.3619034
Vernot EH, MacEwen JD, Haun CC, . 1977. Acute toxicity and skin corrosion data from some organic and inorganic compounds and aqueous solutions. Toxicol Appl Pharm 42:417–423.
Verschueren K. 1983. Cresols In: Handbook of environmental data on organic chemicals. 2nd ed. New York, NY: Van Nostrand Reinhold Company, 403–410.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
Visser SA, LaMontagne G, Zoulalian V, . 1977. Bacteria active in the degradation of phenols in polluted waters of the St. Lawrence River. Arch Environ Contam Toxicol 6:455–469.
Wang YT, Suidan MT, Pfeffer JT, . 1988. Effects of some alkyl phenols on methanogenic degradation of phenol. Appl Environ Microbiol 54(5):1277–1279.3389819
Wang YT, Suidan MT, Pfeffer JT, . 1989. The effect of concentration of phenols on their batch methanogenesis. Biotechnol Bioeng 33(10):1353–1357.18587872
Weber AS, Matsumoto MR. 1987. Feasibility of intermittent biological treatment for hazardous wastes. Environ Prog 6(3):166–171.
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
WHO. 2000. Air quality guidelines. 2nd edition. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/air/activities/20050223_4. March 8, 2006.
WHO. 2004. Guidelines for drinking-water quality. 3rd edition. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/. March 8, 2006.
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York: Academic Press, 1–247.
Williams RT. 1938. CXVIII. Studies in detoxication. I. The influence of (a) dose and (b) o-, m- and p-substitution on the sulfate detoxication of phenol in the rabbit. Biochem J 32:878–887.16746699
Windholz M, Budavari S, Blumetti RF, ., eds. 1983. The Merck index. Rahway, NJ: Merck and Co., Inc., 2568.
Wu ML, Tsai WJ, Yang CC, . 1998. Concentrated cresol intoxication. Vet Hum Toxicol 40(6):341–343.9830694
Wynder EL, Hoffmann D. 1967. Tobacco and tobacco smoke studies in experimental carcinogenesis. New York, NY: Academic Press, 387.
Yalkowsky SH, Valvani SC, Kuu W. 1987. Arizona database of aqueous solutions. http://www.pharmacy.arizona.edu/outreach/aquasol/index.html. August 15, 2006.
Yamazaki K, Tanaka E, Misawa S. 1992. Urinary ortho-cresol concentrations as an indicator of toluene inhalation in glue-sniffers. J Forensic Sci Soc 32(3):215–223.1492880
Yan Z, Zhong HM, Maher N, . 2005. Bioactivation of 4-methylphenol (p-cresol) via cytochrome P450-mediated aromatic oxidation in human liver microsomes. Drug Metab Dispos 33(12):1867–1876.16174805
Yanysheva N, Balenko NV, Chernichenko IA, . 1993. Peculiarities of carcinogenesis under simultaneous oral administration of benzo(a)pyrene and o-cresol in mice. Environ Health Perspect Suppl 101:341–4.8143642
Yashiki M, Kojima T, Miyazaki T, . 1990. Gas chromatographic determination of cresols in the biological fluids of a non-fatal case of cresol intoxication. Forensic Sci Int 47:21–29.2210550
Yasuhara A. 1987. Identification of volatile compounds in poultry manure by gas chromatography-mass spectrometry. J Chromatogr 387:371–378.3558630
Yoshikawa M, Taguchi Y, Arashidani K, ., 1986. Determination of cresols in urine by highperformance liquid chromatography. J Chromatogr 362(3):425–429.3760050
Young RHF, Ryckman DW, Buzzell JC Jr. 1968. An improved tool for measuring biodegradability. J Water Pollut Contr Fed 8:354–368.
Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372