# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Data pertaining to the chemical identity of cresols are listed in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

The physical and chemical properties of cresols are presented in Table 4-2.

Table 4-1 Chemical Identity of Cresols

Characteristics | o-Cresol | p-Cresol | m-Cresol | o-, m-, p-Cresol | References
Chemical name | o-Cresol | p-Cresol | m-Cresol | (o, m, p)-Cresol | ChemID 2008
Synonyms | 2-Methylphenol; 2-hydroxytoluene; o-cresylic acid | 4-Methylphenol; 4-hydroxytoluene; p-cresylic acid | 3-Methylphenol 3-hydroxytoluene; m-cresylic acid | Methylphenol; hydroxytoluene; cresylic acid | ChemID 2008; HSDB 2008; SANSS 1989
Trade names | No data | No data | No data | No data
Chemical formula | C_7_H_8_O | C_7_H_8_O | C_7_H_8_O | C_7_H_8_O | ChemID 2008
Chemical structure | [image] | [image] | [image] | Mixture of three previous isomers
Identification numbers:
CAS registry | 95-48-7 | 106-44-5 | 108-39-4 | 1319-77-3 | ChemID 2008
NIOSH RTECS | GO6300000 | GO6475000 | GO61250000 | GO5950000 | SANSS 1989
EPA hazardous waste | F004; U052 | F004; U052 | F004; U052 | F004; U052 | HSDB 2008
DOT/UN/NA/IMCO shipping | UN 2022; UN 3455; UN 2076; IMO 6.1 | UN 2022; UN 3455; UN 2076; IMO 6.1 | UN 2022; UN 3455; UN 2076; IMO 6.1 | UN 2022; UN 3455; UN 2076; IMO 6.1 | HSDB 2008
HSDB | 1813 | 1814 | 1815 | 250 | HSDB 2008
NCI | No data | No data | No data | No data

CAS = Chemical Abstracts Service; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/Intergovernmental Maritime Consultive Organization; EPA = Environmental Protection Agency; HSDB = Hazardous Substance Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Cresols

Property | o-Cresol | m-Cresol | p-Cresol | Mixture of o-, p-, and m-cresol | References
Molecular weight | 108.14 | 108.14 | 108.14 | 108.14 | O’Neil et al. 2001
Color | White crystals darken with age | Colorless to yellowish | No data | Colorless, yellowish, brownish-yellow, or pinkish | O’Neil et al. 2001
Physical state | Solid | Liquid | Solid | Liquid | O’Neil et al. 2001
Melting point | 30.944 °C | 12.22 °C | 34.739 °C | 11–35 °C | Lewis 2001; Riddick et al. 1986
Boiling point
1 atm | 191.004 °C | 202.32 °C | 201.94 °C | 191–203 °C | Riddick et al. 1986
10 mmHg | 74.9 °C | 86 °C | 85.7 °C | No data | Lewis 2001; Lide 2005
Density (20 °C) | 1.047 g/mL | 1.034 g/mL | 1.0341 g/mL | 1.030–1.038 g/mL | O’Neil et al. 2001
Odor | Phenol-like | Phenol-like | Phenol-like | Phenol-like | O’Neil et al. 2001
Odor threshold
Water | No data | 0.037 ppm | No data | No data | Amoore and Hautala 1983
Air | No data | 0.00028 ppm | No data | No data | Amoore and Hautala 1983
Solubility
Water at 25 °C | 25,950 ppm | 22,700 ppm | 21,520 ppm | No data | Yalkowsky et al. 1987
Organic solvents | Alcohol, ether, acetone, benzene, chloroform, alkali hydroxides (aqueous) | Alcohol, ether, acetone, benzene, chloroform, alkali hydroxides (aqueous) | Alcohol, ether, acetone, benzene, chloroform, alkali hydroxides (aqueous) | Alcohol, glycol, base | Lewis 2001; Lide 2005; O’Neil et al. 2001
Partition coefficients
Log octanol/water | 1.95 | 1.96 | 1.94 | No data | Hansch and Leo 1985
Log K_oc_ | 1.03 | 1.54 | 1.69 | No data | Artiola-Fortuny and Fuller 1982; Boyd 1982
Vapor pressure
25 °C | 0.299 mmHg | 0.138 mmHg | 0.11 mmHg | No data | AIChE 1989,2000, Chao et al. 1983
Henry’s law constant
atm/m^3^-molecule at 25 °C | 1.2×10^−6^ | 8.65×10^−7^ (calculated from vapor pressure and water solubility) | 7.92×10^−7^ | No data | Gaffney et al. 1987; Hine and Mookerjee 1975
Flashpoint (closed cup) | 81 °C | 85 °C | 86 °C | 82 °C | Lewis 2001
Flammability limits | 1.4% (lower) | 1.1% (lower) | 1.1% (lower) | | HSDB 2008
Conversion factors
ppm (v/v) to mg/m^3^ in air (20 °C) | 4.50 | 4.50 | 4.50 | 4.50 | Verschueren 1983
mg/m^3^ to ppm (v/v) in air (20 °C) | 0.22 | 0.22 | 0.22 | 0.22 | Verschueren 1983
Bioconcentration factor
Log BCF | 1.25 (calculated from K_ow_) | 1.30 | 1.24 (calculated from K_ow_) | No data | Freitag et al. 1985; Thomas 1982
Explosive limits | No data | No data | No data | No data