# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Environmental Medicine, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Environmental Medicine, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-32, Atlanta, Georgia 30333.

## Cresols Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Cresols
CAS Numbers: | 95-48-7, 108-39-4, 106-44-5, 1319-77-3
Date: | July 2008
Profile Status: | Final Draft Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 55
Species: | Rat

[underlined: Minimal Risk Level]: 0.1 [X] mg/kg/day [ ] ppm

[underlined: Reference]: NTP. 1992b. NTP report on the toxicity studies of cresols (CAS Nos. 95-48-7, 108-39-4, 106-44-5) in F344/N rats and B6C3F1 mice (feed studies). Research Triangle Park, NC: National Toxicology Program. NIH Publication No. 92-3128. NTP Tox 9.

[underlined: Experimental design]: Groups of Fischer 344 rats (20/sex/group) were administered m/p-cresol (58.5% m-cresol, 40.9% p-cresol) in the diet at levels of 0, 1,880, 3,750, 7,500, 15,000, or 30,000 ppm for 13 weeks (NTP 1992b). The corresponding doses of test compound estimated by the investigators were 0, 123, 241, 486, 991, and 2,014 mg/kg/day for males and 0, 131, 254, 509, 1,024, and 2,050 mg/kg/day for females. End points evaluated included clinical signs, food consumption, organ weights, clinical chemistry and hematology, and gross and microscopic appearance of organs and tissues. Although the dose groups consisted of 20 rats of each sex, 10 males and 10 females were used for clinical chemistry, hematology, and urinalysis studies and the remaining 10 rats/sex/group were used in gross pathology, organ weight, and histopathological studies.

[underlined: Effect noted in study and corresponding doses]: There were no deaths during the study. Final body weight in the 2,014/2,050 mg/kg/day males and females was reduced 17 and 12%, respectively, relative to controls. Food consumption was also reduced (about 10%) in this group during the first week of the study. Additionally, males and females in this group exhibited rough hair coat; females also had a thin appearance. Absolute and relative liver weights were significantly increased (11–12%) in males at 486 mg/kg/day and in females at 1,024 mg/kg/day. Absolute and relative kidney weight were increased in males at 991 mg/kg/day. In general, hematology findings were unremarkable, although there was a tendency to hemoconcentration at 2,014/2,050 mg/kg/day early in the study. Clinical chemistry tests showed an increase in serum alanine aminotransferase (ALT) in males and females exposed to 2,014/2,050 mg/kg/day and in sorbitol dehydrogenase (SDH) in males at 2,014 mg/kg/day only on day 5. Bile acids in serum were increased in females at 2,050 mg/kg/day on day 90 and at 241 and 991 mg/kg/day in males also on day 90. There was no indication of renal injury as judged by the results of urinalyses. Significant histopathological changes included minimal bone marrow hypocellularity in males and females at 2,014/2,050 mg/kg/day, and increased colloid (minimal) in thyroid follicular cells in females at 509 mg/kg/day and in males at 15,000 ppm (991 mg/kg/day). An increased dose-related incidence and severity of hyperplasia and glandular hyperplasia of the nasal respiratory epithelium was observed in male and female rats. Severity was minimal at 123/131 mg/kg/day, mild at 486/509 mg/kg/day, and moderate at 2,014/2,050 mg/kg/day. The lesions were located at the most anterior portions of the nasal septum, dorsal arch, and medial aspect of the nasal turbinates. The hyperplasia was characterized by increased number of goblet cells and pseudogland formation due to the infolding of the hyperplastic cells. The hyperplastic areas were associated with single cell necrosis. The incidences in males dosed with 0, 123, 241, 486, 991, and 2,014 mg/kg/day were 0/10, 3/10, 8/10, 10/10, 8/10, and 10/10, respectively. A similar trend was seen in female rats, but 3/10 control females also exhibited hyperplasia (3/10, 1/10, 5/10, 9/10, 8/10, and 10/10 at 0, 131, 254, 509, 1,024, and 2,050 mg/kg/day, respectively). The LOAELs for nasal lesions in male and female rats were 123 and 254 mg/kg/day, respectively. The NOAEL in females was 131 mg/kg/day and no NOAEL was established in males.

In the 28-day study with m/p-cresol in rats, the incidences of hyperplasia of the nasal respiratory epithelium in females dosed with 0, 27, 95, 268, 886, and 2,570 mg/kg/day were 0/5, 0/5, 3/4, 5/5, 5/5, and 5/5, respectively. However, data from the 13-week study are preferred for MRL derivation because of the longer duration and because only five rats/group were examined in the 28-day study.

Data from the NTP (1992b) were considered adequate for analysis using the benchmark dose approach for MRL derivation. Benchmark dose models in the EPA Benchmark Dose Software (BMDS) (version 2.0) were fit to the incidence data for nasal lesions in male and female rats exposed to m/p-cresol in the diet for 13 weeks in order to determine potential points of departure for the MRL (details of the modeling are presented below).

[underlined: Dose and end point used for MRL derivation]: BMDL_10_ of 13.94 mg/kg/day for nasal lesions in male rats.

[ ] NOAEL [ ] LOAEL [ x ] BMDL_10_

[underlined: Uncertainty Factors used in MRL derivation]:

- [x] 10 for extrapolation from animals to humans
- [x] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Conversion from diet to dose was done by the investigators.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? No.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Almost all of the information available on health effects from intermediate-duration oral exposure is derived from a comprehensive study in rats and mice administered the three cresol isomers and a cresol mixture for 28 days and 13 weeks (NTP 1992b). There are also two multigeneration reproductive studies in mice dosed with o-cresol (NTP 1992a) and a cresol mixture (NTP 1992c). Evaluation of the results of these studies indicates that the most sensitive end point was the nasal respiratory epithelium of rats and mice dosed with p-cresol or an m/p-cresol mixture. No clear target of toxicity emerged for o- or m-cresol. The nasal lesions occurred in rats dosed with p-cresol for 28 days (≥770 mg/kg/day), in rats exposed to m/p-cresol for 28 days (≥95 mg/kg/day), in mice exposed to p-cresol for 28 days (≥163 mg/kg/day), in mice exposed to m/p-cresol for 28 days (≥604 mg/kg/day), in rats exposed to m/p-cresol for 13 weeks (≥123 mg/kg/day), and in mice exposed to m/p-cresol for 13 weeks (≥472 mg/kg/day). Other effects that occurred at higher doses included increases in liver and kidneys weights (≥240 mg/kg/day), bone marrow hypocellularity (≥2,000 mg/kg/day), and mild uterine atrophy (≥1,000 mg/kg/day) (NTP 1992b). Clinical tests of liver and kidney function were generally unremarkable and gross and microscopic evaluation of the liver and kidney showed no significant alterations (NTP 1992b). None of the intermediate-duration oral gavage studies examined the nasal respiratory epithelium of the animals, and neither did the two multigeneration reproductive dietary studies in mice (NTP 1992a, 1992c).

[underlined: Agency Contacts (Chemical Managers)]: Malcolm Williams, Ph.D.; John Risher, Ph.D.; Mike Fay, Ph.D.

#### BENCHMARK MODELING OF NASAL RESPIRATORY LESIONS IN RATS

Benchmark dose models in the EPA Benchmark Dose Software (BMDS version 2.0) were fit to the incidence data for nasal lesions in male and female rats exposed to m/p-cresol in the diet for 13 weeks in order to determine potential points of departure for the MRL. BMDL_10_s (i.e., 95% lower confidence limits on the model-estimated dose associated with a 10% extra risk for nasal lesions) calculated with the best-fitting models for each data set (see Tables A-1, A-2, and, A-3 and Figures A-1 and A-2) were 13.9 mg/kg/day for males and 30.8 mg/kg/day for females. While this difference in benchmark dose may indicate that male rats are more sensitive than females, it also can be a statistical artifact of a rather small sample size, only 10 rats per group. The male rat data set was selected for determining the point of departure for MRL derivation in order to be public health protective.

Table A-1 Incidence Data for Respiratory Epithelium Glandular Hyperplasia or Hyperplasia in Rats Exposed to m/p-Cresol in the Diet for 13 Weeks

| Dietary concentration (ppm) | Dose (mg/kg/day) | Incidence of nasal lesions
Male | 0 | 0 | 0/10
Male | 1,880 | 123 | 3/10
Male | 3,750 | 241 | 8/10
Male | 7,500 | 486 | 10/10
Male | 15,000 | 991 | 9/10
Male | 30,000 | 2,014 | 10/10
Female | 0 | 0 | 3/10
Female | 1,880 | 131 | 2/10
Female | 3,750 | 254 | 6/10
Female | 7,500 | 509 | 10/10
Female | 15,000 | 1,024 | 8/10
Female | 30,000 | 2,050 | 10/10

Source: NTP 1992b

Table A-2 Goodness-of-Fit Statistics and BMD_10_s and BMDL_10_s from Models Fit to Incidence Data for Nasal Lesions in Male Rats Exposed to m/p-Cresol in the Diet for 13 Weeks

Model | AIC | X^2^ p value^a^ | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day)
Gamma | 37.3167 | 0.1221 | 24.1138 | 16.7698
Logistic | 46.7819 | 0.0000 | 63.9362 | 42.8254
Log-Logistic ^b^ | 36.8962 | 0.2605 | 55.8863 | 13.9381
Multistage | 37.3167 | 0.1221 | 24.1138 | 16.7698
Probit | 49.738 | 0.0002 | 71.306 | 50.8541
Log-probit | 37.6831 | 0.2511 | 46.1987 | 26.6915
Quantal-linear | 37.3167 | 0.1221 | 24.1138 | 16.7698
Weibull | 37.3167 | 0.1221 | 24.1138 | 16.7698

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Best-fitting model

AIC = Akaike’s Information Criteria; BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose; p = p value from the Chi-squared test

Source: NTP 1992b

Table A-3 Goodness-of-Fit Statistics and BMD_10_s and BMDL_10_s from Models Fit to Incidence Data for Nasal Lesions in Female Rats Exposed to m/p-Cresol in the Diet for 13 Weeks

Model | AIC | X^2^ p value^a^ | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day)
Gamma | 61.5191 | 0.0477 | 64.2166 | 30.9781
Logistic | 60.7552 | 0.0557 | 89.5533 | 60.4852
Log-Logistic | 60.0961 | 0.0487 | 98.7921 | 28.7889
Multistage ^b^ | 59.5988 | 0.1020 | 48.0244 | 30.7916
Probit | 61.2978 | 0.0600 | 98.0573 | 69.3757
Log-probit | 60.351 | 0.0591 | 99.9316 | 51.3824
Quantal-linear ^b^ | 59.5988 | 0.1020 | 48.0246 | 30.7916
Weibull | 61.5874 | 0.0505 | 52.5879 | 30.8181

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Best-fitting model

AIC = Akaike’s Information Criteria; BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose; p = p value from the Chi-squared test

Source: NTP 1992b

Figure A-1 Observed and Predicted Incidences of Nasal Lesions in Male Rats Exposed to m/p-Cresol in the Diet for 13 Weeks^*^ * BMDs and BMDLs indicated are for a 10% extra risk and are in units of mg/kg/day.

Source: NTP 1992b

Figure A-2 Observed and Predicted Incidences of Nasal Lesions in Female Rats Exposed to m/p-Cresol in the Diet for 13 Weeks^*^ * BMDs and BMDLs Indicated are for a 10% extra risk and are in units of mg/kg/day.

Source: NTP 1992b

BMDs and BMDLs associated with 1, 5, 10, 20, and 30% extra risk were calculated with the best-fitting model of the male rat nasal lesion incidence data (see Table A-4). Following EPA’s Benchmark Dose Guidance (EPA 2000a) to select a point of departure, a benchmark response (BMR) of 10% was selected for the benchmark analysis of nasal lesion incidence data in male rats in the 13-week NTP (1992b) study. The BMD corresponding to a BMR of 10% extra risk is 55.89 mg/kg/day; the corresponding BMDL_10_ is 13.94 mg/kg/day (see Table A-4). Applying an uncertainty factor of 100 (10 each for intra- and interspecies extrapolation) to the BMDL_10_ yields an intermediate-duration oral MRL of 0.1 mg/kg/day for m/p-cresol.

Table A-4 Best-fitting Model Predictions for 1, 5, 10, 20, and 30% Extra Risk for Incidence of Nasal Lesions Observed in Rats Exposed to m/p-Cresol in the Feed for 13 Weeks

Best fitting model | BMR (% extra risk) | BMD (mg/kg/day) | BMDL (mg/kg/day)
Male: Log-Logistic | 1 | 18.38 | 1.70
Male: Log-Logistic | 5 | 39.52 | 7.26
Male: Log-Logistic | 10 | 55.89 | 13.94
Male: Log-Logistic | 20 | 81.41 | 28.08
Male: Log-Logistic | 30 | 104.53 | 44.35
Female: Quantal Linear | 1 | 4.58 | 2.94
Female: Quantal Linear | 5 | 23.38 | 14.99
Female: Quantal Linear | 10 | 48.02 | 30.79
Female: Quantal Linear | 20 | 101.71 | 65.21
Female: Quantal Linear | 30 | 162.58 | 104.24

Source: NTP 1992b

All available dichotomous models in the EPA BMDS (version 2.0) were fit to the incidence data for nasal lesions (respiratory epithelium glandular hyperplasia or hyperplasia) in male and female rats exposed to m/p-cresol in the diet for 13 weeks (NTP 1992b) (Table A-1). Predicted doses associated with 30, 20, 10, 5, and 1% extra risks were calculated.

##### Male Rats

As assessed by the chi-square goodness-of-fit test, several models in the software provided adequate fits to the data for the incidence of nasal lesions in male rats (x^2^ p value ≥0.1) (Table A-2). Comparing across models, a better fit is indicated by a lower Aikake’s Information Criteria value (AIC) (EPA 2000a). The log-logistic model was determined to be the best-fitting model, as indicated by the AIC (Table A-2). Benchmark doses (BMDs and BMDLs) associated with an extra risk of 30, 20, 10, 5, and 1, calculated from the best fitting model, are shown in Table A-4.

The form and parameters of the log-logistic model for the male rat data are as follows:

P [ response ] = background + ( 1 − background ) / [ 1 + EXP ( − intercept − slope * Log ( dose ) ) ]

background = 0;

intercept = −5.78913;

slope = 1.21882.

##### Female Rats

As assessed by the chi-square goodness-of-fit test, only the quantal linear model (which was the similar to the 1-degree polynomial model) provided an adequate fit to the data for the incidence of nasal lesions in female rats (x^2^ p value ≥0.1). Therefore, the quantal linear model was determined to be the best-fitting model (Table A-3). Benchmark doses (BMDs and BMDLs) associated with an extra risk of 30, 20, 10, 5, and 1%, calculated from the quantal linear model, are shown in Table A-4.

The form and parameters of the quantal linear model for the female rat data are as follows:

P [ response ] = background + ( 1 − background ) * [ 1 − EXP ( − slope * dose ) ]

background = 0.318182;

slope = 0.001321;

Power = 1 (Specified)

## Cresols Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Cresols
CAS Numbers: | 95-48-7, 108-39-4, 106-44-5, 1319-77-3
Date: | July 2008
Profile Status: | Final Draft Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 130
Species: | Mice

[underlined: Minimal Risk Level]: 0.1 [X] mg/kg/day [ ] ppm

[underlined: Reference]: NTP. 2008. Toxicology and carcinogenesis studies of cresols (CAS No. 1319-77-3) in male F344/N rats and female B6C3F_1_ mice (feed studies). Research Triangle Park, NC: National Toxicology Program. TR-550. Draft technical report.

Although the report has not yet been finalized by the NTP, a draft technical report has been reviewed by the NTP Board of Scientific Counselors Technical Reports Review Subcommittee, and a draft abstract, pathology tables, and survival and growth curves are available in the NTP web site (http://ntp.niehs.nih.gov/index.cfm?objectid=9B58ADF7-F1F6-975E-78A23152B1596409).

[underlined: Experimental design]: Groups of female B6C3F_1_ mice (50/group) were administered m/p-cresol (60% m-cresol, 40% p-cresol) in the diet at levels of 0, 1,000, 3,000, or 10,000 ppm for 2 years (NTP 2008). The corresponding doses of test compound estimated by the investigators were approximately 0, 100, 300, and 1,040 mg/kg/day. End points evaluated included clinical signs, food consumption, organ weights, and gross and microscopic appearance of organs and tissues at termination.

[underlined: Effect noted in study and corresponding doses]: Dosing with m/p-cresol did not affect survival rate. Food consumption did not appear to vary significantly throughout the study. No significant treatment-related clinical signs were reported. At termination, body weight in the mid- and high-dose groups was significantly lower than controls (11 and 24%, respectively). Significant treatment-related, non-neoplastic effects included: minimal to moderate bronchiolar hyperplasia in the lung (0/50, 42/50/, 44/49, 47/50); minimal to mild hyperplasia of the nasal respiratory epithelium (0/50, 0/50, 28/49, 21/50); mild follicular degeneration of the thyroid gland (7/48, 24/48, 24/49, 21/50); and increased eosinophilic foci in the liver (1/50, 0/50, 2/49, 12/50). NOAELs for bronchiolar hyperplasia and thyroid follicular degeneration were not established, and in both cases, the LOAEL was 100 mg/kg/day.

Since the incidence data indicate that bronchiolar hyperplasia of the lung and follicular degeneration of the thyroid gland had lower thresholds than the liver or nasal effects, the former two responses were considered for analysis using the benchmark dose approach for MRL derivation. After inspection of the dose response data, the use of a LOAEL/NOAEL approach for MRL derivation was considered to be more appropriate than the use of benchmark dose analysis because of the steep increase in the response rates between the control group and the first exposure level.

[underlined: Dose and end point used for MRL derivation]: LOAEL of 100 mg/kg/day for bronchiole hyperplasia of the lung and follicular degeneration of the thyroid gland in female mice.

[ ] NOAEL [x] LOAEL [ ] BMDL_10_

[underlined: Uncertainty Factors used in MRL derivation]:

- [x] 10 for extrapolation from animals to humans
- [x] 10 for human variability
- [x] 10 for use of a LOAEL

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Conversion from diet to dose was done by the investigators.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? No.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: The NTP (2008) is the only chronic-duration study with cresols available. The NTP (2008) also tested male F-344/N rats and the results showed that the most sensitive end point was the nasal respiratory epithelium, as in the shorter-term studies (NTP 1992b). Other less sensitive effects observed in rats included hyperplasia of the transitional epithelium of the renal pelvis, squamous metaplasia in the nasal respiratory epithelium, inflammation of the nose, and eosinophilic foci in the liver. The incidence of respiratory epithelium hyperplasia of minimal to mild severity was 3/50, 17/50, 31/50, and 47/50 in the control, low-, mid-, and high-dose groups, respectively. As discussed in Section 2.3, the data suggest that, over the range of doses used in the NTP (1992b, 2008) studies, exposure beyond 13 weeks had little or no effect on the incidence or severity of the nasal respiratory hyperplasia, indicating that the intermediate-duration MRL, which is based on incidence data for this lesion, should be protective of nasal lesions induced by chronic-duration exposure. This is supported by the fact that fitting the incidence data for nasal respiratory epithelium hyperplasia from the 2-year study to the same BMDS model (Log-Logistic) that provided the BMDL_10_ used to derive the intermediate-duration oral MRL yields a BMDL_10_ for chronic exposure to m/p-cresol of 13.9017 mg/kg/day, essentially the same as the BMDL_10_ of 13.9381 mg/kg/day used to derive the intermediate-duration oral MRL for m/p-cresol.

[underlined: Agency Contacts (Chemical Managers)]: Malcolm Williams, Ph.D.; John Risher, Ph.D.; Mike Fay, Ph.D.