# CHAPTER 8 REFERENCES

Alderman S, Kailas S, Goldfarb S, . 1994. Cholestatic hepatitis after ingestion of chaparral leaf: Confirmation by endoscopic retrograde cholangiopancreatography and liver biopsy. J Clin Gastroenterol 19(3):242–247. 10.1097/00004836-199410000-00016 7806838
Alhamdow A, Lindh C, Hagberg J, . 2018. DNA methylation of the cancer-related genes F2RL3 and AHRR is associated with occupational exposure to polycyclic aromatic hydrocarbons. Carcinogenesis 39(7):869–878. 10.1093/carcin/bgy059.29722794
Alhamdow A, Essig YJ, Krais AM, . 2020. Fluorene exposure among PAH-exposed workers is associated with epigenetic markers related to lung cancer. Occup Environ Med 77(7):488–495. 10.1136/oemed-2020-106413.32385190
Alicandro G, Rota M, Boffetta P, . 2016. Occupational exposure to polycyclic aromatic hydrocarbons and lymphatic and hematopoietic neoplasms: a systematic review and meta-analysis of cohort studies. Arch Toxicol 90(11):2643–2656. 10.1007/s00204-016-1822-8.27530719
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Anderson KA, Szelewski MJ, Wilson G, . 2015. Modified ion source triple quadrupole mass spectrometer gas chromatograph for polycyclic aromatic hydrocarbon analyses. J Chromatogr A 1419:89–98. 10.1016/j.chroma.2015.09.054.26454790
Armstrong BG, Gibbs G. 2009. Exposure-response relationship between lung cancer and polycyclic aromatic hydrocarbons (PAHs). Occup Environ Med 66(11):740–746. 10.1136/oem.2008.043711.19546103
Armstrong B, Hutchinson E, Unwin J, . 2004. Lung cancer risk after exposure to polycyclic aromatic hydrocarbons: a review and meta-analysis. Environ Health Perspect 112(9):970–978. 10.1289/ehp.6895.15198916
Arvin E, Flyvbjerg J. 1992. Groundwater pollution arising from the disposal of creosote waste. J Water Environ Manage 6:646–652. 10.1111/j.1747-6593.1992.tb00715.x.
Assennato G, Bisceglia L, de Nichilo G. 2004. Assessment of occupational exposure to PAHs in a coke-plant by biological monitoring. In: Brebbia CA, ed. Air pollution XII. UK: Wessex Institute of Technology, 741–748. https://www.witpress.com/Secure/elibrary/papers/AIR04/AIR04072FU.pdf. February 13, 2024.
ASTM. 2016. Standard specification for road tar. ASTM International. ASTM D490-92.
ASTM. 2017. Standard specification for emulsified refined coal-tar (Ready to Use, Commercial Grade). ASTM International. ASTM D6945/D6945M.
Atkinson R. 1989. Creosote containing substances. In: Kinetics and mechanisms of the gas-phase reactions of the hydroxyl radical with organic compounds. New York, NY: American Institute of Physics, 3–7.
Atkinson R, Aschmann SM, Winer AM. 1987. Kinetics of the reactions of NO3 radicals with a series of aromatic compounds. Environ Sci Technol 21:1123–1126. 10.1021/es00164a015.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; notice. Fed Regist 54(174):37618–37634.
ATSDR. 1994. Final Report: Site specific surveillance project at the Koppers Company, Inc. National Priorities List Site Texarkana, Texas. Agency for Toxic Substances and Disease Registry. PB94154051.
ATSDR. 1995. Toxicological profile for polycyclic aromatic hydrocarbons. Atlanta, GA: Agency for Toxic Substances and Disease Registry. PB95264370. https://www.atsdr.cdc.gov/toxprofiles/tp69.pdf. November 3, 2022.
ATSDR. 2004. Health consultation: Airborne chemicals from wood treatment chemical - William C. Meredith Company, Incorporated, East Point, Fulton County, Georgia. Atlanta, GA: Agency for Toxic Substances and Disease Registry. EPA Facility ID: GAD003323805. https://www.atsdr.cdc.gov/HAC/pha/MeredithCWilliam092904-GA/MeredithCWilliams092904HC-GA.pdf. June 29, 2023.
ATSDR. 2005. Toxicological profile for naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene. Atlanta, GA: Agency for Toxic Substances and Disease Registry. PB2006100004. https://www.atsdr.cdc.gov/toxprofiles/tp67.pdf. November 2, 2022.
ATSDR. 2006. Health consultation: Hurricane response sampling assessment for Madisonville creosote works, Madisonville, St. Tammany Parish, Louisiana. Atlanta, GA: Agency for Toxic Substances and Disease Registry. PB2008102277. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB2008102277.xhtml. March 2, 2023.
ATSDR. 2007a. Toxicological profile for xylene. Atlanta, GA: Agency for Toxic Substances and Disease Registry. PB2008100008. https://www.atsdr.cdc.gov/toxprofiles/tp71.pdf. November 2, 2022.
ATSDR. 2007b. Health consultation: Exposure investigation report - Meredith William Co. Inc., East Point, Georgia. Atlanta, GA: Agency for Toxic Substances and Disease Registry. EPA FACILITY ID: GAD003323805. https://www.atsdr.cdc.gov/hac/pha/meredithwilliamsccoinc/meredithwilliameihc8-23-07.pdf. June 29, 2023.
ATSDR. 2008a. Toxicological profile for cresols. Atlanta, GA: Agency for Toxic Substances and Disease Registry. PB2009100002. https://www.atsdr.cdc.gov/toxprofiles/tp34.pdf. November 2, 2022.
ATSDR. 2008b. Toxicological profile for phenols. Atlanta, GA: Agency for Toxic Substances and Disease Registry. PB2009100007. https://www.atsdr.cdc.gov/toxprofiles/tp115.pdf. November 2, 2022.
ATSDR. 2009. Public health assessment for air exposures to wood treat chemical - Kerr-McGee Chemical Corporation, Columbus, Mississippi. Atlanta, GA: Agency for Toxic Substances and Disease Registry. EPA FACILITY ID: MSD990866329 https://www.atsdr.cdc.gov/HAC/pha/Kerr-McGeeChemicalCorporation/KerrMcGeeChemCorpAirExposuresPHA10-21-2009.pdf. June 29, 2023.
ATSDR. 2013. Letter health consultation: St. Maries Creosote, St. Maries, Idaho. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/HAC/pha/StMariesCreosote/StMariesCreosoteLHCFINAL207192013_508.pdf. March 2, 2023.
ATSDR. 2016a. ATSDR’s Guidance for evaluating vapor intrusion pathways. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/pha-guidance/resources/ATSDR-SVI-Guidance-508.pdf. March 2, 2023.
ATSDR. 2016b. Evaluation of exposure to groundwater, surface water, soil, and sediment: American Creosote Works, Incorporated, Louisville, Winston County, Mississippi. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/HAC/pha/AmericanCreosote/American_Creosote_Works_PHA_508.pdf. March 2, 2023.
ATSDR. 2020. Public health assessment: Holcomb Creosote Company NPL Site, Yadkinville, Yadkin County, North Carolina. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/HAC/pha/HolcombCreosoteCompany/Holcomb_Creosote_Co_PHA-508.pdf. March 2, 2023.
ATSDR. 2022. Creosote. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/spl/index.html. May 22, 2023.
Attalla MN. 1968. Effect of beechwood creosote and chloramine on periapical tissue of dogs. J Can Dent Assoc (Tor) 34(4):190–195.5248858
Autrup H, Seremet T. 1986. Excretion of benzo[a]pyrene-Gua adduct in the urine of benzo[a]pyrene-treated rats. Chem Biol Interact 60(2):217–226. 10.1016/0009-2797(86)90030-x.3791489
AWPA. 1988. Preservatives. In: AWPA Book of standards. Washington, DC: American Wood Preservers’ Association, P1-78 to P13-85.
Aygun SF, Bagcevan B. 2019. Determination of polycyclic aromatic hydrocarbons (PAHs) in drinking water of Samsun and it’s surrounding areas, Turkey. J Environ Health Sci Eng 17(2):1205–1212. 10.1007/s40201-019-00436-0.32030186
Baedecker MJ, Franks BJ, Goerlitz DF, . 1988. Geochemistry of a shallow aquifer contaminated with creosote products. In: Ragone SE, ed. U.S. Geological Survey Program on toxic waste - Ground-water contamination: Proceedings of the second technical meeting, Cape Cod, Massachusetts, October 21-25, 1985. Reston, VA: U.S. Geological Survey, A17–A20. https://pubs.usgs.gov/of/1986/0481/report.pdf. January 9, 2023.
Baldwin AK, Corsi SR, Oliver SK, . 2020. Primary sources of polycyclic aromatic hydrocarbons to streambed sediment in Great Lakes tributaries using multiple lines of evidence. Environ Toxicol Chem 39(7):1392–1408. 10.1002/etc.4727.32525591
Ball J. 1987. Soil and groundwater contamination at wood preserving plants. In: Bell JM, ed. Proceedings of the 41st Industrial Waste Conference May 1986, Purdue University. Boca Raton: CRC Press, 347–351. 10.1201/9781351069380.
Ball J, Norton CM, Andrews JW. 1985. Environmental feasibility of using creosote contaminated soil and sludges in roadway paving structures. In: Bell JM, ed. Proceedings of the 39th Industrial Waste Conference, May 8, 9, 10, 1984, Purdue University, West Lafayette, Indiana. Boston: Butterworth Publishers, 361–368.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486. 10.1016/0273-2300(88)90047-5.3222488
Bartosek I, Guaitani A, Modica R, . 1984. Comparative kinetics of oral benz(a)anthracene, chrysene and triphenylene in rats: study with hydrocarbon mixtures. Toxicol Lett 23(3):333–339. 10.1016/0378-4274(84)90030-4.6549236
Bedient PB, Rodgers AC, Bouvette TC, . 1984. Groundwater quality at a creosote waste site. Groundwater 22:318–329. 10.1111/j.1745-6584.1984.tb01404.x.
Bender MA, Leonard RC, White O, . 1988. Chromosomal aberrations and sister-chromatid exchanges in lymphocytes from coke oven workers. Mutat Res 206(1):11–16. 10.1016/0165-1218(88)90135-8.3412368
Bender AP, Parker DL, Johnson RA, . 1989. Minnesota highway maintenance worker study: Cancer mortality. Am J Ind Med 15(5):545–556. 10.1002/ajim.4700150507.2741960
Bennett JL, Updegraff DM, Pereira WE, . 1985. Isolation and identification of four species of quinoline-degrading pseudomonads from a creosote-contaminated site at Pensacola, Florida. Microbios Lett 29:147–154.
Berger J, Manz A. 1992. Cancer of the stomach and the colon-rectum among workers in a coke gas plant. Am J Ind Med 22(6):825–834. 10.1002/ajim.4700220605.1463028
Bertrand JP, Chau N, Patris A, . 1987. Mortality due to respiratory cancers in the coke oven plants of the Lorraine coal mining industry (Houilleres du Bassin de Lorraine). Br J Ind Med 44:559–565. 10.1136/oem.44.8.559.3651355
Bestari KTJ, Robinson RD, Solomon KR, . 1998. Distribution and composition of polycyclic aromatic hydrocarbons within experimental microcosms treated with creosote-impregnated Douglas fir pilings. Environ Toxicol Chem 17(12):2369–2377. 10.1002/etc.5620171202.
Bickers DR, Kappas A. 1978. Human skin aryl hydrocarbon hydroxylase. Induction by coal tar. J Clin Invest 62(5):1061–1068. 10.1172/JCI109211.711851
Bieniek G. 1997. Urinary naphthols as an indicator of exposure to naphthalene. Scand J Work Environ Health 23:414–420.9476804
Billinsky J, Maloney K, Krol E, . 2012. A comparison between lignans from creosote bush and flaxseed and their potential to inhibit cytochrome P450 enzyme activity. In: Vallisuta O, ed. Drug discovery research in pharmacognosy. London: IntechOpen Limited, 145–164. 10.5772/34317.
Bjor O, Damber L, Edstrom C, . 2008. Long-term follow-up study of mortality and the incidence of cancer in a cohort of workers at a primary aluminum smelter in Sweden. Scand J Work Environ Health 34(6):463–470. 10.5271/sjweh.1293.19137208
Black JJ. 1982. Movement and identification of a creosote-derived PAH complex below a river pollution point source. Arch Environ Contam Toxicol 11(2):161–166. 10.1007/BF01054892.6284067
Blair A, Linos A, Stewart PA, . 1993. Evaluation of risks for non-Hodgkin’s lymphoma by occupational and industry exposure from a case-control study. Am J Ind Med 23(2):301–312. 10.1002/ajim.4700230207.8427258
Boffetta P, Burstyn I, Partanen T, . 2003. Cancer mortality among European asphalt workers: an international epidemiological study. I. Results of the analysis based on job titles. Am J Ind Med 43(1):18–27. 10.1002/ajim.10181.12494418
Bolin CA, Smith ST. 2013. Life cycle assessment of creosote-treated wooden railroad crossties in the US with comparisons to concrete and plastic composite railroad crossties. J Transp Technol 3(2):149–161. 10.4236/jtts.2013.32015.
Bolt HM, Golka K. 1993. Cases of lung cancer and tar-related skin changes in an aluminum reduction plant [letter]. Med Lav 84(2):178–181.8316147
Borak J, Sirianni G, Cohen H, . 2002. Biological versus ambient exposure monitoring of creosote facility workers. J Occup Environ Med 44(4):310–319. 10.1097/00043764-200204000-00011.11977417
Bordelon NR, Donnelly KC, King LC, . 2000. Bioavailability of the genotoxic components in coal tar contaminated soils in Fischer 344 rats. Toxicol Sci 56(1):37–48. 10.1093/toxsci/56.1.37.10869452
Borden RC. 1986. Influence of adsorption and oxygen limited biodegradation on the transport and fate of a creosote plume: Field methods and simulation techniques. Houston, TX: Rice University. Thesis submitted in partial fulfillment of the requirements for the degree, Doctor of Philosophy.
Borska L, Fiala Z, Krejsek J, . 2006. Selected immunological changes in patients with Coeckerman’s therapy TNF-alpha, sE-selectin, sP-selectin, sICAM-1 and IL-8. Physiol Res 55:699–706. 10.33549/physiolres.930928.16497101
Borthwick PW, Patrick JM. 1982. Use of aquatic toxicology and quantitative chemistry to estimate environmental deactivation of marine-grade creosote in seawater. Environ Toxicol Chem 1:281–288. 10.1002/etc.5620010403.
Bos RP, Jongeneelen FJ. 1988. Nonselective and selective methods for biological monitoring of exposure to coal-tar products. IARC Sci Publ (89):389–395. https://publications.iarc.fr/232. February 13, 2024.3198226
Bos RP, Hulshof CTJ, Theuws JLG, . 1983. Mutagenicity of creosote in the Salmonella/microsome assay. Mutat Res 119:21–25. 10.1016/0165-7992(83)90033-7.6337318
Bos RP, Jongeneelen FJ, Theuws JL, . 1985. Detection of volatile mutagens in creosote and coal tar. Mutat Res 156(3):195–198. 10.1016/0165-1218(85)90064-3.3889636
Bosetti C, Boffetta P, La Vecchia C. 2007. Occupational exposures to polycyclic aromatic hydrocarbons, and respiratory and urinary tract cancers: a quantitative review to 2005. Ann Oncol 18(3):431–446. 10.1093/annonc/mdl172.16936186
Boutwell RK, Bosch DK. 1958. The carcinogenicity of creosote oil: its role in the induction of skin tumors in mice. Cancer Res 18(10):1171–1175.13596959
Bowman CE, Muhleman MF, Walters E. 1984. A fatal case of creosote poisoning. Postgrad Med J 60(705):499–500. 10.1136/pgmj.60.705.499.6463007
Bowman ED, Rothman N, Hackl C, . 1997. Interindividual variation in the levels of certain urinary polycyclic aromatic hydrocarbon metabolites following medicinal exposure to coal tar ointment. Biomarkers 2(5):321–327. 10.1080/135475097231553.23889114
Brooks KM. 2011a. Environmental risk assessments case studies. In: Morrell JJ, Broods KM, Davis CM, eds. Managing treated wood in aquatic environments. LaGrange, GA: Forest Products Society, 309–406.
Brooks KM. 2011b. Treated wood environment. In: Morrell JJ, Broods KM, Davis CM, eds. Managing treated wood in aquatic environments. LaGrange, GA: Forest Products Society, 211–240.
Brooks LR, Hughes TJ, Claxton LD, . 1998. Bioassay-directed fractionation and chemical identification of mutagens in bioremediated soils. Environ Health Perspect 106(Suppl 6):1435–1440. 10.1289/ehp.98106s61435.9860902
Brown DG, Gupta L, Kim TH, . 2006. Comparative assessment of coal tars obtained from 10 former manufactured gas plant sites in the eastern United States. Chemosphere 65(9):1562–1569. 10.1016/j.chemosphere.2006.03.068.16698063
Budavari SB. 1989. Creosotes. In: The Merck index: An encyclopedia of chemicals and drugs. 11th ed. Rahway, NJ: Merck and Co., Inc., 2577.
Burstyn I, Boffetta P, Heederik D, . 2003. Mortality from obstructive lung diseases and exposure to polycyclic aromatic hydrocarbons among asphalt workers. Am J Epidemiol 158(5):468–478. 10.1093/aje/kwg180.12936902
Burstyn I, Kromhout H, Partanen T, . 2005. Polycyclic aromatic hydrocarbons and fatal ischemic heart disease. Epidemiology 16(6):744–750. 10.1097/01.ede.0000181310.65043.2f.16222163
Bye T, Romundstad PR, Ronneberg A, . 1998. Health survey of former workers in a Norwegian coke plant: Part 2. Cancer incidence and cause specific mortality. Occup Environ Med 55(9):622–626. 10.1136/oem.55.9.622.9861185
Byss M, Elhottova D, Triska J, . 2008. Fungal bioremediation of the creosote-contaminated soil: influence of Pleurotus ostreatus and Irpex lacteus on polycyclic aromatic hydrocarbons removal and soil microbial community composition in the laboratory-scale study. Chemosphere 73(9):1518–1523. 10.1016/j.chemosphere.2008.07.030.18782639
Calabrese EJ. 1978. Polycyclic aromatic hydrocarbons. In: Pollutants and high-risk groups. The biological basis of increased human susceptibility to environmental and occupational pollutants. New York: John Wiley and Sons, 24, 79–80, 187, 193.
Carta P, Aru G, Cadeddu C, . 2004. Mortality for pancreatic cancer among aluminium smelter workers in Sardinia, Italy. G Ital Med Lav Ergon 26(2):83–89.15270434
Catallo WJ, Gambrell RP. 1987. The effects of high levels of polycyclic aromatic hydrocarbons on sediment physicochemical properties and benthic organisms in a polluted stream. Chemosphere 16(5):1053–1063. 10.1016/0045-6535(87)90042-7.
CDC. 1980. Pentachlorophenol in log homes-Kentucky. Centers for Disease Control and Prevention. MMWR Morb Mortal Wkly Rep 29(36):431–433.
CDC. 1982. Current trends follow-up on pentachlorophenol in log homes. Centers for Disease Control and Prevention. MMWR Morb Mortal Wkly Rep 31(13):170–171.6804776
CDC. 1983. Occupational mortality in Washington State: 1950-1979. Cincinnati, OH: Centers for Disease Control and Prevention. DHHS Publ No 83-116. https://www.cdc.gov/niosh/docs/83-116/pdfs/83-116.pdf. November 3, 2022.
CDC. 1992. Chaparral-induced toxic hepatitis - California and Texas. Centers for Disease Control and Prevention. MMWR Morb Mortal Wkly Rep 41(43):812–814.1406577
CDC. 2024. [No data]. National health and nutrition examination survey. Centers for Disease Control and Prevention. https://wwwn.cdc.gov/nchs/nhanes/. May 16, 2024.
Cernikova M, Dubsky H, Horacek J. 1983. Detection of acridine in human urine after topical coal-tar treatment. J Chromatogr 273(1):202–206. 10.1016/S0378-4347(00)80939-1.6853651
Chadwick RW, George SE, Kohan MJ, . 1995. Potentiation of 2,6-dinitrotoluene genotoxicity in Fischer 344 rats by pretreatment with coal tar creosote. J Toxicol Environ Health 44(3):319–336. 10.1080/15287399509531962.7897694
Chang LH. 1943. The fecal excretion of polycyclic hydrocarbons following their administration to the rat. J Biol Chem 151:93–99.
Chau N, Bertrand JP, Mur JM, . 1993. Mortality in retired coke oven plant workers. Br J Ind Med 50(2):127–135. 10.1136/oem.50.2.127.8435345
Chen QF, Milburn RK, DeBrou GB, . 2002. Air monitoring of a coal tar cleanup using a mobile TAGA LPCI-MS/MS. J Hazard Mater B 91(1–3):271–284. 10.1016/s0304-3894(01)00395-8.
Clayton GD, Clayton FE. 1981. Creosote. In: Patty’s industrial hygiene and toxicology. Vol. 2A. 3rd ed. New York: John Wiley Sons, 2601–2604.
Clewell HJ. 1995. The application of physiologically based pharmacokinetic modeling in human health risk assessment of hazardous substances. Toxicol Lett 79(1–3):207–217. 10.1016/0378-4274(95)03372-r.7570658
Clonfero E, Zordan M, Venier P, . 1989. Biological monitoring of human exposure to coal tar. Urinary excretion of total polycyclic hydrocarbons, 1-hydroxypyrene and mutagens in psoriatic patients. Int Arch Occup Environ Health 61:363–368. 10.1007/BF00381025.2744865
Constantino JP, Redmond CK, Bearden A. 1995. Occupationally related cancer risk among coke oven workers: 30 years of follow-up. J Occup Environ Med 37(5):597–604. 10.1097/00043764-199505000-00009.7640988
Cookson HA. 1924. Epithelioma of the skin after prolonged exposure to creosote (with special plate). Br Med J 1(3296):368–369. 10.1136/bmj.1.3296.368.
CSCC. 2010. Removal of creosote-treated pilings and structures from San Francisco Bay. Oakland, CA: California State Coastal Conservancy. Report No. 605. https://www.sfei.org/sites/default/files/biblio_files/ReportNo605_Creosote_Dec2010_finalJan13.pdf. September 26, 2022.
Culp SJ, Beland FA. 1994. Comparison of DNA adduct formation in mice fed coal tar or benzo[a]pyrene. Carcinogenesis 15(2):247–252. 10.1093/carcin/15.2.247.8313515
Culp SJ, Gaylor DW, Sheldon WG, . 1996. DNA adduct measurements in relation to small intestine and forestomach tumor incidence during the chronic feeding of coal tar or benzo(a)pyrene to mice. Polycyclic Aromatic Compounds 11:161–168. 10.1080/10406639608544662.
Culp SJ, Gaylor DW, Sheldon WG, . 1998. A comparison of the tumors induced by coal tar and benzo[a]pyrene in a 2-year bioassay. Carcinogenesis 19(1):117–124. 10.1093/carcin/19.1.117.9472702
Culp SJ, Warbritton AR, Smith BA, . 2000. DNA adduct measurements, cell proliferation and tumor mutation induction in relation to tumor formation in B6C3F1 mice fed coal tar or benzo[a]pyrene. Carcinogenesis 21(7):1433–1440. 10.1093/carcin/21.7.1433.10874023
Cusano F, Capozzi M, Errico G. 1992. Allergic contact dermatitis from coal tar. Contact Dermatitis 27(1):51–52. 10.1111/j.1600-0536.1992.tb05199.x.1424593
Dahl AR, Coslett DS, Bond JA, . 1985. Metabolism of benzo[a]pyrene on the nasal mucosa of Syrian hamsters: comparison to metabolism by other extrahepatic tissues and possible role of nasally produced metabolites in carcinogenesis. J Natl Cancer Inst 75(1):135–139. 10.1093/jnci/75.1.135.3859686
Dahlgren J, Warshaw R, Horsak RD, . 2003. Exposure assessment of residents living near a wood treatment plant. Environ Res 92(2):99–109. 10.1016/s0013-9351(02)00064-6.12854689
Dahlgren J, Schecter A, David H, . 2004. Biomonitoring for creosote and pentachlorophenol in nearby residents of a wood treatment plant. Organohalogen Compounds 66:2476–2480.
Dahlgren J, Takhar H, Schecter A, . 2007. Residential and biological exposure assessment of chemicals from a wood treatment plant. Chemosphere 67(9):S279–285. 10.1016/j.chemosphere.2006.05.109.17234249
Davis MW, Glaser JA, Evans JW, . 1993. Field evaluation of the lignin-degrading fungus Phanerochaete sordida to treat creosote-contaminated soil. Environ Sci Technol 27:2572–2576. 10.1021/es00048a040.
Dean AG, Imrey HH, Dusich K. 1988. Adjusting morbidity ratios in two communities using risk factor prevalence in cases. Am J Epidemiol 127:654–662.3341365
Deelman HT. 1962. Induction and other problems of tar cancer. In: Severi L, ed. Morphological precursors of cancer: Proceedings of an International Conference held at the University of Perugia, 26-30 June 1961. Perugia: Division of Cancer Research, 69–73.
DeLeon IR, Ferrario JB, Byrne CJ. 1988. Bioaccumulation of polynuclear aromatic hydrocarbons by the clam, Rangia cuneata, in the vicinity of a creosote spill. Bull Environ Contam Toxicol 41(6):872–879. 10.1007/BF02021049.3233386
de Souza MR, Kahl VFS, Rohr P, . 2018. Shorter telomere length and DNA hypermethylation in peripheral blood cells of coal workers. Mutat Res Genet Toxicol Environ Mutagen 836(Pt B):36–41. 10.1016/j.mrgentox.2018.03.009.
Di Giulio RT, Clark BW. 2015. The Elizabeth River story: A case study in evolutionary toxicology. J Toxicol Environ Health B 18(6):259–298. 10.1080/15320383.2015.1074841.
Diette KM, Gange RW, Stern RS, . 1983. Coal tar phototoxicity: kinetics and exposure parameters. J Invest Dermatol 81(4):347–350. 10.1111/1523-1747.ep12519930.6619565
DOE. 1994. Toxicity studies of mild gasification products. Morgantown, WV: U.S. Department of Energy. DOEMC260183730. DE94004113. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/DE94004113.xhtml. November 3, 2022.
DOE. 2018a. Table 3: Protective action criteria (PAC) rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/docs/Revision_29A_Table3.pdf. July 6, 2022.
DOE. 2018b. Protective action criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/. July 6, 2022.
Donnelly KC, Phillips TD, Onufrock AM, . 1996. Genotoxicity of model and complex mixtures of polycyclic aromatic hydrocarbons. Environ Toxicol Risk Assess 5:138–148.
DOT. 1985. Chemical hazard response information system (CHRIS) hazard assessment handbook. Washington, DC: Department of Transportation. ADA096803. RIA80U891. https://apps.dtic.mil/sti/pdfs/ADA096803.pdf. November 3, 2022.
Duan S, Yuan H, Yu S, . 2021. Epigenetic-based biomarkers in the malignant transformation of BEAS-2B cells induced by coal tar pitch extract. Medicina (Kaunas) 57(1):24. 10.3390/medicina57010024.
Dunn BP, Stich HF. 1976. Monitoring procedures for chemical carcinogens in coastal waters. J Fish Res Board Canada 33:2040–2046.
Ehrlich GG, Godsy EM, Goerlitz DF, . 1983. Microbial ecology of a creosote-contaminated aquifer at St. Louis Park, Minnesota. Dev Ind Microbiol 24:235–245.
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15(1):30–38. 10.1021/es00083a002.
Elder JF, Dresler PV. 1988. Accumulation and bioconcentration of polycyclic aromatic hydrocarbons in a nearshore estuarine environment near a Pensacola (Florida) creosote contamination site. Environ Pollut 49(2):117–132. 10.1016/0269-7491(88)90244-8.15092667
Elovaara E, Heikkila P, Pyy L, . 1995. Significance of dermal and respiratory uptake in creosote workers: exposure to polycyclic aromatic hydrocarbons and urinary excretion of 1-hydroxypyrene. Occup Environ Med 52(3):196–203. 10.1136/oem.52.3.196.7735394
Emmett EA. 1986. Cutaneous and ocular hazards of roofers. Occup Med 1(2):307–322.2956712
Emmett EA, Bingham EM, Barkley W. 1981. A carcinogenic bioassay of certain roofing materials. Am J Ind Med 2(1):59–64. 10.1002/ajim.4700020110.7349035
EPA. 1978. Investigation of selected potential environmental contaminants: Asphalt and coal tar pitch. Final Report. Washington, DC: U.S. Environmental Protection Agency. EPA560277005. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100RXZK.txt. November 3, 2022.
EPA. 1980. Identification and listing of hazardous waste. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261. https://www.govinfo.gov/content/pkg/CFR-2021-title40-vol28/pdf/CFR-2021-title40-vol28-part261.pdf. November 3, 2022.
EPA. 1981a. Wood preservative pesticides. Creosote, pentachlorophenol and the inorganic arsenicals (wood uses). Position document 2/3. Washington, DC: U.S. Environmental Protection Agency. EPA540982004. PB82229956. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000SN8R.txt. February 13, 2024.
EPA. 1981b. Creosote, pentachlorophenol, and the inorganic arsenicals: Preliminary notice of determination concluding the rebuttable presumption against registration of the wood-preservative uses of pesticide products. U.S. Environmental Protection Agency. Fed Regist 46(33):13020–13036. https://www.govinfo.gov/app/details/FR-1982-02-18. January 9, 2023.
EPA. 1984. Coal tar, creosote, and coal tar neutral oil: Non-wood preservative uses: position document no. 2/3. U.S. Environmental Protection Agency. EPA5400987110. PB87178851. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=94001A1H.txt. November 3, 2022.
EPA. 1986a. Creosote, pentachlorophenols, and inorganic arsenicals: Amendment of notice of intent to cancel registrations. U.S. Environmental Protection Agency. Fed Regist 51(7):1334–1348. https://www.govinfo.gov/app/details/FR-1986-01-10. January 9, 2023.
EPA. 1986b. Emissions test report air toxics sampling at Wyckoff, Inc., Bainbridge Island Washington. Seattle, WA: U.S. Environmental Protection Agency. EPA910986149. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100WQJJ.txt. November 3, 2022.
EPA. 1986c. Method 8310: Polynuclear aromatic hydrocarbons. Test methods for evaluating solid waste. Volume IB: Laboratory manual physical/chemical methods. Washington, DC: U.S. Environmental Protection Agency. SW-846. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000G00Y.txt. November 3, 2022.
EPA. 1988a. Toxic chemical release reporting: Community right-to-know. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372. https://www.govinfo.gov/content/pkg/CFR-2021-title40-vol30/pdf/CFR-2021-title40-vol30-part372.pdf. November 3, 2022.
EPA. 1988b. U.S. production of manufactures gases: Assessment of past disposal practices. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600288012. PB88165790. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=20012O71.txt. January 9, 2023.
EPA. 1990. Land disposal restrictions for third scheduled wastes. U.S. Environmental Protection Agency. Fed Regist 55(106):22520–22720. https://www.govinfo.gov/app/details/FR-1990-06-01. January 9, 2023.
EPA. 1993. Guidance for assessing chemical contaminant data for use in fish advisories. Washington, DC: U.S. Environmental Protection Agency. EPA823R93002. PB93237899. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB93237899.xhtml. November 3, 2022.
EPA. 1994. Data evaluation record: Coal tar creosote. Review of acute toxicity studies, Guidelines 81-1 to 81-6. [MRID43032101, 43032102, 43032103, 43032104, 430321015, 4303210, 43032301, 43032302, 43032303, 43032305, 43032305, 43032306]. U.S. Environmental Protection Agency.
EPA. 1995a. Data evaluation record: Developmental toxicity study in rats: P1/P13 creosote [MRID43584201]. U.S. Environmental Protection Agency.
EPA. 1995b. Data evaluation record: Developmental toxicity study in rats: P2 creosote [MRID43584202]. U.S. Environmental Protection Agency.
EPA. 1995c. Data evaluation record: Thirteen week subchronic inhalation toxicity study on North American P2 creosote [MRID43600901]. U.S. Environmental Protection Agency.
EPA. 1995d. Data evaluation record: Thirteen week subchronic inhalation toxicity study on North American P1/P13 creosote [MRID43601001]. U.S. Environmental Protection Agency.
EPA. 1995e. Data record evaluation: 90 day subchronic dermal toxicity study in rats: North American P1/P13 creosote [MRID43616101]. U.S. Environmental Protection Agency.
EPA. 1997. Data evaluation record: A 6-month dermal oncogenicity study of creosote in mice [MRID44844401]. California Environmental Protection Agency.
EPA. 1998. Locating and estimating air emissions from sources of polycyclic organic matter. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB98159882. EPA454R98014. https://www3.epa.gov/ttnchie1/le/pompta.pdf. October 6, 2022.
EPA. 2006. Application of equilibrium partitioning theory to soil PAH contamination. U.S. Environmental Protection Agency. EPA600R06035A. ERASC-012. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=151825. May 10, 2023.
EPA. 2007a. Data evaluation record: Rodent in vivo dermal penetration study - Rat OPPTS 870.7600 [§85-2]; OECD none [MRID47179501]. U.S. Environmental Protection Agency.
EPA. 2007b. Method 8272: Parent and alkyl polycyclic aromatics in sediment pore water by solid-phase microextraction and gas chromatography/mass spectrometry in selected ion monitoring mode. U.S. Environmental Protection Agency. https://www.epa.gov/sites/default/files/2015-12/documents/8272.pdf. September 27, 2022.
EPA. 2008. Reregistration eligibility decision for creosote (Case 0139). Washington, DC: U.S. Environmental Protection Agency. EPA739R08007. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P1002CIB.txt. September 23, 2022.
EPA. 2009a. Data evaluation record: Rodent and human in vitro dermal penetration study - Rat and human non-guideline [MRID47179502]. U.S. Environmental Protection Agency.
EPA. 2009b. National primary drinking water regulations. U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
EPA. 2012. Estimation Programs Interface Suite™ for Microsoft® Windows, v 4.11. Washington, DC: U.S. Environmental Protection Agency. https://www.epa.gov/tsca-screening-tools/epi-suitetm-estimation-program-interface. September 26, 2022.
EPA. 2015. Creosote preliminary work plan. Registration review: Initial docket case number 0139. U.S. Environmental Protection Agency. EPA-HQ-OPP-2014-0823-0003. https://www.regulations.gov/document/EPA-HQ-OPP-2014-0823-0003. September 23, 2022.
EPA. 2016. Fourth five-year review report for Koppers Co., Inc. (Texarkana Plant) Superfund Site (Bowie County, Texas). Dallas, TX: U.S. Environmental Protection Agency. https://semspub.epa.gov/work/06/500023660.pdf. September 27, 2022.
EPA. 2017a. National emission inventory (NEI) data. U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/2017-national-emissions-inventory-nei-data. October 18, 2022.
EPA. 2017b. Fourth five-year review report for Escambia Wood - Pensacola Superfund Site (Escambia County, Florida). Atlanta, GA: U.S. Environmental Protection Agency. https://semspub.epa.gov/work/04/11070132.pdf. September 26, 2022.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822F18001. https://www.epa.gov/system/files/documents/2022-01/dwtable2018.pdf. June 15, 2022.
EPA. 2018b. Compiled AEGL values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2019. Memorandum: Registration review draft risk assessment for creosote. U.S. Environmental Protection Agency. EPA-HQ-OPP-2014-0823-0014. https://www.regulations.gov/document/EPA-HQ-OPP-2014-0823-0014. September 23, 2022.
EPA. 2020a. Creosote: Proposed interim registration review decision (case number 0139). U.S. Environmental Protection Agency. EPA-HQ-OPP-2014-0823-0019. https://www.regulations.gov/document/EPA-HQ-OPP-2014-0823-0019. September 23, 2022.
EPA. 2020b. Characterizing community exposure to atmospheric polycyclic aromatic hydrocarbons (PAHs) in the Memphis Tri-State area: Final report. U.S. Environmental Protection Agency. https://www.epa.gov/sites/default/files/2020-01/documents/memphis_pahs_study_final_report_08.pdf. September 27, 2022.
EPA. 2022a. Non-confidential TSCA Inventory. U.S. Environmental Protection Agency. https://www.epa.gov/tsca-inventory/how-access-tsca-inventory. September 27, 2022.
EPA. 2022b. Creosote. 2020 Chemical data reporting (CDR) data. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/access-cdr-data. November 20, 2023.
EPA. 2022c. Toxic chemical release inventory reporting forms and instructions: Revised 2021 version. U.S. Environmental Protection Agency. EPA740B22002. https://ordspub.epa.gov/ords/guideme_ext/guideme_ext/guideme/file/ry_2021_rfi.pdf. August 22, 2023.
Eriksson M, Karlsson M. 1992. Occupational and other environmental factors and multiple myeloma: a population based case-control study. Br J Ind Med 49(2):95–103. 10.1136/oem.49.2.95.1536825
Evanoff BA, Gustavsson P, Hogstedt C. 1993. Mortality and incidence of cancer in a cohort of Swedish chimney sweeps: an extended follow up study. Br J Ind Med 50(5):450–459. 10.1136/oem.50.5.450.8507598
Fannick N, Gonshor LT, Shockley J. 1972. Exposure to coal tar pitch volatiles at coke ovens. Am Ind Hyg Assoc J 33(7):461–468. 10.1080/0002889728506687.4661167
FDA. 2023a. Food additives permitted for direct addition to food for human consumption. Subpart F - Flavoring agents and related substances. Synthetic flavoring substances and adjuvants. Food and Drug Administration. Code of Federal Regulations. 21 CFR 172.515. https://www.govinfo.gov/content/pkg/CFR-2023-title21-vol3/pdf/CFR-2023-title21-vol3-sec172-515.pdf. February 5, 2024.
FDA. 2023b. Drugs for human use. Subpart E - Requirements for specific new drugs or devices. Drug products containing certain active ingredients offered over-the-counter (OTC) for certain uses. Food and Drug Administration. Code of Federal Regulations. 21 CFR 310.545. https://www.govinfo.gov/content/pkg/CFR-2023-title21-vol5/pdf/CFR-2023-title21-vol5-sec310-545.pdf. February 5, 2024.
FDA. 2023c. Interpretative statements re warnings on drugs and devices for over-the-counter sale. Subpart B - Warning and caution statements for drugs. Drugs; recommended warning and caution statements. Food and Drug Administration. Code of Federal Regulations. 21 CFR 369.20. https://www.govinfo.gov/content/pkg/CFR-2023-title21-vol5/pdf/CFR-2023-title21-vol5-sec369-20.pdf. February 5, 2024.
FDA. 2023d. Miscellaneous external drug products for over-the-counter human use. Subpart H - Drug products for the control of dandruff, seborrheic dermatitis, and psoriasis. Active ingredients for the control of dandruff, seborrheic dermatitis, or psoriasis. Food and Drug Administration. Code of Federal Regulations. 21 CFR 358.710. https://www.govinfo.gov/content/pkg/CFR-2023-title21-vol5/pdf/CFR-2023-title21-vol5-sec358-710.pdf. February 5, 2024.
Fellows EJ. 1937. Studies on calcium creosotate: III. The elimination of volatile phenols in rabbit urine after the administration of “calcium creosotate solution” and after creosote solution. J Pharmacol Exp Ther 60:183–188.
Fellows EJ. 1939a. Studies on calcium creosotate. IV. Observations on its use in pulmonary tuberculosis. Am J Med Sci 197:683–690.
Fellows EJ. 1939b. Calcium creosotate: V. Nature of phenols eliminated in urine. Proc Society Exp Biol Med 42(1):103–107. 10.3181/00379727-42-10814.
Feng F, Yang Y, Li Z, . 2015. Changes in telomere length and telomerase activity in human bronchial epithelial cells induced by coal tar pitch extract. Toxicol Res 4(6):1535–1544. 10.1039/c5tx00121h.
Fielden MR, Wu ZF, Sinal CJ, . 2000. Estrogen receptor- and aryl hydrocarbon receptor-mediated activities of a coal-tar creosote. Environ Toxicol Chem 19(5):1262–1271. 10.1002/etc.5620190507.
Flyvbjerg J, Arvin E, Jensen BK, . 1993. Microbial degradation of phenols and aromatic hydrocarbons in creosote-contaminated groundwater under nitrate-reducing conditions. J Contam Hydrol 12:133–150. 10.1016/0169-7722(93)90018-N.
Franco F, Chellini E, Seniori Costantini A, . 1993. Mortality in the coke oven plant of Carrara, Italy. Med Lav 84(6):443–447.8177128
Franssen ME, van der Wilt GJ, de Jong PC, . 1999. A retrospective study of the teratogenicity of dermatological coal tar products. Acta Derm Venereol 79(5):390–391. 10.1080/000155599750010373.10494722
Friesen MC, Benke G, Del Monaco A, . 2009. Relationship between cardiopulmonary mortality and cancer risk and quantitative exposure to polycyclic aromatic hydrocarbons, fluorides, and dust in two prebake aluminum smelters. Cancer Causes Control 20(6):905–916. 10.1007/s10552-009-9329-8.19294522
Friesen MC, Demers PA, Spinelli JJ, . 2010. Chronic and acute effects of coal tar pitch exposure and cardiopulmonary mortality among aluminum smelter workers. Am J Epidemiol 172(7):790–799. 10.1093/aje/kwq208.20702507
Fritschi L, Sim MR, Forbes A, . 2003. Respiratory symptoms and lung-function changes with exposure to five substances in aluminium smelters. Int Arch Occup Environ Health 76(2):103–110. 10.1007/s00420-002-0398-1.12733082
FWS. 1987. Polycyclic aromatic hydrocarbon hazards to fish, wildlife, and invertebrates: A synoptic review. Laurel, MD: U.S. Fish and Wildlife Service. Biological Report 85. Contaminant Hazard Review Report No. 11. https://pubs.er.usgs.gov/publication/5200072. November 1, 2022.
Gallacher C, Thomas R, Lord R, . 2017a. Comprehensive database of manufactured gas plant tars. Part B. Aliphatic and aromatic compounds. Rapid Commun Mass Spectrom 31(15):1239–1249. 10.1002/rcm.7900.28494122
Gallacher C, Thomas R, Lord R, . 2017b. Comprehensive database of manufactured gas plant tars. Part C. Heterocyclic and hydroxylated polycyclic aromatic hydrocarbons. Rapid Commun Mass Spectrom 31(15):1250–1260. 10.1002/rcm.7904.28514513
Gallacher C, Thomas R, Lord R, . 2017c. Supplemental material: Comprehensive database of manufactured gas plant tars. Part C. Heterocyclic and hydroxylated polycyclic aromatic hydrocarbons. Rapid Commun Mass Spectrom 31(15) 10.1002/rcm.7904.
Gallego E, Roca FJ, Perales JF, . 2008. VOCs and PAHs emissions from creosote-treated wood in a field storage area. Sci Total Environ 402(1):130–138. 10.1016/j.scitotenv.2008.04.008.18501954
Gaylor DW, Culp SJ, Goldstein LS, . 2000. Cancer risk estimation for mixtures of coal tars and benzo(a)pyrene. Risk Analysis 20(1):81–85. 10.1111/0272-4332.00008.10795341
Geddie JE, Amin S, Huie K, . 1987. Formation and tumorigenicity of benzo[b]fluoranthene metabolites in mouse epidermis. Carcinogenesis 8(11):1579–1584. 10.1093/carcin/8.11.1579.3664950
Genevois C, Pfohl-Leszkowicz A, Boillot K, . 1998. Implication of cytochrome P-450 1A isoforms and the AH receptor in the genotoxicity of coal-tar fume condensate and bitumen fume condensates. Environ Toxicol Pharmacol 5(4):283–294. 10.1016/s1382-6689(98)00013-1.21781875
Gevao B, Jones KC. 1998. Kinetics and potential significance of polycyclic aromatic hydrocarbon desorption from creosote-treated wood. Environ Sci Technol 32:640–646. 10.1021/es9706413.
Gibbs GW. 1985. Mortality of aluminum reduction plant workers, 1950 through 1977. J Occup Med 27:761–770.4067680
Gibbs GW, Sevigny M. 2007a. Mortality and cancer experience of Quebec aluminum reduction plant workers. Part 3: monitoring the mortality of workers first employed after January 1, 1950. J Occup Environ Med 49(11):1269–1287. 10.1097/JOM.0b013e3181593da8.17993932
Gibbs GW, Sevigny M. 2007b. Mortality and cancer experience of Quebec aluminum reduction plant workers, part 4: cancer incidence. J Occup Environ Med 49(12):1351–1366. 10.1097/JOM.0b013e318156ecbc.18231082
Gibbs GW, Armstrong B, Sevigny M. 2007. Mortality and cancer experience of Quebec aluminum reduction plant workers. Part 2: mortality of three cohorts hired on or before January 1, 1951. J Occup Environ Med 49(10):1105–1123. 10.1097/JOM.0b013e318157d34a.18000416
Gibbs GW, Labrèche F, Busque M, . 2014. Mortality and cancer incidence in aluminum smelter workers: a 5-year update. J Occup Environ Med 56(7):739–764. 10.1097/jom.0000000000000175.24988102
Gile JD, Collins JC, Gillett JW. 1982. Fate and impact of wood preservatives in a terrestrial microcosm. J Agric Food Chem 30:295–301. 10.1021/jf00110a020.
Giri SK, Yadav A, Kumar A, . 2011. Association of GSTM1 and GSTT1 polymorphisms with DNA damage in coal-tar workers. Sci Total Environ 409(20):4465–4469. 10.1016/j.scitotenv.2011.07.009.21824642
Giri SK, Yadav A, Kumar A, . 2012. CYP1A1 gene polymorphisms: modulator of genetic damage in coal-tar workers. Asian Pac J Cancer Prev 13(7):3409–3416. 10.7314/apjcp.2012.13.7.3409.22994769
Godschalk RW, Ostertag JU, Moonen EJ, . 1998. Aromatic DNA adducts in human white blood cells and skin after dermal application of coal tar. Cancer Epidemiol Biomarkers Prev 7(9):767–773.9752984
Godschalk RW, Ostertag JU, Zandsteeg AM, . 2001. Impact of GSTM1 on aromatic-DNA adducts and p53 accumulation in human skin and lymphocytes. Pharmacogenetics 11(6):537–543. 10.1097/00008571-200108000-00008.11505223
Goerlitz DF, Troutman DE, Godsy EM, . 1985. Migration of wood-preserving chemicals in contaminated groundwater in a sand aquifer at Pensacola, Florida. Environ Sci Technol 19:955–961. 10.1021/es00140a012.
Goodfield M, Kownacki S, Berth-Jones J. 2004. Double-blind, randomised, multicentre, parallel group study comparing a 1% coal tar preparation (Exorex) with a 5% coal tar preparation (Alphosyl) in chronic plaque psoriasis. J Dermatolog Treat 15(1):14–22. 10.1080/09546630310017843.14754644
Gordon DW, Rosenthal G, Hart J, . 1995. Chaparral ingestion: The broadening spectrum of liver injury caused by herbal medications. JAMA 273(6):489–490. 10.1001/jama.1995.03520300063038.7837368
Grimmer G, Jacob J, Dettbarn G, . 1997. Determination of urinary metabolites of polycyclic aromatic hydrocarbons (PAH) for the risk assessment of PAH-exposed workers. Int Arch Occup Environ Health 69:231–239. 10.1007/s004200050141.9137996
Grosjean D. 1991. Atmospheric fate of toxic aromatic compounds. Sci Total Environ 100:367–414. 10.1016/0048-9697(91)90386-S.
Guillén MD, Iglesias MJ, Dominguez A, . 1992. Polynuclear aromatic hydrocarbon retention indices on SE-54 stationary phase of the volatile components of a coal tar pitch: Relationships between chromatographic retention and thermal reactivity. J Chromatogr 591:287–295. 10.1016/0021-9673(92)80246-Q.
Gunster DG, Bonnevie NL, Gillis CA, . 1993. Assessment of chemical loadings to Newark Bay, New Jersey from petroleum and hazardous chemical accidents occurring from 1986 to 1991. Ecotoxicol Environ Saf 25(2):202–213. 10.1006/eesa.1993.1019.7682504
Gustavsson P, Reuterwall C. 1990. Mortality and incidence of cancer among Swedish gas workers. Br J Ind Med 47(3):169–174. 10.1136/oem.47.3.169.2328224
Hackett PL, Rommereim DN, Sikov MR. 1984. Developmental toxicity following oral administration of a high-boiling coal liquid to pregnant rats. J Appl Toxicol 4(1):57–62. 10.1002/jat.2550040111.6715782
Haldin-Davis H. 1935. Multiple warts in a creosote worker. Proc R Soc Med 29(2):89–90. 10.1177/003591573502900204.19990537
Hanlon G. 1938. Creosote poisoning of cattle. Aust Vet J 14:73. 10.1111/j.1751-0813.1938.tb04186.x.
Hansen ES. 1983. Mortality from cancer and ischemic heart disease in Danish chimney sweeps: a five-year follow-up. Am J Epidemiol 117(2):160–164. 10.1093/oxfordjournals.aje.a113526.6829545
Hansen KS, Viskum S, Pedersen MS. 1986. [Mortality among gas workers]. Ugeskr Laeger 148(10):610–612. (Danish)3961944
Hansen AM, Poulsen OM, Menne T. 1993. Longitudinal study of excretion of metabolites of polycyclic aromatic hydrocarbons in urine from two psoriatic patients. Acta Derm Venereol 73(3):188–190. 10.2340/0001555573188190 8105615
Hard GC, Banton MI, Bretzlaff RS, . 2013. Consideration of rat chronic progressive nephropathy in regulatory evaluations for carcinogenicity. Toxicol Sci 132(2):268–275. 10.1093/toxsci/kfs305.23104430
Haverkos HW, Haverkos GP, O’Mara M. 2017. Co-carcinogenesis: Human papillomaviruses, coal tar derivatives, and squamous cell cervical cancer. Front Microbiol 8:2253. 10.3389/fmicb.2017.02253.29180993
Hawley GG. 1977. Coal tar. In: The condensed chemical dictionary. 9th ed. New York, NY: Van Nostrand Reinhold Company, 214.
Hecht SS, Grabowski W, Groth K. 1979. Analysis of feces for benzo[a]pyrene after consumption of charcoal-broiled beef by rats and humans. Food Cosmet Toxicol 17:223–227. 10.1016/0015-6264(79)90284-0.499948
Hecht SS, Carmella SG, Villalta PW, . 2010. Analysis of phenanthrene and benzo[a]pyrene tetraol enantiomers in human urine: relevance to the bay region diol epoxide hypothesis of benzo[a]pyrene carcinogenesis and to biomarker studies. Chem Res Toxicol 23(5):900–908. 10.1021/tx9004538.20369855
Heikkilä PR, Luotamo M, Riihimaki V. 1997. Urinary 1-naphthanol excretion in the assessment of exposure to creosote in an impregnation facility. Scand J Work Environ Health 23:199–205.9243730
Heikkilä P, Luotamo M, Pyy L, . 1995. Urinary 1-naphthol and 1-pyrenol as indicators of exposure to coal tar products. Int Arch Occup Environ Health 67:211–217. 10.1007/BF00626355.7591181
Heinrich U, Pott F, Roller M. 1994a. Estimation of a lifetime unit lung cancer risk for benzo(a)pyrene (BAP) based on tumor rates in rats exposed to coal tar/pitch condensation aerosol (CTP). Toxicol Lett 72:155–156. 10.1016/0378-4274(94)90023-X.8202928
Heinrich U, Dungworth DL, Pott F, . 1994b. The carcinogenic effects of carbon black particles and tar-pitch condensation aerosol after inhalation exposure of rats. Ann Occup Hyg 38:351–356. 10.1093/annhyg/38.inhaled_particles_VII.351.7978959
Henningsson B. 1983. Environmental protection and health risks in connection with the use of creosote. Holz Roh Werkst 41:471–475. 10.1007/BF02608108.
Henry SA. 1946. Coal tar distillers. In: Cancer of the scrotum in relation to occupation. London: Humphrey Milford Oxford University Press, 16–19.
Henry SA. 1947. Occupational cutaneous cancer attributable to certain chemicals in industry. Br Med Bull 4:389–401. 10.1093/oxfordjournals.bmb.a072833.
Heron S, Yarnell E. 2001. The safety of low-dose Larrea tridentata (DC) Coville (creosote bush or chaparral): a retrospective clinical study. J Altern Complement Med 7(2):175–185. 10.1089/107555301750164262.11327523
Heussner JC, Ward JB, Legator MS. 1985. Genetic monitoring of aluminum workers exposed to coal tar pitch volatiles. Mutat Res 155(3):143–155. 10.1016/0165-1218(85)90133-8.3974629
Hickok EA, Erdmann JB, Simonett MJ, . 1982. Groundwater contamination with creosote wastes. In: Johnson WK, Martenson DR, eds. National conference on environmental engineering. Minneapolis, MN: American Society of Civil Engineers, 430–437.
Hiemstra TF, Bellamy CO, Hughes JH. 2007. Coal tar creosote abuse by vapour inhalation presenting with renal impairment and neurotoxicity: a case report. J Med Case Rep 1:102. 10.1186/1752-1947-1-102.17892538
Hopkins RP, Brooks CJ, Young L. 1962. Biochemical studies of toxic agents. 13. The metabolism of acenaphthylene. Biochem J 82:457–466. 10.1042/bj0820457.14448806
Howarth RW, Ingraffea A, Engelder T. 2011. Natural gas: Should fracking stop? Nature 477(7364):271–275. 10.1038/477271a.21921896
Hueper WC, Payne WW. 1960. Carcinogenic studies on petroleum asphalt, cooling oil, and coal tar. Arch Pathol 70:372–384.14403794
Hughes NC, Pfau W, Hewer A, . 1993. Covalent binding of polycyclic aromatic hydrocarbon components of coal tar to DNA in mouse skin. Carcinogenesis 14(1):135–144. 10.1093/carcin/14.1.135.8425262
Huntley SL, Bonnevie NL, Wenning RJ, . 1993. Distribution of polycyclic aromatic hydrocarbons (PAHs) in three northern New Jersey waterways. Bull Environ Contam Toxicol 51(6):865–872. 10.1007/BF00198283.8257814
Hussar E, Richards S, Lin ZQ, . 2012. Human health risk assessment of 16 priority polycyclic aromatic hydrocarbons in soils of Chattanooga, Tennessee, USA. Water Air Soil Pollut 223(9):5535–5548. 10.1007/s11270-012-1265-7.23243323
Hyötyläinen T, Oikari A. 1999. Assessment of toxicity hazards of dredged lake sediment contaminated by creosote. Sci Total Environ 243–244:97–105. 10.1016/s0048-9697(99)00364-2.
IARC. 1973. Historical review of cancer in workers exposed to polycyclic aromatic hydrocarbons and heterocyclic compounds and their role in other environmental situations. International Agency for Research on Cancer. IARC Monogr Eval Carcinog Risk Chem Hum 3:22–42. https://publications.iarc.fr/21. January 9, 2023.
IARC. 1985. Coal-tars and derived products. International Agency for Research on Cancer. IARC Monogr Eval Carcinog Risk Chem Hum 35:83–161. https://monographs.iarc.who.int/wp-content/uploads/2018/06/mono35.pdf. November 3, 2022.3860475
IARC. 1987. Creosotes. In: IARC Monographs on the evaluation of carcinogenic risk to humans. Supplement 7: Overall evaluation of carcinogenicity: An updating of IARC Monographs Volume 1 to 42. International Agency for Research on Cancer, 177–178. https://monographs.iarc.who.int/wp-content/uploads/2018/06/Suppl7.pdf. November 3, 2022.
IARC. 1997. Silica, some silicates, coal dust and para-aramid fibrils. In: IARC Monographs on the Evaluation of the Carcinogenic Risks of Chemicals to Humans. Vol. 68. Lyon, France: International Agency for Research on Cancer, 337–408. https://publications.iarc.fr/86. April 2, 2024.
IARC. 2010. Some non-heterocyclic polycyclic aromatic hydrocarbons and some related exposures. IARC Monographs on the evaluation of carcinogenic risk to humans. Vol. 92. Lyon, France: International Agency for Research on Cancer. https://publications.iarc.fr/110. October 17, 2022.
IARC. 2012a. Occupational exposures during coal-tar distillation. International Agency for Research on Cancer. IARC Monogr Eval Carcinog Risk Chem Hum 100F:153–160. https://publications.iarc.fr/123. October 17, 2022.
IARC. 2012b. Coal-tar pitch. International Agency for Research on Cancer. IARC Monogr Eval Carcinog Risk Chem Hum 100F:161–166. https://publications.iarc.fr/123. October 18, 2022.
Ingram LL, McGinnis GD, Gjovik LR, . 1982. Migration of creosote and its components from treated piling sections in a marine environment. Proc Am Wood Preserv Assoc 78:120–128.
IPCS. 2004. Coal tar creosote. Concise international chemical assessment document 62. Geneva, Switzerland: International Programme on Chemical Safety. https://apps.who.int/iris/bitstream/handle/10665/42943/9241530626.pdf. October 11, 2022.
IRIS. 1988. Creosote; CASRN 8001-58-9. Integrated Risk Information System: Chemical assessment summary. Washington, DC: U.S. Environmental Protection Agency. https://iris.epa.gov/static/pdfs/0360_summary.pdf. October 17, 2022.
IRIS. 1989. Coke oven emissions; CASRN NA. Integrated Risk Information System: Chemical assessment summary. Washington, DC: U.S. Environmental Protection Agency. https://iris.epa.gov/static/pdfs/0395_summary.pdf. October 17, 2022.
Iyer PR, Irvin TR, Martin JE. 1993. Developmental effects of petroleum creosote on mice following oral exposure. Res Commun Chem Pathol Pharmacol 82(3):371–374.8122038
Jenkins WD, Christian WJ, Mueller G, Robbins KT. 2013. Population cancer risks associated with coal mining: a systematic review. PLoS One 8(8):e71312. 10.1371/journal.pone.0071312.23977014
Johnston N, Sadler R, Shaw GR, . 1993. Environmental modification of PAH composition in coal tar containing samples. Chemosphere 27(7):1151–1158. 10.1016/0045-6535(93)90163-y.
Jonas AD. 1943. Creosote burns. J Ind Hyg Toxicol 25:418–420.
Jongeneelen FJ. 1992. Biological exposure limit for occupational exposure to coal tar pitch volatiles at cokeovens. Int Arch Occup Environ Health 63(8):511–516. 10.1007/BF00386338.1587624
Jongeneelen FJ, Anzion RB, Leijdekkers CM. 1988. 1-Hydroxypyrene in human urine as a biological indicator of exposure to polycyclic aromatic hydrocarbons in several work environments. Ann Occup Hyg 32:34–43. 10.1093/annhyg/32.1.35.
Jongeneelen FJ, Anzion RB, Leijdekkers CM, . 1985. 1-Hydroxypyrene in human urine after exposure to coal tar and a coal tar derived product. Int Arch Occup Environ Health 57(1):47–55. 10.1007/BF00383545.4077281
Jongeneelen FJ, Bos RP, Anzion RB, . 1986. Biological monitoring of polycyclic aromatic hydrocarbons. Metabolites in urine. Scand J Work Environ Health 12(2):137–143. 10.5271/sjweh.2166.3726495
Jonsson G, Bechmann RK, Bamber SD, . 2004. Bioconcentration, biotransformation, and elimination of polycyclic aromatic hydrocarbons in sheepshead minnows (Cyprinodon variegatus) exposed to contaminated seawater. Environ Toxicol Chem 23(6):1538–1548. 10.1897/03-173.15376540
Kang SM, Morrell JJ, Simonsen J, . 2005. Creosote movement from treated wood immersed in fresh water. For Prod J 25(12):42–46.
Karlehagen S, Andersen A, Ohlson CG. 1992. Cancer incidence among creosote-exposed workers. Scand J Work Environ Health 18(1):26–29. 10.5271/sjweh.1612.1553509
Katz M, Saibil F. 1990. Herbal hepatitis: subacute hepatic necrosis secondary to chaparral leaf. J Clin Gastroenterol 12(2):203–206. 10.1097/00004836-199004000-00021.2324485
Kawai M, Amamoto H, Harada K. 1967. Epidemiologic study of occupational lung cancer. Arch Environ Health 14(6):859–864. 10.1080/00039896.1967.10664852.6027173
Kerr MA, Nasca PC, Mundt KA, . 2000. Parental occupational exposures and risk of neuroblastoma: a case-control study (United States). Cancer Causes Control 11(7):635–643. 10.1023/a:1008951632482.10977108
King MWG, Barker JF. 1999. Migration and natural fate of a coal tar creosote plume. 1. Overview and plume development. J Contam Hydrol 39:249–279. 10.1016/S0169-7722(99)00039-X.
King MWG, Barker JF, Devlin JF, . 1999. Migration and natural fate of a coal tar creosote plume. 2. Mass balance and biodegradation indicators. J Contam Hydrol 39:281–307. 10.1016/S0169-7722(99)00048-0.
Kligman AM, Kligman LH. 1994. Carcinogens show comedogenic activity: A potential animal screen for tumorigenic substances. Cancer Lett 87(2):171–178. 10.1016/0304-3835(94)90219-4.7812937
Klingner TD, McCorkle T. 1994. The application and significance of wipe samples. Am Ind Hyg Assoc J 55(3):251–254. 10.1080/15428119491019104.
Koganti A, Singh R, Rozett K, . 2000. 7H-benzo[c]fluorene: a major DNA adduct-forming component of coal tar. Carcinogenesis 21(8):1601–1609. 10.1093/carcin/21.8.1601.10910965
Koganti A, Singh R, Ma BL, . 2001. Comparative analysis of PAH:DNA adducts formed in lung of mice exposed to neat coal tar and soils contaminated with coal tar. Environ Sci Technol 35(13):2704–2709. 10.1021/es001532i.11452595
Koppers Company. 1979. Cross-sectional health study of workers of four forest products plants of Koppers Company Inc. Volume A. Koppers Company Incorporated. Submitted to the U.S. Environmental Protection Agency under TSCA Section FYI. FYIOTS02850385.
Koppers Company. 1981. 1979 Cross-sectional health study of workers at nine Koppers coal tar plants combined report. Tabershaw Occupational Medicine Associates. Koppers Company, Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8. OTS0206278. 878210574. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0206278.xhtml. January 9, 2023.
Kozicki M, Nieslochowski A. 2020. Materials contamination and indoor air pollution caused by tar products and fungicidal impregnations: Intervention research in 2014-2019. Sensors (Basel) 20(15):4099. 10.3390/s20154099.32717863
Kuehl DW, Ankley GT, Burkhard LP, . 1990. Bioassay directed characterization of the acute aquatic toxicity of a creosote leachate. Hazard Waste Hazard Mater 7(3):283–291. 10.1089/hwm.1990.7.283.
Kuge T, Shibata T, Willett MS. 2003a. Wood creosote, the principal active ingredient of Seirogan, an herbal antidiarrheal medicine: a single-dose, dose-escalation safety and pharmacokinetic study. Pharmacotherapy 23(11):1391–1400. 10.1592/phco.23.14.1391.31940.14620385
Kuge T, Shibata T, Willett MS. 2003b. Multiple-dose escalation, safety, and tolerability study of wood creosote, the principal active ingredient of Seirogan, an herbal antidiarrheal medication, in healthy subjects. J Clin Pharmacol 43(3):284–290. 10.1177/0091270002250606.12638397
Kuge T, Shibata T, Willett MS. 2004. Multicenter, double-blind, randomized comparison of wood creosote, the principal active ingredient of Seirogan, an herbal antidiarrheal medication, and loperamide in adults with acute nonspecific diarrhea. Clin Ther 26(10):1644–1651. 10.1016/j.clinthera.2004.10.001.15598481
Kuge T, Shibata T, Willett MS, . 2001. Lack of oncogenicity of wood creosote, the principal active ingredient of Seirogan, an herbal antidiarrheal medication, in Sprague-Dawley rats. Int J Toxicol 20(5):297–305. 10.1080/109158101753253036.11766127
Kumar R, Kaur M, Kumari M. 2012. Acridine: a versatile heterocyclic nucleus. Acta Pol Pharm 69(1):3–9.22574501
Kumar A, Yadav A, Giri SK, . 2011. Effect of genetic polymorphism of GSTM1 and GSTT1 genotypes on cytogenetic biomarkers among coaltar workers. Environ Toxicol Pharmacol 32(2):128–135. 10.1016/j.etap.2011.04.002.21843791
Lavoué J, Gérin M, Côté J, . 2007. Mortality and cancer experience of Quebec aluminum reduction plant workers. Part 1: The reduction plants and coal tar pitch volatile (CTPV) exposure assessment. J Occup Environ Med 49(9):997–1008. 10.1097/JOM.0b013e3181484cf3.17848856
Lee LS, Suresh P, Rao C, . 1992. Equilibrium partitioning of polycyclic aromatic hydrocarbons from coal tar into water. Environ Sci Technol 26:2110–2115. 10.1021/es00035a006.
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77. 10.1016/s0031-3955(05)70463-6.9057784
Lenson N. 1956. Multiple cutaneous carcinoma after creosote exposure. N Engl J Med 254:520–522. 10.1056/NEJM195603152541106.13297146
Leonforte JF. 1986. Contact dermatitis from Larrea (creosote bush). J Am Acad Dermatol 14(2 Pt 1):202–207. 10.1016/s0190-9622(86)70022-4.3950120
Letzel S, Drexler H. 1998. Occupationally related tumors in tar refinery workers. J Am Acad Dermatol 39(5):712–720. 10.1016/s0190-9622(98)70043-x.9810887
Lewtas J, Walsh D, Williams R, . 1997. Air pollution exposure-DNA adduct dosimetry in humans and rodents: evidence for non-linearity at high doses. Mutat Res 378:51–63. 10.1016/S0027-5107(97)00097-3.9288885
Li XY, Astrom A, Duell EA, . 1995. Retinoic acid antagonizes basal as well as coal tar and glucocorticoid-induced cytochrome P4501A1 expression in human skin. Carcinogenesis 16(3):519–524. 10.1093/carcin/16.3.519.7697808
Li Z, Wang W, Meng L, . 2020. Identification and analysis of key lncRNAs in malignant-transformed BEAS-2B cells induced with coal tar pitch by microarray analysis. Environ Toxicol Pharmacol 79:103376. 10.1016/j.etap.2020.103376.32470693
Lijinsky W, Saffiotti U, Shubik P. 1957. A study of the chemical constitution and carcinogenic action of creosote oil. J Natl Cancer Inst 18(5):687–692. 10.1093/jnci/18.5.687.13502688
Liu N, Wang Z, Dong D, . 1997. Cancer mortality among carbon workers in China: retrospective cohort study. J Occup Health 29:325–330. 10.1539/joh.39.325.
Lloyd JW. 1971. Long-term mortality study of steelworkers. V. Respiratory cancer in coke plant workers. J Occup Med 13(2):53–68.5546197
Lloyd JW, Lundin FE, Redmond CK, . 1970. Long-term mortality study of steelworkers. IV. Mortality by work area. J Occup Med 12(5):151–157.5423391
Luukkanen L, Elovaara E, Lautala P, . 1997. Characterization of 1-hydroxypyrene as a novel marker substrate of 3-methylcholanthrene-inducible phenol UDP-glucuronosyltransferase(s). Pharmacol Toxicol 80:152–158. 10.1111/j.1600-0773.1997.tb00389.x.9101589
MacEwen JD, Hall A, Scheel LD. 1977. Experimental oncogenesis in rats and mice exposed to coal tar aerosols. In: Proceedings of the annual conference on environmental toxicology. Wright-Patterson AFB, OH: Aerospace Medical Research Lab, 66–81.
Madhavan ND, Naidu KA. 1995. Polycyclic aromatic hydrocarbons in placenta, maternal blood, umbilical cord blood and milk of Indian women. Hum Exp Toxicol 14(6):503–506. 10.1177/096032719501400607.8519527
Madsen EL, Mann CL, Bilotta SE. 1996. Oxygen limitations and aging as explanations for the field persistence of naphthalene in coal tar-contaminated surface sediments. Environ Toxicol Chem 15(11):1876–1882. 10.1002/etc.5620151104.
Madsen EL, Bilotta-Best S, Sandoli RL, . 1993. Final electron acceptor limitations and sorption may explain the persistence of polycyclic aromatic hydrocarbons in coal-tar contaminated surface sediments [abstract]. Abstracts of the General Meeting of the American Society for Microbiology 93:407.
Mahler BJ, Metre PC, Wilson JT, . 2010. Coal-tar-based parking lot sealcoat: an unrecognized source of PAH to settled house dust. Environ Sci Technol 44(3):894–900. 10.1021/es902533r.20063893
Mahler BJ, Metre PC, Crane JL, . 2012. Coal-tar-based pavement sealcoat and PAHs: implications for the environment, human health, and stormwater management. Environ Sci Technol 46(6):3039–3045. 10.1021/es203699x.22296333
Mahlum DD. 1983. Initiation/promotion studies with coal-derived liquids. J Appl Toxicol 3(1):31–34. 10.1002/jat.2550030107.6308082
Malkin R, Kiefer M, Tolos W. 1996. 1-Hydroxypyrene levels in coal-handling workers at a coke oven. J Occup Environ Med 38(11):1141–1144. 10.1097/00043764-199611000-00014.8941904
Marston CP, Pereira C, Ferguson J, . 2001. Effect of a complex environmental mixture from coal tar containing polycyclic aromatic hydrocarbons (PAH) on the tumor initiation, PAH-DNA binding and metabolic activation of carcinogenic PAH in mouse epidermis. Carcinogenesis 22(7):1077–1086. 10.1093/carcin/22.7.1077.11408352
Martin JC, Imbernon E, Goldberg M, . 2000. Occupational risk factors for lung cancer in the French electricity and gas industry: a case-control survey nested in a cohort of active employees. Am J Epidemiol 151(9):902–912. 10.1093/oxfordjournals.aje.a010294.10791563
Mastrangelo G, Veller Fornasa C, Pavanello S, . 2003. Polyaromatic hydrocarbons administered in humans by dermal route increase total IgE. Int J Immunopathol Pharmacol 16(2):145–150. 10.1177/039463200301600208.12797905
Mayura K, Huebner HJ, Dwyer MR, . 1999. Multi-bioassay approach for assessing the potency of complex mixtures of polycyclic aromatic hydrocarbons. Chemosphere 38(8):1721–1732. 10.1016/S0045-6535(98)00389-0.10101844
Mazumdar S, Redmond C, Sollecito W, . 1975. An epidemiological study of exposure to coal tar pitch volatiles among coke oven workers. J Air Pollut Control Assoc 25(4):382–289. 10.1080/00022470.1975.10470095.
McClean MD, Rinehart RD, Sapkota A, . 2007. Dermal exposure and urinary 1-hydroxypyrene among asphalt roofing workers. J Occup Environ Med 4(Suppl 1):118–126. 10.1080/15459620701334756.
McCormick S, Snawder JE, Chen IC, . 2022. Exposure assessment of polycyclic aromatic hydrocarbons in refined coal tar sealant applications. Int J Hyg Environ Health 242:113971. 10.1016/j.ijheh.2022.113971.35472749
McKinlay R. 1933. The creosote treatment of lobar pneumonia. J Royal Army Med Corps 61:54–55. 10.1136/jramc-61-01-07.
Meylan WM, Howard PH. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26(12):2293–2299. 10.1016/0045-6535(93)90355-9.
Milham S. 1979. Mortality in aluminum reduction plant workers. J Occup Med 21(7):475–480.469612
Miyazato T, Matsumoto M, Uenishi C, . 1981. [Studies on the toxicity of beechwood creosote. 1. Acute and subacute toxicity in mice and rats]. Oyo Yakuri 21:899–919. (Japanese)
Miyazato T, Suzuki A, Nohno M, . 1984a. [Studies on the toxicity of beechwood creosote. 2. Chronic toxicity and carcinogenicity in mice]. Oyo Yakuri 28:909–924. (Japanese)
Miyazato T, Suzuki A, Uenishi C, . 1984b. [Studies on the toxicity of beechwood creosote. 3. Chronic toxicity and carcinogenicity in rats]. Oyo Yakuri 28:925–947. (Japanese)
Modica R, Fiume M, Guaitani A, . 1983. Comparative kinetics of benz(a)anthracene, chrysene and triphenylene in rats after oral administration. I. Study with single compounds. Toxicol Lett 18(1–2):103–109. 10.1016/0378-4274(83)90078-4.6623531
Mohammed SA, Sorensen DL, Sims RC, . 1998. Pentachlorophenol and phenanthrene biodegradation in creosote contaminated aquifer material. Chemosphere 37(1):103–111. 10.1016/s0045-6535(98)00026-5.9637006
Moret S, Purcaro G, Conte LS. 2007. Polycyclic aromatic hydrocarbon (PAH) content of soil and olives collected in areas contaminated with creosote released from old railway ties. Sci Total Environ 386(1–3):1–8. 10.1016/j.scitotenv.2007.07.008.17689591
Morgan B, Hansgen R, Hawthorne W, . 2015. Industrial odor sources and air pollutant concentrations in Globeville, a Denver, Colorado neighborhood. J Air Waste Manag Assoc 65(9):1127–1140. 10.1080/10962247.2015.1064833.26110447
Moulin JJ, Mur JM, Wild P, . 1988. [Epidemiologic study of the mortality among the employees of a coal tar distillery]. Rev Epidemiol Sante Publique 36(2):99–107. (French)3413326
Moulin JJ, Clavel T, Buclez B, . 2000. A mortality study among workers in a French aluminium reduction plant. Int Arch Occup Environ Health 73(5):323–330. 10.1007/s004200000124.10963416
Mueller JG, Chapman PJ, Pritchard PH. 1989. Creosote-contaminated sites: Their potential for bioremediation. Environ Sci Technol 23(10):1197–1201. 10.1080/15298669391354685.
Mueller JG, Middaugh DP, Lantz SE, . 1991. Biodegradation of creosote and pentachlorophenol in contaminated groundwater: chemical and biological assessment. Appl Environ Microbiol 57(5):1277–1285. 10.1128/AEM.57.5.1277-1285.1991.1854192
Mumtaz MM, Ray M, Crowell SR, . 2012a. Translational research to develop a human PBPK models tool kit-volatile organic compounds (VOCs). J Toxicol Environ Health A 75(1):6–24. 10.1080/15287394.2012.625546.22047160
Mumtaz M, Fisher J, Blount B, . 2012b. Application of physiologically based pharmacokinetic models in chemical risk assessment. J Toxicol 2012:904603. 10.1155/2012/904603.22523493
Mur JM, Moulin JJ, Meyer-Bisch C, . 1987. Mortality of aluminium reduction plant workers in France. Int J Epidemiol 16(2):257–264. 10.1093/ije/16.2.257.3610453
NAS/NRC. 2006. Human biomonitoring for environmental chemicals. Washington, DC: The National Academies Press, National Research Council. 10.17226/11700.
NC DHHS. 2020. Holcomb Creosote Company NPL site. Yadkinville, Yadkin County, North Carolina. Public health assessment (final release). Raleigh, NC: North Carolina Department of Health and Human Services. https://www.atsdr.cdc.gov/HAC/pha/HolcombCreosoteCompany/Holcomb_Creosote_Co_PHA-508.pdf. September 26, 2022.
NCI. 2018. Coal tar and coal-tar pitch. National Cancer Institute. https://www.cancer.gov/about-cancer/causes-prevention/risk/substances/coal-tar. October 11, 2022.
Niemeier RW, Thayer PS, Menzies KT, . 1988. A comparison of skin carcinogenicity of condensed roofing asphalt and coal tar pitch fumes. In: Polynuclear aromatic hydrocarbons: A decade of progress. Columbus: Battelle Press, 609–647.
NIOSH. 1977. Criteria for recommended standard. Occupational exposure to coal-tar products. Cincinnati, OH: National Institute for Occupational Safety and Health. NIOSH-78-107. https://www.cdc.gov/niosh/docs/78-107/default.html. November 3, 2022.
NIOSH. 1980a. Health hazard evaluation determination report No. HE-79-43-663, Harbison-Walker refractories, Clearfield, Pennsylvania. Cincinnati, OH: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/hhe/reports/pdfs/79-43-663.pdf?id=10.26616/NIOSHHHE7943663. November 3, 2022.
NIOSH. 1980b. Industrial hygiene report comprehensive survey of wood preservative treatment facility at Santa Fe Centralized Tie Plant, Somerville, Texas. Cincinnati, OH: National Institute for Occupational Safety and Health. PB83133892. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB83133892.xhtml. November 3, 2022.
NIOSH. 1981. Health hazard evaluation report: New York Port Authority, Brooklyn, New York. Cincinnati, OH: National Institute for Occupational Safety and Health. HHE 80-238-931. https://www.cdc.gov/niosh/hhe/reports/pdfs/80-238-931.pdf?id=10.26616/NIOSHHHE80238931. November 3, 2022.
NIOSH. 1982. Health hazard evaluation report. Mid-South Terminals Memphis, Tennessee. Cincinnati, OH: National Institute for Occupational Safety and Health. HETA No. 80-206-1164. https://www.cdc.gov/niosh/hhe/reports/pdfs/80-206-1164.pdf. November 3, 2022.
NIOSH. 1983. Health hazard evaluation report. Chemical Leaman Tank Lines, Inc., Stockertown, Pennsylvania. Cincinnati, OH: National Institute for Occupational Safety and Health. PB84149178. https://www.cdc.gov/niosh/hhe/reports/pdfs/82-324-1279.pdf. November 3, 2022.
NIOSH. 1994. Coal tar pitch volatiles. Immediately dangerous to life or health concentrations (IDLH). National Institute of Occupational Safety and Health. https://www.cdc.gov/niosh/idlh/65996932.html. August 8, 2023.
NIOSH. 2018. Coal tar pitch volatiles. Appendix C, Supplementary exposure limits. NIOSH pocket guide to chemical hazards. National Institute of Occupational Safety and Health. https://www.cdc.gov/niosh/npg/nengapdxc.html. February 5, 2024.
Niqui-Arroyo JL, Ortega-Calvo JJ. 2007. Integrating biodegradation and electroosmosis for the enhanced removal of polycyclic aromatic hydrocarbons from creosote-polluted soils. J Environ Qual 36(5):1444–1451. 10.2134/jeq2006.0516.17766823
NLM. 2022a. PubChem: Coal tar creosote (8001-58-9). National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/substance/363903955. September 23, 2022.
NLM. 2022b. PubChem: Coal tar (8007-45-2). National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/substance/363906580. September 23, 2022.
NLM. 2023. PubChem: Naphthalene (91-20-3). National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/Naphthalene. June 29, 2023.
NPIRS. 2022. Creosote products. National Pesticide Information Retrieval System. Purdue University. http://npirspublic.ceris.purdue.edu/ppis/default.aspx. January 4, 2023.
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments - February 2013. National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/hat/review/index-2.html. November 17, 2022.
NTP. 2015. OHAT risk of bias rating tool for human and animal studies. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/pubs/riskofbiastool_508.pdf. March 19, 2019.
NTP. 2021. Coal tars and coal-tar pitches. Report on carcinogens. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/coaltars.pdf. October 16, 2022.
Ny ET, Heederik D, Kromhout H, . 1993. The relationship between polycyclic aromatic hydrocarbons in air and in urine of workers in a Soderberg potroom. Am Ind Hyg Assoc J 54(6):277–284. 10.1080/15298669391354685.8328359
O’Donovan WJ. 1920. Epitheliomatous ulceration among tar workers. Br J Dermatol 32(8–9):245–252. 10.1111/j.1365-2133.1920.tb08987.x.
Ogata N, Baba T. 1989. Analysis of beechwood creosote by gas chromatography-mass spectrometry and high-performance liquid chromatography. Res Commun Chem Pathol Pharmacol 66(3):411–423.2609018
Ogata N, Baba T, Shibata T. 1993. Demonstration of antidiarrheal and antimotility effects of wood creosote. Pharmacology 46(3):173–180. 10.1159/000139043.8441764
Ogata N, Matsushima N, Shibata T. 1995. Pharmacokinetics of wood creosote: Glucuronic acid and sulfate conjugation of phenolic compounds. Pharmacology 51:195–204. 10.1159/000139335.7501706
Olsson A, Kromhout H, Agostini M, . 2010. A case-control study of lung cancer nested in a cohort of European asphalt workers. Environ Health Perspect 118(10):1418–1424. 10.1289/ehp.0901800.20529766
O’Reilly K, Pietari J, Boehm P. 2011. Comment on “PAHs underfoot: contaminated dust from coal-tar sealcoated pavement is widespread in the U.S.”. Environ Sci Technol 45(7):3185–3186. 10.1021/es200240g.21395218
OSHA. 2021a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol6/pdf/CFR-2021-title29-vol6-sec1910-1000.pdf. August 28, 2022.
OSHA. 2021b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol7/pdf/CFR-2021-title29-vol7-sec1915-1000.pdf. August 28, 2022.
OSHA. 2021c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol8/pdf/CFR-2021-title29-vol8-sec1926-55.pdf. August 28, 2022.
Osol A. 1980. Creosote. In: Remington’s pharmaceutical sciences. 16th ed. Easton, PA: Mack Publishing Co, 378.
Paleologo M, van Schooten FJ, Pavanello S, . 1992. Detection of benzo[a]pyrene-diol-epoxide-DNA adducts in white blood cells of psoriatic patients treated with coal tar. Mutat Res 281:11–16. 10.1016/0165-7992(92)90030-L.1371585
Pavanello S, Levis AG. 1992. Coal tar therapy does not influence in vitro benzo[a]pyrene metabolism and DNA adduct formation in peripheral blood lymphocytes of psoriatic patients. Carcinogenesis 13(9):1569–1573. 10.1093/carcin/13.9.1569.1394841
Pavanello S, Levis AG. 1994. Human peripheral blood lymphocytes as a cell model to evaluate the genotoxic effect of coal tar treatment. Environ Health Perspect 102(Suppl 9):95–99. 10.1289/ehp.94102s995.
Pereira WE, Rostad CE. 1986. Investigations of organic contaminants derived from wood-treatment processes in a sand and gravel aquifer near Pensacola, Florida. In: Selected papers in the hydrologic sciences 1986. Washington, DC: U.S. Geological Survey, 65–80. https://pubs.usgs.gov/wsp/wsp2290/pdf/wsp_2290.pdf. January 11, 2023.
Pereira WE, Rostad CE, Garbarino JR, . 1983. Groundwater contamination by organic bases derived from coal-tar wastes. Environ Toxicol Chem 2:283–294. 10.1002/etc.5620020304.
Persoons R, Roseau L, Petit P, . 2020. Towards a recommended biomonitoring strategy for assessing the occupational exposure of roofers to PAHs. Toxicol Lett 324:54–64. 10.1016/j.toxlet.2020.01.025.32007588
Persson B, Dahlander AM, Fredriksson M, . 1989. Malignant lymphomas and occupational exposures. Br J Ind Med 46(8):516–520. 10.1136/oem.46.8.516.2775671
Petridou-Fischer J, Whaley SL, Dahl AR. 1988. In vivo metabolism of nasally instilled benzo[a]pyrene in dogs and monkeys. Toxicology 48(1):31–40. 10.1016/0300-483x(88)90056-x.3336881
Petsonk EL, Storey E, Becker PE, . 1988. Pneumoconiosis in carbon electrode workers. J Occup Med 30(11):887–891. 10.1097/00043764-198811000-00017.3230438
Phillips DH, Alldrick AJ. 1994. Tumorigenicity of a combination of psoriasis therapies. Br J Cancers 69:1043–1045. 10.1038/bjc.1994.205.
Piñeiro R, Jimenez-Relinque E, Nevshupa R, . 2021. Primary and secondary emissions of VOCs and PAHs in indoor air from a waterproof coal-tar membrane: Diagnosis and remediation. Int J Environ Res Public Health 18(23):12855. 10.3390/ijerph182312855.34886578
Poel WE, Kammer AG. 1957. Experimental carcinogenicity of coal tar fractions: the carcinogenicity of creosote oils. J Natl Cancer Inst 18:41–55. 10.1093/jnci/18.1.41.13398814
Povey AC, Brouet I, Bartsch H, . 1987. Binding of benzo[a]pyrene metabolites in the rat intestinal lumen by magnetic polyethyleneimine microcapsules following an intragastric dose of [14C]benzo[a]pyrene. Carcinogenesis 8(6):825–831. 10.1093/carcin/8.6.825.3608080
Poynter JN, Richardson M, Roesler M, . 2017. Chemical exposures and risk of acute myeloid leukemia and myelodysplastic syndromes in a population-based study. Int J Cancer 140(1):23–33. 10.1002/ijc.30420.27603749
Preuss R, Drexler H, Böttcher M, . 2005. Current external and internal exposure to naphthalene of workers occupationally exposed to polycyclic aromatic hydrocarbons in different industries. Int Arch Occup Environ Health 78(5):355–362. 10.1007/s00420-004-0593-3.15864631
Pukkala E. 1995. Selected occupational categories. In: Cancer risk by social class and occupation: A survey of 109,000 cancer cases among Finns of working age. New York, NY: Karger, 50–57.
Quynh AN, Sharma N, Cho KK, . 2014. Efficacious rat model displays non-toxic effect with Korean beechwood creosote: a possible antibiotic substitute. Biotechnol Biotechnol Equip 28(3):447–454. 10.1080/13102818.2014.931696.26019530
Rahman A, Barrowman JA, Rahimtula A. 1986. The influence of bile on the bioavailability of polynuclear aromatic hydrocarbons from the rat intestine. Can J Physiol Pharmacol 64(9):1214–1218. 10.1139/y86-205.3096546
Ramesh A, Kumar A, Aramandla MP, . 2015. Polycyclic aromatic hydrocarbon residues in serum samples of autopsied individuals from Tennessee. Int J Environ Res Public Health 12(1):322–334. 10.3390/ijerph120100322.
Raulf-Heimsoth M, Angerer J, Pesch B, . 2008. Biological monitoring as a useful tool for the detection of a coal-tar contamination in bitumen-exposed workers. J Toxicol Environ Health A 71(11–12):746–750. 10.1080/15287390801985315.18569572
Redmond CK, Strobino BR, Cypess RH. 1976. Cancer experience among coke by-product workers. Ann NY Acad Sci 271:102–115. 10.1111/j.1749-6632.1976.tb23099.x 1069492
Redmond CK, Ciocco A, Lloyd JW, . 1972. Long-term mortality study of steelworkers. VI. Mortality from malignant neoplasms among coke oven workers. J Occup Med 14(8):621–629.4673324
Rees ED, Mandelstam P, Lowry JQ, . 1971. A study of the mechanism of intestinal absorption of benzo(a)pyrene. Biochim Biophys Acta 225(1):96–107. 10.1016/0005-2736(71)90288-4.5543579
RePORTER. 2024. Creosote. Research Portfolio Online Reporting Tools. National Institutes of Health. https://reporter.nih.gov/. February 1, 2024.
Rice JE, Hosted TJ, DeFloria MC, . 1986. Tumor-initiating activity of major in vivo metabolites of indeno[1,2,3-cd]pyrene on mouse skin. Carcinogenesis 7(10):1761–1764. 10.1093/carcin/7.10.1761.3757177
Rockette HE, Arena VC. 1983. Mortality studies of aluminum reduction plant workers: potroom and carbon department. J Occup Med 25(7):549–557.6886861
Roe FJC, Bosch D, Boutwell RK. 1958. The carcinogenicity of creosote oil: The induction of lung tumors in mice. Cancer Res 18:1176–1178.13596960
Roelofzen JH, Aben KK, Oldenhof UT, . 2010. No increased risk of cancer after coal tar treatment in patients with psoriasis or eczema. J Invest Dermatol 130(4):953–961. 10.1038/jid.2009.389.20016499
Roelofzen JH, van der Valk PG, Godschalk R, . 2012. DNA adducts in skin biopsies and 1-hydroxypyrene in urine of psoriasis patients and healthy volunteers following treatment with coal tar. Toxicol Lett 213(1):39–44. 10.1016/j.toxlet.2011.06.030.21810456
Roelofzen JHJ, Aben KKH, Van de Kerkhof PCM, . 2015. Dermatological exposure to coal tar and bladder cancer risk: a case-control study. Urol Oncol 33(1):20e19–20e22. 10.1016/j.urolonc.2013.12.006.
Rogaczewska T, Ligocka D. 1994. Occupational exposure to coal tar pitch volatiles, benzo/a/pyrene and dust in tyre production. Int J Occup Med Environ Health 7(4):379–386.7719665
Rojas M, Godschalk R, Alexandrov K, . 2001. Myeloperoxidase - 463A variant reduces benzo[a]pyrene diol epoxide DNA adducts in skin of coal tar treated patients. Carcinogenesis 22(7):1015–1018. 10.1093/carcin/22.7.1015.11408343
Romundstad P, Haldorsen T, Andersen A. 2000a. Lung and bladder cancer among workers in a Norwegian aluminum reduction plant. Occup Environ Med 57(7):495–499. 10.1136/oem.57.7.495.10854504
Romundstad P, Andersen A, Haldorsen T. 2000b. Cancer incidence among workers in six Norwegian aluminum plants. Scand J Work Environ Health 26(6):461–469. 10.5271/sjweh.569.11201392
Romundstad P, Haldorsen T, Andersen A. 2000c. Cancer incidence and cause specific mortality among workers in two Norwegian aluminum reduction plants. Am J Ind Med 37(2):175–183. 10.1002/(sici)1097-0274(200002)37:2<175::aid-ajim3>3.0.co;2-t.10615098
Rønneberg A. 1995. Mortality and cancer morbidity in workers from an aluminum smelter with prebaked carbon anodes - part I: exposure assessment. Occup Environ Med 52(4):242–249. 10.1136/oem.52.4.242.7795739
Rønneberg A, Andersen A. 1995. Mortality and cancer morbidity in workers from an aluminum smelter with prebaked carbon anodes - part II: cancer morbidity. Occup Environ Med 52(4):250–254. 10.1136/oem.52.4.250.7795740
Rønneberg A, Haldorsen T, Romundstad P, . 1999. Occupational exposure and cancer incidence among workers from an aluminum smelter in western Norway. Scand J Work Environ Health 25(3):207–214. 10.5271/sjweh.425.10450770
Rooney AA, Boyles AL, Wolfe MS, . 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Rostad CE, Pereira WE. 1987. Creosote compounds in snails obtained from Pensacola Bay, Florida, near an onshore hazardous-waste site. Chemosphere 16(10–12):2397–2404. 10.1016/0045-6535(87)90298-0.
Ruiz P, Ray M, Fisher J, . 2011. Development of a human Physiologically Based Pharmacokinetic (PBPK) Toolkit for environmental pollutants. Int J Mol Sci 12(11):7469–7480. 10.3390/ijms12117469.22174611
Sall RD, Shear MJ. 1940. Studies in carcinogenesis. XII. Effect of the basic fraction of creosote oil on the production of tumors in mice by chemical carcinogens. J Natl Cancer Inst 1:45–55. 10.1093/jnci/1.1.45.
Samson JG, Limkako G. 1923. Preliminary report on creosote as an adjuvant in leprosy treatment. Philipp J Sci 23:515–529.
Sanders CL, Skinner C, Gelman RA. 1986. Percutaneous absorption of 7,10 14C-benzo[a]pyrene and 7,12 14C-dimethylbenz[a]anthracene in mice. J Environ Pathol Toxicol Oncol 7(1–2):25–34. 10.1016/0013-9351(84)90033-1.3098955
Santella RM, Nunes MG, Blaskovic R, . 1994. Quantitation of polycyclic aromatic hydrocarbons, 1-hydroxypyrene, and mutagenicity in urine of coal tar-treated psoriasis patients and untreated volunteers. Cancer Epidemiol Biomarkers Prev 3(2):137–140.8049634
Santella RM, Perera FP, Young TL, . 1995. Polycyclic aromatic hydrocarbon-DNA and protein adducts in coal tar treated patients and controls and their relationship to glutathione S-transferase genotype. Mutat Res 334:117–124. 10.1016/0165-1161(95)90001-2.7885362
Sarto F, Zordan M, Tomanin R, . 1989. Chromosomal alterations in peripheral blood lymphocytes, urinary mutagenicity and excretion of polycyclic aromatic hydrocarbons in six psoriatic patients undergoing coal tar therapy. Carcinogenesis 10(2):329–334. 10.1093/carcin/10.2.329.2643486
Sasser LB, Lundstrom DL, Zangar RC, . 1989. Elevated blood pressure and heart rate in rats exposed to a coal-derived complex organic mixture. J Appl Toxicol 9(1):47–52. 10.1002/jat.2550090109.2538501
Scarnato C, Morelli C. 2012. Mortality study in secondary aluminum foundry workers. Eur J Oncol 17(4):205–212. 10.1017/CBO9781107415324.004.
Scheepers PT, van Houtum JL, Anzion RB, . 2009. Uptake of pyrene in a breast-fed child of a mother treated with coal tar. Pediatr Dermatol 26(2):184–187. 10.1111/j.1525-1470.2009.00880.x.19419468
Schoket B, Horkay I, Kosa A, . 1990. Formation of DNA adducts in the skin of psoriasis patients, in human skin in organ culture, and in mouse skin and lung following topical application of coal-tar and juniper tar. J Invest Dermatol 94(2):241–246. 10.1111/1523-1747.ep12874576.2299199
Schwartz L. 1942. Dermatitis from creosote-treated wooden floors. Ind Med 11(8):387.
Selden AI, Westberg HB, Axelson O. 1997. Cancer morbidity in workers at aluminum foundries and secondary aluminum smelters. Am J Ind Med 32(5):467–477. 10.1002/(sici)1097-0274(199711)32:5<467::aid-ajim6>3.0.co;2-p.9327070
Sharma M, Sharma G, Singh B, . 2020. Holistic development of coal tar lotion by embedding design of experiments (DoE) technique: preclinical investigations. Expert Opin Drug Deliv 17(2):255–273. 10.1080/17425247.2020.1723545.31990219
Shoeb M, Meier HCS, Antonini JM. 2021. Telomeres in toxicology: Occupational health. Pharmacol Ther 220:107742. 10.1016/j.pharmthera.2020.107742.33176178
Siddens LK, Bunde KL, Harper TA, . 2015. Cytochrome P450 1b1 in polycyclic aromatic hydrocarbon (PAH)-induced skin carcinogenesis: Tumorigenicity of individual PAHs and coal-tar extract, DNA adduction and expression of select genes in the Cyp1b1 knockout mouse. Toxicol Appl Pharmacol 287(2):149–160. 10.1016/j.taap.2015.05.019.26049101
Siemiatycki J, Dewar R, Nadon L, . 1994. Occupational risk factors for bladder cancer: results from a case-control study in Montreal, Quebec, Canada. Am J Epidemiol 140(12):1061–1080. 10.1093/oxfordjournals.aje.a117207.7998589
Sim MR, Del Monaco A, Hoving JL, . 2009. Mortality and cancer incidence in workers in two Australian prebake aluminium smelters. Occup Environ Med 66(7):464–470. 10.1136/oem.2008.040964.19218259
Smith LM. 1937. Dermatitis caused by creosote bush. J Allergy Clin Immunol 8:187–188.
Smith G, Wolf CR, Deeni YY, . 2003. Cutaneous expression of cytochrome P450 CYP2S1: individuality in regulation by therapeutic agents for psoriasis and other skin diseases. Lancet 361(9366):1336–1343. 10.1016/s0140-6736(03)13081-4.12711469
Smith G, Ibbotson SH, Comrie MM, . 2006. Regulation of cutaneous drug-metabolizing enzymes and cytoprotective gene expression by topical drugs in human skin in vivo. Br J Dermatol 155(2):275–281. 10.1111/j.1365-2133.2006.07317.x.16882163
Smułek W, Sydow M, Zabielska-Matejuk J, . 2020. Bacteria involved in biodegradation of creosote PAH - A case study of long-term contaminated industrial area. Ecotoxicol Environ Saf 187:109843. 10.1016/j.ecoenv.2019.109843.31678701
Spinelli JJ, Band PR, Svirchev LM, . 1991. Mortality and cancer incidence in aluminum reduction plant workers. J Occup Med 33(11):1150–1155. 10.1097/00043764-199111000-00011.1765856
Spinelli JJ, Demers PA, Le ND, . 2006. Cancer risk in aluminum reduction plant workers (Canada). Cancer Causes Control 17(7):939–948. 10.1007/s10552-006-0031-9.16841261
Springer DL, Poston KA, Mahlum DD, . 1982. Teratogenicity following inhalation exposure of rats to a high-boiling coal liquid. J Appl Toxicol 2(5):260–264. 10.1002/jat.2550020509.7184947
Springer DL, Hackett PL, Miller RA, . 1986a. Lung development and postnatal survival for rats exposed in utero to a high-boiling coal liquid. J Appl Toxicol 6:129–133. 10.1002/jat.2550060212.3700962
Springer DL, Miller RA, Weimer WC, . 1986b. Effects of inhalation exposure to a high-boiling (288 to 454 °C) coal liquid. Toxicol Appl Pharmacol 82:112–131. 10.1016/0041-008X(86)90444-8.3753804
Springer DL, Miller RA, Wright CW, . 1987. Effects of subchronic inhalation exposure of mice to a high-boiling coal liquid. Fundam Appl Toxicol 9(2):277–286. 10.1016/0272-0590(87)90050-9.3653570
Springer DL, Mann DB, Dankovic DA, . 1989. Influences of complex organic mixtures on tumor-initiating activity, DNA binding and adducts of benzo[a]pyrene. Carcinogenesis 10(1):131–137. 10.1093/carcin/10.1.131.2491965
Srivastava VK, Chauhan SS, Srivastava PK, . 1986. Fetal translocation and metabolism of PAH obtained from coal fly ash given intratracheally to pregnant rats. J Toxicol Environ Health 18:459–469. 10.1080/15287398609530885.3712502
Stangroom SJ, Collins CD, Lester JN. 1998. Sources of organic micropollutants to lowland rivers. Environ Technol 19(7):643–666. 10.1080/09593331908616722.
Steineck G, Plato N, Alfredsson L, . 1989. Industry-related urothelial carcinogens: application of a job-exposure matrix to census data. Am J Ind Med 16(2):209–224. 10.1002/ajim.4700160212.2773949
Stern FB, Ruder AM, Chen G. 2000. Proportionate mortality among unionized roofers and waterproofers. Am J Ind Med 37(5):478–492. 10.1002/(sici)1097-0274(200005)37:5<478::aid-ajim4>3.0.co;2-8.10723042
Stjernsward J. 1966. Effect of noncarcinogenic and carcinogenic hydrocarbons on antibody-forming cells measured at the cellular level in vitro. J Natl Cancer Inst 36:1189–1195. 10.1093/jnci/36.6.1189.5949751
Stjernsward J. 1969. Immunosuppression by carcinogens. Antibiot Chemother 15:213–233.5780389
Strickland P, Kang D, Sithisarankul P. 1996. Polycyclic aromatic hydrocarbon metabolites in urine as biomarkers of exposure and effect. Environ Health Perspect 104(Suppl 5):927–932. 10.1289/ehp.96104s5927.8933036
Swaen GMH, Slangen JMM. 1997. Mortality in a group of tar distillery workers and roofers. Int Arch Occup Environ Health 70:133–137. 10.1007/s004200050197.9253642
Swann RL, Laskowski DA, McCall PJ, . 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Res Rev 85:17–28. 10.1007/978-1-4612-5462-1_3.
Swartz RC, Kemp PF, Schults DW, . 1989. Acute toxicity of sediment from Eagle Harbor, Washington, to the infaunal amphipod Rhepoxynius abronius. Environ Toxicol Chem 8:215–222. 10.1002/etc.5620080304.
Sweeney LM, Gearhart JM. 2020. Examples of physiologically based pharmacokinetic modeling applied to risk assessment. In: Fisher JW, Gearhart JM, Lin Z, eds. Physiologically based pharmacokinetic (PBPK) modeling. Academic Press: 281–299. 10.1016/B978-0-12-818596-4.00011-4.
Szakal AK, Hanna MG. 1972. Immune suppression and carcinogenesis in hamsters during topical application of 7,12-dimethylbenz(a)anthracene. Natl Cancer Inst Monogr 35:173–182.4572824
Takemori H, Hamamoto A, Isogawa K, . 2020. Mouse model of metformin-induced diarrhea. BMJ Open Diabetes Res Care 8(1):e000898. 10.1136/bmjdrc-2019-000898.
Tan YM, Chan M, Chukwudebe A, . 2020. PBPK model reporting template for chemical risk assessment applications. Regul Toxicol Pharmacol 115:104691. 10.1016/j.yrtph.2020.104691.32502513
Tham SN, Lun KC, Cheong WK. 1994. A comparative study of calcipotriol ointment and tar in chronic plaque psoriasis. Br J Dermatol 131(5):673–677. 10.1111/j.1365-2133.1994.tb04981.x.7999599
Thein N, Møller P, Amtoft H, . 2000. A strong genotoxic effect in mouse skin of a single painting of coal tar in hairless mice and in MutaMouse. Mutat Res 468(2):117–124. 10.1016/s1383-5718(00)00050-4.10882890
Thériault G, De Guire L, Cordier S. 1981. Reducing aluminum: an occupation possibly associated with bladder cancer. Can Med Assoc J 124(4):419–422, 425.7214271
Thériault G, Cordier S, Tremblay C, . 1984. Bladder cancer in the aluminium industry. Lancet 323(8383):947–950. 10.1016/s0140-6736(84)92399-7.
Tornqvist S, Norell S, Ahlbom A, . 1986. Cancer in the electric power industry. Br J Ind Med 43(3):212–213. 10.1136/oem.43.3.212.3947586
Tremblay C, Armstrong B, Thériault G, . 1995. Estimation of risk of developing bladder cancer among workers exposed to coal tar pitch volatiles in the primary aluminum industry. Am J Ind Med 27(3):335–348. 10.1002/ajim.4700270303.7747740
TRI22. 2024. Creosote. TRI explorer: release reports. Washington, DC: Toxics Release Inventory. U.S. Environmental Protection Agency. https://enviro.epa.gov/triexplorer/tri_release.chemical. February 8, 2024.
UK HSE. 2002. Cancer risk following exposure to polycyclic aromatic hydrocarbons (PAHs): A meta-analysis. London, England: UK Health and Safety Executive. https://www.hse.gov.uk/research/rrpdf/rr068.pdf. November 2, 2022.
USDA. 1980. The biologic and economic assessment of pentachlorophenol, inorganic arsenicals, creosote. Volume 1: Wood preservatives. Washington, DC: U.S. Department of Agriculture. 193–227. Technical Bulletin number 1658-1. https://www.nal.usda.gov/exhibits/speccoll/files/original/19a5a526a051467d30ac29e656fe2dd7.pdf. November 3, 2022.
USDA. 2004. Polycyclic aromatic hydrocarbon migration from creosote-treated railway ties into ballast and adjacent wetlands. Madison, WI: United States Department of Agriculture. FPL-RP-617. https://www.fpl.fs.usda.gov/documnts/fplrp/fpl_rp617.pdf. September 26, 2022.
USITC. 2022. DataWeb: Imports for consumption. United States International Trade Commission. https://dataweb.usitc.gov/. October 19, 2022.
Van Metre PC, Mahler BJ. 2010. Contribution of PAHs from coal-tar pavement sealcoat and other sources to 40 U.S. lakes. Sci Total Environ 409(2):334–344. 10.1016/j.scitotenv.2010.08.014.21112613
Van Metre PC, Mahler BJ, Wilson JT. 2009. PAHs underfoot: contaminated dust from coal-tar sealcoated pavement is widespread in the United States. Environ Sci Technol 43(1):20–25. 10.1021/es802119h.19209579
Van Metre PC, Majewski MS, Mahler BJ, . 2012. Volatilization of polycyclic aromatic hydrocarbons from coal-tar-sealed pavement. Chemosphere 88(1):1–7. 10.1016/j.chemosphere.2011.12.072.22289152
Van Rooij JGM, De RJHC, Bodelier-Bade MM, . 1993a. Absorption of polycyclic aromatic hydrocarbons through human skin: Differences between anatomical sites and individuals. J Toxicol Environ Health A 38:355–368. 10.1080/15287399309531724.
Van Rooij JGM, Van Lieshout EMA, Bodelier-Bade MM, . 1993b. Effect of the reduction of skin contamination on the internal dose of creosote workers exposed to polycyclic aromatic hydrocarbons. Scand J Work Environ Health 19(3):200–207. 10.5271/sjweh.1322.8367698
Van Rooij JGM, Vinke E, De Lange J, . 1995. Dermal absorption of polycyclic aromatic hydrocarbons in the blood-perfused pig ear. J Appl Toxicol 15(3):193–200. 10.1002/jat.2550150309.7560739
van Schooten F, Moonen E, Rhijnsburger E, . 1994. Dermal uptake of polycyclic aromatic hydrocarbons after hairwash with coal-tar shampoo. Lancet 344:1505–1506. 10.1016/S0140-6736(94)90323-9.7968140
Veenhuis RT, van Horssen J, Bos RP, . 2002. Highly increased urinary 1-hydroxypyrene excretion rate in patients with atopic dermatitis treated with topical coal tar. Arch Dermatol Res 294(4):168–171. 10.1007/s00403-002-0311-5.12111346
Viau C, Vyskocil A. 1995. Patterns of 1-hydroxypyrene excretion in volunteers exposed to pyrene by the dermal route. Sci Total Environ 163:187–190. 10.1016/0048-9697(95)04495-M.7716497
Viau C, Vyskocil A, Martel L. 1995. Background urinary 1-hydroxypyrene levels in non-occupationally exposed individuals in the province of Quebec, Canada, and comparison with its excretion in workers exposed to PAH mixtures. Sci Total Environ 163:191–194. 10.1016/0048-9697(95)04496-N.7716498
Vogel U, Thein N, Møller P, . 2001. Pharmacological coal tar induces G:C to T:A transversion mutations in the skin of MutaTM mouse. Pharmacol Toxicol 89(1):30–34. 10.1034/j.1600-0773.2001.d01-132.x.11484907
Volckens J, Leith D. 2003. Partitioning theory for respiratory deposition of semivolatile aerosols. Ann Occup Hyg 47(2):157–164. 10.1093/annhyg/meg015.12582000
von Burg R, Stout T. 1992. Toxicology update: creosote. J Appl Toxicol 12(2):153–156. 10.1002/jat.2550120214.1556384
Wallcave L, Garcia H, Feldman R, . 1971. Skin tumorigenesis in mice by petroleum asphalts and coal-tar pitches of known polynuclear aromatic hydrocarbon content. Toxicol Appl Pharmacol 18(1):41–52. 10.1016/0041-008x(71)90313-9.5542832
Walter JF, Stoughton RB, Dequoy PR. 1978. Suppression of epidermal DNA synthesis by ultraviolet light, coal tar and anthralin. Br J Dermatol 99:89–96. 10.1111/j.1365-2133.1978.tb01965.x.678469
Wan MT. 1991. Railway right-of-way contaminants in the lower mainland of British Columbia: Polycyclic aromatic hydrocarbons. J Environ Qual 20(1):228–234. 10.2134/jeq1991.00472425002000010036x.
Ward JB. 1988. Sperm evaluation in human genetic monitoring. Reprod Toxicol 2(3–4):177–182. 10.1016/0890-6238(88)90019-6.2980343
Watson AF, Mellanby E. 1930. Tar cancer in mice. II: The condition of the skin when modified by external treatment or diet, as a factor in influencing the cancerous reaction. Br J Exp Pathol 11(5):311–322.
Weiss G. 1986. Coal tar creosote, wood creosote, and coal tar. In: Hazardous chemicals data book. 2nd ed. Park Ridge, NJ: Noyes Data Corp, 306.
West JE, Carey AJ, Ylitalo GM, . 2019. Polycyclic aromatic hydrocarbons in Pacific herring (Clupea pallasii) embryos exposed to creosote-treated pilings during a piling-removal project in a nearshore marine habitat of Puget Sound. Mar Pollut Bull 142:253–262. 10.1016/j.marpolbul.2019.03.028.31232302
Weston A, Santella RM, Bowman ED. 1994. Detection of polycyclic aromatic hydrocarbon metabolites in urine from coal tar treated psoriasis patients and controls. Polycyclic Aromatic Compounds 5:241–247. 10.1080/10406639408015177.
Weyand EH, Bevan DR. 1987. Covalent binding of benzo[a]pyrene to macromolecules in lung and liver of rats following intratracheal instillation. Cancer Lett 36(2):149–159. 10.1016/0304-3835(87)90086-3.2441851
Weyand EH, Wu Y, Patel S, . 1991. Urinary excretion and DNA binding of coal tar components in B6C3F1 mice following ingestion. Chem Res Toxicol 4(4):466–473. 10.1021/tx00022a011.1912335
Weyand EH, Wu Y, Patel S, . 1994. Biochemical effects of manufactured gas plant residue following ingestion by B6C3F1 mice. J Toxicol Environ Health 42(1):89–107. 10.1080/15287399409531865.8169998
Weyand EH, Chen YC, Wu Y, . 1995. Differences in the tumorigenic activity of a pure hydrocarbon and a complex mixture following ingestion: benzo[a]pyrene vs manufactured gas plant residue. Chem Res Toxicol 8(7):949–954. 10.1021/tx00049a008.8555410
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2022. Guidelines for drinking-water quality. Fourth edition incorporating the first and second addenda. World Health Organization. https://www.who.int/publications/i/item/9789240045064. June 22, 2022.
Wigle DT. 1977. Bladder cancer: Possible new high-risk occupation. Lancet 310(8028):83–84. 10.1016/s0140-6736(77)90079-4.
Williams ES, Mahler BJ, Van Metre PC. 2012. Coal-tar pavement sealants might substantially increase children’s PAH exposures. Environ Pollut 164:40–41. 10.1016/j.envpol.2012.01.010.22327113
Williams ES, Mahler BJ, Van Metre PC. 2013. Cancer risk from incidental ingestion exposures to PAHs associated with coal-tar-sealed pavement. Environ Sci Technol 47(2):1101–1109. 10.1021/es303371t.23181746
Wilson JT, McNabb JF, Cochran JW, . 1985. Influence of microbial adaptation on the fate of organic pollutants in ground water. Environ Toxicol Chem 4:721–726. 10.1002/etc.5620040602.
Wong O, Harris F. 2005. Retrospective cohort mortality study and nested case-control study of workers exposed to creosote at 11 wood-treating plants in the United States. J Occup Environ Med 47(7):683–697. 10.1097/01.jom.0000165016.71465.7a.16010195
Wright MC, Kaufhold A, Hevert F, . 1992. [Investigations into possible nephrotoxicity of a coal tar preparation]. Hautarzt 43(8):483–486. (German)1506213
Wu W. 1988. Occupational cancer epidemiology in the People’s Republic of China. J Occup Med 30(12):968–974. 10.1097/00043764-198812000-00017.3068337
Wu-Williams AH, Xu ZY, Blot WJ, . 1993. Occupation and lung cancer risk among women in northern China. Am J Ind Med 24(1):67–79. 10.1002/ajim.4700240107.8352293
Xie M, Hannigan MP, Barsanti KC. 2014. Impact of gas/particle partitioning of semivolatile organic compounds on source apportionment with positive matrix factorization. Environ Sci Technol 48(16):9053–9060. 10.1021/es5022262.25083820
Yadav JS, Seth N. 1998. Effect of polycyclic aromatic hydrocarbons on somatic chromosomes of coal tar workers. Cytobios 93(374):165–173.9779589
Yamazaki H, Terada M, Tsuboi A. 1987. Distribution and binding pattern of benzo(a)pyrene in rat liver, lung and kidney constituents after oral administration. Toxicol Environ Chem 15:71–81. 10.1080/02772248709357223.
Zangar RC, Springer DL, Buschbom RL, . 1989. Comparison of fetotoxic effects of a dermally applied complex organic mixture in rats and mice. Fundam Appl Toxicol 13(4):662–669. 10.1016/0272-0590(89)90324-2.2620790
Zeiger E, Anderson B, Haworth S, . 1992. Salmonella mutagenicity tests: V. Results from the testing of 311 chemicals. Environ Mol Mutagen 19(Suppl 21):2–141. 10.1002/em.2850190603.1541260
Zepp RG, Schlotzhauer PF. 1979. Photoreactivity of selected aromatic hydrocarbons in water. In: Jones PW, Leber P, eds. Polynuclear aromatic hydrocarbons: Third international symposium on chemistry and biology – Carcinogenesis and mutagenesis. Ann Arbor, MI: Ann Arbor Science Publishers Inc, 141–158.
Zhang YJ, Li Y, DeLeo VA, . 1990. Detection of DNA adducts in skin biopsies of coal tar-treated psoriasis patients: immunofluorescence and 32P postlabeling. Skin Pharmacol 3(3):171–179. 10.1159/000210867.2127679
Zhang P, Li Z, Wang N, . 2017. Coal tar pitch extract could induce chromosomal instability of human bronchial epithelial cells mediated by spindle checkpoint-related proteins. Oncotarget 8(34):56506–56517. 10.18632/oncotarget.17025.28915607