# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Breanna Alman, M.P.H. (Lead)
  Obaid Faroon, D.V.M., Ph.D.
  Carolyn Harper, Ph.D.
  Mohammad Shoeb, Ph.D.
- ATSDR, Office of Innovation and Analytics, Toxicology Section, Atlanta, GA

- Julie M. Klotzbach, Ph.D.
  Jessica L. Myers, Ph.D.
  Gary L. Diamond, Ph.D.
  Mario Citra, Ph.D.
- SRC, Inc., North Syracuse, NY

## REVIEWERS

Interagency Minimal Risk Level Workgroup:

- Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Safety and Health (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).

Additional reviews for science and/or policy:

- ATSDR, Office of Community Health Hazard Assessment; ATSDR, Office of Capacity Development and Applied Prevention Science; ATSDR, Office of Science; NCEH, Division of Laboratory Sciences; NCEH, Division of Environmental Health Science and Practice; EPA, Office of Research and Development; EPA, Office of Water.

## PEER REVIEWERS

1. David Williams, Ph.D.; University Distinguished Professor; Department of Environmental and Molecular Toxicology; Oregon State University; Corvallis, Oregon
2. Robert Herrick, Sc.D.; Harvard School of Public Health; Department of Environmental Health; Boston, Massachusetts
3. Edward Levin, Ph.D.; Professor; Duke University; Durham, North Carolina

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.