# VERSION HISTORY

Date | Description
July 2024 | Final toxicological profile released
August 2023 | Draft for public comment toxicological profile released
September 2002 | Final toxicological profile released
August 1996 | Final toxicological profile released
December 1990 | Final toxicological profile released