# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding creosote in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. Note that no MRLs have been derived for creosote (see Section 1.3 and Appendix A for detailed information).

Table 7-1 Regulations and Guidelines Applicable to Coal Tar Creosote, Coal Tar, Coal Tar Pitch, Coal Tar Pitch Volatiles, and Wood Creosote

Agency | Description | Information | Reference
Air
EPA | RfC | Not assessed | IRIS 1988
WHO | Air quality guidelines | No data | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | Not listed | EPA 2018a
EPA | National primary drinking water regulations | Not listed | EPA 2009b
EPA | RfD | Not assessed | IRIS 1988
WHO | Drinking water quality guidelines | Not listed^a^ | WHO 2022
FDA | Food and drugs regulations
FDA | Beechwood creosote | Allowed under synthetic flavoring substances and adjuvants regulation | FDA 2023a
FDA | Coal tar 0.5–5% | Allowed as active ingredient for the control of dandruff, seborrheic dermatitis, and psoriasis | FDA 2023d
FDA | Any over-the-counter drug product introduced after the dates specified that is labeled, represented, or promoted for the uses specified is regarded as a new drug for which an approved new drug application is required for marketing | | FDA 2023b
FDA | Beechwood creosote (1990) | Expectorant drug products
FDA | Beechwood creosote and creosote (1993) | Poison ivy, oak, and sumac drug products
FDA | Beechwood creosote, oral (1991) and topical (1995) | Nasal decongestant drug products
FDA | Coal tar (1991) | Topical acne drug products and diaper rash drug products
FDA | Drugs, recommended warning and caution statements | | FDA 2023c
FDA | Creosote in preparations for external use | Caution: do not apply to large areas of the body
FDA | Creosote in douche preparations | The use of solutions stronger than those recommended may result in severe local irritation, burns, or serious poisoning. Do not use more often than twice weekly unless directed by physician
Cancer
HHS | Carcinogenicity classification | | NTP 2021
HHS | Coal tars and coal-tar pitches | Known to be human carcinogens
EPA | Carcinogenicity classification | | IRIS 1988
EPA | Creosote | B1^b^
IARC | Carcinogenicity classification
IARC | Creosotes | Group 2A^c^ | IARC 2010
IARC | Occupational exposures during coal tar distillation | Group 1^d^ | IARC 2012a
IARC | Coal tar pitch | Group 1^d^ | IARC 2012b
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards, and construction | | OSHA 2021a, 2021b, 2021c
OSHA | Coal-tar pitch volatiles (benzene-soluble fraction) | 0.2 mg/m^3^
NIOSH | REL (up to 10-hour TWA)
NIOSH | Coal-tar pitch volatiles (cyclohexane-extractable fraction) | 0.1 mg/m^3^ ^e^ | NIOSH 1977, 2018
NIOSH | IDLH | 80 mg/m^3^ ^e^ | NIOSH 1994
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2018b
DOE | PACs-air | | DOE 2018a
DOE | Creosote (coal tar)
DOE | PAC-1^f^ | 0.6 mg/m^3^
DOE | PAC-2^f^ | 120 mg/m^3^
DOE | PAC-3^f^ | 700 mg/m^3^
DOE | Coal tar pitch volatiles
DOE | PAC-1^f^ | 0.6 mg/m^3^
DOE | PAC-2^f^ | 120 mg/m^3^
DOE | PAC-3^f^ | 700 mg/m^3^
DOE | Coal tar, aerosol
DOE | PAC-1^f^ | 2.8 mg/m^3^
DOE | PAC-2^f^ | 31 mg/m^3^
DOE | PAC-3^f^ | 190 mg/m^3^

a In relation to benzo[a]pyrene drinking-water contamination, it is recommended that coal tar-based pipe linings and coatings on storage tanks be discontinued.

b B1: probable human carcinogen (limited evidence of carcinogenicity from epidemiological studies) based on EPA’s 1986 cancer guidelines.

c Group 2A: probably carcinogenic to humans.

d Group 1: carcinogenic to humans.

e Potential occupational carcinogen.

f Definitions of PAC terminology are available from DOE (2018b).

AEGL = acute exposure guideline levels; DOE = Department of Energy; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; NIOSH = National Institute for Occupational Safety and Health; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; WHO = World Health Organization