# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity, chemical synonyms, and identification numbers for wood creosote, coal tar creosote, and coal tar is provided in Tables 4-1 through 4-3. Coal tar pitch is similar in composition to coal tar creosote and is not presented separately. Coal tar pitch volatiles are compounds given off from coal tar pitch when it is heated. The volatile component is not shown separately because it varies with the composition of the pitch. Creosotes and coal tars are complex mixtures of variable composition containing primarily condensed aromatic ring compounds (coal-derived substances) or phenols (wood creosote). Therefore, it is not possible to represent these materials with a single chemical formula and structure. The sources, chemical properties, and composition of coal tar creosote, coal tar pitch, and coal tar justify treating these materials as a whole. Wood creosote is discussed separately because it is different in nature, use, and risk. The partitioning behavior of PAHs and other semi-volatile substances between the vapor and particulate phase in air is well understood (Eisenreich et al. 1981; Xie et al. 2014). In general, several of the low molecular weight constituents are semi-volatile and exist in air in the vapor-phase, while larger PAHs are less volatile and tend to exist in the particulate phase; this affects atmospheric transport, degradation, and deposition into the lungs (Volckens and Leith 2003).

Table 4-1 Chemical Identity of Wood Creosote

Characteristic | Information | Reference
Chemical mixture name | Wood creosote | Budavari 1989
Synonym(s) and registered trade name(s) | Beechwood creosote; creosote; creasote | Budavari 1989
Chemical formula^a^ | Not applicable
SMILES | Not applicable
Chemical structure^a^ | Not applicable
CAS Registry Number | 8021-39-4 | Budavari 1989
TSCA definition | A complex combination of phenols obtained as a distillate from wood tar. | EPA 2022a

a Wood creosote is a mixture composed primarily of phenolic compounds.

CAS = Chemical Abstracts Service; TSCA = Toxic Substances Control Act

Table 4-2 Chemical Identity of Coal Tar Creosote

Characteristic | Information | Reference
Chemical mixture name | Coal tar creosote | AWPA 1988
Synonym(s) and registered trade name(s) | Creosote; standard creosote oil; creosote, coal tar; creosotum; naphthalene oil; heavy oil; brick oil; wash oil; cresylic creosote; coal tar oil; liquid patch oil; petroleum creosote, creosote P1; sakresote 100; Emulsified Refined Coal-Tar (Ready to Use, Commercial Grade; Road Tar (RT-1, RT-2, RT-3, RT-4, RT-5, RT-6, RT-7, RT-8, RT-9, RT-10, RT-11, RT-12, RT.C.B.-5, and RT.C.B.-6) | ASTM 2016, 2017; NLM 2022a
Chemical formula^a^ | Not applicable
SMILES | Not applicable
Chemical structure^a^ | Not applicable
CAS Registry Number | 8001-58-9 | Budavari 1989; Weiss 1986; NLM 2022a
TSCA definition | The distillate of coal tar produced by the high temperature carbonization of bituminous coal. It consists primarily of aromatic hydrocarbons, tar acids, and tar bases. | EPA 2022a

a Coal tar creosote is a mixed compound composed primarily of polycyclic aromatic hydrocarbons including phenanthrene, acenaphthene, fluorene, anthracene, and pyridine.

CAS = Chemical Abstracts Service; TSCA = Toxic Substances Control Act

Table 4-3 Chemical Identity of Coal Tar

Characteristic | Information | Reference
Chemical mixture name | Coal tar | Budavari 1989
Synonym(s) and registered trade name(s) | Crude coal tar; pixalbol; tar; Psorigel; Clinitar; coal tar extract | Budavari 1989; NLM 2022b
Chemical formula^a^ | Not applicable
SMILES | Not applicable
Chemical structure^a^ | Not applicable
CAS Registry Number | 8007-45-2 | NLM 2022b
TSCA definition | The byproduct from the destructive distillation of coal. Almost black semisolid. A complex combination of aromatic hydrocarbons, phenolic compounds, nitrogen bases, and thiophene. | EPA 2022a

a Coal tar is a mixed compound composed primarily of polycyclic aromatic hydrocarbons including phenanthrene, acenaphthene, fluorene, anthracene, and pyridine.

CAS = Chemical Abstracts Service; TSCA = Toxic Substances Control Act

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Wood creosote, coal tar creosote, coal tar, and coal tar pitch differ from each other with respect to their composition. Descriptions of each mixture are presented below.

Wood Creosote. Wood creosotes are derived from either beechwood (referred to herein as beechwood creosote) or the resin from leaves of the creosote bush (Larrea, referred to herein as creosote bush resin). Beechwood creosote consists mainly of phenol, cresols, guaiacols, and xylenols. It is a colorless or pale yellowish liquid, and it has a characteristic smoky odor and burnt taste (Miyazato et al. 1981). It had therapeutic applications in the past as a disinfectant, laxative, and stimulating expectorant, but it is not a major pharmaceutical ingredient today in the United States. Beechwood creosote is obtained from fractional distillation (200–220°C at atmospheric pressure) of beechwood or related plants. The mixture has been characterized by Ogata and Baba (1989). Phenol, p-cresol, and guaiacols (guaiacol and 4-methylguaiacol) comprise the bulk of beechwood creosote. Xylenols, other methylated guaiacols, and trimethylphenols account for virtually all the remaining phenolics in the material. Since beechwood creosote is obtained from different sources using no standardized procedures, its composition may vary to some degree. For the sample analyzed by Ogata and Baba (1989), more than two-thirds of the more than 20 compounds identified (see Table 4-4) were represented by just four components (phenol, p-cresol, guaiacol, and 4-methylguaiacol). Information regarding selected chemical and physical properties of wood creosote are shown in Table 4-5.

Table 4-4 Identity of Major Components of Beechwood Creosote^a^

Compound | Relative peak area (percentage identified in mixture)
Phenol | 14.5%
Methylhydroxycyclopentenone | 0.23%
o-Cresol | 3.22%
Dimethylhydroxycyclopentanone | 0.50%
p-Cresol | 13.6%
Guaiacol | 23.76%
2,6-Xylenol | 1.04%
3,4-Xylenol | 0.70%
6-Methylguaiacol | 0.31%
3,5-Xylenol | 2.94%
2,4-Xylenol | 2.80%
2,5-Xylenol | 0.68%
Unknown | 1.31%
2,3-Xylenol | 0.70%
3-Methylguaiacol | 1.85%
5-Methylguaiacol | 1.29%
4-Methylguaiacol | 19.01%
2,4,6-Trimethylphenol | 0.40%
2,3,6-Trimethylphenol | 0.48%
4-Ethylguaiacol | 6.36%
4-Ethyl-5-methylguaiacol | 0.21%
4-Propylguaiacol | 0.45%

a As identified by gas chromatography/mass spectrometry (Ogata and Baba 1989); composition of wood creosotes may vary from source to source.

Table 4-5 Physical and Chemical Properties of Wood Creosote^a^

Property | Information | Reference
Molecular weight | Not applicable
Color | Yellowish to colorless | Budavari 1989
Physical state | Liquid | Weiss 1986
Melting point | No data
Boiling point | 203°C | Budavari 1989
Density at 20°C | Not applicable
Odor | Characteristic smokey odor | Budavari 1989
Odor threshold:
Water | No data
Air | No data
Solubility:
Water | 150–200 parts water | Budavari 1989
Organic solvents | Miscible with alcohol, ether, fixed or volatile oils | Budavari 1989
Partition coefficients:
Log K_ow_ | Not applicable
Log K_oc_ | Not applicable
Vapor pressure at 20°C | Not applicable
Henry’s law constant at 25°C | Not applicable
Autoignition temperature | No data
Flashpoint | 74°C (closed cup) | Clayton and Clayton 1981
Flammability limits | No data
Conversion factors | Not applicable
Explosive limits | No data

a Physical-chemical properties will vary by sample as the constituents of the complex mixture are not constant. Not applicable has been used for several properties since a wide range of values are expected based upon chemical composition of the mixture.

Creosote bush resin consists of phenolics (e.g., flavonoids and nordihydroguaiaretic acid), neutrals (e.g., waxes), basics (e.g., alkaloids), and acidics (e.g., phenolic acids). The phenolic portion comprises 83–91% of the total resin. Nordihydroguaiaretic acid accounts for 5–10% of the dry weight of the leaves (Leonforte 1986). No other relevant chemical/physical data are available for creosote bush resin; the substance is therefore not addressed further in this profile.

Coal Tar Creosote, Coal Tar, and Coal Tar Pitch. These three substances are very similar mixtures obtained from the distillation of coal tars. The physical and chemical properties of each are similar, although limited data are available for coal tar, and coal tar pitch. Chemical Abstracts Service (CAS) Registry Numbers are associated with coal tar creosote (8001-58-9), coal tar pitch (67996-93-2), and coal tar (8007-45-2). Literature searches for coal tar pitch produce data identical to that obtained for coal tar creosote. A distinction between these materials is provided in the following discussion.

Coal tars are byproducts of the carbonization of coal to produce coke and/or natural gas. Physically, they are usually viscous liquids or semi-solids that are black or dark brown with a naphthalene-like odor. The coal tars are complex combinations of PAHs, phenols, heterocyclic oxygen, sulfur, and nitrogen compounds. By comparison, coal tar creosotes are distillation products of coal tar. They have an oily liquid consistency and range in color from yellowish-dark green to brown. The coal tar creosotes consist of aromatic hydrocarbons, anthracene, naphthalene, and phenanthrene derivatives. At least 75% of the coal tar creosote mixture is PAHs. Unlike the coal tars and coal tar creosotes, coal tar pitch is a residue produced during the distillation of coal tar. The pitch is a shiny, dark brown to black residue, which contains PAHs and their methyl and polymethyl derivatives, as well as heteronuclear compounds (AWPA 1988). Coal tar creosote is defined by the latter organization as:

A distillate derived from coal tar. As used in the wood preserving industry, creosote denotes a distillate of coal tar produced by the high temperature carbonization of bituminous coal. Coal tar creosote consists principally of liquid and solid aromatic hydrocarbons and contains some tar acids and tar bases; it is heavier than water and has a continuous boiling range beginning at about 200°C (AWPA 1988).

Coal tar creosote is now commonly defined by function and refers to “the fractions or blends of fractions specifically used for timber preservation” (IARC 1987). The substance is a complex mixture typically composed of approximately 85% PAHs and 2–17% phenolics (Bedient et al. 1984). The composition of the creosote mixture is dependent on the sources and preparation parameters of the coal tar, and as a result the creosote components are rarely consistent in their type and concentration. An example of the composition variability among creosote samples was presented by Weyand et al. (1991). In that study, the concentrations of several PAHs were analyzed in four coal tars. All of the PAHs identified exhibited 2-fold to nearly 20-fold differences in concentration among the four samples. Benzo[a]pyrene, a component whose individual toxicity has been examined extensively, ranged from nondetectable levels (detection limit 0.3 g/kg) to 1.7, 6.4, and 3.9 g/kg of coal tar.

The International Programme on Chemical Safety (IPCS) Concise International Chemical Assessment Document (CICAD) for coal tar creosote lists some common constituents of some coal tar creosotes that were analyzed for their chemical identity (IPCS 2004). These are summarized in Table 4-6.

Table 4-6 Some Constituents and Weight Percentage of Eight Coal Tar Creosote Mixtures

| Weight percentage^a^
Coal tar creosote mixture | A | B | C | D | E | F | G | H
Aromatic hydrocarbons
Indene | | | | | 0.6 | 0.43 | 0.87
Biphenyl | 0.8/1.6 | 2.1 | 1–4 | 0.8 | 1.3 | 1.45 | 4.1
PAHs
Naphthalene | 1.3/3.0* | 11 | 13–18 | 7.6 | 12.9 | 12.32 | 11.4
1-Methylnaphthalene | 0.9*/1.7 | | 12–17 | 0.9 | 2.2 | 3.29 | 8.87
2-Methylnaphthalene | 1.2*/2.8 | 3.0 | 12.0 | 2.1 | 4.5 | 7.51 | 11.5
Dimethylnaphthalenes | 2.0*/2.3 | 5.6 | | | 1.6 | 3.42 | 5.16
Acenaphthylene | | | | | 0.2 | 0.15 | 0.1
Acenaphthene | 9.0*/14.7 | 3.1 | 9.0 | 8.3 | 5.8 | 12.51 | 5.86
Fluorene | 7.3/10.0* | 3.1 | 7–9 | 5.2 | 4.6 | 5.03 | 6.33
Methylfluorenes | 2.3/3.0* | | | | 3.1
Phenanthrene | 21* | 12.2 | 12–16 | 16.9 | 11.2 | 10.21 | 6.7 | 1–3.3
Methylphenanthrenes | 3.0* | | | | 3.1 | 0.45 | 0.54
Anthracene | 2.0* | | 2–7 | 8.2 | 1.7 | 0.9 | 0.8 | 0.4–1.2
Methylanthracenes | 4.0* | 5.9
Fluoranthene | 7.6/10.0* | 3.4 | 2–3 | 7.5 | 4.6 | 4.41 | 2.27 | 0.2–2.2
Pyrene | 7.0/8.5* | 2.2 | 1–5 | 5.3 | 3.7 | 2.0 | 1.13 | 0.1–1.5
Benzofluorenes | 1.0/2.0* | 3.4 | | | 2.2
Benz[a]anthracene | | | | | 0.5 | 0.26 | 0.17
Benzo[k]fluoranthene | | | | | 0.22 | | | 0.16–0.3
Chrysene | 2.6/3.0* | 2.2 | 1 | | 0.5–1.0 | 0.21 | <0.05
Benzo[a]pyrene | | | | 0.43 | 0.2 | <0.1 | <0.05 | 0.02–0.16
Benzo[e]pyrene | | | | | 0.2
Perylene | | | | | 0.1
Tar acids/phenolics
Phenol | | | | | 0.24 | 0.56 | 0.24
o-Cresol | | | | | 0.10 | | 0.2
m-, p-Cresol | | | | | 0.24 | 2.31 | 0.6
2,4-Dimethylphenol | | | | | 0.12 | 0.59 | 0.48
Naphthols | | | | | 0.12
Tar bases/nitrogen-containing heterocycles
Indole | | | | 2
Quinoline | | | 1 | 2.0 | 0.59 | 0.58 | 0.89
Isoquinoline | | | | 0.7 | 0.18 | 0.30 | 0.59
Benzoquinoline | | | | 4 | 0.29 | 0.05 | 0.5
Methylbenzoquinoline | | | | 0.3
Carbazole | | 2.4 | | 3.9 | 0.7 | 0.53 | 0.22
Methylcarbazoles | | | | 2
Benzocarbazoles | | | | 2.8 | 0.1
Dibenzocarbazoles | | | | 3.1
Acridine | | | | 2 | 0.2 | 1.5 | 0.12
Aromatic amines
Aniline | | | | 0.05 | 0.21
Sulfur heterocycles
Benzothiophene | | | | 0.3 | 0.4 | 0.3 | 0.5
Dibenzothiophene | | | | | 1.0 | 0.78 | 0.73
Oxygen-containing heterocycles/furans
Benzofuran | | | | | | <0.1 | <0.1
Dibenzofuran | 5.0*/7.5 | 1.1 | 4–6 | 3.9 | 3.7 | 6.14 | 5.59
Other not specified components
Unidentified component | | | | | 23.1

a An asterisk indicates that data were obtained from a literature survey; measurements without an asterisk indicate main components in an AWPA standard creosote.

AWPA = American Wood-Preservers’ Association; PAH = polycyclic aromatic hydrocarbon

Source: IPCS 2004

Coal tar itself is produced by the carbonization, or coking, of coal. Coal tar is defined by Hawley (1977) as:

A black, viscous liquid (or semi-solid), naphthalene-like odor, sharp burning taste; obtained by the destructive distillation of bituminous coal, as in coke ovens; 1 ton of coal yields 8.8 gallons of coal tar. Combustible. Specific gravity 1.18–1.23 (66/60°F). Soluble in ether, benzene, carbon disulfide, chloroform; partially soluble in alcohol, acetone, methanol, and benzene; only slightly soluble in water.

The composition of the mixture will vary across lots and across manufacturers. Gallacher et al. (2017a, 2017b) performed an analysis of 16 coal tar samples obtained from five different production processes. They identified a total of 2,369 unique compounds. This included 948 aromatics, 196 aliphatics, 380 sulfur-containing compounds, 209 oxygen-containing compounds, 262 nitrogen-containing compounds, and 865 heterocyclic compounds (15 mixed heterocycles); of all the PAHs, 359 were hydroxylated. The contents of both heterocyclic and hydroxylated PAHs varied greatly with the production process used. Of the 2,369 compounds identified, 173 were found to be present in all samples (the majority of these were PAHs). A full list of these compounds can be obtained (Gallacher et al. (2017c). Properties of coal tar creosote are shown in Table 4-7.

Table 4-7 Physical and Chemical Properties of Coal Tar Creosote^a^

Property | Information | Reference
Molecular weight | Not applicable^b^
Color | Translucent brown to black; oily liquid; yellowish to dark green-brown | Budavari 1989
Physical state | Liquid | Weiss 1986
Melting point | No data
Boiling point | 194–400°C | Clayton and Clayton 1981
Density at 20°C | Not applicable
Odor | Aromatic smokey smell; characteristic smokey odor | Budavari 1989; DOT 1985
Odor threshold:
Water | No data
Air | No data
Solubility:
Water | Slightly soluble | Clayton and Clayton 1981
Organic solvents | Miscible with alcohol, ether, fixed or volatile oils | Clayton and Clayton 1981
Partition coefficients:
Log K_ow_ | Not applicable
Log K_oc_ | Not applicable
Vapor pressure at 20°C | Not applicable
Henry’s law constant at 25°C | Not applicable
Autoignition temperature | 335°C | Budavari 1989
Flashpoint | 74°C (closed cup) | Budavari 1989
Flammability limits | No data
Conversion factors | Not applicable
Explosive limits | No data

a Physical-chemical properties will vary by sample as the constituents of the complex mixture are not constant.

b Not applicable has been used for several properties since a wide range of values are expected based upon chemical composition of the mixture.

Coal tar pitch is the tar distillation residue produced during coking operations (NIOSH 1977). The grade of pitch thus produced is dependent on distillation conditions, including time and temperature. The fraction consists primarily of condensed ring aromatics, including 2–6 ring systems, with minor amounts of phenolic compounds and aromatic nitrogen bases. The number of constituents in coal tar pitch is estimated to be in the thousands (EPA 2015). A list of the components comprising the PAH fraction of coal tar pitch is shown in Table 4-8. Table 4-9 summarizes physical/chemical data for coal tar. Properties for this substance are similar or identical to those shown in Table 4-7 for coal tar creosote. Because these substances are all complex mixtures, physical-chemical properties such as log K_ow_ and Henry’s Law constants cannot be represented by a single value. Ranges of values for several physical-chemical properties for the chemical classes of coal tar creosote have been published (IPCS 2004). Because of the variability in feedstock and manufacturing processes, presentation of exact values for various properties presented in Tables 4-7 and 4-9 is not possible.

Table 4-8 Identity of PAH Components of Coal Tar Pitch^a^

Peak No. | Compound^b^
1 | Naphthalene
2 | Benzo[b]thiophene
3 | Quinoline
4 | 2-Methylnaphthalene
5 | 1-Methylnaphthalene
6 | Biphenyl
7 | 2-Ethylnaphthalene
8 | Dimethylnaphthalene
9 | Dimethylnaphthalene
10 | Dimethylnaphthalene
11 | Methylbiphenyl
12 | Acenaphthene
13 | Naphthonitrile or azaacenaphthylene
14 | Dibenzofuran
15 | Fluorene
16 | Methylacenaphthene
17 | Methylacenaphthene
18 | Methylacenaphthene
19 | Methyldibenzofuran
20 | Methyldibenzofuran
21 | 9,10-Dihydroanthracene
22 | 9,10-Dihydrophenanthrene
23 | Methylfluorene
24 | Methylfluorene
25 | Methylfluorene
26 | Methylfluorene
27 | 1,2,3,4-Tetrahydroanthracene
28 | Dibenzo[bd]thiophene
29 | Phenanthrene
30 | Anthracene
31 | Acridine
32 | Phenanthridine
33 | Carbazole
34 | Methylphenanthrene, -anthracene
35 | Methylphenanthrene, -anthracene
36 | Methylphenanthrene, -anthracene
37 | 4H-Cyclopenta[def]phenanthrene
38 | Methylphenanthrene, -anthracene
39 | Methylphenanthrene, -anthracene
40 | Methylcarbazole
41 | Methylcarbazole
42 | 2-Phenylnaphthalene
43 | Dihydropyrene or isomer
44 | Fluoranthene
45 | Azafluoranthene, -pyrene
46 | Phenanthro[4,5-bcd]thiophene
47 | Azafluoranthene, -pyrene
48 | Pyrene
49 | Benzonaphthofuran
50 | Benzacenaphthene or isomer
51 | Benzacenaphthene or isomer
52 | Benzonaphthofuran
53 | Benzonaphthofuran
54 | Benzo[lmn]phenanthridine
55 | Benzo[kl]xanthene
56 | Methylfluoranthene, -pyrene
57 | 4H-Benzo[def]carbazole
58 | Azafluoranthene, -pyrene
59 | Benzo[a]fluorene
60 | Methylfluoranthene, -pyrene
61 | Benzo[a]fluorene
62 | Benzo[c]fluorene or isomer
63 | Methylbenzacenaphthene or isomer
64 | Methylbenzonaphthofuran or isomer
65 | Methylpyrene or isomer
66 | Methylpyrene or isomer
67 | Methylbenzonaphthofuran or isomer
68 | Methylbenzonaphthofuran or isomer
69 | Methylazapyrene or isomer
70 | Methylbenzonaphthofuran or isomer
71 | Methylbenzofluorene
72 | Dihydrochrysene or isomer
73 | Dimethylfluoranthene, -pyrene
74 | Trimethylfluoranthene, -pyrene
75 | Dimethylfluoranthene, -pyrene
76 | Benzo[b]naphtho(2,1-d)thiophene
77 | Benzo[c]phenanthrene
78 | Benzo[ghi]fluoranthene
79 | Dimethylbenzonaphthofuran
80 | Benzo[b]naphtho[1,2-d]thiophene
81 | Dibenzoquinoline or isomer
82 | Tetrahydrochrysene or isomer
83 | Benzo[a]naphtho[2,3-d]thiophene
84 | Benz[a]anthracene
85 | Chrysene
86 | 11H-Benzo[a]carbazole
87 | Naphthacene
88 | Methylbenzonaphthothiophene
89 | Methylbenz[a]anthracene or isomer
90 | Tetramethylfluoranthene or isomer
91 | 7H-benzo[c]carbazole
92 | Methylbenz[a]anthracene or isomer
93 | Tetramethylfluoranthene or isomer
94 | 5H-benzo[b]carbazole
95 | Methylbenzophenanthridine or isomer
96 | Dimethylbenzo[cdf]carbazole
97 | Methylchrysene or isomer
98 | Methylchrysene or isomer
99 | Methylbenz[a]anthracene or isomer
100 | Dimethylbenz[a]anthracene or isomer
101 | Methylbenz[a]anthracene or isomer
102 | Dimethylbenz[a]anthracene or isomer
103 | 11H-Benz[bc]aceanthrylene or isomer
104 | Methylbenz[a]anthracene or isomer
105 | 4H-Cyclopenta[def]chrysene or isomer
106 | Methylbenz[a]anthracene or isomer
107 | Binaphthalene or isomer
108 | 4H-Cyclopenta[def]triphenylene or isomer
109 | Dimethylbenz[a]anthracene or isomer
110 | Methylbenz[a]anthracene or isomer
111 | Binaphthalene or isomer
112 | Dimethylbenz[a]anthracene or isomer
113 | Methylbenz[a]anthracene or isomer
114 | Binaphthalene or isomer
115 | Phenylphenanthrene or isomer
116 | Dihydrobenzofluoranthene or isomer
117 | Dimethylchrysene or isomer
118 | Dibenzophenanthridine or isomer
119 | Biquinoline
120 | Biquinoline
121 | Benzo[j]fluoranthene
122 | Dihydrobenzofluoranthene or isomer
123 | Benzo[b]fluoranthene
124 | Dihydrobenzofluoranthene or isomer
125 | Benzo[k]fluoranthene
126 | Dibenzonaphthofuran or isomer
127 | Dihydrobenzofluoranthene or isomer
128 | Dimethylchrysene or isomer
129 | Azabenzopyrene or isomer
130 | Dibenzonaphthofuran or isomer
131 | Benzophenanthrothiophene
132 | Azabenzopyrene or isomer
133 | Benzo[e]pyrene
134 | Dibenzonaphthofuran or isomer
135 | Benzo[a]pyrene
136 | Dibenzonaphthofuran or isomer
137 | Perylene
138 | Dibenzonaphthofuran or isomer
139 | Methylbenzofluoranthene or isomer
140 | Methylbenzofluoranthene or isomer
141 | Azabenzopyrene or isomer
142 | 4H-Naphtho[1,2,3,4-def]carbazole or isomer
143 | Methylbenzofluoranthene or isomer
144 | Dibenzofluorene or isomer
145 | Dihydroindenopyrene or isomer
146 | Dibenzofluorene or isomer
147 | Dibenzofluorene or isomer
148 | Methylbenzopyrene or isomer
149 | Dibenzo[cg]phenanthrene or isomer
150 | Dimethyldibenzonaphthofuran or isomer
151 | Methylbenzopyrene or isomer
152 | Methylbenzopyrene or isomer
153 | 11H-Cyclopenta[ghi]perylene or isomer
154 | Methylbenzopyrene or isomer
155 | Dimethylbenzopyrene or isomer
156 | Methylbenzopyrene or isomer
157 | Methylbenzopyrene or isomer
158 | Dimethylbenzopyrene or isomer
159 | 11H-Indeno[2,1,7-cde]pyrene or isomer
160 | Dimethylbenzopyrene or isomer
161 | Dinaphthothiophene
162 | Dimethylbenzopyrene or isomer
163 | Dibenzophenanthridine or isomer
164 | Dibenzonaphthothiophene
165 | Dimethylbenzopyrene or isomer
166 | Dibenzocarbazole
167 | Dimethylbenzopyrene or isomer
168 | Dibenzo[bg]phenanthrene or isomer
169 | Benzo[g]chrysene or isomer
170 | Dinaphthothiophene
171 | Dimethylbenzofluoranthene or isomer
172 | Dibenzoacridine or isomer
173 | Dinaphthothiophene
174 | Dinaphthothiophene
175 | Benzo[c]chrysene or isomer
176 | Dibenzocarbazole
177 | Dimethylbenzofluoranthene or isomer
178 | Dibenz[aj]anthracene
179 | Indenopyrene or isomer
180 | Dimethyldibenzonaphthofuran
181 | Methyldibenzophenanthrene, anthracene
182 | Indenopyrene or isomer
183 | Methylbenzophenanthrothiophene
184 | Dibenz[ac]anthracene
185 | Methyldibenzophenanthrene, anthracene
186 | Dimethylbenzofluoranthene or isomer
187 | Dibenz[ah]anthracene
188 | Trimethylbenzofluoranthene or isomer
189 | Dimethyldibenzophenanthrene, anthracene
190 | Benzo[b]chrysene
191 | Dimethyldibenzonaphthofuran
192 | Picene
193 | Dimethylbenzopyrene or isomer
194 | Dimethyldibenzonaphthofuran
195 | Benzo[ghi]perylene
196 | Benzo[a]naphthacene or pentacene
197 | Dimethyldibenzonaphthofuran
198 | Anthanthrene
199 | Methyl indenopyrene or isomer

a The amount and specific PAHs in coal tar pitch will vary as the constituents of the complex mixture are not constant.

b PAHs identified in GC-MS elution peaks from a coal tar sample. Some PAHs will elute in multiple peaks.

GC-MS = gas chromatography-mass spectrometry; PAH = polycyclic aromatic hydrocarbon

Source: Guillén et al. 1992

Table 4-9 Physical and Chemical Properties of Coal Tar^a^

Property | Information | Reference
Molecular weight | Not applicable^b^
Color | Almost black, thick liquid, or semisolid | Budavari 1989
Physical state | Semisolid | Weiss 1986
Melting point | No data
Boiling point | No data
Density at 20°C | Not applicable
Odor | Naphthalene-like | Osol 1980
Odor threshold:
Water | No data
Air | No data
Solubility:
Water | Slightly soluble | Budavari 1989
Organic solvents | Mostly dissolves in benzene; partially dissolves in alcohol, ether, chloroform, acetone, and petroleum ether | Budavari 1989
Partition coefficients:
Log K_ow_ | Not applicable
Log K_oc_ | Not applicable
Vapor pressure at 20°C | No data
Henry’s law constant at 25°C | Not applicable
Autoignition temperature | No data
Flashpoint | No data
Flammability limits | No data
Conversion factors | Not applicable
Explosive limits | No data

a Physical-chemical properties will vary by sample as the constituents of the complex mixture are not constant.

b Not applicable has been used for several properties since a wide range of values are expected based upon chemical composition of the mixture.