# APPENDIX C FRAMEWORK FOR ATSDR’S SYSTEMATIC REVIEW OF HEALTH EFFECTS DATA FOR CREOSOTE

To increase the transparency of ATSDR’s process of identifying, evaluating, synthesizing, and interpreting the scientific evidence on the health effects associated with exposure to creosote, ATSDR utilized a slight modification of NTP’s Office of Health Assessment and Translation (OHAT) systematic review methodology (NTP 2013, 2015; Rooney et al. 2014). ATSDR’s framework is an eight-step process for systematic review with the goal of identifying the potential health hazards of exposure to creosote:

- Step 1. Problem Formulation
- Step 2. Literature Search and Screen for Health Effects Studies
- Step 3. Extract Data from Health Effects Studies
- Step 4. Identify Potential Health Effect Outcomes of Concern
- Step 5. Assess the Risk of Bias for Individual Studies
- Step 6. Rate the Confidence in the Body of Evidence for Each Relevant Outcome
- Step 7. Translate Confidence Rating into Level of Evidence of Health Effects
- Step 8. Integrate Evidence to Develop Hazard Identification Conclusions

## C.1 PROBLEM FORMULATION

The objective of the toxicological profile and this systematic review was to identify the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to creosote. The inclusion criteria used to identify relevant studies examining the health effects of creosote are presented in Table C-1.

Data from human and laboratory animal studies were considered relevant for addressing this objective. Human studies were divided into two broad categories: observational epidemiology studies and controlled exposure studies. The observational epidemiology studies were further divided: cohort studies (retrospective and prospective studies), population studies (with individual data or aggregate data), and case-control studies.

Table C-1 Inclusion Criteria for Identifying Health Effects Studies

Species; Human; Laboratory mammals
Route of exposure; Inhalation; Oral; Dermal (or ocular); Parenteral (these studies will be considered supporting data)
Health outcome; Death; Systemic effects; Body weight effects; Respiratory effects; Cardiovascular effects; Gastrointestinal effects; Hematological effects; Musculoskeletal effects; Hepatic effects; Renal effects; Dermal effects; Ocular effects; Endocrine effects; Immunological effects; Neurological effects; Reproductive effects; Developmental effects; Other noncancer effects; Cancer

## C.2 LITERATURE SEARCH AND SCREEN FOR HEALTH EFFECTS STUDIES

As noted in Appendix B, the current literature search was intended to update the Draft Toxicological Profile for Creosote released for public comment in 2023; thus, the literature search was restricted to studies published between November 2000 and November 2023. See Appendix B for the databases searched and the search strategy.

A total of 377 records relevant to all sections of the toxicological profile were identified (after duplicate removal).

### C.2.1 Literature Screening

As described in Appendix B, a two-step process was used to screen the literature search to identify relevant studies examining the health effects of creosote.

Title and Abstract Screen. In the Title and Abstract Screen step, 377 records were reviewed; there were no new documents that were considered to meet the health effects inclusion criteria in Table C-1 and were moved to the next step in the process.

Full Text Screen. In the second step in the literature screening process for the systematic review, a full text review of 155 health effect documents (documents cited in older versions of the profile) was performed. From those 155 documents, 193 studies were considered for inclusion in the qualitative review.

## C.3 EXTRACT DATA FROM HEALTH EFFECTS STUDIES

Relevant data extracted from the individual studies selected for inclusion in the systematic review were collected in customized data forms. A summary of the type of data extracted from each study is presented in Table C-2. For references that included more than one experiment or species, data extraction records were created for each experiment or species.

Table C-2 Data Extracted from Individual Studies

Citation
Chemical form
Route of exposure (e.g., inhalation, oral, dermal)
Specific route (e.g., gavage in oil, drinking water)
Species
Strain
Exposure duration category (e.g., acute, intermediate, chronic)
Exposure duration
Frequency of exposure (e.g., 6 hours/day, 5 days/week)
Exposure length
Number of animals or subjects per sex per group
Dose/exposure levels
Parameters monitored
Description of the study design and method
Summary of calculations used to estimate doses (if applicable)
Summary of the study results
Reviewer’s comments on the study
Outcome summary (one entry for each examined outcome)
No-observed-adverse-effect level (NOAEL) value
Lowest-observed-adverse-effect level (LOAEL) value
Effect observed at the LOAEL value

A summary of the extracted data for each study is presented in the Supplemental Document for Creosote and overviews of the results of the inhalation, oral, and dermal exposure studies are presented in Sections 2.2–2.18 of the profile and in the Levels Significant Exposures tables in Section 2.1 of the profile (Tables 2-1, 2-2, 2-3, and 2-4, respectively).

## C.4 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN

Overviews of the potential health effect outcomes for coal tar products and wood creosotes identified in human and animal studies are presented in Tables C-3, C-4, C-5, and C-6 respectively. The available human studies are focused mainly on mortality and cancer following occupational exposure. Additional studies have reported respiratory, dermal, and hepatic effects. Animal studies have examined a number of endpoints following inhalation, oral, or dermal exposure, including cancer, and have reported body weight, respiratory, hematological, hepatic, reproductive, and developmental effects.

Studies were not carried through the systematic review process due to the complicated nature of creosote products. Coal tars products are complex mixtures of PAHs, phenols, heterocyclic oxygen, sulfur, and nitrogen compounds. Wood creosotes are derived from beechwood and the resin from leaves of the creosote bush. Beechwood creosote consists mainly of phenol, cresols, guaiacol, xylenol, and creosol, while creosote bush resin consists of phenolic (e.g., flavonoids and nordihydroguaiaretic acid), neutral (e.g., waxes), basic (e.g., alkaloids), and acidic (e.g., phenolic acids) compounds.

When evaluating health effect data for creosote, it is important to consider the composition of a particular creosote mixture. Wood creosote and coal tar product mixtures have highly variable compositions and the individual components do not always share the same mode of action. The mixtures’ composition is dependent on the sources and preparation parameters of coal tar creosote and, as a result, the creosote components are rarely consistent in their type and concentration. Thus, comparisons across studies are problematic, as toxicological evaluations of one creosote sample, for instance, is most likely inadequate for extrapolation to other creosote samples, unless their compositions are similar. This is demonstrated by inconsistent results observed in studies evaluating the same class of compounds; a single LOAEL value may not be representative for a class of compounds.

Therefore, ATSDR elected not to take the identified studies through the systematic review process for creosote, including wood creosote, coal tar creosote, coal tar, coal tar pitch, and coal tar pitch volatiles.

Table C-3 Overview of the Health Outcomes for Creosote (Coal Tar Products) Evaluated in Human Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other Noncancer | Caner
Inhalation studies
Cohort | | 2 | | | | | | | 2 | 3 | | | | | | | 61
Cohort | | 2 | | | | | | | 2 | 3 | | | | | | | 41
Case control | | | | | | | | | | | | | | | | | 8
Case control | | | | | | | | | | | | | | | | | 4
Population | | | | | | | | | | | | | | | | | 2
Population | | | | | | | | | | | | | | | | | 2
Case series | | 1 | | | | | | 1 | 3 | 1 | | | 2
Case series | | 1 | | | | | | 1 | 3 | 1 | | | 2
Cross sectional | | 5 | 1 | | 3 | | 2 | 1 | 4 | 1 | | | 1 | 2 | 1 | | 3
Cross sectional | | 5 | 1 | | 3 | | 0 | 1 | 4 | 1 | | | 1 | 0 | 0 | | 2
Oral studies
Cohort
Case control
Population
Case series | | | | 1 | | | 1 | 1
Case series | | | | 1 | | | 1 | 1
Dermal studies
Cohort | | | | | | | | | | | | | | 1
Cohort | | | | | | | | | | | | | | 0
Case control
Population
Case series | | | | | | | | | 3 | | | 1
Case series | | | | | | | | | 3 | | | 1
Clinical trial | | | | | | | 1 | 1 | 2 | | | 1
Clinical trial | | | | | | | 0 | 0 | 2 | | | 1

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

Table C-4 Overview of the Health Outcomes for Creosote (Coal Tar Products) Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Caner
Inhalation studies
Acute-duration | 3 | 1 | | | | | 1 | 1 | | | 1 | 1 | 2 | | 1
Acute-duration | 1 | 0 | | | | | 0 | 0 | | | 0 | 0 | 2 | | 1
Intermediate-duration | 7 | 5 | 4 | 3 | 5 | | 5 | 4 | | 2 | 3 | 3 | 3 | 3 | | | 3
Intermediate-duration | 4 | 5 | 1 | 2 | 5 | | 4 | 2 | | 0 | 0 | 2 | 0 | 3 | | | 3
Chronic-duration | 2 | | | | | | | | | | | | | | | | 2
Chronic-duration | 1 | | | | | | | | | | | | | | | | 2
Oral studies
Acute-duration | 11 | 1 | | | | | 6 | 4 | | | 2 | 1 | 2 | 5 | 5
Acute-duration | 4 | 0 | | | | | 0 | 2 | | | 0 | 0 | 2 | 0 | 5
Intermediate-duration | 5 | 2 | 2 | 4 | 2 | | 2 | 2 | | | 2 | 2 | | 2 | | | 1
Intermediate-duration | 0 | 0 | 0 | 2 | 0 | | 0 | 0 | | | 0 | 0 | | 0 | | | 1
Chronic-duration | 2 | 2 | | | | | 2 | 2 | | | | | | | | | 2
Chronic-duration | 0 | 0 | | | | | 2 | 0 | | | | | | | | | 2
Dermal studies
Acute-duration | 4 | | | | | | 2 | 2 | 2 | 3 | 2 | 2 | 3 | 2 | 2
Acute-duration | 2 | | | | | | 0 | 0 | 2 | 3 | 0 | 0 | 0 | 0 | 2
Intermediate-duration | 4 | | | | 1 | | | | 1 | 1 | | | | | | | 15
Intermediate-duration | 0 | | | | 0 | | | | 0 | 0 | | | | | | | 13
Chronic-duration | 1 | | | | | | | | 1 | | | 1 | | | | | 7
Chronic-duration | 0 | | | | | | | | 1 | | | 1 | | | | | 7

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

a Number of studies examining endpoint includes study evaluating histopathology, but not evaluating function.

Table C-5 Overview of the Health Outcomes for Creosote (Wood Creosotes) Evaluated in Human Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other Noncancer | Caner
Inhalation studies
Cohort
Case control
Population
Case series
Oral studies
Cohort
Case control
Population
Case series | | | | | 1 | | 4 | 2 | 1 | | | | 1
Case series | | | | | 1 | | 4 | 1 | 1 | | | | 1
Clinical trial | | | 2 | | | | 1 | | | | | | 2
Clinical trial | | | 0 | | | | 0 | | | | | | 2
Dermal studies
Cohort
Case control
Population
Case series | | | | | | | | | 2 | | | 2
Case series | | | | | | | | | 2 | | | 2
Clinical trial | | | | | | | | 1 | 1
Clinical trial | | | | | | | | 0 | 0

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

Table C-6 Overview of the Health Outcomes for Creosote (Wood Creosotes) Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Caner
Inhalation studies
Acute-duration
Intermediate-duration
Chronic-duration
Oral studies
Acute-duration | 2 | | | | | | 2 | | | | 2 | | 2
Acute-duration | 0 | | | | | | 0 | | | | 0 | | 2
Intermediate-duration | 3 | 2 | 2 | | 3 | | 3 | 3 | | | 2 | 2 | 2 | 2
Intermediate-duration | 0 | 0 | 0 | | 0 | | 1 | 0 | | | 0 | 0 | 0 | 0
Chronic-duration | 3 | 3 | 3 | | 3 | | 3 | 3 | | | 3 | 3 | 2 | 3 | | | 3
Chronic-duration | 2 | 1 | 1 | | 0 | | 1 | 1 | | | 0 | 0 | 0 | 0 | | | 0
Dermal studies
Acute-duration
Intermediate-duration
Chronic-duration

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

a Number of studies examining endpoint includes study evaluating histopathology, but not evaluating function.