# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR CREOSOTE

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to creosote.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen were conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for creosote. ATSDR primarily focused on peer-reviewed articles without language restrictions. Foreign language studies are reviewed based on available English-language abstracts and/or tables (or summaries in regulatory assessments, such as International Agency for Research on Cancer [IARC] documents). If the study appears critical for hazard identification or MRL derivation, translation into English is requested. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of creosote have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of creosote are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Health Effects; Species; Human; Laboratory mammals; Route of exposure; Inhalation; Oral; Dermal (or ocular); Parenteral (these studies will be considered supporting data); Health outcome; Death; Systemic effects; Body weight effects; Respiratory effects; Cardiovascular effects; Gastrointestinal effects; Hematological effects; Musculoskeletal effects; Hepatic effects; Renal effects; Dermal effects; Ocular effects; Endocrine effects; Immunological effects; Neurological effects; Reproductive effects; Developmental effects; Other noncancer effects; Cancer
Toxicokinetics; Absorption; Distribution; Metabolism; Excretion; PBPK models; Biomarkers; Biomarkers of exposure; Biomarkers of effect; Interactions with other chemicals; Potential for human exposure; Releases to the environment; Air; Water; Soil; Environmental fate; Transport and partitioning; Transformation and degradation; Environmental monitoring; Air; Water; Sediment and soil; Other media; Biomonitoring; General populations; Occupation populations

### B.1.1 Literature Search

The current literature search was intended to update the Draft Toxicological Profile for Creosote released for public comment in 2023; thus, the literature search was restricted to studies published between November 2020 and November 2023. The following main databases were searched in November 2023:

- PubMed
- National Technical Reports Library (NTRL)
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for creosote. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to creosote were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
11/2023 | ((“Creosote”[mh] OR “Coal Tar”[mh] OR 8021-39-4[rn] OR 8007-45-2[rn] OR 8001-58-9[rn] OR 65996-93-2[rn]) AND 2020/11/01:3000[mhda]) OR ((“alquitran, hulla”[tw] OR “AquaTar”[tw] OR “Brick oil”[tw] OR “Carbo-cort”[tw] OR “Coal tar”[tw] OR “Coal tars”[tw] OR “Coke-oven tar”[tw] OR “Coking tar”[tw] OR “Creosote”[tw] OR “Creosotes”[tw] OR “Creosotum”[tw] OR “Fototar”[tw] OR “Impervotar”[tw] OR “Ionil-T”[tw] OR “KC 261”[tw] OR “KOHLENTEER”[tw] OR “Lavatar”[tw] OR “Liquid pitch oil”[tw] OR “Naphthalene oil”[tw] OR “Oil pitch”[tw] OR “Particulate polycyclic aromatic hydrocarbons”[tw] OR “Picis carbonis”[tw] OR “Pitch, coal tar”[tw] OR “Pixalbol”[tw] OR “Polytar bath”[tw] OR “Preserv-O-sote”[tw] OR “Sakresote 100”[tw] OR “STEINKOHLENTEER”[tw] OR “TAR LIQUID”[tw] OR “Tar, coal”[tw] OR “Tar, coking”[tw] OR “Tarcron 180”[tw] OR “Tarcron 180L”[tw] OR “Tarcron 230”[tw] OR “Teer, Kohlen-”[tw] OR “Vanseb-T”[tw] OR “Wash oil”[tw] OR “Zetar”[tw] OR (“PPAH”[tw] AND (particl* OR particul* OR hydrocarbon*)) OR “tar distillates”[tw] OR “Tar oil”[tw] OR “Tar oils”[tw] OR “Wood tar”[tw]) AND (2020/11/01:3000[edat] OR 2020/11/01:3000[crdat]))
NTRL
11/2023 | Date Published 2020 to 2023; Searched in Title or Keyword; “alquitran, hulla” OR “AquaTar” OR “Brick oil” OR “Carbo-cort” OR “Coal tar” OR “Coal tars” OR “Coke-oven tar” OR “Coking tar” OR “Creosote” OR “Creosotes” OR “Creosotum” OR “Fototar” OR “Impervotar” OR “Ionil-T” OR “KC 261” OR “KOHLENTEER” OR “Lavatar” OR “Liquid pitch oil” OR “Naphthalene oil” OR “Oil pitch” OR “Particulate polycyclic aromatic hydrocarbons” OR “Picis carbonis” OR “Pitch, coal tar” OR “Pixalbol” OR “Polytar bath” OR “Preserv-O-sote” OR “Sakresote 100” OR “STEINKOHLENTEER” OR “TAR LIQUID” OR “Tar, coal” OR “Tar, coking” OR “Tarcron 180” OR “Tarcron 180L” OR “Tarcron 230” OR “Teer, Kohlen-” OR “Vanseb-T” OR “Wash oil” OR “Zetar” OR “PPAH” OR “tar distillates” OR “Tar oil” OR “Tar oils” OR “Wood tar”
Toxcenter
11/2023 | FILE ‘TOXCENTER’ ENTERED AT 13:52:12 ON 17 NOV 2023; CHARGED TO COST=EH038.09.02.LB.05; L1 1340 SEA FILE=TOXCENTER 8021-39-4 OR 8007-45-2 OR 8001-58-9 OR 65996-93-2; L2 8855 SEA FILE=TOXCENTER “ALQUITRAN, HULLA” OR “AQUATAR” OR “BRICK; OIL” OR “CARBO-CORT” OR “COAL TAR” OR “COAL TARS” OR “COKE-OVEN; TAR” OR “COKING TAR” OR “CREOSOTE” OR “CREOSOTES” OR “CREOSOTU; M” OR “FOTOTAR” OR “IMPERVOTAR” OR “IONIL-T” OR “KC 261” OR “KOHLENTEER” OR “LAVATAR”; L3 325 SEA FILE=TOXCENTER “LIQUID PITCH OIL” OR “NAPHTHALENE OIL” OR; “OIL PITCH” OR “PARTICULATE POLYCYCLIC AROMATIC HYDROCARBONS”; OR “PICIS CARBONIS” OR “PITCH, COAL TAR” OR “PIXALBOL” OR “POLYTAR BATH” OR “PRESERV-O-SOTE” OR “SAKRESOTE 100” OR “STEINKOHLENTEER”; L4 237 SEA FILE=TOXCENTER “TAR LIQUID” OR “TAR, COAL” OR “TAR, COKING” OR “TARCRON 180” OR “TARCRON 180L” OR “TARCRON 230” OR “TEER, KOHLEN-” OR “VANSEB-T” OR “WASH OIL” OR “ZETAR”; L5 81 SEA FILE=TOXCENTER PPAH AND (PARTICL? OR PARTICUL? OR HYDROCARB ON?); L6 1069 SEA FILE=TOXCENTER “TAR OIL” OR “TAR OILS” OR “WOOD TAR” OR “TAR DISTILLATES”; L7 10202 SEA FILE=TOXCENTER L1 OR L2 OR L3 OR L4 OR L5 OR L6; L8 8288 SEA FILE=TOXCENTER L7 NOT PATENT/DT; L9 411 SEA FILE=TOXCENTER L8 AND ED>20201031; ACTIVATE TOXQUERY/Q; ---------; L10 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L11 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L12 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L13 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L14 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L15 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L16 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L17 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L18 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L19 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L20 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L21 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L22 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L23 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L24 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L25 QUE (ENDOCRIN? AND DISRUPT?); L26 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L27 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L28 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L29 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L30 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L31 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L32 QUE (NEPHROTOX? OR HEPATOTOX?); L33 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L34 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L35 QUE L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30 OR L31 OR L32 OR L33 OR L34; L36 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L37 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L38 QUE L35 OR L36 OR L37; L39 QUE (NONHUMAN MAMMALS)/ORGN; L40 QUE L38 OR L39; L41 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L42 QUE L40 OR L41; ---------; L43 234 SEA FILE=TOXCENTER L9 AND L42; L44 70 SEA FILE=TOXCENTER L43 AND MEDLINE/FS; L45 164 SEA FILE=TOXCENTER L43 NOT MEDLINE/FS; L46 184 DUP REM L44 L45 (50 DUPLICATES REMOVED); L*** DEL 70 S L43 AND MEDLINE/FS; L*** DEL 70 S L43 AND MEDLINE/FS; L47 70 SEA FILE=TOXCENTER L46; L*** DEL 164 S L43 NOT MEDLINE/FS; L*** DEL 164 S L43 NOT MEDLINE/FS; L48 114 SEA FILE=TOXCENTER L46; L49 114 SEA FILE=TOXCENTER (L47 OR L48) NOT MEDLINE/FS; D SCAN L49

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via ChemView
11/2023 | Compounds searched: 8021-39-4; 8007-45-2; 8001-58-9; 65996-93-2
NTP
11/2023 | Limited to 2020-present or ROC/Testing Status/CEBS; “Creosote” “Creosotes” “Coal tar” “Coal tars”; “8021-39-4” “8007-45-2” “8001-58-9” “65996-93-2”; “alquitran, hulla” “AquaTar” “AWPA 1” “Brick oil”; “Carbo-cort” “Coke-oven tar” “Coking tar” “Creosotum”; “Fototar” “Impervotar” “Ionil-T” “KC 261”; “KOHLENTEER” “Lavatar” “Liquid pitch oil” “Naphthalene oil”; “Oil pitch” “Particulate polycyclic aromatic hydrocarbons” “Picis carbonis” “Pitch, coal tar”; “Pixalbol” “Polytar bath” “Preserv-O-sote” “Sakresote 100”; “STEINKOHLENTEER” “TAR LIQUID” “Tar, coal” “Tar, coking”; “Tarcron 180” “Tarcron 180L” “Tarcron 230” “Teer, Kohlen-”; “Vanseb-T” “Wash oil” “Zetar”; “PPAH”; “Tar oil” “Tar oils” “Wood tar” “tar distillates”
Regulations.gov
11/2023 | Limited to posted date 11/1/2020-present; Dockets/Notices; “8021-39-4”; “8007-45-2”; “8001-58-9”; “65996-93-2”; creosote; “coal tar”
NPIRS
11/2023 | Limited to submission date 01/01/2020-11/17/2023; Active Ingredient: Creosote, wood (CAS #: 8021-39-4) (PC Code: 25002), Coal tar (CAS #: 8007-45-2) (PC Code: 22003), Coal tar creosote (CAS #: 8001-58-9) (PC Code: 25004), Coal Tar Pitch >351 deg.C (AWPI) (CAS #: 65996-93-2) (PC Code: 128939)
NIH RePORTER
02/2024 | Search Criteria:; Fiscal Year: Active Projects; Text Search: “alquitran, hulla” OR “AquaTar” OR “Brick oil” OR “Carbo-cort” OR “Coal tar” OR “Coal tars” OR “Coke-oven tar” OR “Coking tar” OR “Creosote” OR “Creosotes” OR “Creosotum” OR “Fototar” OR “Impervotar” OR “Ionil-T” OR “KC 261” OR “KOHLENTEER” OR “Lavatar” OR “Liquid pitch oil” OR “Naphthalene oil” OR “Oil pitch” OR “Particulate polycyclic aromatic hydrocarbons” OR “Picis carbonis” OR “Pitch, coal tar” OR “Pixalbol” OR “Polytar bath” OR “Preserv-O-sote” OR “Sakresote 100” OR “STEINKOHLENTEER” OR “TAR LIQUID” OR “Tar, coal” OR “Tar, coking” OR “Tarcron 180” OR “Tarcron 180L” OR “Tarcron 230” OR “Teer, Kohlen-” OR “Vanseb-T” OR “Wash oil” OR “Zetar” OR “PPAH” OR “tar distillates” OR “Tar oil” OR “Tar oils” OR “Wood tar” (advanced) Limit to: Project Title, Project Terms, Project Abstracts
Other | Identified throughout the assessment process

The 2023 results were:

- Number of records identified from PubMed, TOXLINE, and TOXCENTER (after duplicate removal): 339
- Number of records identified from other strategies: 38
- Total number of records to undergo literature screening: 377

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on creosote:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 377
- Number of studies considered relevant and moved to the next step: 49

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 49
- Number of studies cited in the pre-public draft of the toxicological profile: 543
- Total number of studies cited in the profile: 493

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 November 2023 Literature Search Results and Screen for Creosote