# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs for creosote, including wood creosote, coal tar creosote, coal tar, coal tar pitch, and coal tar pitch volatiles, cannot be determined because available data are insufficient for exposures of all durations (acute, intermediate, chronic) via any route (inhalation, oral, dermal). Creosote is a complex mixture originating from high temperature treatments of coal tar and beechwood or occurring in the resin of the creosote bush. About 300 chemicals have been identified in coal tar creosote, and there could be as many as 10,000 other chemicals present in the mixture. Creosote derived from plants is composed of various organic compounds including phenols, cresols, and guaiacol. Additionally, wood creosote and coal tar product mixtures have highly variable compositions and the individual components do not always share the same mode of action. The mixtures’ composition is dependent on the sources and preparation parameters of coal tar creosote and, as a result, the creosote components are rarely consistent in their type and concentration. Hence, toxicological evaluations of one creosote sample, for instance, is most likely inadequate for extrapolation to other creosote samples, unless their compositions are similar.

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. LOAELs for serious health effects (such as irreparable damage to the liver or kidneys, or serious birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S106-5, Atlanta, Georgia 30329-4027.

This profile addresses the toxicological database for several creosote mixtures: wood creosote, coal tar creosote, coal tar, coal tar pitch, and coal tar pitch volatiles. These mixtures are composed of many individual compounds of varying physical and chemical characteristics and differ from each other with respect to their composition.

Coal tars are byproducts of the carbonization of coal to produce coke or natural gas. They are complex combinations of PAHs, phenols, heterocyclic oxygen, sulfur, and nitrogen compounds. Coal tar creosotes are distillation products of coal tar. At least 75% of the coal tar creosote mixture is PAHs. Unlike the coal tars and coal tar creosotes, coal tar pitch is a residue produced during the distillation of coal tar. The pitch contains PAHs and their methyl and polymethyl derivatives, as well as heteronuclear compounds (AWPA 1988). Volatile components of the coal tar pitch can be given off during operations involving coal tar pitch, including transporting, and in the coke, aluminum, and steel industries (Bender et al. 1988; Mazumdar et al. 1975; NIOSH 1983; Rønneberg 1995; Rønneberg and Anderson 1995). Coal tar creosote, coal tar, and coal tar products are used as wood preservatives, herbicides, fungicides, insecticides, and disinfectants (EPA 1981a, 1984).

Wood creosotes are derived from beechwood (Fagus, referred as beechwood creosote) and the resin from leaves of the creosote bush (Larrea, referred as creosote bush resin). Wood creosote consists mainly of phenol, cresols, guaiacol, xylenol, and creosol. Creosote bush resin consists of phenolic (e.g., flavonoids and nordihydroguaiaretic acid), neutral (e.g., waxes), basic (e.g., alkaloids), and acidic (e.g., phenolic acids) compounds. The phenolic portion comprises 83–91% of the total resin. Nordihydroguaiaretic acid accounts for 5–10% of the dry weight of the leaves (Leonforte 1986).

Although wood creosote and coal tar creosote have some components in common, such as phenols, the differences in composition are pronounced enough to assume with reasonable certainty that they will have different toxicological properties. For the purposes of this profile, the creosote mixtures have been grouped into coal tar products (coal tar creosote, coal tar, coal tar pitch, and coal tar pitch volatiles) and wood creosotes (creosote bush and beechwood creosote).

Rationale for Not Deriving an MRL: When evaluating health effect data for creosote, it is important to consider that the composition of a particular creosote mixture, although referred to by specific name (e.g., wood creosote or coal tar creosote), is not consistent because the components and properties of the mixture depend on the temperature of the destructive distillation (carbonization) and on the nature of the carbon-containing material used as a feedstock for combustion. Creosote is a complex mixture originating from high temperature treatments of coal tar and beechwood or occurring in the resin of the creosote bush. About 300 chemicals have been identified in coal tar creosote, and there could be as many as 10,000 other chemicals present in the mixture. Creosote derived from plants is composed of various organic compounds including phenols, cresols, and guaiacol. Additionally, wood creosote and coal tar product mixtures have highly variable compositions and the individual components do not always share the same mode of action. The mixtures’ composition is dependent on the sources and preparation parameters of coal tar creosote and, as a result, the creosote components are rarely consistent in their type and concentration. Thus, comparisons across studies are problematic, as toxicological evaluations of one creosote sample, for instance, is most likely inadequate for extrapolation to other creosote samples, unless their compositions are similar. This is demonstrated by inconsistent results observed in studies evaluating the same class of compounds; a single LOAEL value may not be representative for a class of compounds. Thus, derivation of an MRL based on single study or group of studies may not be protective for other exposures. Therefore, ATSDR elected not to derive MRLs for creosote, including wood creosote, coal tar creosote, coal tar, coal tar pitch, and coal tar pitch volatiles.