# CHAPTER 8 REFERENCES

Aaseth J, Skalny AV, Roos PM, 2021. Copper, iron, selenium and lipo-glycemic dysmetabolism in Alzheimer's disease. Int J Mol Sci 22(17):9461. 10.3390/ijms22179461.34502369
Abdel-Baky ES. 2019. Effects of copper sulphate supplementation on some physiological parameters in male albino rats. Egypt Acad J Biol Sci B Zool 11(2):137–145. 10.21608/eajbsz.2019.51037.
Abe M, Usuda K, Hayashi S, 2008. Carcinogenic risk of copper gluconate evaluated by a rat medium-term liver carcinogenicity bioassay protocol. Arch Toxicol 82(8):563–571. 10.1007/s00204-008-0294-x.18350280
Acevedo K, Masaldan S, Opazo CM, 2019. Redox active metals in neurodegenerative diseases. J Biol Inorg Chem 24(8):1141–1157. 10.1007/s00775-019-01731-9.31650248
Adams W, Blust R, Dwyer R, 2020. Bioavailability assessment of metals in freshwater environments: A historical review. Environ Toxicol Chem 39(1):48–59. 10.1002/etc.4558.31880839
Adele BO, Eddie-Anunobi OF, Adewoye EO. 2023. Oral iron supplementation ameliorated alterations in iron uptake and utilization in copper-toxic female Wistar rats. JBRA Assist Reprod 27(3):474–481. 10.5935/1518-0557.20230014.37294699
Adeleke PA, Ajayi AM, Ben-Azu B, 2023. Involvement of oxidative stress and pro-inflammatory cytokines in copper sulfate-induced depression-like disorders and abnormal neuronal morphology in mice. Naunyn Schmiedebergs Arch Pharmacol 396:3123–3133. 10.1007/s00210-023-02519-0.37154924
Adrianto LR, Pfister S, Hellweg S. 2022. Regionalized life cycle inventories of global sulfidic copper tailings. Environ Sci Technol 56(7):4553–4564. 10.1021/acs.est.1c01786.35294189
Agarwal K, Sharma A, Talukder G. 1990. Clastogenic effects of copper sulfate on the bone marrow chromosomes of mice in vivo. Mutat Res 243(1):1–6. 10.1016/0165-7992(90)90115-z.2300079
Agilent Technologies. 2012. Handbook of hyphenated ICP-MS applications. 2^nd^ edition. Agilent Technologies, Inc. https://www.ohsu.edu/sites/default/files/2018-08/Handbook-of-Hyphenated-ICP-MS-Applications.pdf. September 10, 2021.
Ahasan HA, Chowdhury MA, Azhar MA, 1994. Copper sulphate poisoning. Trop Doct 24(2):52–53. 10.1177/004947559402400203.8009613
Ajeel MA, Ajeel AA, Nejres AM, 2021. Assessment of heavy metals and related impacts on antioxidants and physiological parameters in oil refinery workers in Iraq. J Health Pollut 11(31):210907. 10.5696/2156-9614-11.31.210907.34434599
Akintonwa A, Mabadeje AFB, Odutola TA. 1989. Fatal poisonings by copper sulfate ingested from "spiritual water". Vet Hum Toxicol 31(5):453–454.2603365
Akinwande KS, Olateru-Olagbegi O, Okwor CJ, 2021. Prolonged blood coagulation time among occupationally exposed automobile technicians in Abeokuta, Nigeria. Toxicol Ind Health 37(9):528–534. 10.1177/07482337211030425.34388958
Alarifi S, Ali D, Verma A, 2013. Cytotoxicity and genotoxicity of copper oxide nanoparticles in human skin keratinocytes cells. Int J Toxicol 32(4):296–307. 10.1177/1091581813487563.23667135
Alharbi B, Fadda L, Ali HM. 2019. Evaluation of the renoprotective effect of nano turmeric against toxic dose of copper sulfate: Role of vascular cell adhesion molecule-1, kidney injury molecule-1, and signal transducer and activator of transcription 3 protein expressions. J Biochem Mol Toxicol 33(2):e22243. 10.1002/jbt.22243.30431687
Alhusaini A, Hasan IH, Aldowsari N, 2018a. Prophylactic administration of nanocurcumin abates the incidence of liver toxicity induced by an overdose of copper sulfate: Role of CYP4502E1, NF-kappaB and bax expressions. Dose Response 16(4):1559325818816284. 10.1177/1559325818816284.30622449
Alhusaini A, Fadda L, Hassan I, 2018b. Liposomal curcumin attenuates the incidence of oxidative stress, inflammation, and DNA damage induced by copper sulfate in rat liver. Dose Response 16(3):1559325818790869. 10.1177/1559325818790869.30116168
Ali SA, Bommaraju S, Patwa J, 2023. Melatonin attenuates extracellular matrix accumulation and cardiac injury manifested by copper. Biol Trace Elem Res 201(9):4456–4471. 10.1007/s12011-022-03509-8.36449149
Allen SK, Allen JM, Lucas S. 1996. Dissolved metal concentrations in surface waters from west-central Indiana contaminated with acidic mine drainage. Bull Environ Contam Toxicol 56(2):240–243. 10.1007/s001289900036.8720095
Allen-Gil SM, Gubala CP, Landers DH, 1997. Heavy metal accumulation in sediment and freshwater fish in US Arctic lakes. Environ Toxicol Chem 16(4):733–741. 10.1002/etc.5620160418.
Al-Musawi MMS, Al-Shmgani H, Al-Bairuty GA. 2022. Histopathological and biochemical comparative study of copper oxide nanoparticles and copper sulphate toxicity in male albino mice reproductive system. Int J Biomater 2022:4877637. 10.1155/2022/4877637.35615428
Ameh T, Sayes CM. 2019. The potential exposure and hazards of copper nanoparticles: A review. Environ Toxicol Pharmacol 71:103220. 10.1016/j.etap.2019.103220.31306862
Anchordoquy JM, Anchordoquy JP, Nikoloff N, 2017. High copper concentrations produce genotoxicity and cytotoxicity in bovine cumulus cells. Environ Sci Pollut Res Int 24(24):20041–20049. 10.1007/s11356-017-9683-0.28699012
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Anderson JR, Aggett FJ, Buseck PR, 1988. Chemistry of individual aerosol particles from Chandler, Arizona, an arid urban environment. Environ Sci Technol 22(7):811–818. 10.1021/es00172a011.22195666
Ankley GT, Di Toro DM, Hansen DJ, 1996. Technical basis and proposal for deriving sediment quality criteria for metals. Environ Toxicol Chem 15(12):2056–2066. 10.1002/etc.5620151202.
Annibaldi A, Truzzi C, Illuminati S, 2007. Determination of water-soluble and insoluble (dilute-HCl-extractable) fractions of Cd, Pb and Cu in Antarctic aerosol by square wave anodic stripping voltammetry: distribution and summer seasonal evolution at Terra Nova Bay (Victoria Land). Anal Bioanal Chem 387(3):977–998. 10.1007/s00216-006-0994-0.17200845
Anreddy RNR. 2018. Copper oxide nanoparticles induces oxidative stress and liver toxicity in rats following oral exposure. Toxicol Rep 5:903–904. 10.1016/j.toxrep.2018.08.022.30191135
Arafa MH, Amin DM, Samir GM, 2019. Protective effects of tribulus terrestris extract and angiotensin blockers on testis steroidogenesis in copper overloaded rats. Ecotoxicol Environ Saf 178:113–122. 10.1016/j.ecoenv.2019.04.012.30999179
Araya M, Koletzko B, Uauy R. 2003d. Copper deficiency and excess in infancy: Developing a research agenda. J Pediatr Gastroenterol Nutr 37(4):422–429. 10.1097/00005176-200310000-00005.14508211
Araya M, McGoldrick MC, Klevay LM, 2001. Determination of an acute no-observed-adverse-effect level (NOAEL) for copper in water. Regul Toxicol Pharmacol 34(2):137–145. 10.1006/rtph.2001.1492.11603956
Araya M, Peña C, Pizarro F, 2003a. Gastric response to acute copper exposure. Sci Total Environ 303(3):253–257. 10.1016/s0048-9697(02)00495-3.12606165
Araya M, Olivares M, Pizarro F, 2003b. Gastrointestinal symptoms and blood indicators of copper load in apparently healthy adults undergoing controlled copper exposure. Am J Clin Nutr 77(3):646–650. 10.1093/ajcn/77.3.646.12600855
Araya M, Chen B, Klevay LM, 2003c. Confirmation of an acute no-observed-adverse-effect and low-observed-adverse-effect level for copper in bottled drinking water in a multi-site international study. Regul Toxicol Pharmacol 38(3):389–399. 10.1016/j.yrtph.2003.08.001.14623488
Araya M, Olivares M, Pizarro F, 2004. Community-based randomized double-blind study of gastrointestinal effects and copper exposure in drinking water. Environ Health Perspect 112(10):1068–1073. 10.1289/ehp.6913.15238279
Araya M, Kelleher SL, Arredondo MA, 2005. Effects of chronic copper exposure during early life in rhesus monkeys. Am J Clin Nutr 81(5):1065–1071. 10.1093/ajcn/81.5.1065.15883430
Araya M, Nunez H, Pavez L, 2012. Administration of high doses of copper to capuchin monkeys does not cause liver damage but induces transcriptional activation of hepatic proliferative responses. J Nutr 142(2):233–237. 10.3945/jn.111.140103.22223567
Arcega-Cabrera F, Fargher LF. 2016. Education, fish consumption, well water, chicken coops, and cooking fires: Using biogeochemistry and ethnography to study exposure of children from Yucatan, Mexico to metals and arsenic. Sci Total Environ 568:75–82. 10.1016/j.scitotenv.2016.05.209.27288762
Arendsen LP, Thakar R, Sultan AH. 2019. The use of copper as an antimicrobial agent in health care, including obstetrics and gynecology. Clin Microbiol Rev 32(4):e00125–e00128. 10.1128/CMR.00125-18.31413046
Armstrong CW, Moore LW, Hackler RL, 1983. An outbreak of metal fume fever. Diagnostic use of urinary copper and zinc determinations. J Occup Med 25(12):886–888.6655523
Arowoogun J, Akanni OO, Adefisan AO, 2021. Rutin ameliorates copper sulfate-induced brain damage via antioxidative and anti-inflammatory activities in rats. J Biochem Mol Toxicol 35(1):e22623. 10.1002/jbt.22623.32881150
Askergren A, Mellgren M. 1975. Changes in the nasal mucosa after exposure to copper salt dust. A preliminary report. Scand J Work Environ Health 1(1):45–49. 10.5271/sjweh.2861.1235857
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634. https://archives.federalregister.gov/issue_slice/1989/9/11/37613-37634.pdf#page=6. March 21, 2024.
ATSDR. 2022. Copper. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/SPL/resources/index.html. January 25, 2024.
Aulerich RJ, Ringer RK, Bleavins MR, 1982. Effects of supplemental dietary copper on growth, reproductive performance and kit survival of standard dark mink and the acute toxicity of copper to mink. J Anim Sci 55(2):337–343. 10.2527/jas1982.552337x.7142050
Babaei H, Abshenas J. 2013. Zinc therapy improves adverse effects of long term administration of copper on epididymal sperm quality of rats. Iran J Reprod Med 11(7):577–582.24639793
Babaei H, Roshangar L, Sakhaee E, 2012. Ultrastructural and morphometrical changes of mice ovaries following experimentally induced copper poisoning. Iran Red Crescent Med J 14(9):558–568.23115718
Badri MA, Aston SR. 1983. Observations on heavy metal geochemical associations in polluted and non-polluted estuarine sediments. Environ Pollut 6(3):181–193. 10.1016/0143-148X(83)90033-2.
Baker DH, Odle J, Funk MA, 1991. Research note: bioavailability of copper in cupric oxide, cuprous oxide, and in a copper-lysine complex. Poult Sci 70(1):177–179. 10.3382/ps.0700177.1901993
Balogh S. 1996. The fate of metals in sewage sludge incinerators. Water Air Soil Pollut 91(3–4):249–254. 10.1007/BF00666261.
Banavi P, Sadeghi E, Garavand F, 2020. Release behavior of metals from tin-lined copper cookware into food simulants during cooking and cold storage. Environ Sci Pollut Res Int 27(31):38591–38601. 10.1007/s11356-020-09970-z.32623684
Banerjee P, Mohan AK, Baid H, 2023. Off with the blues: Therapeutic plasma exchange in a case of copper sulphate poisoning. Transfus Apher Sci 62(6):103811. 10.1016/j.transci.2023.103811.37730446
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486. 10.1016/0273-2300(88)90047-5.3222488
Barranco VP. 1972. Eczematous dermatitis caused by internal exposure to copper. Arch Dermatol 106(3):386–387. 10.1001/archderm.1972.01620120070019.5055098
Barrie LA, Lindberg SE, Chan WH, 1987. On the concentration of trace metals in precipitation. Atmos Environ 21(5):1133–1135. 10.1016/0004-6981(87)90240-X.
Bassetti OG, McDonough RA, Shakya KM. 2023. Soil contamination in community gardens of Philadelphia and Pittsburgh, Pennsylvania. Environ Monit Assess 195(6):782. 10.1007/s10661-023-11329-z.37261617
Behera C, Rautji R, Dogra TD. 2007. An unusual suicide with parenteral copper sulphate poisoning: a case report. Med Sci Law 47(4):357–358. 10.1258/rsmmsl.47.4.357.18069545
Behzadfar L, Abdollahi M, Sabzevari O, 2017. Potentiating role of copper on spatial memory deficit induced by beta amyloid and evaluation of mitochondrial function markers in the hippocampus of rats. Metallomics 9(7):969–980. 10.1039/c7mt00075h.28644490
Benson NU, Anake WU, Adedapo AE, 2017. Toxic metals in cigarettes and human health risk assessment associated with inhalation exposure. Environ Monit Assess 189(12):619. 10.1007/s10661-017-6348-x.29119337
Bentur Y, Koren G, McGuigan M, 1988. An unusual skin exposure to copper; clinical and pharmacokinetic evaluation. J Toxicol Clin Toxicol 26(5–6):371–380. 10.1080/15563658809167101.3193491
Beyer WN, Cromartie EJ. 1987. A survey of Pb, Cu, Zn, Cd, Cr, As, and Se in earthworms and soil from diverse sites. Environ Monit Assess 8(1):27–36. 10.1007/bf00396605.24253769
Bhandari P, Andrews PL. 1991. Preliminary evidence for the involvement of the putative 5-HT4 receptor in zacopride- and copper sulphate-induced vomiting in the ferret. Eur J Pharmacol 204(3):273–280. 10.1016/0014-2999(91)90852-h.1663456
Bhave SA, Pandit AN, Pradhan AM, 1982. Liver disease in India. Arch Dis Child 57(12):922–928. 10.1136/adc.57.12.922.7181521
Bhave SA, Pandit AN, Tanner MS. 1987. Comparison of feeding history of children with Indian childhood cirrhosis and paired controls. J Pediatr Gastroenterol Nutr 6(4):562–567. 10.1097/00005176-198707000-00013.3430265
Bhunya SP, Pati PC. 1987. Genotoxicity of an inorganic pesticide, copper sulphate in mouse in vivo test system. Cytologia (Tokyo) 52(4):801–808. 10.1508/cytologia.52.801.
Bhunya SP, Jena GB. 1996. Clastogenic effect of copper sulphate in chick in vivo test system. Mutat Res 367(2):57–63. 10.1016/0165-1218(95)00061-5.8643116
Bilal M, Ali Shah J, Ashfaq T, 2013. Waste biomass adsorbents for copper removal from industrial wastewaster - a review. J Hazard Mater 263(2):322–333. 10.1016/j.jhazmat.2013.07.071.23972667
Biswas S, Mishra U. 2016. Treatment of copper contaminated municipal wastewater by using UASB reactor and sand-chemically carbonized rubber wood sawdust column. Biomed Res Int 2016:5762781. 10.1155/2016/5762781.26904681
Blanuša M, Ivicic N, Simeon V. 1990. Lead, iron, copper, zinc and ash in deciduous teeth in relation to age and distance from a lead smelter. Bull Environ Contam Toxicol 45(4):478–485. 10.1007/BF01700618.2279110
Bolan NS, Khan MA, Donaldson J, 2003. Distribution and bioavailability of copper in farm effluent. Sci Total Environ 309(1–3):225–236. 10.1016/S0048-9697(03)00052-4.12798106
Boogaard H, Fischer PH, Janssen NA, 2013. Respiratory effects of a reduction in outdoor air pollution concentrations. Epidemiology 24(5):753–761. 10.1097/EDE.0b013e31829e1639.23873073
Bopp R, Simpson H, Chillrud S, 1993. Sediment-derived chronologies of persistent contaminants in Jamaica Bay, New York. Estuaries 16(3):608–616. 10.2307/1352798.
Borak J, Cohen H, Hethmon TA. 2000. Copper exposure and metal fume fever: lack of evidence for a causal relationship. AIHAJ 61(6):832–836. 10.1080/15298660008984594.11192216
Bost M, Houdart S, Oberli M, 2016. Dietary copper and human health: Current evidence and unresolved issues. J Trace Elem Med Biol 35:107–115. 10.1016/j.jtemb.2016.02.006.27049134
Boullata J, Muthukumaran G, Piarulli A, 2017. Oral copper absorption in men with morbid obesity. J Trace Elem Med Biol 44:146–150. 10.1016/j.jtemb.2017.07.005.28965570
Boyadzhiev A, Solorio-Rodriguez SA, Wu D, 2022. The high-throughput in vitro CometChip assay for the analysis of metal oxide nanomaterial induced DNA damage. Nanomaterials 12(11):1844. 10.3390/nano12111844.35683698
Boyden E, Potter VE, Elvehjem CA. 1938. Effect of feeding high levels of copper to albino rats. J Nutr 15(4):397–402. 10.1093/jn/15.4.397.
Bradley RW, Morris JR. 1986. Heavy metals in fish from a series of metal-contaminated lakes near Sudbury, Ontario. Water Air Soil Pollut 27(3–4):341–354. 10.1007/BF00649416.
Breault RF, Colman JA, Aiken GR, 1996. Copper speciation and binding by organic matter in copper-contaminated streamwater. Environ Sci Technol 30(12):3477–3486.
Breslin VT. 1999. Retention of metals in agricultural soils after amending with MSW and MSW-biosolids compost. Water Air Soil Pollut 109(1–4):163–178. 10.1023/A:1005026131978.
Brewer GJ. 2010. Copper toxicity in the general population. Clin Neurophysiol 121(4):459–460. 10.1016/j.clinph.2009.12.015.20071223
Brewer GJ, Askari F, Lorincz MT, 2006. Treatment of Wilson disease with ammonium tetrathiomolybdate: IV. Comparison of tetrathiomolybdate and trientine in a double-blind study of treatment of the neurologic presentation of Wilson disease. Arch Neurol 63(4):521–527. 10.1001/archneur.63.4.521.16606763
Brix KV, DeForest DK, Tear L, 2017. Use of multiple linear regression models for setting water quality criteria for copper: A complementary approach to the biotic ligand model. Environ Sci Technol 51(9):5182–5192. 10.1021/acs.est.6b05533.28409924
Brown KW, Thomas JC, Slowey JF. 1983. The movement of metals applied to soils in sewage effluent. Water Air Soil Pollut 19(1):43–54. 10.1007/BF00176794.
Bruce BW, McMahon PB. 1996. Shallow ground-water quality beneath a major urban center: Denver, Colorado, USA. J Hydrol 186(1–4):129–151. 10.1016/S0022-1694(96)03031-4.
Buchanan SD, Diseker RA, Sinks T, 1999. Copper in drinking water, Nebraska, 1994. Int J Occup Environ Health 5(4):256–261. 10.1179/oeh.1999.5.4.256.10633241
Buchholz B, Landsberger S. 1995. Leaching dynamics studies of municipal solid waste incinerator ash. J Air Waste Manage Assoc 45(8):579–590. 10.1080/10473289.1995.10467388.
Budavari S, O'Neil MJ, Smith A, 2001. [Copper and compounds]. In: The Merck index: an encyclopedia of chemicals, drugs and biologicals. Whitehouse Station, NJ: Merck & Co. Inc., 393, 412.
Buseck PR, Pósfai M. 1999. Airborne minerals and related aerosol particles: effects on climate and the environment. Proc Natl Acad Sci U S A 96(7):3372–3379. 10.1073/pnas.96.7.3372.10097046
Bush JA, Mahoney JP, Markowitz H, 1955. Studies on copper metabolism. XVI. Radioactive copper studies in normal subjects and in patients with hepatolenticular degeneration. J Clin Invest 34:1766–1778. 10.1172/JCI103232.13271562
Cadle SH, Mulawa PA, Hunsanger EC, 1999. Composition of light-duty motor vehicle exhaust particulate matter in the Denver, Colorado Area. Environ Sci Technol 33(14):2328–2339. 10.1021/es9810843.
Cagnarini C, Lofts S, D'Acqui LP, 2021. Modelling of long-term Zn, Cu, Cd and Pb dynamics from soils fertilised with organic amendments. Soil 7(1):107–123. 10.5194/soil-7-107-2021.
Cai R, Zhang C, Ding W, 2009. Corneal melting induced by a presumed copper-containing foreign body. Clin Exp Ophthalmol 37(3):328–330. 10.1111/j.1442-9071.2009.02027.x.19459877
Cai M, McBride MB, Li K. 2016. Bioaccesibility of Ba, Cu, Pb, and Zn in urban garden and orchard soils. Environ Pollut 208:145–152. 10.1016/j.envpol.2015.09.050.26477581
Caicedo M, Jacobs JJ, Reddy A, 2008. Analysis of metal ion-induced DNA damage, apoptosis, and necrosis in human (Jurkat) T-cells demonstrates Ni2+ and V3+ are more toxic than other metals: Al3+, Be2+, Co2+, Cr3+, Cu2+, Fe3+, Mo5+, Nb5+, Zr2+. J Biomed Mater Res A 86(4):905–913. 10.1002/jbm.a.31789.18050301
Calabrese EJ, Moore GS. 1979. Can elevated levels of copper in drinking water precipitate acute hemolysis in G-6-PD deficient individuals. Med Hypotheses 5(4):493–498. 10.1016/0306-9877(79)90116-6.459996
Campbell KR. 1994. Concentrations of heavy metals associated with urban runoff in fish living in stormwater treatment ponds. Arch Environ Contam Toxicol 27(3):352–356. 10.1007/bf00213171.
Cao ZH, Hu ZY. 2000. Copper contamination in paddy soils irrigated with wastewater. Chemosphere 41(1–2):3–6. 10.1016/s0045-6535(99)00383-5.10819173
Cao Y, Conklin M, Betterton E. 1995. Competitive complexation of trace metals with dissolved humic acid. Environ Health Perspect 103(Suppl 1):29–32. 10.1289/ehp.95103s129.
Cao Y, Ma C, Chen H, 2020. Copper stress in flooded soil: Impact on enzyme activities, microbial community composition and diversity in the rhizosphere of Salix integra. Sci Total Environ 704:135350. 10.1016/j.scitotenv.2019.135350.31822423
Cardwell RD, Deforest DK, Brix KV, 2013. Do Cd, Cu, Ni, Pb, and Zn biomagnify in aquatic ecosystems? Rev Environ Contam Toxicol 226:101–122. 10.1007/978-1-4614-6898-1_4.23625131
CDC. 2018. Copper, selenium & zinc - serum. National Health and Nutrition Examination Survey. NHANES 2015–2016 Laboratory Data. Centers for Disease Control and Prevention. https://wwwn.cdc.gov/nchs/nhanes/search/datapage.aspx?Component=Laboratory&CycleBeginYear=2015. October 21, 2020.
CEIDARS. 2000. Chemical speciation. California Emission Inventory and Reporting System. http://www.arb.ca.gov/emisinv/speciate/speciate.htm. June 20, 2000.
Chan WH, Tang AJS, Chung DHS, 1986. Concentration and deposition of trace metals in Ontario-1982. Water Air Soil Pollut 29(4):373–389. 10.1007/BF00283444.
Chang Y, Zhang M, Xia L, 2012. The toxic effects and mechanisms of CuO and ZnO nanoparticles. Materials 5(12):2850–2871. 10.3390/ma5122850.
Chen LC, Lippmann M. 2009. Effects of metals within ambient air particulate matter (PM) on human health. Inhal Toxicol 21(1):1–31. 10.1080/08958370802105405.
Chen R, Wei L, Huang H. 1993. Mortality from lung cancer among copper miners. Br J Ind Med 50(6):505–509. 10.1136/oem.50.6.505.8329315
Chen R, Wei L, Chen R- L. 1995. Lung cancer mortality update and prevalence of smoking among copper miners and smelters. Scand J Work Environ Health 21(6):513–516. 10.5271/sjweh.68.8824758
Chen Z, Meng H, Xing G, 2006. Acute toxicological effects of copper nanoparticles in vivo. Toxicol Lett 163(2):109–120. 10.1016/j.toxlet.2005.10.003.16289865
Chen M, Ogunseitan OA, Wang J, 2016. Evolution of electronic waste toxicity: Trends in innovation and regulation. Environ Int 89-90:147–154. 10.1016/j.envint.2016.01.022.
Chen H, Kang Z, Qiao N, 2020. Chronic copper exposure induces hypospermatogenesis in mice by increasing apoptosis without affecting testosterone secretion. Biol Trace Elem Res 195(2):472–480. 10.1007/s12011-019-01852-x.31444770
Chen J, Cui Z, Qiu Y, 2021. Exposure to copper compromises the maturational competency of porcine oocytes by impairing mitochondrial function. Front Cell Dev Biol 9:678665. 10.3389/fcell.2021.678665.34150773
Chen Y, Guan F, Wang P, 2023. Copper exposure induces ovarian granulosa cell apoptosis by activating the caspase-dependent apoptosis signaling pathway and corresponding changes in microRNA patterns. Ecotoxicol Environ Saf 264:115414. 10.1016/j.ecoenv.2023.115414.37647803
Cheng T, Choudhuri S, Muldoon-Jacobs K. 2012. Epigenetic targets of some toxicologically relevant metals: a review of the literature. J Appl Toxicol 32:643–653. 10.1002/jat.2717.22334439
Chernenkov YV, Bochkova LG, Kadymova LI, 2018. Copper concentration in the blood serum of low birth weight newborns. Biomed Pharmacol J 11(4):1807–1810. 10.13005/bpj/1553.
Chesapeake Bay Foundation. 2004. Manure’s impact on rivers, streams and the Chesapeake Bay: Keeping manure out of the water. Chesapeake Bay Foundation. https://www.cbf.org/document-library/cbf-reports/0723manurereport_noembargo_7567.pdf. January 25, 2024.
Cho YS, Moon JM, Jeong YH, 2018. Successful extracorporeal life support in respiratory failure after copper sulphate ingestion. Natl Med J India 31(2):83–85. 10.4103/0970-258X.253166.30829223
Choi YK, Kim JM, Lee JE, 2016. Association of maternal diet with zinc, copper, and iron concentrations in transitional human milk produced by Korean mothers. Clin Nutr Res 5(1):15–25. 10.7762/cnr.2016.5.1.15.26839873
Christensen TH, Kjeldsen P, Albrechtsen HJ, 1994. Attenuation of landfill leachate pollutants in aquifers. Crit Rev Environ Sci Technol 24(2):119–202. 10.1080/10643389409388463.
Chugh KS, Sakhuja V. 1979. Acute copper intoxication. Int J Artif Organs 2(4):181–182.457302
Chung MK, Baek SS, Lee SH, 2009. Combined repeated dose and reproductive/developmental toxicities of copper monochloride in rats. Environ Toxicol 24(4):315–326. 10.1002/tox.20433.18767139
Chuttani HK, Gupta PS, Gulati S, 1965. Acute copper sulfate poisoning. Am J Med 39(5):849–854. 10.1016/0002-9343(65)90105-1.5833579
Ciacci L, Fishman T, Elshkaki A, 2020. Exploring future copper demand, recycling and associated greenhouse gas emissions in the EU-28. Global Environ Change 63:102093. 10.1016/j.gloenvcha.2020.102093.
Clemens S. 2001. Molecular mechanisms of plant metal tolerance and homeostasis. Planta 212(4):475–486. 10.1007/s004250000458.11525504
Clewell HJ. 1995. The application of physiologically based pharmacokinetic modeling in human health risk assessment of hazardous substances. Toxicol Lett 79(1–3):207–217. 10.1016/0378-4274(95)03372-r.7570658
Coale KH, Bruland KW. 1988. Copper complexation in the Northeast Pacific. Limnol Oceanogr 33(5):1084–1101. 10.4319/lo.1988.33.5.1084.
Coelho FC, Cerchiaro G, Araújo SES, 2022. Is there a connection between the metabolism of copper, sulfur, and molybdenum in Alzheimer's disease? New insights on disease etiology. Int J Mol Sci 23(14):7935. 10.3390/ijms23147935.35887282
Cole RH, Frederick RE, Healy RP, 1984. Preliminary findings of the priority pollutant monitoring project of the nationwide urban runoff program. J Water Pollut Control Fed 56(7):898–908.
Coleman ME, Elder RS, Basu P, 1992. Trace metals in edible tissues of livestock and poultry. J AOAC Int 75(4):615–625. 10.1093/jaoac/75.4.615.
Conry RR. 2006. Copper: Inorganic & coordination chemistry. In: King RB, Crabtree RH, Lukehart CM, , eds. Encyclopedia of inorganic chemistry. John Wiley & Sons, Ltd, ia052. 10.1002/0470862106.ia052.
Crawford DW, Bonnevie NL, Wenning RJ. 1995. Sources of pollution and sediment contamination in Newark Bay, New Jersey. Ecotoxicol Environ Saf 30(1):85–100. 10.1006/eesa.1995.1010.7540541
Cui X, Okayasu R. 2008. Arsenic accumulation, elimination, and interaction with copper, zinc and manganese in liver and kidney of rats. Food Chem Toxicol 46(12):3646–3650. 10.1016/j.fct.2008.09.040.18848598
Cui J, Zhang L. 2008. Metallurgical recovery of metals from electronic waste: a review. J Hazard Mater 158(2–3):228–256. 10.1016/j.jhazmat.2008.02.001.18359555
Cushing CA, Golden R, Lowney YW. 2007. Human Health risk evaluation of ACQ-treated wood. Human and ecological risk assessment 13(5):1014–1041. 10.1080/10807030701506173.
Cyr F, Mehra MC, Mallet VN. 1987. Leaching of chemical contaminants from a municipal landfill site. Bull Environ Contam Toxicol 38(5):775–782. 10.1007/BF01616700.3580592
Dab H, Ben Hamed S, Jery A, 2023. Effect of Salvia officinalis aqueous infusion on copper sulfate-induced inflammatory response and oxidative stress imbalance in mice liver and kidney. Drug Chem Toxicol 26:1–10. 10.1080/01480545.2023.2228516.
Dai C, Liu Q, Li D, 2020. Molecular insights of copper sulfate exposure-induced nephrotoxicity: Involvement of oxidative and endoplasmic reticulum stress pathways. Biomolecules 10(7):1010. 10.3390/biom10071010.32650488
Dai C, Li M, Liu Y, 2023. Involvement of the inhibition of mitochondrial apoptotic, p53, NF-κB pathways and the activation of Nrf2/HO-1 pathway in the protective effects of curcumin against copper sulfate-induced nephrotoxicity in mice. Ecotoxicol Environ Saf 249:114480. 10.1016/j.ecoenv.2022.114480.38321692
Daskalakis KD, O'Connor TP. 1995. Distribution of chemical concentrations in US coastal and estuarine sediment. Mar Environ Res 40(4):381–398. 10.1016/0141-1136(94)00150-N.
Davenport WG. 2001. Copper production. In: Buschow KHJ, Cahn RW, Flemings MC, al. e, eds. Encyclopedia of materials: Science and technology. Oxford: Elsevier, 1671–1680. 10.1016/b0-08-043152-6/00294-1.
Davidson CI, Wiersma GB, Brown KW, 1985. Airborne trace elements in Great Smoky Mountains, Olympic, and Glacier National Parks. Environ Sci Technol 19(1):27–35. 10.1021/es00131a001.
Davies NT, Campbell JK. 1977. The effect of cadmium on intestinal copper absorption and binding in the rat. Life Sci 20(6):955–960. 10.1016/0024-3205(77)90281-8.850464
Davies DJA, Bennett BG. 1985. Exposure of man to environmental copper-An exposure commitment assessment. Sci Total Environ 46(1–4):215–227. 10.1016/0048-9697(85)90295-5.4081783
Davies-Colley RJ, Nelson PO, Williamson KJ. 1984. Copper and cadmium uptake by estuarine sedimentary phases. Environ Sci Technol 18(7):491–499. 10.1021/es00125a002.
Davies-Colley RJ, Nelson PO, Williamson KJ. 1985. Sulfide control of cadmium and copper concentrations in anaerobic estuarine sediments. Mar Chem 16(2):173–186. 10.1016/0304-4203(85)90021-0.
Davis RD, Carlton-Smith CH, Stark JH, 1988. Distribution of metals in grassland soils following surface applications of sewage sludge. Environ Pollut 49(2):99–115. 10.1016/0269-7491(88)90243-6.15092666
Davis AP, Shokouhian M, Ni S. 2001. Loading estimates of lead, copper, cadmium, and zinc in urban runoff from specific sources. Chemosphere 44(5):997–1009. 10.1016/s0045-6535(00)00561-0.11513434
De Jong WH, De Rijk E, Bonetto A, 2019. Toxicity of copper oxide and basic copper carbonate nanoparticles after short-term oral exposure in rats. Nanotoxicology 13(1):50–72. 10.1080/17435390.2018.1530390.30451559
De Olivera JVD, Bonfleur LA, Dos Santos CE, 2012. Occupational genotoxicity among copper smelters. Toxicol Ind Health 28(9):789–795. 10.1177/0748233711422735.22042770
De Schamphelaere KA, Vasconcelos FM, Tack FM, 2004. Effect of dissolved organic matter source on acute copper toxicity to Daphnia magna. Environ Toxicol Chem 23(5):1248–1255. 10.1897/03-184.15180376
De Vries DJ, Sewell RB, Beart PM. 1986. Effects of copper on dopaminergic function in the rat corpus striatum. Exp Neurol 91(3):546–558. 10.1016/0014-4886(86)90051-8.3948959
Demerec M, Bertani G, Flint J. 1951. A survey of chemicals for mutagenic action on E. coli. Am Nat 85(821):119–136.
Denizeau F, Marion M. 1989. Genotoxic effects of heavy metals in rat hepatocytes. Cell Biol Toxicol 5(1):15–25. 10.1007/BF00141061.2920297
Di Toro DM, Mahony JD, Hansen DJ, 1996. A model of the oxidation of iron and cadmium sulfide in sediments. Environ Toxicol Chem 15(12):2168–2186. 10.1002/etc.5620151212.
Di Toro DM, Allen HE, Bergman HL, 2001. Biotic ligand model of the acute toxicity of metals. 1. Technical basis. Environ Toxicol Chem 20(10):2383–2396. 10.1002/etc.5620201034.11596774
Diks DM, Allen HE. 1983. Correlation of copper distribution in a freshwater-sediment system to bioavailability. Bull Environ Contam Toxicol 30(1):37–43. 10.1007/BF01610096.6831071
Dinu MI, Shkinev VM, Moiseenko TI, 2020. Quantification and Speciation of Trace Metals under Pollution Impact: Case Study of a Subarctic Lake. Water 12(6):1641. 10.3390/w12061641.
DOE. 2018. Table 2: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed in alphabetical order. June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/docs/Revision_29A_Table2.pdf. December 4, 2020.
DOE. 2023. Definition of PACs. U.S. Department of Energy. https://pacteels.pnnl.gov/#/definitions.September 18, 2023.
DOI. 1986. Extractable cadmium, mercury, copper, lead, and zinc in the lower Columbia River Estuary, Oregon and Washington. Water Resources Investigations Report. Portland, OR: U.S. Department of the Interior. WRI 86–4088. https://pubs.usgs.gov/wri/1986/4088/report.pdf. March 21, 2024.
Domellof M, Lonnerdal B, Dewey KG, 2004. Iron, zinc, and copper concentrations in breast milk are independent of maternal mineral status. Am J Clin Nutr 79(1):111–115. 10.1093/ajcn/79.1.111.14684406
Domellof M, Hernell O, Abrams SA, 2009. Iron supplementation does not affect copper and zinc absorption in breastfed infants. Am J Clin Nutr 89(1):185–190. 10.3945/ajcn.2008.26887.19056575
Domergue FL, Védy JC. 1992. Mobility of heavy metals in soil profiles. Int J Environ Anal Chem 46(1–3):13–23. 10.1080/03067319208026993.
Donley SA, Ilagan BJ, Rim H, 2002. Copper transport to mammary gland and milk during lactation in rats. Am J Physiol Endocrinol Metab 283(4):E667–E675. 10.1152/ajpendo.00115.2002.12217883
Donoso A, Cruces P, Camacho J, 2007. Acute respiratory distress syndrome resulting from inhalation of powdered copper. Clin Toxicol (Phila) 45(6):714–716. 10.1080/15563650701438912.17849249
Dörner K, Dziadzka S, Höhn A, 1989. Longitudinal manganese and copper balances in young infants and preterm infants fed on breast-milk and adapted cow's milk formulas. Br J Nutr 61(3):559–572. 10.1079/bjn19890143.2758010
Draper M, Bester M, Van Rooy M, 2023. Adverse pulmonary effects after oral exposure to copper, manganese and mercury, alone and in mixtures, in a Sprague-Dawley rat model. Ultrastruct Pathol 47(3):146–159. 10.1080/01913123.2023.2184891.36857290
Dressler RL, Storm GL, Tzilkowski WM, 1986. Heavy metals in cottontail rabbits on mined lands treated with sewage sludge. J Environ Qual 15(3):278–281. 10.2134/jeq1986.00472425001500030014x.
Drummond JG, Aranyi C, Schiff LJ, 1986. Comparative study of various methods used for determining health effects of inhaled sulfates. Environ Res 41(2):514–528. 10.1016/s0013-9351(86)80146–3.3780648
Du Y, Mou Y. 2019. The role of plasmapheresis in treating lethal cupric sulfate poisoning. Am J Med Sci 357(4):338–342. 10.1016/j.amjms.2018.11.014.30638603
Eary LE, Mattigod SV, Rai D, 1990. Geochemical factors controlling the mobilization of inorganic constituents from fossil fuel combustion residues: I. Review of the major elements. J Environ Qual 19(2):188–201. 10.2134/jeq1990.00472425001900020004x.
Eckel WP, Jacob TA. 1988. Ambient levels of 24 dissolved metals in US surface and ground waters. Prepr Ext Abst Div Environ Chem Am Chem Soc 28:371–372.
Edwards M, Powers K, Hidmi L, 2001. The role of pipe ageing in copper corrosion by-product release. Water Supply 1(3):25–32. 10.2166/ws.2001.0050.
Effler SW, Litten S, Field SD, 1980. Whole lake responses to low level copper sulfate treatment. Water Res 14(10):1489–1499. 10.1016/0043-1354(80)90015–9.
Eife R, Weiss M, Barros V, 1999. Chronic poisoning by copper in tap water: I. Copper intoxications with predominantly gastrointestinal symptoms. Eur J Med Res 4(6):219–223.10383875
Elhaj Baddar Z, Peck E, Xu X. 2021. Temporal deposition of copper and zinc in the sediments of metal removal constructed wetlands. PLoS ONE 16(8):e0255527. 10.1371/journal.pone.0255527.34343201
Elliott HA, Liberati MR, Huang CP. 1986. Competitive adsorption of heavy metals by soils. J Environ Qual 15(3):214–219. 10.2134/jeq1986.00472425001500030002x.
El-Masri HA, Mumtaz MM, Yushak ML. 2004. Application of physiologically-based pharmacokinetic modeling to investigate the toxicological interaction between chlorpyrifos and parathion in the rat. Environ Toxicol Pharmacol 16(1–2):57–71. 10.1016/j.etap.2003.10.002.21782694
EPA. 1979. Water-related environmental fate of 129 priority pollutants. Volume 1: Introduction and technical background, metals and inorganics, pesticides and PCBs. Washington, DC: U.S. Environmental Protection Agency. EPA440479029a. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100K7FH.txt. March 21, 2024.
EPA. 1980a. Industrial process profiles for environmental use. Chapter 29: Primary copper industry. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600280170. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=20006FY4.txt. March 21, 2024.
EPA. 1980b. An exposure and risk assessment for copper. Washington, DC: U.S. Environmental Protection Agency. EPA440481015. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9101FLWV.txt. March 21, 2024.
EPA. 1981a. Project Summary: Data base for influent heavy metals in publicly owned treatment works. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600S281220. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000TKV2.tx. March 21, 2024.
EPA. 1981b. Treatability manual. Volume 1. Treatability data. Washington, DC: U.S. Environmental Protection Agency. EPA600282001a. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30005R3P.txt. March 21, 2024.
EPA. 1984. Air quality data for metals 1977 through 1979 from the National Air Surveillance Networks. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600S483053. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000TT9Q.txt. March 21, 2024.
EPA. 1986. Land disposal, remedial action, incineration and treatment of hazardous waste: Proceedings of the twelfth annual research symposium. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600986022. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30001TGF.txt. March 20, 2024.
EPA. 1987. Assessment of copper as a potentially toxic air pollutant. U.S. Environmental Protection Agency. Fed Regist 52(35):5496–5499. https://www.govinfo.gov/content/pkg/FR-1987-02-23/pdf/FR-1987-02-23.pdf. March 21, 2024.
EPA. 1993. Standards for the use or disposal of sewage sludge. U.S. Environmental Protection Agency. Fed Regist 58(32):9248–9415. https://www.epa.gov/sites/default/files/2020-02/documents/fr-2-19-1993-sewage-sludge.pdf. March 20, 2024.
EPA. 1994a. Method 200.7: Determination of metals and trace elements in water and wastes by inductively coupled plasma-atomic emission spectrometry. Revision 4.4. Cincinnati, OH: U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2015-08/documents/method_200-7_rev_4-4_1994.pdf. March 21, 2024.
EPA. 1994b. Method 200.8: Determination of trace elements in waters and wastes by inductively coupled plasma – mass spectrometry. Revision 5.4. Cincinnati, OH: U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2015-08/documents/method_200-8_rev_5-4_1994.pdf. October 21, 2020.
EPA. 1994c. Method 200.9: Determination of trace elements by stabilized temperature graphic furnace atomic absorption. Revision 2.2. Cincinnati, OH: U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2015-08/documents/method_200-9_rev_2-2_1994.pdf. December 4, 2020.
EPA. 1995. Effect of pH, DIC, orthophosphate and sulfate on drinking water cuprosolvency. Washington, DC: U.S. Environmental Protection Agency. EPA600R95085. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30003CGQ.TXT. January 25, 2024.
EPA. 2003. Method 200.5: Determination of trace elements in drinking water by axially viewed inductively coupled plasma - atomic emission spectrometry. Revision 4.2. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600R06115. https://www.epa.gov/sites/production/files/2015-08/documents/method_200-5_rev_4-2_2003.pdf. December 4, 2020.
EPA. 2006. Coppers: Revised human health chapter of the reregistration eligibility decision document (RED) and response to comments from the phase 3 public comment period. Reregistration case numbers 0636, 0649, 4025, and 4026. DP barcode D330433. U.S. Environmental Protection Agency. EPA-HQ-OPP-2005–0558-0207. https://www.regulations.gov/document/EPA-HQ-OPP-2005-0558-0207. March 21, 2024.
EPA. 2007. National recommended water quality criteria-Aquatic life criteria table. U.S. Environmental Protection Agency. https://www.epa.gov/wqc/national-recommended-water-quality-criteria-aquaticlife-criteria-table. October 21, 2020.
EPA. 2009a. National primary drinking water regulations. U.S. Environmental Protection Agency. EPA816F09004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. December 4, 2020.
EPA. 2009b. Reregistration eligibility decision (RED) for coppers. U.S. Environmental Protection Agency. EPA738R09304. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P1004513.txt. March 21, 2024.
EPA. 2018a. Standards for the use or disposal of sewage sludge. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 503. https://www.govinfo.gov/content/pkg/CFR-2018-title40-vol32/xml/CFR-2018-title40-vol32-part503.xml. January 25, 2024.
EPA. 2018b. 2018 edition of the drinking water standards and health advisories tables. Washington, DC: U.S. Environmental Protection Agency. EPA822F18001. https://www.epa.gov/system/files/documents/2022-01/dwtable2018.pdf. December 4, 2020.
EPA. 2018c. Compiled AEGL values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. August 24, 2022.
EPA. 2019. National primary drinking water regulations: Proposed lead and copper rule revisions. U.S. Environmental Protection Agency. Fed Regist 84(219):61684–61744. https://www.govinfo.gov/content/pkg/FR-2019-11-13/pdf/2019-22705.pdf. January 31, 2024.
EPA. 2020a. Sampling methods for all parameters. AQS reference table. U.S. Environmental Protection Agency. https://aqs.epa.gov/aqsweb/documents/codetables/methods_all.html. October 21, 2020.
EPA. 2020b. Understanding the lead and copper rule. U.S. Environmental Protection Agency. https://www.epa.gov/sites/default/files/2019-10/documents/lcr101_factsheet_10.9.19.final_.2.pdf. January 25, 2024.
EPA. 2021a. Memorandum: Registration review draft risk assessment for copper 8-quinolinolate (bis(8-quinolinolato)copper(II)). U.S. Environmental Protection Agency. https://www.regulations.gov/document/EPA-HQ-OPP-2010-0454-0012. March 21, 2024.
EPA. 2021b. National primary drinking water regulations: Lead and copper rule revisions; delay of effective and compliance dates. U.S. Environmental Protection Agency. 40 CFR Part 141. Fed Regist 86(47):14063–14066. https://www.govinfo.gov/content/pkg/FR-2021-03-12/pdf/FR-2021-03-12.pdf. March 21, 2024.
EPA. 2022a. Annual summary data: Copper. Air quality system: Concentration by monitor. U.S. Environmental Protection Agency. https://www.epa.gov/aqs. January 25, 2024.
EPA. 2022b. Toxic chemical release inventory reporting forms and instructions: Revised 2021 version. U.S. Environmental Protection Agency. EPA740B22002. https://ordspub.epa.gov/ords/guideme_ext/guideme_ext/guideme/file/ry_2021_rfi.pdf. August 22, 2023.
EPA. 2022c. Effluent limitations guidelines and standards (ELG) database. U.S. Environmental Protection Agency. https://owapps.epa.gov/elg/. January 25, 2024.
EPA. 2022d. National primary drinking water regulations. Subpart I - Control of lead and copper. General requirements. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.80. https://www.govinfo.gov/content/pkg/CFR-2022-title40-vol25/pdf/CFR-2022-title40-vol25-sec141-80.pdf. October 31, 2023.
Epstein O, Spisni R, Parbhoo S, 1982. The effect of oral copper loading and portasystemic shunting on the distribution of copper in the liver, brain, kidney, and cornea of the rat. Am J Clin Nutr 35(3):551–555. 10.1093/ajcn/35.3.551.7064906
Erickson RJ, Benoit DA, Mattson VR, 1996. The effects of water chemistry on the toxicity of copper to fathead minnows. Environ Toxicol Chem 15(2):181–193. 10.1002/etc.5620150217.
Evans GW, Majors PF, Cornatzer WE. 1970. Mechanism for cadmium and zinc antagonism of copper metabolism. Biochem Biophys Res Commun 40(5):1142–1148. 10.1016/0006-291x(70)90913-7.5503788
Fahmy MA. 2000. Potential genotoxicity in copper sulphate treated mice. Cytologia (Tokyo) 65:235–242. 10.1508/cytologia.65.235.
Fahmy HM, Ali OA, Hassan AA, 2020. Biodistribution and toxicity assessment of copper nanoparticles in the rat brain. J Trace Elem Med Biol 61:126505. 10.1016/j.jtemb.2020.126505.32480052
Farrer P, Mistilis S. 1967. Absorption of exogenous and endogenous biliary copper in the rat. Nature 213(5073):291–292. 10.1038/213291b0.
FDA. 2017. Analytical results of the Total Diet Study. Individual year analytical results: Copper. U.S. Food and Drug Administration. https://www.fda.gov/food/total-diet-study/analytical-results-totaldiet-study. August 18, 2020.
FDA. 2019a. Direct food substances affirmed as generally recognized as safe. Copper sulfate. U.S. Food and Drug Administration. Code of Federal Regulations. 40 CFR 184.1261. Code of Federal Regulations. 21 CFR 184.1261. https://www.govinfo.gov/content/pkg/CFR-2019-title21-vol3/pdf/CFR-2019-title21-vol3-sec184-1261.pdf. October 30, 2023.
FDA. 2019b. Direct food substances affirmed as generally recognized as safe. Copper gluconate. U.S. Food and Drug Administration. Code of Federal Regulations. 40 CFR 184.1261. Code of Federal Regulations. 21 CFR 184.1260. https://www.govinfo.gov/content/pkg/CFR-2019-title21-vol3/pdf/CFR-2019-title21-vol3-sec184-1260.pdf. October 30, 2023.
FDA. 2020. Elemental analysis manual for food and related products. 4.7 Inductively coupled plasma-mass spectrometric determination of arsenic, cadmium, chromium, lead, mercury, and other elements in food using microwave assisted digestion. Version 1.2. U.S. Food and Drug Administration. https://www.fda.gov/media/87509/download. October 21, 2020.
FDA. 2022. Beverages. Subpart B - Requirements for specific standardized beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. https://www.govinfo.gov/content/pkg/CFR-2022-title21-vol2/pdf/CFR-2022-title21-vol2-sec165-110.pdf. January 4, 2023.
Feiler HD, Storch TJ, Southworth R. 1980. Organics in municipal sludges: survey of forty cities. In: Proceedings of the national conference on municipal industrial sludge utility disposal, Washington, D.C., May 28–30, 1980. Silver Spring, MD: Information Transfer, 53–57.
Feng X, Melander AP, Klaue B. 2000. Contribution of municipal waste incineration to trace metal deposition on the vicinity. Water Air Soil Pollut 119(1–4):295–316. 10.1023/A:1005211320637.
Fergusson JE, Stewart C. 1992. The transport of airborne trace elements copper, lead, cadmium, zinc and manganese from a city into rural areas. Sci Total Environ 121:247–269. 10.1016/0048-9697(92)90319-n.1439727
Finelli VN, Boscolo P, Salimei E, 1981. Anemia in men occupationally exposed to low levels of copper. In: International conference: Heavy metals in the environment, Amsterdam - September 1981. World Health Organization, 475–478.
Finley EB, Cerklewski FL. 1983. Influence of ascorbic acid supplementation on copper status in young adult men. Am J Clin Nutr 37(4):553–556. 10.1093/ajcn/37.4.553.6837490
Fleckman P. 1985. Anatomy and physiology of the nail. Dermatol Clin 3(3):373–381. 10.1016/S0733-8635(18)30874-X.3830499
Fouad MM, Ramadan MA. 2022. Serum intracellular adhesion molecule-1 and interleukin-8 as predictors of pulmonary impairment among workers in secondary copper smelters. Int Arch Occup Environ Health 95(2):365–375. 10.1007/s00420-021-01770-3.34609586
Franchitto N, Gandia-Mailly P, Georges B, 2008. Acute copper sulphate poisoning: A case report and literature review. Resuscitation 78(1):92–96. 10.1016/j.resuscitation.2008.02.017.18482790
Franke SI, Pra D, Giulian R, 2006. Influence of orange juice in the levels and in the genotoxicity of iron and copper. Food Chem Toxicol 44(3):425–435. 10.1016/j.fct.2005.08.016.16263202
Freire BM, Gonzaga RG, Pedron T, 2021. Occupational exposure to potentially toxic elements in the foundry industry: an integrated environmental and biological monitoring. Environ Sci Pollut Res Int 28(26):34630–34641. 10.1007/s11356-021-13099-y.33650056
Fuentealba IC, Mullins JE, Aburto EM, 2000. Effect of age and sex on liver damage due to excess dietary copper in Fischer 344 rats. J Toxicol Clin Toxicol 38(7):709–717. 10.1081/clt-100102384.11192458
Fukui H, Yamamoto M, Sasaki S, 1993. Involvement of 5-HT3 receptors and vagal afferents in copper sulfate- and cisplatin-induced emesis in monkeys. Eur J Pharmacol 249(1):13–18. 10.1016/0014-2999(93)90656-3.8282015
Fukui H, Yamamoto M, Sasaki S, 1994. Possible involvement of peripheral 5-HT4 receptors in copper sulfate-induced vomiting in dogs. Eur J Pharmacol 257(1–2):47–52. 10.1016/0014-2999(94)90692-0.8082706
Furst A. 1971. Trace elements related to specific chronic diseases: Cancer. In: Cannon HL, Hopps HC, eds. Environmental geochemistry in health and disease. Vol. 123. Geological Society of America, 109–130. 10.1130/MEM123-p109.
Gaetke LM, Chow-Johnson HS, Chow CK. 2014. Copper: toxicological relevance and mechanisms. Arch Toxicol 88(11):1929–1938. 10.1007/s00204-014-1355-y.25199685
Galarneau JM, Beach J, Cherry N. 2022. Urinary metals as a marker of exposure in men and women in the welding and electrical trades: A Canadian cohort study. Ann Work Expo Health 66(9):1111–1121. 10.1093/annweh/wxac005.35211721
Galloway JN, Thornton JD, Norton SA, 1982. Trace metals in atmospheric deposition: A review and assessment. Atmos Environ 16(7):1677–1700. 10.1016/0004-6981(82)90262-1.
Galust H, Seltzer JA, Hardin JR, 2023. "Campfire corrosive: Isolated gastrointestinal injury following ingestion of copper salts". Am J Emerg Med 70:210.e215–210.e218. 10.1016/j.ajem.2023.05.021.
Gamakaranage CS, Rodrigo C, Weerasinghe S, 2011. Complications and management of acute copper sulphate poisoning; a case discussion. J Occup Med Toxicol 6(1):34. 10.1186/1745-6673-6-34.22182712
Gao S, Walker WJ, Dahlgren RA, 1997. Simultaneous sorption of Cd, Cu, Ni, Zn, Pb, and Cr on soils treated with sewage sludge supernatant. Water Air Soil Pollut 93:331–345. 10.1007/BF02404765.
Gao P, Lei T, Jia L, 2018. Bioaccesible trace metals in lip cosmetics and their health risks to female consumers. Environ Pollut 238:554–561. 10.1016/j.envpol.2018.03.072.29605615
García-Martínez BA, Montes S, Tristán-López L, 2021. Copper biodistribution after acute systemic administration of copper gluconate to rats. Biometals 34(3):687–700. 10.1007/s10534-021-00304-1.33900531
Gardner MJ, Ravenscroft JE. 1991. The range of copper-complexing ligands in the Tweed estuary. Chem Speciat Bioavail 3(1):22–29. 10.1080/09542299.1991.11083137.
Garrett NE, Lewtas J. 1983. Cellular toxicity in Chinese hamster ovary cells culture. I. Analysis of cytotoxicity endpoints for twenty-nine priority pollutants. Environ Res 32(2):455–465. 10.1016/0013-9351(83)90125-1.6641673
Garvey KA, Edwards MA, Blacker LS, 2023. A comprehensive examination of the contaminants in drinking water in public schools in California, 2017–2022. Public Health Rep 0(0):333549231192471. 10.1177/00333549231192471.
Gatzke-Kopp LM, Riis JL, Ahmadi H, 2023. Environmental tobacco smoke exposure is associated with increased levels of metals in children's saliva. J Expo Sci Environ Epidemiol 33(6):903–910. 10.1038/s41370-023-00554-w.37147431
Ge X, Liu Z, Hou Q, 2020. Plasma metals and serum bilirubin levels in workers from manganese-exposed workers healthy cohort (MEWHC). Environ Pollut 258:113683. 10.1016/j.envpol.2019.113683.31838386
Ge X, Yang A, Huang S, 2021. Sex-specific associations of plasma metals and metal mixtures with glucose metabolism: An occupational population-based study in China. Sci Total Environ 760:143906. 10.1016/j.scitotenv.2020.143906.33341635
Ge X, Ye G, He J, 2022. Metal mixtures with longitudinal changes in lipid profiles: findings from the manganese-exposed workers healthy cohort. Environ Sci Pollut Res Int 29(56):85103–85113. 10.1007/s11356-022-21653-5.35793018
Gehring U, Beelen R, Eeftens M, 2015. Particulate matter composition and respiratory health: the PIAMA Birth Cohort study. Epidemiology 26(3):300–309. 10.1097/EDE.0000000000000264.25688676
Georgieva S, Popov B, Petrov V. 2013. Genotoxic effects of copper sulfate in rabbits. Arch Biol Sci 65(3):963–967. 10.2298/abs1303963g.
Georgopoulos PG, Roy A, Yonone-Lioy MJ, 2001. Environmental copper: Its dynamics and human exposure issues. J Toxicol Environ Health B Crit Rev 4(4):341–394. 10.1080/109374001753146207.11695043
Gerritse RG, Van Driel W. 1984. The relationship between adsorption of trace metals, organic matter, and pH in temperate soils. J Environ Qual 13(2):197–204. 10.2134/jeq1984.00472425001300020005x.
Gibson A, Faucher L, Schurr M. 2011. Molten copper inhalation. Burns 37(6):e50–e53. 10.1016/j.burns.2011.05.009.21726951
Giesy JP, Briese LA, Leversee GJ. 1978. Metal binding capacity of selected Maine surface waters. Environ Geol 2(5):257–268. 10.1007/BF02430672.
Giesy JP, Newell A, Leversee GJ. 1983. Copper speciation in soft, acid, humic waters: Effects on copper bioaccumulation by and toxicity to Simocephalus serrulatus (Daphnidae). Sci Total Environ 28(1–3):23–36. 10.1016/S0048-9697(83)80005-9.
Giesy JP, Alberts JJ, Evans DW. 1986. Conditional stability constants and binding capacities for copper (II) by dissolved organic carbon isolated from surface waters of the southeastern United States. Environ Toxicol Chem 5(2):139–154. 10.1002/etc.5620050204.
Gill JS, Bhagat CI. 1999. Acute copper poisoning from drinking lime cordial prepared and left overnight in an old urn. Med J Aust 170(10):510. 10.5694/j.1326-5377.1999.tb127863.x.
Gilman JPW. 1962. Metal carcinogenesis: II. A study on the carcinogenic activity of cobalt, copper, iron, and nickel compounds. Cancer Res 22:158–162.13898693
Giusquiani PL, Gigliotti G, Businelli D. 1992. Mobility of heavy metals in urban waste-amended soils. J Environ Qual 21(3):330–335. 10.2134/jeq1992.00472425002100030004x.
Giusti L, Yang YL, Hewitt CN, 1993. The solubility and partitioning of atmospherically derived trace metals in artificial and natural waters: A review. Atmos Environ 27(10):1567–1578. 10.1016/0960-1686(93)90156-s.
Gleason RP. 1968. Exposure to copper dust. Am Ind Hyg Assoc J 29(5):461–462. 10.1080/00028896809343035.5727084
Goldberg ED. 1986. The Mussel Watch concept. Environ Monit Assess 7(1):91–103. 10.1007/BF00398031.24254800
Goldin A, Bigelow C, Veneman PLM. 1992. Concentrations of metals in ash from municipal solid waste combusters. Chemosphere 24(3):271–280. 10.1016/0045-6535(92)90296-4.
Gollan JL, Deller DJ. 1973. Studies on the nature and excretion of biliary copper in man. Clin Sci 44(1):9–15. 10.1042/cs0440009.4630718
Golomb D, Ryan D, Eby N, 1997. Atmospheric deposition of toxics onto Massachusetts Bay-I. Metals. Atmos Environ 31(9):1349–1359. 10.1016/S1352-2310(96)00276-2.
Gonzalez-Jimenez N, Gray N, Pappas RS, 2021. Analysis of toxic metals in aerosols from devices associated with electronic cigarette, or vaping, product use associated lung injury. Toxics 9(10):240. 10.3390/toxics9100240.34678936
Gorter RW, Butorac M, Cobian EP. 2004. Examination of the cutaneous absorption of copper after the use of copper-containing ointments. Am J Ther 11(6):453–458. 10.1097/01.mjt.0000127148.83065.e5.15543084
Gotteland M, Araya M, Pizarro F, 2001. Effect of acute copper exposure on gastrointestinal permeability in healthy volunteers. Dig Dis Sci 46(9):1909–1914. 10.1023/a:1010683014390.11575443
Grace S, Darren AL, Mark NG. 2012. Control of new copper corrosion in high-alkalinity drinking water. J Am Water Works Assoc 104(1):E15–E25. 10.5942/jawwa.2012.104.0002.
Gralak MA, Leontowicz M, Morawiec M, 1996. Comparison of the influence of dietary fibre sources with different proportions of soluble and insoluble fibre on Ca, Mg, Fe, Zn, Mn and Cu apparent absorption in rats. Arch Tierernahr 49(4):293–299. 10.1080/17450399609381892.8988315
Gray N, Halstead M, Valentin-Blasini L, 2022. Toxic metals in liquid and aerosol from pod-type electronic cigarettes. J Anal Toxicol 46(1):69–75. 10.1093/jat/bkaa185.33270129
Greene FL, Lamb LS, Barwick M, 1987. Effect of dietary copper on colonic tumor production and aortic integrity in the rat. J Surg Res 42(5):503–512. 10.1016/0022-4804(87)90025-4.3586623
Grillo CA, Reigosa MA, de Mele MA. 2010. Does over-exposure to copper ions released from metallic copper induce cytotoxic and genotoxic effects on mammalian cells? Contraception 81(4):343–349. 10.1016/j.contraception.2009.12.003.20227553
Griswold MK, Nordberg A, Babu KM, 2017. Accidental copper sulfate toxicity after flame colorant ingestion. Clin Toxicol (Phila) 55(8):943–945. 10.1080/15563650.2017.1330958.28594239
Gu XY, Wang X, Guo LN, 2012. [The related study of first pregnancy women with Cu-IUD on copper content of blood serum and decidua, chorion tissues]. Zhonghua Yi Xue Za Zhi 92(5):324–326. (Chinese)22490836
Gunay N, Yildirim C, Karcioglu O, 2006. A series of patient in the emergency department diagnosed with copper poisoning: Recognition equals treatment. Tohoku J Exp Med 209(3):243–248. 10.1620/tjem.209.243.16778371
Guo X, Wang J. 2021. Projecting the sorption capacity of heavy metal ions onto microplastics in global aquatic environments using artificial neural networks. J Hazard Mater 402:123709. 10.1016/j.jhazmat.2020.123709.33254753
Guo H, Ouyang Y, Wang J, 2021. Cu-induced spermatogenesis disease is related to oxidative stress-mediated germ cell apoptosis and DNA damage. J Hazard Mater 416:125903. 10.1016/j.jhazmat.2021.125903.34492839
Guo H, Wang Y, Cui H, 2022a. Copper induces spleen damage through modulation of oxidative stress, apoptosis, DNA damage, and inflammation. Biol Trace Elem Res 200(2):669–677. 10.1007/s12011-021-02672-8.33740180
Guo F, Lin Y, Meng L, 2022b. Association of copper exposure with prevalence of chronic kidney disease in older adults. Clin Nutr 41(12):2720–2728. 10.1016/j.clnu.2022.10.016.36368257
Gupta UC. 1979. Copper in agricultural crops. In: Nriagu JO, ed. Copper in the environment. Part I: Ecological cycling. New York: John Wiley & Sons, Inc., 255–288.
Gupta D, Kerai S, Budoo MS. 2018. A fatal and deceiving case of copper sulphate poisoning. Indian J Anaesth 62(10):819–820. 10.4103/ija.IJA_71_18.30443069
Gupta A, Kumar A, Naqvi S, 2021. Chronic exposure to multi-metals on testicular toxicity in rats. Toxicol Mech Methods 31(1):53–66. 10.1080/15376516.2020.1828522.32972309
Gupta A, Puri S, Aggarwal NP, 2023. Intravascular hemolysis, methemoglobinemia and acute renal failure in a young female. Indian J Nephrol 33(2):136–139. 10.4103/ijn.ijn_410_21.37234441
Gutenmann WH, Rutzke M, Kuntz TH, 1994. Elements and polychlorinated biphenyls in sewage sludges of large cities in the United States. Chemosphere 28(4):725–728. 10.1016/0045-6535(94)90225-9.
Guttmann S, Bernick F, Naorniakowska M, 2018. Functional characterization of novel ATP7B variants for diagnosis of Wilson Disease. Front Pediatr 6:106. 10.3389/fped.2018.00106.29761093
Ha JH, Doguer C, Wang X, 2016. High-iron consumption impairs growth and causes copper-deficiency anemia in weanling Sprague-Dawley rats. PLoS ONE 11(8):e0161033. 10.1371/journal.pone.0161033.27537180
Haase LM, Birk T, Bachand AM, 2021. A health surveillance study of workers employed at a copper smelter-effects of long-term exposure to copper on lung function using spirometric data. J Occup Environ Med 63(8):e480–e489. 10.1097/jom.0000000000002252.34074954
Haase LM, Birk T, Poland CA, 2022. Cross-sectional study of workers employed at a copper smelter-effects of long-term exposures to copper on lung function and chronic inflammation. J Occup Environ Med 64(9):e550–e558. 10.1097/JOM.0000000000002610.35902212
Hall AC, Young BW, Bremner I. 1979. Intestinal metallothionein and the mutual antagonism between copper and zinc in the rat. J Inorg Biochem 11(1):57–66. 10.1016/s0162-0134(00)80054-9.479878
Halstead M, Gray N, Gonzalez-Jimenez N, 2020. Analysis of toxic metals in electronic cigarette aerosols using a novel trap design. J Anal Toxicol 44(2):149–155. 10.1093/jat/bkz078.31588518
Harada M, Honma Y, Yoshizumi T, 2020. Idiopathic copper toxicosis: Is abnormal copper metabolism a primary cause of this disease? Med Mol Morphol 53:50–55. 10.1007/s00795-019-00227-4.31161407
Hardman B, Michalczyk A, Greenough M, 2007. Distinct functional roles for the Menkes and Wilson copper translocating P-type ATPases in human placental cells. Cell Physiol Biochem 20(6):1073–1084. 10.1159/000110718.17975309
Harmesa H, Lestari L, Budiyanto F, 2023. Preliminary study of geochemical speciation of copper and nickel in coastal sediments in Surabaya, Indonesia. Environ Sci Pollut Res Int 30(30):75925–75942. 10.1007/s11356-023-27711-w.37231129
Harris ED. 1993. The transport of copper. Prog Clin Biol Res 380:163–179.8456124
Harvey LJ, Majsak-Newman G, Dainty JR, 2003. Adaptive responses in men fed low- and high-copper diets. Br J Nutr 90(1):161–168. 10.1079/bjn2003887.12844388
Harvey LJ, Dainty JR, Hollands WJ, 2005. Use of mathematical modeling to study copper metabolism in humans. Am J Clin Nutr 81(4):807–813. 10.1093/ajcn/81.4.807.15817856
Haschke F, Ziegler EE, Edwards BB, 1986. Effect of iron fortification of infant formula on trace mineral absorption. J Pediatr Gastroenterol Nutr 5(5):768–773. 10.1097/00005176-198609000-00018.3761108
Hashimyousif E, Obaid HM, Karim AJ, 2019. Toxico pathological study of copper sulfate modulate by zinc oxide and Coriandrum sativum plant treatment in mice. Plant Archives 19(1):299–308.
Hashish EA, Elgaml SA. 2016. Hepatoprotective and nephroprotective effect of curcumin against copper toxicity in rats. Indian J Clin Biochem 31(3):270–277. 10.1007/s12291-015-0527-8.27382197
Hassan S, Shaikh MU, Ali N, 2010. Copper sulphate toxicity in a young male complicated by methemoglobinemia, rhabdomyolysis and renal failure. J Coll Physicians Surg Pak 20(7):490–491. 10.2010/JCPSP.490491.20642956
Haynes WM, Lide DR, Bruno TJ. 2015. Copper. In: CRC handbook of chemistry and physics: A ready-reference book of chemical and physical data. 95^th^ ed. Boca Raton, FL: CRC Press, 4–10, 14–61, 14–62.
Haywood S. 1980. The effect of excess dietary copper on the liver and kidney of the male rat. J Comp Pathol 90(2):217–232. 10.1016/0021-9975(80)90058-4.7430449
Haywood S. 2019. Brain-barrier regulation, metal (Cu, Fe) dyshomeostasis, and neurodegenerative disorders in man and animals. Inorganics 7:108. 10.3390/inorganics7090108.
Haywood S, Comerford B. 1980. The effect of excess dietary copper on plasma enzyme activity and on the copper content of the blood of the male rat. J Comp Pathol 90(2):233–238. 10.1016/0021-9975(80)90059-6.7430450
Haywood S, Loughran M. 1985. Copper toxicosis and tolerance in the rat. II. Tolerance-a liver protective adaptation. Liver 5(5):267–275. 10.1111/j.1600-0676.1985.tb00248.x.4079667
He XT, Logan TJ, Traina SJ. 1995. Physical and chemical characteristics of selected US municipal solid waste composts. J Environ Qual 24(3):543–552. 10.2134/jeq1995.00472425002400030022x.
He P, Li H, Liu C, 2022. U-shaped association between dietary copper intake and new-onset hypertension. Clin Nutr 41(2):536–542. 10.1016/j.clnu.2021.12.037.35030528
Heit M, Klusek CS. 1985. Trace element concentrations in the dorsal muscle of white suckers and brown bullheads from two acidic Adirondack lakes. Water Air Soil Pollut 25:87–96. 10.1007/BF00159627.
Hellman NE, Gitlin JD. 2002. Ceruloplasmin metabolism and function. Annu Rev Nutr 22:439–458. 10.1146/annurev.nutr.22.012502.114457.12055353
Helz GR, Huggett RJ, Hill JM. 1975. Behavior of Mn, Fe, Cu, Zn, Cd and Pb discharged from a wastewater treatment plant into an estuarine environment. Water Res 9(7):631–636. 10.1016/0043-1354(75)90168-2.
Henckens MLCM, Worrell E. 2020. Reviewing the availability of copper and nickel for future generations. The balance between production growth, sustainability and recycling rates. J Clean Prod 264:121460. 10.1016/j.jclepro.2020.121460.
Herawati N, Suzuki S, Hayashi K, 2000. Cadmium, copper, and zinc levels in rice and soil of Japan, Indonesia, and China by soil type. Bull Environ Contam Toxicol 64:33–39. 10.1007/s001289910006.10606690
Hermann R, Neumann-Mahlkau P. 1985. The mobility of zinc, cadmium, copper, lead, iron and arsenic in ground water as a function of redox potential and pH. Sci Total Environ 43(1–2):1–12. 10.1016/0048-9697(85)90027-0.
Hernandez LM, Gonzalez MJ, Rico MC, 1985. Presence and biomagnification of organochlorine pollutants and heavy metals in mammals of Donana National Park (Spain), 1982–1983. J Environ Sci Health B 20(6):633–650. 10.1080/03601238509372501.4093545
Herrero M, Rovira J, Esplugas R, 2020. Human exposure to trace elements, aromatic amines and formaldehyde in swimsuits: Assessment of the health risks. Environ Res 181:108951. 10.1016/j.envres.2019.108951.31784079
Hickey C, Gordon C, Galdanes K, 2020. Toxicity of particles emitted by fireworks. Part Fibre Toxicol 17:28. 10.1186/s12989-020-00360-4.32611421
Higny J, Vanpee D, Boulouffe C. 2014. Bluish vomiting: A rare clinical presentation of poisoning. Acta Clin Belg 69(4):299–301. 10.1179/2295333714Y.0000000033.24846181
Hirano S, Sakai S, Ebihara H. 1990. Metabolism and pulmonary toxicity of intratracheally instilled cupric sulfate in rats. Toxicology 64(3):223–233. 10.1016/0300-483x(90)90115-w.2267662
Hollis L, Muench L, Playle RC. 1997. Influence of dissolved organic matter on copper binding, and calcium on cadmium binding, by gills of rainbow trout. J Fish Biol 50(4):703–720. 10.1111/j.1095-8649.1997.tb01966.x.
Holtzman NA, Elliott DA, Heller RH. 1966. Copper intoxication. Report of a case with observations on ceruloplasmin. N Engl J Med 275(7):347–352. 10.1056/NEJM196608182750702.5947547
Hoogenraad T, Koevoet R, de Ruyter Kover E. 1979. Oral zinc sulphate as long-term treatment in Wilson's disease (hepatolenticular degeneration) Eur Neurol 18(3):205–211. 10.1159/000115077.477692
Hopps HC. 1977. The biologic bases for using hair and nail for analyses of trace elements. Sci Total Environ 7(1):71–89. 10.1016/0048-9697(77)90018-3.319530
Horn CC, Meyers K, Lim A, 2014. Delineation of vagal emetic pathways: intragastric copper sulfate-induced emesis and viral tract tracing in musk shrews. Am J Physiol Regul Integr Comp Physiol 306(5):R341–351. 10.1152/ajpregu.00413.2013.24430885
Hostynek JJ, Dreher F, Maibach HI. 2010. Human skin retention and penetration of a copper tripeptide in vitro as function of skin layer towards anti-inflammatory therapy. Inflamm Res 59(11):983–988. 10.1007/s00011-010-0214-4.20703511
Huang H, Shih H, Lee C, 2008. In vitro efficacy of copper and silver ions in eradicating Pseudomonas aeruginosa, Stenotrophomonas maltophilia and Acinetobacter baumannii: Implications for on-site disinfection for hospital infection control. Water Res 42(1):73–80. 10.1016/j.watres.2007.07.003.17655912
Huh C. 1996. Fluxes and budgets of anthropogenic metals in the Santa Monica and San Pedro Basins off Los Angeles: Review and reassessment. Sci Total Environ 179:47–60. 10.1016/s0048-9697(96)90048-0.
Hunt JR, Vanderpool RA. 2001. Apparent copper absorption from a vegetarian diet. Am J Clin Nutr 74(6):803–807. 10.1093/ajcn/74.6.803.11722963
Husain N, Mahmood R. 2019. Copper(II) generates ROS and RNS, impairs antioxidant system and damages membrane and DNA in human blood cells. Environ Sci Pollut Res Int 26(20):20654–20668. 10.1007/s11356-019-05345-1.31104239
Husain N, Mahmood R. 2020. Mitigation of Cu(II)-induced damage in human blood cells by carnosine: An in vitro study. Toxicol In Vitro 68:104956. 10.1016/j.tiv.2020.104956.32745495
Husain N, Hasan S, Khan AA, 2021. Copper chloride inhibits brush border membrane enzymes, alters antioxidant and metabolic status and damages DNA in rat intestine: a dose-dependent study. Environ Sci Pollut Res Int 28(32):43711–43724. 10.1007/s11356-021-13804-x.33837945
Husain N, Ali SN, Arif H, 2023. Oral administration of copper chloride damages DNA, lowers antioxidant defense, alters metabolic status, and inhibits membrane bound enzymes in rat kidney. Biol Trace Elem Res 201(7):3367–3380. 10.1007/s12011-022-03406-0.36068418
Hutchinson TC. 1979. Copper contamination of ecosystems caused by smelter activities. In: Nriagu JO, ed. Copper in the environment. Part I: Ecological cycling. New York: John Wiley and Sons, Inc., 451–502.
Iannuzzi TJ, Huntley SL, Schmidt CW, 1997. Combined sewer overflows (CSOs) as sources of sediment contamination in the lower Passaic River, New Jersey. I. Priority pollutants and inorganic chemicals. Chemosphere 34(2):213–231. 10.1016/s0045-6535(96)00373-6.
IARC. 1987. Results and conclusions: copper 8-hydroxyquinoline. IARC monographs on the evaluation of carcinogenic risks to humans. Supplement 7. Overall evaluations of carcinogenicity: an updating of IARC monographs volumes 1–42. Lyon, France: International Agency for Research on Cancer. 61. https://publications.iarc.fr/139. October 30, 2023.
Igic PG, Lee E, Harper W, 2002. Toxic effects associated with consumption of zinc. Mayo Clin Proc 77(7):713–716. 10.4065/77.7.713.12108610
IOM. 2001. Dietary reference intakes for vitamin A, vitamin K, arsenic, boron, chromium, copper, iodine, iron, manganese, molybdenum, nickel, silicon, vanadium, and zinc. Institute of Medicine. https://www.ncbi.nlm.nih.gov/books/NBK222310/. January 25, 2024.
IOM. 2006. Copper. Dietary reference intakes: The essential guide to nutrient requirements. Washington, DC: Institute of Medicine. 10.17226/11537. https://www.nal.usda.gov/sites/default/files/fnic_uploads/DRIEssentialGuideNutReq.pdf.
IRIS. 1988. Integrated risk information system (IRIS). Chemical assessment summary. Copper; CASRN 7440–50-8. U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0368_summary.pdf. December 4, 2020.
Isaac RA, Gil L, Cooperman AN. 1997. Corrosion in drinking water distribution systems: A major contributor of copper and lead to wastewaters and effluents. Environ Sci Technol 31(11):3198–3203. 10.1021/es970185i.
Isibor H, Ajayi AM, Ben-Azu B, 2022. D-ribose-L-cysteine reduces oxidative stress and inflammatory cytokines to mitigate liver damage, and memory decline induced by copper sulfate in mice. J Trace Elem Med Biol 73:127001. 10.1016/j.jtemb.2022.127001.35617721
Iyanda AA, Anetor J, Adeniyi FAA. 2011. Altered copper level and renal dysfunction in Nigerian women using skin-whitening agents. Biol Trace Elem Res 143(3):1264–1270. 10.1007/s12011-011-8962-8.21253890
Jaccob AA. 2020. Evaluation of lead and copper content in hair of workers from oil product distribution companies in Iraq. Braz J Pharm Sci 56:e18061. 10.1590/s2175-97902019000318061.
Jacob RA, Skala JH, Omaye ST, 1987. Effect of varying ascorbic acid intakes on copper absorption and ceruloplasmin levels of young men. J Nutr 117(12):2109–2115. 10.1093/jn/117.12.2109.3694287
Janssen RPT, Posthuma L, Baerselman R, 1997. Equilibrium partitioning of heavy metals in Dutch field soils. II. Prediction of metal accumulation in earthworms. Environ Toxicol Chem 16(12):2479–2488. 10.1002/etc.5620161207.
Jenkins D, Russell LL. 1994. Heavy metals contribution of household washing products to municipal wastewater. Water Environ Res 66(6):805–813. 10.2175/WER.66.6.7.
Jing M, Liu Y, Song W, 2016. Oxidative damage induced by copper in mouse primary hepatocytes by single-cell analysis. Environ Sci Pollut Res Int 23(2):1335–1343. 10.1007/s11356-015-5360-3.26358217
Johansson A, Camner P, Jarstrand C, 1983. Rabbit alveolar macrophages after inhalation of soluble cadmium, cobalt, and copper: A comparison with the effects of soluble nickel. Environ Res 31(2):340–354. 10.1016/0013-9351(83)90012-9.6884294
Johansson A, Curstedt T, Robertson B, 1984. Lung morphology and phospholipids after experimental inhalation of soluble cadmium, copper, and cobalt. Environ Res 34(2):295–309. 10.1016/0013-9351(84)90098-7.6745232
Johnson CA, Sigg L, Zobrist J. 1987. Case studies on the chemical composition of fogwater: The influence of local gaseous emissions. Atmos Environ 21(11):2365–2374. 10.1016/0004-6981(87)90371-4.
Johnson PE, Milne DB, Lykken GI. 1992. Effects of age and sex on copper absorption, biological half-life, and status in humans. Am J Clin Nutr 56(5):917–925. 10.1093/ajcn/56.5.917.1329483
Johnson DB, Hedrich S, Pakostova E. 2017. Indirect redox transformations of iron, copper, and chromium catalyzed by extremely acidophilic bacteria. Front Microbiol 8:211. 10.3389/fmicb.2017.00211.28239375
Kadammattil AV, Sajankila SP, Prabhu S, 2018. Systemic toxicity and teratogenicity of copper oxide nanoparticles and copper sulfate. J Nanosci Nanotechnol 18(4):2394–2404. 10.1166/jnn.2018.14542.29442908
Kalita J, Kumar V, Misra UK, 2020. Movement disorder in copper toxicity rat model: Role of inflammation and apoptosis in the corpus striatum. Neurotox Res 37(4):904–912. 10.1007/s12640-019-00140-9.31811585
Kamamoto Y, Makiura S, Sugihara S, 1973. The inhibitory effects of copper on DL-ethionine carcinogenesis in rats. Cancer Res 33(5):1129–1135.4122165
Kang J, Lin C, Chen J, Liu Q. 2004. Copper induces histone hypoacetylation through directly inhibiting histone acetyltransferase activity. Chem Biol Interact 148(3):115–123. 10.1016/j.cbi.2004.05.003.15276868
Karlsson B, Noren L. 1965. Ipecacuanha and copper sulphate as emetics in intoxications in children. Acta Paediatr Scand 54:331–335. 10.1111/j.1651-2227.1965.tb06380.x.14343442
Karlsson HL, Cronholm P, Gustafsson J, 2008. Copper oxide nanoparticles are highly toxic: A comparison between metal oxide nanoparticles and carbon nanotubes. Chem Res Toxicol 21(9):1726–1732. 10.1021/tx800064j.18710264
Kaur S, Raj K, Gupta YK, Singh S. 2021. Allicin ameliorates aluminium- and copper-induced cognitive dysfunction in Wistar rats: relevance to neuro-inflammation, neurotransmitters and Aβ((1–42)) analysis. J Biol Inorg Chem 26(4):495–510. 10.1007/s00775-021-01866-8.34023945
Kennedy E, Everson TM, Punshon T, 2020. Copper associates with differential methylation in placentae from two US birth cohorts. Epigenetics 15(3):215–230. 10.1080/15592294.2019.1661211.31462129
Kennish MJ. 1998. Trace metal-sediment dynamics in estuaries: Pollution assessment. Rev Environ Contam Toxicol 155:69–110. 10.1007/978-1-4612-1684-1_2.
Keshavarzi M, Khodaei F, Siavashpour A, 2019. Hormesis effects of nano- and micro-sized copper oxide. Iran J Pharm Res 18(4):2042–2054. 10.22037/ijpr.2019.13971.12030.32184868
Khaghani S, Ezzatpanah H, Mazhari N, 2010. Zinc and copper concentrations in human milk and infant formulas. Iran J Pediatr 20(1):53–57.23056682
Kheirandish R, Askari N, Babaei H. 2014. Zinc therapy improves deleterious effects of chronic copper administration on mice testes: histopathological evaluation. Andrologia 46(2):80–85. 10.1111/and.12047.23137167
Khushboo M, Murthy MK, Devi MS, 2018. Testicular toxicity and sperm quality following copper exposure in Wistar albino rats: ameliorative potentials of L-carnitine. Environ Sci Pollut Res Int 25(2):1837–1862. 10.1007/s11356-017-0624-8.29103113
Kilbride KM, Paveglio FL, Altstatt AL, 1998. Contaminant loading in drainage and fresh water used for wetland management at Stillwater National Wildlife Refuge. Arch Environ Contam Toxicol 35(2):236–248. 10.1007/s002449900372.9680516
Kim ND, Fergusson JE. 1994. Seasonal variations in the concentrations of cadmium, copper, lead and zinc in leaves of the horse chestnut (Aesculus hippocastanum L.). Environ Pollut 86(1):89–97. 10.1016/0269-7491(94)90010-8.15091650
Kim JS, Adamcakova-Dodd A, O'Shaughnessy PT, 2011. Effects of copper nanoparticle exposure on host defense in a murine pulmonary infection model. Part Fibre Toxicol 8(1):29. 10.1186/1743-8977-8-29.21943386
Kim SY, Park JH, Kim EA, 2012. Longitudinal study on trace mineral compositions (selenium, zinc, copper, manganese) in Korean human preterm milk. J Korean Med Sci 27(5):532–536. 10.3346/jkms.2012.27.5.532.22563219
Kimball KD. 1973. Seasonal fluctuations of ionic copper in Knights Pond, Massachusetts. Limnol Oceanogr 18(1):169–172. 10.4319/lo.1973.18.1.0169.
King LD. 1988. Retention of metals by several soils of the southeastern United States. J Environ Qual 17(2):239–246. 10.2134/jeq1988.00472425001700020013x.
Kjaergaard K, Sandahl TD, Frisch K, 2020. Intravenous and oral copper kinetics, biodistribution and dosimetry in healthy humans studied by [64 Cu] Copper PET/CT. EJNMMI Radiopharm Chem 5(1):15. 10.1186/s41181-020-00100-1.32556736
Kline RD, Hays VW, Cromwell GL. 1971. Effects of copper, molybdenum and sulfate on performance, hematology and copper stores of pigs and lambs. J Anim Sci 33(4):771–779. 10.2527/jas1971.334771x.5092772
Knobeloch L, Ziarnik M, Howard J, 1994. Gastrointestinal upsets associated with ingestion of copper-contaminated water. Environ Health Perspect 102(11):958–961. 10.1289/ehp.94102958.9738210
Knobeloch L, Schubert C, Hayes J, 1998. Gastrointestinal upsets and new copper plumbing - is there a connection? Wis Med J 97(1):49–53.
Kodama H, Fujisawa C, Bhadhprasit W. 2012. Inherited copper transport disorders: Biochemical mechanisms, diagnosis, and treatment. Curr Drug Metab 13(3):237–250. 10.2174/138920012799320455.21838703
Kolbaum AE, Sarvan I, Bakhiya N, 2023. Long-term dietary exposure to copper in the population in Germany - Results from the BfR MEAL study. Food Chem Toxicol 176:113759. 10.1016/j.fct.2023.113759.37028745
Koo YJ, Pack EC, Lee YJ, 2020. Determination of toxic metal release from metallic kitchen utensils and their health risks. Food Chem Toxicol 145:111651. 10.1016/j.fct.2020.111651.32763438
Koutrakis P, Briggs SLK, Leaderer BP. 1992. Source apportionment of indoor aerosols in Suffolk and Onondaga counties, New York. Environ Sci Technol 26(3):521–527. 10.1021/es00027a012.
Krabbe J, Beilmann V, Gerhards B, 2019. The effects of repeated exposure to zinc- and copper-containing welding fumes on healthy volunteers. J Occup Environ Med 61(1):8–15. 10.1097/jom.0000000000001455.30256298
Krabbe J, Hansen C, Otte N, 2023. Short-term exposure to zinc- and copper-containing welding fumes: Effects on pulmonary function in humans. J Trace Elem Med Biol 78:127169. 10.1016/j.jtemb.2023.127169.37004479
Kumar A, Sharma CB. 1987. Hematological indices in copper-poisoned rats. Toxicol Lett 38(3):275–278. 10.1016/0378-4274(87)90009-9.
Kumar V, Kalita J, Misra UK, 2015. A study of dose response and organ susceptibility of copper toxicity in a rat model. J Trace Elem Med Biol 29:269–274. 10.1016/j.jtemb.2014.06.004.25022334
Kumar V, Kalita J, Bora HK, 2016a. Temporal kinetics of organ damage in copper toxicity: A histopathological correlation in rat model. Regul Toxicol Pharmacol 81:372–380. 10.1016/j.yrtph.2016.09.025.27670080
Kumar V, Kalita J, Bora HK, 2016b. Relationship of antioxidant and oxidative stress markers in different organs following copper toxicity in a rat model. Toxicol Appl Pharmacol 293:37–43. 10.1016/j.taap.2016.01.007.26780401
Kumar J, Sathua KB, Flora SJS. 2019. Chronic copper exposure elicit neurotoxic responses in rat brain: Assessment of 8-hydroxy-2-deoxyguanosine activity, oxidative stress and neurobehavioral parameters. Cell Mol Biol 65(1):27–35. 10.14715/cmb/2019.65.1.5.30782290
Kust RN. 1978. Copper compounds. In: Kirk-Othmer encyclopedia of chemical technology. Vol. 7. 3^rd^ ed. New York, NY: John Wiley & Sons, 97–109.
Kvietkauskaite R, Dringeliene A, Markevicius A, 2004. Effect of low copper exposure on the antioxidant system and some immune parameters. Vet Hum Toxicol 46(4):169–172.15303382
Lacerda LD, Santos JA, Lopes DV. 2009. Fate of copper in intensive shrimp farms: bioaccumulation and deposition in pond sediments. Braz J Biol 69(3):851–858. 10.1590/s1519-69842009000400012.19802444
Lagos GE, Cuadrado CA, Letelier MV. 2001. Aging of copper pipes by drinking water. J Am Water Works Assoc 93(11):94–103. 10.1002/j.1551-8833.2001.tb09338.x.
Lamont DL, Duflou JA. 1988. Copper sulfate. Not a harmless chemical. Am J Forensic Med Pathol 9(3):226–227. 10.1097/00000433-198809000-00010.3177352
Landing WM, Perry JJ, Guentzel JL, 1995. Relationships between the atmospheric deposition of trace elements, major ions, and mercury in Florida: The FAMS project (1992–1993). Water Air Soil Pollut 80(1–4):343–352. 10.1007/bf01189684.
Lapid O. 2008. Copper sulphate burns to the hands, a complication of traditional medicine. J Burn Care Res 29(3):544–547. 10.1097/BCR.0b013e3181711183.18388570
Lauenstein GG, Daskalakis KD. 1998. U.S. long-term coastal contaminant temporal trends determined from mollusk monitoring programs, 1965–1993. Mar Pollut Bull 37(1–2):6–13. 10.1016/s0025-326x(98)00125-8.
Law LW. 1938. The effects of chemicals on the lethal mutation rate in Drosophilia melanogaster. Proc Natl Acad Sci U S A 24(12):546–550. 10.1073/pnas.24.12.546.16577855
Lecyk M. 1980. Toxicity of CuSO4 in mice embryonic development. Zool Pol 28:101–105.
Lee IC, Ko JW, Park SH, 2016. Comparative toxicity and biodistribution assessments in rats following subchronic oral exposure to copper nanoparticles and microparticles. Part Fibre Toxicol 13(1):56. 10.1186/s12989-016-0169-x.27788687
Levenson CW, Janghorbani M. 1994. Long-term measurement of organ copper turnover in rats by continuous feeding of a stable isotope. Anal Biochem 221(2):243–249. 10.1006/abio.1994.1408.7810863
Levy DB, Barbarick KA, Siemer EG, 1992. Distribution and partitioning of trace metals in contaminated soils near Leadville, Colorado. J Environ Qual 21(2):185–195. 10.2134/jeq1992.00472425002100020006x.
Li F, Wu X, Liu H, 2021. Dietary copper supplementation enhances lipolysis in Rex rabbits. J Trace Elem Med Biol 68:126851. 10.1016/j.jtemb.2021.126851.34464873
Lifset RJ, Gordon RB, Graedel TE, 2002. Where has all the copper gone: The stocks and flows project, part 1. JOM (1989) 54(10):21–26. 10.1007/bf02709216.
Lifset RJ, Eckelman MJ, Harper EM, 2012. Metal lost and found: dissipative uses and releases of copper in the United States 1975–2000. Sci Total Environ 417–418:138–147. 10.1016/j.scitotenv.2011.09.075.
Lioy PJ, Daisey JM, Morandi MT, 1987. The airborne toxic element and organic substances (ATEOS) study design. In: Lioy PJ, Daisey JM, eds. Toxic air pollution: A comprehensive study of non-criteria air pollutants. Chelsea, MI: Lewis Publishing, Inc., 3–42.
Lisk DJ, Gutenmann WH, Rutzke M, 1992. Survey of toxicants and nutrients in composted waste materials. Arch Environ Contam Toxicol 22(2):190–194. 10.1007/bf00213284.
Liszewski W, Warshaw EM. 2019. Pigments in American tattoo inks and their propensity to elicit allergic contact dermatitis. J Am Acad Dermatol 81(2):379–385. 10.1016/j.jaad.2019.01.078.30731175
Liu C-CF, Medeiros DM. 1986. Excess diet copper increases systolic blood pressure in rats. Biol Trace Elem Res 9(1):15–24. 10.1007/bf02916530.
Liu C, Liang D. 2023. High copper intake is associated with decreased likelihood of abdominal aortic calcification in middle-aged and older US adults. Biol Trace Elem Res 202(4):1390–1400. 10.1007/s12011-023-03765-2.37434038
Liu R, Zhao D, Barnett MO. 2006. Fate and transport of copper applied in channel catfish ponds. Water Air Soil Pollut 176(1–4):139–162. 10.1007/s11270-006-9155-5.
Liu JY, Yang X, Sun XD, 2016. Suppressive effects of copper sulfate accumulation on the spermatogenesis of rats. Biol Trace Elem Res 174(2):356–361. 10.1007/s12011-016-0710-7.27129317
Liu J, Luan J, Zhou X, 2017. Epidemiology, diagnosis, and treatment of Wilson's disease. Intractable Rare Dis Res 6(4):249–255. 10.5582/irdr.2017.01057.29259852
Liu H, Guo H, Deng H, 2020a. Copper induces hepatic inflammatory responses by activation of MAPKs and NF-κB signalling pathways in the mouse. Ecotoxicol Environ Saf 201:110806. 10.1016/j.ecoenv.2020.110806.32512418
Liu H, Guo H, Jian Z, 2020b. Copper induces oxidative stress and apoptosis in the mouse liver. Oxid Med Cell Longev 2020:1359164. 10.1155/2020/1359164.32411316
Liu H, Deng H, Jian Z, 2021a. Copper exposure induces hepatic G0/G1 cell-cycle arrest through suppressing the Ras/PI3K/Akt signaling pathway in mice. Ecotoxicol Environ Saf 222:112518. 10.1016/j.ecoenv.2021.112518.34271501
Liu H, Deng H, Cui H, 2021b. Copper induces hepatocyte autophagy via the mammalian targets of the rapamycin signaling pathway in mice. Ecotoxicol Environ Saf 208:111656. 10.1016/j.ecoenv.2020.111656.33396170
Liu H, Zhou J, Li M, 2021c. Chemical speciation of trace metals in atmospheric deposition and impacts on soil geochemistry and vegetable bioaccumulation near a large copper smelter in China. J Hazard Mater 413:125346. 10.1016/j.jhazmat.2021.125346.33621776
Llewellyn GC, Floyd EA, Hoke GD, 1985. Influence of dietary aflatoxin, zinc, and copper on bone size, organ weight, and body weight in hamsters and rats. Bull Environ Contam Toxicol 35(2):149–156. 10.1007/BF01636493.4027418
Lodenius M, Braunschweiler H. 1986. Volatilisation of heavy metals from a refuse dump. Sci Total Environ 57:253–255. 10.1016/0048-9697(86)90027-6.
Long DT, Angino EE. 1977. Chemical speciation of Cd, Cu, Pb, and Zn in mixed freshwater, seawater, and brine solutions. Geochim Cosmochim Acta 41(9):1183–1191. 10.1016/0016-7037(77)90064-3.
Long P, Wang Q, Zhang Y, 2021. Profile of copper-associated DNA methylation and its association with incident acute coronary syndrome. Clin Epigenetics 13(1):19. 10.1186/s13148-021-01004-w.33499918
Loranger S, Tetrault M, Kennedy G, 1996. Manganese and other trace elements in urban snow near an expressway. Environ Pollut 92(2):203–211. 10.1016/0269-7491(95)00082-8.15091400
Lores EM, Pennock JR. 1998. The effect of salinity on binding of Cd, Cr, Cu and Zn to dissolved organic matter. Chemosphere 37(5):861–874. 10.1016/s0045-6535(98)00090-3.
Lubica C, Rudolf M, Jiri L. 2017. Acute copper sulphate poisoning. J Coll Physicians Surg Pak 27(8):527–528.28903855
Luncan-Bouché ML, Couderchet M, Vernet G, 1997. The simultaneous influence of pH and temperature on binding and mobilization of metals in sand: 1-Copper. Fresenius Environ Bull 6:711–718.
Luo J, Hao S, Zhao L, 2020. Oral exposure of pregnant rats to copper nanoparticles caused nutritional imbalance and liver dysfunction in fetus. Ecotoxicol Environ Saf 206:111206. 10.1016/j.ecoenv.2020.111206.32889309
Ma LQ, Rao GN. 1997. Chemical fractionation of cadmium, copper, nickel, and zinc in contaminated soils. J Environ Qual 26(1):259–264. 10.2134/jeq1997.00472425002600010036x.
Maessen O, Freedman B, McCurdy R. 1985. Metal mobilization in home well water systems in Nova Scotia. J Am Water Works Assoc 77(6):73–80. 10.1002/j.1551-8833.1985.tb05557.x.
Mahdy AM, Elkhatib EA, Fathi NO. 2007. Cadmium, copper, nickel, and lead availability in biosolids-amended alkaline soils. Aust J Basic Appl Sci 1(4):354–363.
Makale MT, King GL. 1992. Surgical and pharmacological dissociation of cardiovascular and emetic responses to intragastric CuSO4. Am J Physiol 263(2 Pt 2):R284–291. 10.1152/ajpregu.1992.263.2.R284.1354943
Malik M, Mansur A. 2011. Copper sulphate poisoning and exchange transfusion. Saudi J Kidney Dis Transpl 22(6):1240–1242.22089793
Mandil R, Prakash A, Rahal A, 2020. In vitro and in vivo effects of flubendiamide and copper on cyto-genotoxicity, oxidative stress and spleen histology of rats and its modulation by resveratrol, catechin, curcumin and α-tocopherol. BMC Pharmacol Toxicol 21(1):29. 10.1186/s40360-020-00405-6.32326976
Mannsville Chemical Products. 1984. Chemical products synopsis: Copper sulfate. Cortland, NY: Mannsville Chemical Products Corp. 115–117.
Marinussen MPJC, Zee SEATM, Haan FAM, 1997. Heavy metal (copper, lead, and zinc) accumulation and excretion by the earthworm, Dendrobaena veneta. J Environ Qual 26(1):278–284. 10.2134/jeq1997.00472425002600010039x.
Mark AB, Kapolna E, Laursen KH, 2013. Consumption of organic diets does not affect intake and absorption of zinc and copper in men - evidence from two cross-over trials. Food Funct 4(3):409–419. 10.1039/c2fo30247k.23192634
Markert A, Baumann R, Gerhards B, 2016. Single and combined exposure to zinc- and copper-containing welding fumes lead to asymptomatic systemic inflammation. J Occup Environ Med 58(2):127–132. 10.1097/JOM.0000000000000652.26849256
Mart L, Nürnberg HW, Dyrssen D. 1984. Trace metal levels in the Eastern Arctic Ocean. Sci Total Environ 39(1):1–14. 10.1016/0048-9697(84)90020-2.
Martin M, Castle W. 1984. Petrowatch: Petroleum hydrocarbons, synthetic organic compounds, and heavy metals in mussels from the Monterey Bay area of central California. Mar Pollut Bull 15(7):259–266. 10.1016/0025-326x(84)90366-7.
Marzin DR, Phi HV. 1985. Study of the mutagenicity of metal derivatives with Salmonella typhimurium. Mutat Res 155:49–51. 10.1016/0165-1218(85)90024-2.3881664
Massie HR, Aiello VR. 1984. Excessive intake of copper: influence on longevity and cadmium accumulation in mice. Mech Ageing Dev 26(2–3):195–203. 10.1016/0047-6374(84)90093-9.6482518
May TW, Wiedmeyer RH, Gober J, 2001. Influence of mining-related activities on concentrations of metals in water and sediment from streams of the Black Hills, South Dakota. Arch Environ Contam Toxicol 40(1):1–9. 10.1007/s002440010142.11116335
McArdle HJ. 1995. The metabolism of copper during pregnancy-a review. Food Chem 54(1):79–84. 10.1016/0308-8146(95)92666-8.
McCrady JK, Chapman GA. 1979. Determination of copper complexing capacity of natural river water, well water and artificially reconstituted water. Water Res 13(2):143–150. 10.1016/0043-1354(79)90085-x.
McGeer JC, Brix KV, Skeaff JM, 2003. Inverse relationship between bioconcentration factor and exposure concentration for metals: Implications for hazard assessment of metals in the aquatic environment. Environ Toxicol Chem 22(5):1017–1037. 10.1002/etc.5620220509.12729211
McIlroy LM, Depinto JV, Young TC, 1986. Partitioning of heavy metals to suspended solids of the Flint River, Michigan. Environ Toxicol Chem 5(7):609–623. 10.1002/etc.5620050702.
Melake BA, Endalew SM, Alamirew TS, 2023. Bioaccumulation and biota-sediment accumulation factor of metals and metalloids in edible fish: A systematic review in Ethiopian surface waters. Environ Health Insights 17:11786302231159349. 10.1177/11786302231159349.36969092
Melino S, Nepravishta R, Bellomaria A, 2009. Nucleic acid binding of the RTN1-C C-terminal region: Toward the functional role of a reticulon protein. Biochemistry 48(2):242–253. 10.1021/bi801407w.19140693
Meranger JC, Subramanian KS, Chalifoux C. 1979. A national survey for cadmium, chromium, copper, lead, zinc, calcium, and magnesium in Canadian drinking water supplies. Environ Sci Technol 13(6):707–711. 10.1021/es60154a009.
Mercadante CJ, Herrera C, Pettiglio MA, 2016. The effect of high dose oral manganese exposure on copper, iron and zinc levels in rats. Biometals 29(3):417–422. 10.1007/s10534-016-9924-6.26988220
Mercer JF, Lazdins I, Stevenson T, 1981. Copper induction of translatable metallothionein messenger RNA. Biosci Rep 1(10):793–800. 10.1007/BF01114802.6796153
Mezzaroba L, Alfieri DF, Colado Simão AN, 2019. The role of zinc, copper, manganese and iron in neurodegenerative diseases. Neurotoxicology 74:230–241. 10.1016/j.neuro.2019.07.007.31377220
Miller DR, Byrd JE, Perona MJ. 1987. The source of Pb, Cu, and Zn in fogwater. Water Air Soil Pollut 32(3–4):329–340. 10.1007/bf00225119.
Mills GL, Quinn JG. 1984. Dissolved copper and copper-organic complexes in the Narragansett Bay estuary. Mar Chem 15(2):151–172. 10.1016/0304-4203(84)90013-6.
Moffett J, Zika R. 1987. Photochemistry of copper complexes in sea water. ACS Symp Ser 327:116–130. 10.1021/bk-1987-0327.ch009.
Montagnino E, Lytle DA, Rose J, 2022. School and childcare center drinking water: Copper chemistry, health effects, occurrence, and remediation. AWWA Water Sci 4(2):e1270. 10.1002/aws2.1270.35865674
Moriya M, Ho YH, Grana A, 2008. Copper is taken up efficiently from albumin and α2-macroglobulin by cultured human cells by more than one mechanism. Am J Physiol Cell Physiol 295(3):C708–C721. 10.1152/ajpcell.00029.2008.18579803
Morris AE, Wadsley M. 2001. Metal extraction: Phase stability diagrams. In: Buschow KHJ, Cahn RW, Flemings MC, , eds. Encyclopedia of materials: Science and technology. Oxford: Elsevier, 5362–5377. 10.1016/b0-08-043152-6/00936-0.
Mortazavi F, Jafari-Javid A. 2009. Acute renal failure due to copper sulfate poisoning: A case report. Iran J Pediatr 19(1):75–78.
Motlhatlhedi K, Firth JA, Setlhare V, 2014. A novel and fatal method of copper sulphate poisoning. Afr J Emerg Med 4(4):e23–e25. 10.1016/j.afjem.2014.02.002.
Mourad BH, El-Sherif GH. 2022. Exploring the link between the serum/blood levels of heavy metals (Pb, As, Cd, and Cu) and 2 novel biomarkers of cardiovascular stress (growth differentiation factor 15 and soluble suppression of tumorigenicity 2) in copper smelter workers. J Occup Environ Med 64(11):976–984. 10.1097/JOM.0000000000002624.35902369
Moussiegt A, Ferreira L, Aboab J, 2020. She has the blues: An unusual case of copper sulphate intoxication. Eur J Case Rep Intern Med 7(2):001394. 10.12890/2020_001394.32133310
Mulder EG, van Veen WL. 1968. Effect of microorganisms on the transformation of mineral fractions in soil. Trans Int Cong Soil Sci 9:651–661.
Müller T, Feichtinger H, Berger H, 1996. Endemic Tyrolean infantile cirrhosis: an ecogenetic disorder. Lancet 347(9005):877–880. 10.1016/s0140-6736(96)91351-3.8622397
Müller T, Müller W, Feichtinger H. 1998. Idiopathic copper toxicosis. Am J Clin Nutr 67(5):1082S–1086S. 10.1093/ajcn/67.5.1082S.9587156
Mullins MJP, Norman JB. 1994. Solubility of metals in windblown dust from mine waste dump sites. Appl Occup Environ Hyg 9(3):218–223. 10.1080/1047322x.1994.10388301.
Mumma RO, Raupach DC, Waldman JP, 1984. National survey of elements and other constituents in municipal sewage sludges. Arch Environ Contam Toxicol 13(1):75–83. 10.1007/bf01055648.
Mumtaz MM, Ray M, Crowell SR, 2012a. Translational research to develop a human PBPK models tool kit-volatile organic compounds (VOCs). J Toxicol Environ Health A 75(1):6–24. 10.1080/15287394.2012.625546.22047160
Mumtaz M, Fisher J, Blount B, 2012b. Application of physiologically based pharmacokinetic models in chemical risk assessment. J Toxicol 2012:904603. 10.1155/2012/904603.22523493
Murphy EA. 1993. Effectiveness of flushing on reducing lead and copper levels in school drinking water. Environ Health Perspect 101(3):240–241. 10.1289/ehp.93101240.8404761
Murthy RC, Lal S, Saxena DK, 1981. Effect of manganese and copper interaction on behavior and biogenic amines in rats fed a 10% casein diet. Chem Biol Interact 37(3):299–308. 10.1016/0009-2797(81)90116-2.7296699
Musci G, Bonaccorsi di Patti MC, Calabrese L. 1993. The state of the copper sites in human ceruloplasmin. Arch Biochem Biophys 306(1):111–118. 10.1006/abbi.1993.1487.8215390
Mussalo-Rauhamaa H, Leppanen A, Salmela SS, 1986. Cigarettes as a source of some trace and heavy metals and pesticides in man. Arch Environ Health 41(1):49–55. 10.1080/00039896.1986.9935765.3963887
Myint ZW, Oo TH, Thein KZ, 2018. Copper deficiency anemia: review article. Ann Hematol 97(9):1527–1534. 10.1007/s00277-018-3407-5.29959467
NAS/NRC. 2006. Human biomonitoring for environmental chemicals. Washington, DC: The National Academies Press, National Research Council. 10.17226/11700.
Naveed M, Moldrup P, Arthur E, 2014. Simultaneous loss of soil biodiversity and functions along a copper contamination gradient: When soil goes to sleep. Soil Sci Soc Am J 78(4):1239–1250. 10.2136/sssaj2014.02.0052.
Nayak NC, Chitale AR. 2013. Indian childhood cirrhosis (ICC) & ICC-like diseases: the changing scenario of facts versus notions. Indian J Med Res 137(6):1029–1042.23852284
Naz S, Gul A, Zia M. 2020. Toxicity of copper oxide nanoparticles: a review study. IET Nanobiotechnol 14(1):1–13. 10.1049/iet-nbt.2019.0176.31935671
Ndilila W, Callan AC, McGregor LA, 2014. Environmental and toenail metals concentrations in copper mining and non-mining communities in Zambia. Int J Hyg Environ Health 217(1):62–69. 10.1016/j.ijheh.2013.03.011.23623595
Nerín C, Domeño C, García JI, 1999. Distribution of Pb, V, Cr, Ni, Cd, Cu and Fe in particles formed from the combustion of waste oils. Chemosphere 38(7):1533–1540. 10.1016/s0045-6535(98)00373-7.10070733
Neuhauser EF, Cukic ZV, Malecki MR, 1995. Bioconcentration and biokinetics of heavy metals in the earthworm. Environ Pollut 89(3):293–301. 10.1016/0269-7491(94)00072-l.15091519
Ni L, Li S. 2008. Effects of organic matters coming from Chinese tea on soluble copper release from copper teapot. Sci Total Environ 389(1):202–207. 10.1016/j.scitotenv.2007.08.039.17904199
NIH. 2022. Copper. Fact sheet for consumers. National Institutes of Health. https://ods.od.nih.gov/factsheets/Copper-Consumer/. January 25, 2024.
NIOSH. 1988. National occupational exposure survey as of 05/10/88. National Institute for Occupational Safety and Health.
NIOSH. 1989. National Occupational Exposure Survey (potential exposure agents list). Cincinnati, OH: National Institute for Occupational Safety and Health.
NIOSH. 2014a. Method 7302: Elements by ICP (microwave digestion). National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/docs/2003-154/pdfs/7302.pdf. March 20, 2024.
NIOSH. 2014b. Method 7304: Elements by ICP (microwave digestion). National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/docs/2003-154/pdfs/7304.pdf. March 20, 2024.
NIOSH. 2018. Method 8200: Elements by tissues. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/docs/2014-151/pdfs/methods/8200.pdf. March 20, 2024.
NIOSH. 2019a. Copper (dust and mists, as Cu). NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0150.html. October 30, 2023.
NIOSH. 2019b. Copper fume (as Cu). NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0151.html. October 30, 2023.
Nishioka H. 1975. Mutagenic activities of metal compounds in bacteria. Mutat Res 31(3):185–189. 10.1016/0165-1161(75)90088-6.805366
Nishito Y, Kambe T. 2018. Absorption mechanisms of iron, copper, and zinc: An overview. J Nutr Sci Vitaminol (Tokyo) 64(1):1–7. 10.3177/jnsv.64.1.29491267
NLM. 2024. Copper; copper chloride; copper sulfate. PubChem. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/. January 25, 2024.
Nölte J. 1988. Pollution source analysis of river water and sewage sludge. Environ Technol Lett 9(8):857–868. 10.1080/09593338809384642.
NRC. 1993. Pesticides in the diets of infants and children. National Research Council. https://www.ncbi.nlm.nih.gov/books/NBK236275/. January 25, 2024.
NRC. 1995. Nutrient requirements of laboratory animals, fourth revised edition. Washington, DC: National Research Council. 10.17226/4758.
NRC. 2000. Copper in drinking water. Washington, DC: National Academies Press. 10.17226/9782.
Nriagu JO, Coker RD. 1980. Trace metals in humic and fulvic acids from Lake Ontario sediments. Environ Sci Technol 14(4):443–446. 10.1021/es60164a001.22288632
Nriagu JO, Pacyna JM. 1988. Quantitative assessment of worldwide contamination of air, water and soils by trace metals. Nature 333(6169):134–139. 10.1038/333134a0.3285219
Nriagu JO, Lawson G, Wong HKT, 1996. Dissolved trace metals in Lakes Superior, Erie, and Ontario. Environ Sci Technol 30(1):178–187. 10.1021/es950221i.
NSF. 2021. NSF product and service listings. NSF/ANSI/CAN 60. Drinking water treatment chemicals - health effects. NSF International. http://info.nsf.org/Certified/PwsChemicals/Listings.asp?ChemicalName=Copper+Sulfate&PlantCou ntry=UNITED+STATES&. April 9, 2021.
NTP. 1993. NTP technical report on toxicity studies of cupric sulfate (CAS No. 7758–99-8) administered in drinking water and feed to F344/N rats and B6C3F1 mice. Research Triangle Park, NC: National Toxicology Program. NIH Publication 93–3352. NTP TR 29. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB94120870.xhtml. March 21, 2024.
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments – February 2013. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/draftohatapproach_february2013.pdf. October 4, 2023.
NTP. 2015. OHAT risk of bias rating tool for human and animal studies. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/pubs/riskofbiastool_508.pdf. March 19, 2019.
NTP. 2021. CASRN index. In: Report on carcinogens. 15^th^ ed. National Toxicology Program, https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. January 10, 2022.
O'Connor JM, Bonham MP, Turley E, 2003. Copper supplementation has no effect on markers of DNA damage and liver function in healthy adults (FOODCUE project). Ann Nutr Metab 47(5):201–206. 10.1159/000070486.12748413
Odai T, Terauchi M, Suzuki R, 2020. Severity of subjective forgetfulness is associated with high dietary intake of copper in Japanese senior women: A cross-sectional study. Food Sci Nutr 8(8):4422–4431. 10.1002/fsn3.1740.32884722
O'Donohue JW, Reid MA, Varghese A, 1993. Micronodular cirrhosis and acute liver failure due to chronic copper self-intoxication. Eur J Gastroenterol Hepatol 5(7):561–562.
Ognik K, Cholewinska E, Juskiewicz J, 2019. The effect of copper nanoparticles and copper (II) salt on redox reactions and epigenetic changes in a rat model. J Anim Physiol Anim Nutr (Berl) 103(2):675–686. 10.1111/jpn.13025.30618103
Ogra Y, Ohmichi M, Suzuki KT. 1996. Mechanisms of selective copper removal by tetrathiomolybdate from metallothionein in LEC rats. Toxicology 106(1–3):75–83. 10.1016/0300-483x(95)03171-b.8571404
Ogunbileje JO, Sadagoparamanujam VM, Anetor JI, 2013. Lead, mercury, cadmium, chromium, nickel, copper, zinc, calcium, iron, manganese and chromium (VI) levels in Nigeria and United States of America cement dust. Chemosphere 90(11):2743–2749. 10.1016/j.chemosphere.2012.11.058.23261125
Ohgami RS, Campagna DR, McDonald A, 2006. The Steap proteins are metalloreductases. Blood 108(4):1388–1394. 10.1182/blood-2006-02-003681.16609065
Olivares M, Pizarro F, Speisky H, 1998. Copper in infant nutrition: safety of World Health Organization provisional guideline value for copper content of drinking water. J Pediatr Gastroenterol Nutr 26(3):251–257. 10.1097/00005176-199803000-00003.9523857
Olivares M, Araya M, Uauy R. 2000. Copper homeostasis in infant nutrition: Deficit and excess. J Pediatr Gastroenterol Nutr 31:102–111. 10.1097/00005176-200008000-00004.10941959
Olivares M, Araya M, Pizarro F, 2001. Nausea threshold in apparently healthy individuals who drink fluids containing graded concentrations of copper. Regul Toxicol Pharmacol 33(3):271–275. 10.1006/rtph.2000.1440.11407930
Olivares M, Lonnerdal B, Abrams SA, 2002. Age and copper intake do not affect copper absorption, measured with the use of 65Cu as a tracer, in young infants. Am J Clin Nutr 76(3):641–645. 10.1093/ajcn/76.3.641.12198012
Oliveri V. 2023. Unveiling the effects of copper ions in the aggregation of amyloidogenic proteins. Molecules 28(18):6446. 10.3390/molecules28186446.37764220
Olmedo P, Hernández AF, Pla A, 2013. Determination of essential elements (copper, manganese, selenium and zinc) in fish and shellfish samples. Risk and nutritional assessment and mercury– selenium balance. Food Chem Toxicol 62:299–307. 10.1016/j.fct.2013.08.076.24007738
Oon S, Yap CH, Ihle BU. 2006. Acute copper toxicity following copper glycinate injection. Intern Med J 36(11):741–743. 10.1111/j.1445-5994.2006.01195.x.17040362
Oorts K. 2012. Copper. In: Alloway B, ed. Heavy metals in soils. Dodrecht: Springer, online. 10.1007/978-94-007-4470-7_13.
Osán J, Meirer F, Groma V, 2010. Speciation of copper and zinc in size-fractionated atmospheric particulate matter using total reflection mode X-ray absorption near-edge structure spectrometry. Spectrochim Acta Part B At Spectrosc 65(12):1008–1013. 10.1016/j.sab.2010.11.002.
OSHA. 2020a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000: https://www.govinfo.gov/content/pkg/CFR-2020-title29-vol6/pdf/CFR-2020-title29-vol6-sec1910-1000.pdf. November 5, 2023.
OSHA. 2020b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.govinfo.gov/content/pkg/CFR-2020-title29-vol7/pdf/CFR-2020-title29-vol7-sec1915-1000.pdf. November 5, 2023.
OSHA. 2020c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55 Appendix A. https://www.govinfo.gov/content/pkg/CFR-2020-title29-vol8/pdf/CFR-2020-title29-vol8-sec1926-55.pdf. November 5, 2023.
OSHA. 2023. Copper, fume (as Cu). OSHA occupational chemical database. Occupational Safety and Health Administration. https://www.osha.gov/chemicaldata/1031. January 25, 2024.
Ostro B, Hu J, Goldberg D, 2015. Associations of mortality with long-term exposures to fine and ultrafine particles, species and sources: results from the California Teachers Study Cohort. Environ Health Perspect 123(6):549–556. 10.1289/ehp.1408565.25633926
Pacyna JM, Pacyna EG. 2001. An assessment of global and regional emissions of trace metals to the atmosphere from anthropogenic sources worldwide. Environmental Reviews 9(4):269–298. 10.1139/a01-012.
Page GW. 1981. Comparison of groundwater and surface water for patterns and levels of contamination by toxic substances. Environ Sci Technol 15(12):1475–1481. 10.1021/es00094a008.
Pandit A, Bhave S. 1996. Present interpretation of the role of copper in Indian childhood cirrhosis. Am J Clin Nutr 63(5):830S–835S. 10.1093/ajcn/63.5.830.8615370
Paode RD, Sofuoglu SC, Sivadechathep J, 1998. Dry deposition fluxes and mass size distributions of Pb, Cu, and Zn measured in Southern Lake Michigan during AEOLOS. Environ Sci Technol 32(11):1629–1635. 10.1021/es970892b.
Pappas RS, Gray N, Halstead M, 2024. Lactic acid salts of nicotine potentiate the transfer of toxic metals into electronic cigarette aerosols. Toxics 12(1):65. 10.3390/toxics12010065.38251020
Park KS, Kwon JH, Park SH, 2018. Acute copper sulfate poisoning resulting from dermal absorption. Am J Ind Med 61:783–788. 10.1002/ajim.22892.
Parlak Ak T, Tatli Seven P, Gur S, 2021. Chrysin and flunixin meglumine mitigate overloaded copper-induced testicular and spermatological damages via modulation of oxidative stress and apoptosis in rats. Andrologia 54(2):e14327. 10.1111/and.14327.34817900
Patwa J, Flora SJS. 2020. MiADMSA abrogates chronic copper-induced hepatic and immunological changes in Sprague Dawley rats. Food Chem Toxicol 145:111692. 10.1016/j.fct.2020.111692.32871191
Patwa J, Thakur A, Flora SJS. 2022. Alpha lipoic acid and monoisoamyl-DMSA combined treatment ameliorates copper-induced neurobehavioral deficits, oxidative stress, and inflammation. Toxics 10(12):718. 10.3390/toxics10120718.36548551
Pekelharing HL, Lemmens AG, Beynen AC. 1994. Iron, copper and zinc status in rats fed on diets containing various concentrations of tin. Br J Nutr 71(1):103–109. 10.1079/bjn19940115.8312234
Peng X, Dai C, Zhang M, 2020. Molecular mechanisms underlying protective role of quercetin on copper sulfate-induced nephrotoxicity in mice. Front Vet Sci 7:586033. 10.3389/fvets.2020.586033.33490128
Pennington JA, Schoen SA. 1996. Contributions of food groups to estimated intakes of nutritional elements: results from the FDA total diet studies, 1982–1991. Int J Vitam Nutr Res 66(4):342–349.8979163
Pennington JA, Young BE, Wilson DB, 1986. Mineral content of foods and total diets: the Selected Minerals in Foods Survey, 1982 to 1984. J Am Diet Assoc 86(7):876–891.3722652
Peralta AA, Schwartz J, Gold DR, 2021. Associations between PM2.5 metal components and QT interval length in the Normative Aging Study. Environ Res 195:110827. 10.1016/j.envres.2021.110827.33549618
Perestrelo AP, Miranda G, Gonçalves MI, 2021. Chronic copper sulfate poisoning. Eur J Case Rep Intern Med 8(3):002309. 10.12890/2021_002309.33768078
Petruzzelli G. 1997. Chapter 5: Soil sorption of heavy metals. In: Ecological issues and environmental impact assessment. Houston, TX: Gulf Publications, 145–175.
Petruzzelli G, Lubrano L, Petronio BM, 1994. Soil sorption of heavy metals as influenced by sewage sludge addition. J Environ Sci Health A Tox Hazard Subst Environ Eng 29(1):31–50. 10.1080/10934529409376020.
Pettersson R, Rasmussen F, Oskarsson A. 2003. Copper in drinking water: Not strong risk factor for diarrhoea among young children. A population-based study from Sweden. Acta Paediatr 92(4):473–480. 10.1111/j.1651-2227.2003.tb00581.x.12801116
Pimentel JC, Marques F. 1969. "Vineyard sprayer's lung": A new occupational disease. Thorax 24(6):678–688. 10.1136/thx.24.6.678.5350718
Pimentel JC, Menezes AP. 1975. Liver granulomas containing copper in vineyard sprayer's lung. A new etiology of hepatic granulomatosis. Am Rev Respir Dis 111(2):189–195. 10.1164/arrd.1975.111.2.189.1111404
Pinochet H, De Gregori I, Lobos MG, 1999. Selenium and copper in vegetables and fruits grown on long-term impacted soils from Valparaiso region, Chile. Bull Environ Contam Toxicol 63(3):327–334. 10.1007/s001289900984.10475910
Pirot F, Millet J, Kalia YN, 1996a. In vitro study of percutaneous absorption, cutaneous bioavailability and bioequivalence of zinc and copper from five topical formulations. Skin Pharmacol 9(4):259–269. 10.1159/000211423.8896117
Pirot F, Panisset F, Agache P, 1996b. Simultaneous absorption of copper and zinc through human skin in vitro: influence of counter-ion and vehicle. Skin Pharmacol 9(1):43–52. 10.1159/000211389.8868032
Pirrone N, Keeler GJ. 1993. Deposition of trace metals in urban and rural areas in the lake michigan basin. Water Sci Technol 28(3–5):261–270. 10.2166/wst.1993.0427.
Pitt R, Field R, Lalor M, 1995. Urban stormwater toxic pollutants: assessment, sources, and treatability. Water Environ Res 67(3):260–275. 10.2175/106143095x131466.
Pizarro F, Olivares M, Uauy R, 1999. Acute gastrointestinal effects of graded levels of copper in drinking water. Environ Health Perspect 107(2):117–121. 10.1289/ehp.99107117.9924006
Pizarro F, Olivares M, Araya M, 2001. Gastrointestinal effects associated with soluble and insoluble copper in drinking water. Environ Health Perspect 109(9):949–952. 10.1289/ehp.01109949.11673125
Plamenac P, Santic Z, Nikulin A, 1985. Cytologic changes of the respiratory tract in vineyard spraying workers. Eur J Respir Dis 67(1):50–55.4054256
Poland CA, Hubbard SA, Levy L, 2022. Inhalation toxicity of copper compounds: Results of 14-day range finding study for copper sulphate pentahydrate and dicopper oxide and 28-day subacute inhalation exposure of dicopper oxide in rats. Toxicology 474:153221. 10.1016/j.tox.2022.153221.35659515
Poulton DJ, Simpson KJ, Barton DR, 1988. Trace metals and benthic invertebrates in sediments of nearshore Lake Ontario at Hamilton Harbour. J Great Lakes Res 14(1):52–65. 10.1016/s0380-1330(88)71532-4.
Prá D, Franke SI, Giulian R, 2008. Genotoxicity and mutagenicity of iron and copper in mice. Biometals 21(3):289–297. 10.1007/s10534-007-9118-3.17926008
Prasad AS, Brewer GJ, Schoomaker EB, 1978. Hypocupremia induced by zinc therapy in adults. JAMA 240(20):2166–2168. 10.1001/jama.1978.03290200044019.359844
Prasad R, Kumar SR, Kumar S. 2006. Hydrogen peroxide commences copper induced DNA damage isolated from human blood: in vitro study. Indian J Exp Biol 44(5):377–380.16708890
Pratt WB, Omdahl JL, Sorenson JR. 1985. Lack of effects of copper gluconate supplementation. Am J Clin Nutr 42(4):681–682. 10.1093/ajcn/42.4.681.2931973
Puchkova LV, Babich PS, Zatulovskaia YA, 2018. Copper metabolism of newborns is adapted to milk ceruloplasmin as a nutritive source of copper: Overview of the current data. Nutrients 10(11):1591. 10.3390/nu10111591.30380720
Que Hee SS, Finelli VN, Fricke FL, 1982. Metal content of stack emissions, coal and fly ash from some eastern and western power plants in the U.S.A. as obtained by ICP-AES. Int J Environ Anal Chem 13(1):1–18. 10.1080/03067318208071579.
Rader KJ, Carbonaro RF, van Hullebusch ED, 2019. The fate of copper added to surface water: Field, laboratory, and modeling studies. Environ Toxicol Chem 38(7):1386–1399. 10.1002/etc.4440.30969442
Raghunath R, Tripathi RM, Khandekar RN, 1997. Retention times of Pb, Cd, Cu and Zn in children's blood. Sci Total Environ 207(2–3):133–139. 10.1016/s0048-9697(97)00255-6.9447742
Raghunath R, Tripathi RM, Kumar AV, 1999. Assessment of Pb, Cd, Cu, and Zn exposures of 6-to 10-year-old children in Mumbai. Environ Res 80(3):215–221. 10.1006/enrs.1998.3919.10092442
Rajaratnam G, Winder C, An M. 2002. Metals in drinking water from new housing estates in the Sydney area. Environ Res 89(2):165–170. 10.1006/enrs.2002.4356.12123649
Rammah A, Whitworth KW, Han I, 2019. PM2.5 metal constituent exposure and stillbirth risk in Harris County, Texas. Environ Res 176:108516. 10.1016/j.envres.2019.05.047.31195296
Rana SV, Kumar A. 1980. Biological haematological and histological observations in copper poisoned rats. Ind Health 18(1):9–17. 10.2486/indhealth.18.9.7451247
Ranucci G, Di Dato F, Spagnuolo M, 2014. Zinc monotherapy is effective in Wilson's disease patients with mild liver disease diagnosed in childhood: A retrospective study. J Rare Dis (Berlin) 9:41. 10.1186/1750-1172-9-41.
Raspor B, Nürnberg HW, Valenta P, 1984. Studies in seawater and lake water on interactions of trace metals with humic substances isolated from marine and estuarine sediments. Mar Chem 15(3):231–249. 10.1016/0304-4203(84)90020-3.
Rauch JN, Graedel TE. 2007. Earth's anthrobiogeochemical copper cycle. Global Biogeochem Cycles 21(2):GB2010. 10.1029/2006GB002850.
Raven KP, Loeppert RH. 1997. Trace element composition of fertilizers and soil amendments. J Environ Qual 26(2):551–557. 10.2134/jeq1997.00472425002600020028x.
Reed JS, Henningson JC. 1984. Acid precipitation and drinking water supplies. J Am Water Works Assoc 76:60–65.
Reisgen M, Thomas K, Beilmann V, 2020. Increased neutrophil granulocyte and myeloperoxidase levels indicate acute inflammation due to the exposure of zinc- and copper-containing welding fumes. J Occup Environ Med 62(8):618–627. 10.1097/jom.0000000000001905.32404823
RePORTER. 2024. Copper. Research Portfolio Online Reporting Tools. National Institutes of Health. https://reporter.nih.gov/. January 16, 2024.
Rice KC. 1999. Trace-element concentrations in streambed sediment across the conterminous United States. Environ Sci Technol 33(15):2499–2504. 10.1021/es990052s.
Richards BK, Steenhuis TS, Peverly JH, 1998. Metal mobility at an old, heavily loaded sludge application site. Environ Pollut 99(3):365–377. 10.1016/s0269-7491(98)00011-6.15093301
Rieuwerts JS, Thornton I, Farago ME, 1998. Factors influencing metal bioavailability in soils: preliminary investigations for the development of a critical loads approach for metals. Chem Speciat Bioavail 10(2):61–75. 10.3184/095422998782775835.
Ritter WF, Eastburn RP. 1978. Leaching of heavy metals from sewage sludge through coastal plain soils. Commun Soil Sci Plant Anal 9(9):785–798. 10.1080/00103627809366853.
Rodriguez-Castro KI, Hevia-Urrutia FJ, Sturniolo GC. 2015. Wilson's disease: A review of what we have learned. World J Hepatol 7(29):2859–2870. 10.4254/wjh.v7.i29.2859.26692151
Rohr U, Senger M, Selenka F, 1999. Four years of experience with silver-copper ionization for control of legionella in a German university hospital hot water plumbing system. Clin Infect Dis 29(6):1507–1511. 10.1086/313512.10585804
Rojas-Sobarzo L, Olivares M, Brito A, 2013. Copper supplementation at 8 mg neither affects circulating lipids nor liver function in apparently healthy Chilean men. Biol Trace Elem Res 156(1–3):1–4. 10.1007/s12011-013-9823-4.24096552
Romeu-Moreno A, Aguilar C, Arola L, 1994. Respiratory toxicity of copper. Environ Health Perspect 102 (Suppl 3):339–340. 10.1289/ehp.94102s3339.7843131
Romo-Kröger CM, Morales JR, Dinator MI, 1994. Heavy metals in the atmosphere coming from a copper smelter in Chile. Atmos Environ 28(4):705–711. 10.1016/1352-2310(94)90047-7.
Rooney AA, Boyles AL, Wolfe MS, 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Rösner U. 1998. Effects of historical mining activities on surface water and groundwater - an example from northwest Arizona. Environ Geol 33(4):224–230. 10.1007/s002540050241.
Rossner P, Vrbova K, Rossnerova A, 2020. Gene expression and epigenetic changes in mice following inhalation of copper(II) oxide nanoparticles. Nanomaterials 10:550. 10.3390/nano10030550.32197515
Roy WR. 1994. Groundwater contamination form municipal landfills in the USA. In: Adriano D, ed. Contamination of groundwaters: Case studies. Northwood, UK: Scientific Review, 411–446.
Ruiz P, Ray M, Fisher J, 2011. Development of a human physiologically based pharmacokinetic (PBPK) toolkit for environmental pollutants. Int J Mol Sci 12(11):7469–7480. 10.3390/ijms12117469.22174611
Rutzke MA, Gutenmann WH, Lisk DJ, 2000. Toxic and nutrient element concentrations in soft tissues of zebra and quagga mussels from Lakes Erie and Ontario. Chemosphere 40(12):1353–1356. 10.1016/s0045-6535(99)00281-7.10789974
Saadiani E, Hosseinkhani Z, Safari-Variani A. 2023. Investigating the effect of welding fume in pulmonary function of welders in an automobile industry. Indian J Occup Environ Med 27(2):166–171. 10.4103/ijoem.ijoem_194_21.37600648
Sacco JE, Dodd KW, Kirkpatrick SI, 2013. Voluntary food fortification in the United States: Potential for excessive intakes. Eur J Clin Nutr 67(6):592–597. 10.1038/ejcn.2013.51.23462939
Saenko EL, Yaropolov AI, Harris ED. 1994. Biological function of ceruloplasmin expressed through copper-binding sites and cellular receptor. J Trace Elem Exp Med 7:69–88.
Saha A, Karnik A, Sathawara N, 2008. Ceruloplasmin as a marker of occupational copper exposure. J Expo Sci Environ Epidemiol 18(3):332–337. 10.1038/jes.2008.2.18285839
Sakhaee E, Emadi L, Abshenas J, 2012. Evaluation of epididymal sperm quality following experimentally induced copper poisoning in male rats. Andrologia 44(S1):110–116. 10.1111/j.1439-0272.2010.01147.x.21729134
Sakhaee E, Abshenas J, Emadi L, 2014. Effects of vitamin C on epididymal sperm quality following experimentally induced copper poisoning in mice. Comp Clin Pathol 23(1):181–186. 10.1007/s00580-012-1592-5.
Sakhaee E, Emadi L, Azari O, 2016a. Effects of Cuminum cyminum L. essential oil on some epididymal sperm parameters and histopathology of testes following experimentally induced copper poisoning in mice. Andrologia 48(5):542–547. 10.1111/and.12476.26332396
Sakhaee E, Emadi L, Siahkouhi H. 2016b. Histopathological evaluation of supportive effects of Rosa damascene on mice testes, following long term administration of copper sulfate. Asian Pac J Reprod 5(1):46–50. 10.1016/j.apjr.2015.12.008.
Saleem M, Sens DA, Somji S, 2023. Contamination assessment and potential human health risks of heavy metals in urban soils from Grand Forks, North Dakota, USA. Toxics 11(2):132. 10.3390/toxics11020132.36851006
Saleha Banu B, Ishaq M, Danadevi K, 2004. DNA damage in leukocytes of mice treated with copper sulfate. Food Chem Toxicol 42(12):1931–1936. 10.1016/j.fct.2004.07.007.15500930
Saltzer EI, Wilson JW. 1968. Allergic contact dermatitis due to copper. Arch Dermatol 98(4):375–376. 10.1001/archderm.1968.01610160049009.
Saltzman BE, Gross SB, Yeager DW, 1990. Total body burdens and tissue concentrations of lead, cadmium, copper, zinc, and ash in 55 human cadavers. Environ Res 52(2):126–145. 10.1016/s0013-9351(05)80248-8.2394204
Samuelsson C, Björkman B. 2014. Copper recycling. In: Worrell E, Reuter MA, eds. Handbook of recycling. Boston: Elsevier, 85–94. 10.1016/B978-0-12-396459-5.00007-6.
Sani A, Gaya MB, Abubakar FA. 2016. Determination of some heavy metals in selected cosmetic products sold in kano metropolis, Nigeria. Toxicol Rep 3:866–869. 10.1016/j.toxrep.2016.11.001.28959614
Sansinanea AS, Cerone SI, Elperding A, 1996. Glucose-6-phosphate dehydrogenase activity in erythrocytes from chronically copper-poisoned sheep. Comp Biochem Physiol C Pharmacol Toxicol Endocrinol 114(3):197–200. 10.1016/0742-8413(96)00034-5.8856959
Santschi PH, Nixon S, Pilson M, 1984. Accumulation of sediments, trace metals (Pb, Cu) and total hydrocarbons in Narragansett Bay, Rhode Island. Estuarine Coastal Shelf Sci 19(4):427–449. 10.1016/0272-7714(84)90095-7.
Sañudo-Wilhelmy SA, Gill GA. 1999. Impact of the clean water act on the levels of toxic metals in urban estuaries: The Hudson River Estuary revisited. Environ Sci Technol 33(20):3477–3481. 10.1021/es981130z.
Sarawi WS, Alhusaini AM, Fadda LM, 2021. Nano-curcumin prevents cardiac injury, oxidative stress and inflammation, and modulates TLR4/NF-κB and MAPK signaling in copper sulfate-intoxicated rats. Antioxidants (Basel) 10(9):1414. 10.3390/antiox10091414.34573046
Sarawi WS, Alhusaini AM, Fadda LM, 2022. Nano-curcumin prevents copper reproductive toxicity by attenuating oxidative stress and inflammation and improving NrF2/HO-1 signaling and pituitary-gonadal axis in male rats. Toxics 10(7):356. 10.3390/toxics10070356.35878260
Scarl RT, Lawrence CM, Gordon HM, 2017. STEAP4: its emerging role in metabolism and homeostasis of cellular iron and copper. J Endocrinol 234(3):R123–R134. 10.1530/JOE-16-0594.28576871
Scharenberg W, Ebeling E. 1996. Distribution of heavy metals in a woodland food web. Bull Environ Contam Toxicol 56(3):389–396. 10.1007/s001289900056.8825960
Scheinberg IH, Sternlieb I. 1996. Wilson disease and idiopathic copper toxicosis. Am J Clin Nutr 63(5):842S–845S. 10.1093/ajcn/63.5.842.8615372
Schilsky M. 2019. Wilson disease: Epidemiology and pathogenesis. UpToDate. https://www.uptodate.com/contents/wilson-disease-epidemiology-and-pathogenesis. January 13, 2021.
Schipper BW, Lin H, Meloni MA, 2018. Estimating global copper demand until 2100 with regression and stock dynamics. Resources Conserv Recycl 132:28–36. 10.1016/j.resconrec.2018.01.004.
Schlesinger ME, King MJ, Sole KC, 2011a. Overview. In: Extractive metallurgy of copper. 5th ed. Oxford: Elsevier, 1–12. 10.1016/B978-0-08-096789-9.10001-0.
Schlesinger ME, King MJ, Sole KC, 2011b. Production and use. In: Extractive metallurgy of copper. 5^th^ ed. Oxford: Elsevier, 13–30. 10.1016/B978-0-08-096789-9.10002-2.
Schlesinger ME, King MJ, Sole KC, 2011c. Collection and processing of recycled copper. In: Extractive metallurgy of copper. 5^th^ ed. Oxford: Elsevier, 373–387. 10.1016/B978-0-08-096789-9.10018-6.
Schock MR, Neff CH. 1988. Trace metal contamination from brass fittings. J Am Water Works Assoc 80(11):47–56. 10.1002/j.1551-8833.1988.tb03134.x.
Schock MR, Sandvig AM. 2009. Long-term effects of orthophosphate treatment on copper concentration. J Am Water Works Assoc 101(7):71–82. 10.1002/j.1551-8833.2009.tb09925.x.
Schraufnagel DE. 2020. The health effects of ultrafine particles. Exp Mol Med 52(3):311–317. 10.1038/s12276-020-0403-3.32203102
Schroeder WH, Dobson M, Kane DM, 1987. Toxic trace elements associated with airborne particulate matter: A review. JAPCA 37(11):1267–1285. 10.1080/08940630.1987.10466321.3327920
Schwerdtle T, Hamann I, Jahnke G, 2007. Impact of copper on the induction and repair of oxidative DNA damage, poly(ADP-ribosyl)ation and PARP-1 activity. Mol Nutr Food Res 51(2):201–210. 10.1002/mnfr.200600107.17230584
Scott K, Turnlund JR. 1994. Compartmental model of copper metabolism in adult men. J Nutr Biochem 5(7):342–350. 10.1016/0955-2863(94)90064-7.
Sedlak DL, Phinney JT, Bedsworth WW. 1997. Strongly complexed Cu and Ni in wastewater effluents and surface runoff. Environ Sci Technol 31(10):3010–3016. 10.1021/es970271i.
Seffner W, Schiller F, Lippold U, 1997. Experimental induction of liver fibrosis in young guinea pigs by combined application of copper sulphate and aflatoxin B1. Toxicol Lett 92(3):161–172. 10.1016/s0378-4274(97)00052-0.9334826
Seki M, Okusa T, Takei H, 2021. Contact urticaria syndrome from copper. Contact Dermatitis 85(3):375–376. 10.1111/cod.13863.33864393
Sethi S, Grover S, Khodaskar MB. 1993. Role of copper in Indian childhood cirrhosis. Ann Trop Paediatr 13(1):3–5. 10.1080/02724936.1993.11747618.7681642
Seven PT, Baykalir BG, Seven I, 2018. The protective effects of chrysin and flunixin meglumine against excess copper in male rats. Turk J Vet Anim Sci 42(5):376–387. 10.3906/vet-1710-70.
Seven I, Tatli Seven P, Gul Baykalir B, 2020. Bee glue (propolis) improves reproductive organs, sperm quality and histological changes and antioxidant parameters of testis tissues in rats exposed to excess copper. Andrologia 52(4):e13540. 10.1111/and.13540.32068907
Shahin SA, Mossad M, Fouad M. 2019. Evaluation of copper removal efficiency using water treatment sludge. Water Sci Eng 12(1):37–44. 10.1016/j.wse.2019.04.001.
Shankar JA, Kaur A, Tyagi L, 2023. Severe copper sulphate poisoning: A case rescued with plasmapheresis. Trop Doct 53(2):327–328. 10.1177/00494755231151256.36628444
Sharda B, Bhandari B. 1984. Copper concentration in plasma, cells, liver, urine, hair and nails in hepatobiliary disorders in children. Indian Pediatr 21(2):167–171.6469299
Sharma A. 2011. Acute copper sulphate poisoning: A case report and review of literature. Medico-Legal Update 11(2):7–8.
Sharma VK, Millero FJ. 1988. Oxidation of copper(I) in seawater. Environ Sci Technol 22(7):768–771. 10.1021/es00172a004.22195659
Shi Y, Hu H, Wu Z, 2023. Associations between dietary copper intake and hypertriglyceridemia among children and adolescents in the US. Nutr Metab Cardiovasc Dis 33(4):809–816. 10.1016/j.numecd.2023.01.020.36775709
Shubber E, Amin NS, El-Adhami BH. 1998. Cytogenetic effects of copper-containing intrauterine contraceptive device (IUCD) on blood lymphocytes. Mutat Res 417(2–3):57–63. 10.1016/s1383-5718(98)00090-4.9733918
Shukla AK, Pragya P, Chowdhuri DK. 2011. A modified alkaline Comet assay for in vivo detection of oxidative DNA damage in Drosophila melanogaster. Mutat Res 726(2):222–226. 10.1016/j.mrgentox.2011.09.017.22005018
Sideris EG, Charalambous SC, Tsolomyty A, 1988. Mutagenesis; carcinogenesis and the metal elements-DNA interaction. Prog Clin Biol Res 259:13–25.3362874
Sina JF, Bean CL, Dysart GR, 1983. Evaluation of the alkaline elution/rat hepatocyte assay as a predictor of carcinogenic/mutagenic potential. Mutat Res 113:357–391. 10.1016/0165-1161(83)90228-5.6877265
Singh I. 1983. Induction of reverse mutation and mitotic gene conversion by some metal compounds in Saccharomyces cerevisiae. Mutat Res 117:149–152. 10.1016/0165-1218(83)90162-3.6339905
Singh N, Duan H, Ogunseitan OA, 2019. Toxicity trends in E-Waste: A comparative analysis of metals in discarded mobile phones. J Hazard Mater 380:120898. 10.1016/j.jhazmat.2019.120898.31330384
Sinkovic A, Strdin A, Svensek F. 2008. Severe acute copper sulphate poisoning: a case report. Arh Hig Rada Toksikol 59(1):31–35. 10.2478/10004-1254-59-2008-1847.18407869
Sirkovich EC, Walser SL, Perdrial N, 2023. Evaluating trace elements in urban forest soils across three contrasting New England USA towns and cities by pXRF and mass spectrometry. Environ Pollut 336:122441. 10.1016/j.envpol.2023.122441.37652231
Sirover MA, Loeb LA. 1976. Infidelity of DNA synthesis in vitro: screening for potential metal mutagens or carcinogens. Science 194(4272):1434–1436. 10.1126/science.1006310.1006310
Skeaff JM, Thibault Y, Hardy DJ. 2011. A new method for the characterisation and quantitative speciation of base metal smelter stack particulates. Environ Monit Assess 177(1–4):165–192. 10.1007/s10661-010-1627-9.20676929
Smolders E, Oorts K, Van Sprang P, 2009. Toxicity of trace metals in soil as affected by soil type and aging after contamination: using calibrated bioavailability models to set ecological soil standards. Environ Toxicol Chem 28(8):1633–1642. 10.1897/08-592.1.19301943
Smolders E, Oorts K, Lombi E, 2012. The availability of copper in soils historically amended with sewage sludge, manure, and compost. J Environ Qual 41(2):506–514. 10.2134/jeq2011.0317.22370413
Sood N, Verma P. 2011. Life-threatening haemolysis in a patient with acute copper sulphate poisoning. Indian J Anaesth 55(2):204–205. 10.4103/0019-5049.79878.21712887
Sora S, Carbone MLA, Pacciarini M, 1986. Disomic and diploid meiotic products induced in Saccharomyces cerevisiae by the salts of 27 elements. Mutagenesis 1(1):21–28.3325730
Spitalny KC, Brondum J, Vogt RL, 1984. Drinking-water-induced copper intoxication in a Vermont family. Pediatrics 74(6):1103–1106. 10.1542/peds.74.6.1103.6504631
Stark P. 1981. Vineyard sprayer's lung - a rare occupational disease. J Can Assoc Radiol 32(3):183–184.7298709
Stiff MJ. 1971. Copper/bicarbonate equilibria in solutions of bicarbonate ion at concentrations similar to those found in natural water. Water Res 5(5):171–176. 10.1016/0043-1354(71)90049-2.
Strain WH, Hershey CO, McInnes S, 1984. Hazards to groundwater from acid rain. Trace Subst Environ Health 18:178–184.
Strickland GT, Beckner WM, Leu ML. 1972. Absorption of copper in homozygotes and heterozygotes for Wilson's disease and controls: isotope tracer studies with 67Cu and 64Cu. Clin Sci 43:617–625. 10.1042/cs0430617.5083937
Suciu I, Prodan L, Lazar V, 1981. Research on copper poisoning. Med Lav 72(3):190–197.7300791
Sugawara N, Li D, Sugawara C, 1995. Response of hepatic function to hepatic copper deposition in rats fed a diet containing copper. Biol Trace Elem Res 49(2–3):161–169. 10.1007/BF02788965.8562284
Suttle NF, Mills CF. 1966. Studies of the toxicity of copper to pigs. 1. Effects of oral supplements of zinc and iron salts on the development of copper toxicosis. Br J Nutr 20(2):135–148. 10.1079/bjn19660018.5938697
Suzuki KT, Kanno S, Misawa S, 1995. Copper metabolism leading to and following acute hepatitis in LEC rats. Toxicology 97(1–3):81–92. 10.1016/0300-483x(94)02927-m.7716795
Swastika M, Harahap AR, Panggalo LV, 2020. Determining a critical threshold for G6PD activity below which red blood cell response to oxidative stress is poor. Malar J 19(1):208. 10.1186/s12936-020-03272-y.32552815
Sweeney LM, Gearhart JM. 2020. Examples of physiologically based pharmacokinetic modeling applied to risk assessment. In: Fisher JW, Gearhart JM, Lin Z, eds. Physiologically based pharmacokinetic (PBPK) modeling. Academic Press: 281–299. 10.1016/B978-0-12-818596-4.00011-4.
Sweet CW, Vermette SJ, Landsberger S. 1993. Sources of toxic trace elements in urban air in Illinois. Environ Sci Technol 27(12):2502–2510. 10.1021/es00048a030.
Sylva R. 1976. The environmental chemistry of copper (II) in aquatic systems. Water Res 10(9):789–792. 10.1016/0043-1354(76)90097-x.
Tan WT, Tan GS, Nather Khan IS. 1988. Solubilities of trace copper and lead species and the complexing capacity of river water in the Linggi River Basin. Environ Pollut 52(3):221–235. 10.1016/0269-7491(88)90005-x.15092608
Tan YM, Chan M, Chukwudebe A, 2020. PBPK model reporting template for chemical risk assessment applications. Regul Toxicol Pharmacol 115:104691. 10.1016/j.yrtph.2020.104691.32502513
Tang H, Xu M, Shi F, 2018. Effects and mechanism of nano-copper exposure on hepatic cytochrome P450 enzymes in rats. Int J Mol Sci 19(7):2140. 10.3390/ijms19072140.30041454
Tang Y, Wang C, Holm PE, 2023. Impacts of biochar materials on copper speciation, bioavailability, and toxicity in chromated copper arsenate polluted soil. J Hazard Mater 459:132067. 10.1016/j.jhazmat.2023.132067.37478594
Tanner MS. 1998. Role of copper in Indian childhood cirrhosis. Am J Clin Nutr 67(5):1074S–1081S. 10.1093/ajcn/67.5.1074S.9587155
Tanner MS, Kantarjian AH, Bhave SA, 1983. Early introduction of copper-contaminated animal milk feeds as a possible cause of Indian childhood cirrhosis. Lancet 2:992–995. 10.1016/S0140-6736(83)90980-7.6138594
Tapia L, Gonzalez-Aguero M, Cisternas FA, 2004. Metallothionein is crucial for safe intracellular copper storage and cell survival at normal and supra-physiological exposure levels. Biochem J 378(2):617–624. 10.1042/BJ20031174.14627437
Taylor GJ, Crowder AA. 1983. Accumulation of atmospherically deposited metals in wetland soils of Sudbury, Ontario. Water Air Soil Pollut 19(1):29–42. 10.1007/bf00176793.
Taylor AA, Tsuji JS, Garry MR, 2020. Critical review of exposure and effects: Implications for setting regulatory health criteria for ingested copper. Environ Manage 65(1):131–159. 10.1007/s00267-019-01234-y.31832729
Temiz MA, Temur A, Akgeyik Y, 2021. Protective effect of Celtis tournefortii against copper-induced toxicity in rat liver. Acta Vet Brno 90(1):91–98. 10.2754/avb202190010091.
Theresa OC, Onebunne OC, Dorcas W, 2011. Potentially toxic metals exposure from body creams sold in Lagos, Nigeria. Researcher 3(1):30–37.
Tian Y, Wu B, Li X, 2019. The resveratrol alleviates the hepatic toxicity of CuSO4 in the rat. Biol Trace Elem Res 187(2):464–471. 10.1007/s12011-018-1398-7.29980948
Tinwell H, Ashby J. 1990. Inactivity of copper sulphate in a mouse bone-marrow micronucleus assay. Mutat Res 245(3):223–226. 10.1016/0165-7992(90)90054-n.2233844
Tipping E. 1994. WHAMC-A chemical equilibrium model and computer code for waters, sediments, and soils incorporating a discrete site/electrostatic model of ion-binding by humic substances. Computers Geosci 20(6):973–1023. 10.1016/0098-3004(94)90038-8.
Tong J, An X, Zhao L, 2022. Combining multiaspect factors to predict the risk of childhood hypertension incidence. J Clin Hypertens 24:1015–1025. 10.1111/jch.14544.
Town RM, Filella M. 2000. Dispelling the myths: Is the existence of L1 and L2 ligands necessary to explain metal ion speciation in natural waters? Limnol Oceanogr 45(6):1341–1357. 10.4319/lo.2000.45.6.1341.
Toyokuni S, Tanaka T, Nishiyama Y, 1996. Induction of renal cell carcinoma in male Wistar rats treated with cupric nitrilotriacetate. Lab Invest 75(2):239–248.8765324
TRI22. 2024. Copper and copper compounds. TRI explorer: release reports. Washington, DC: Toxics Release Inventory. U.S. Environmental Protection Agency. https://enviro.epa.gov/triexplorer/tri_release.chemical. January 25, 2024.
Troost FJ, Brummer RJ, Dainty JR, 2003. Iron supplements inhibit zinc but not copper absorption in vivo in ileostomy subjects. Am J Clin Nutr 78(5):1018–1023. 10.1093/ajcn/78.5.1018.14594790
Truitt RE, Weber JH. 1981. Copper(II)- and cadmium(II)-binding abilities of some New Hampshire freshwaters determined by dialysis titration. Environ Sci Technol 15(10):1204–1208. 10.1021/es00092a008.22299699
Tsao HS, Allister L, Chiba T, 2020. A case report of cake frosting as a source of copper toxicity in a pediatric patient. Clin Pract Cases Emerg Med 4(3):384–388. 10.5811/cpcem.2020.7.47267.32926692
Tso WW, Fung WP. 1981. Mutagenicity of metallic cations. Toxicol Lett 8(4–5):195–200. 10.1016/0378-4274(81)90100-4.7022752
Turek NF, Kasten L, Lytle DA, 2011. Impact of plumbing age on copper levels in drinking water. J Water Suppl Res Technol Aqua 60(1):1–15. 10.2166/aqua.2011.014.
Turnlund JR, Michel MC, Keyes WR, 1982. Copper absorption in elderly men determined by using stable 65Cu. Am J Clin Nutr 36(4):587–591. 10.1093/ajcn/36.4.587.7124660
Turnlund JR, Swanson CA, King JC. 1983. Copper absorption and retention in pregnant women fed diets based on animal and plant proteins. J Nutr 113(11):2346–2352. 10.1093/jn/113.11.2346.6631551
Turnlund JR, King JC, Gong B, 1985. A stable isotope study of copper absorption in young men: effect of phytate and alpha-cellulose. Am J Clin Nutr 42(1):18–23. 10.1093/ajcn/42.1.18.2990188
Turnlund JR, Wada L, King JC, 1988. Copper absorption in young men fed adequate and low zinc diets. Biol Trace Elem Res 17:31–41. 10.1007/BF02795445.2484367
Turnlund JR, Keyes WR, Anderson HL, 1989. Copper absorption and retention in young men at three levels of dietary copper by use of the stable isotope 65Cu. Am J Clin Nutr 49(5):870–878. 10.1093/ajcn/49.5.870.2718922
Turnlund JR, Keyes WR, Peiffer GL, 1998. Copper absorption, excretion, and retention by young men consuming low dietary copper determined by using the stable isotope 65Cu. Am J Clin Nutr 67(6):1219–1225. 10.1093/ajcn/67.6.1219.9625096
Turnlund JR, Jacob RA, Keen CL, 2004. Long-term high copper intake: effects on indexes of copper status, antioxidant status, and immune function in young men. Am J Clin Nutr 79(6):1037–1044. 10.1093/ajcn/79.6.1037.15159234
Turnlund JR, Keyes WR, Kim SK, 2005. Long-term high copper intake: effects on copper absorption, retention, and homeostasis in men. Am J Clin Nutr 81(4):822–828. 10.1093/ajcn/81.4.822.15817858
Tyler LD, McBride MB. 1982. Mobility and extractability of cadmium, copper, nickel, and zinc in organic and mineral soil columns. Soil Sci 134(3):198–205.
U.S. NRC. 1980. Concentration and speciation of copper in waters collected near the San Onofre and Diablo Canyon nuclear power stations. Livermore, CA: U.S. Nuclear Regulatory Commission. NUREG/CR-0750.
U.S. NRC. 1984. Review of the impact of copper released into freshwater environments. U.S. Nuclear Regulatory Commission. Livermore, CA: U.S. Nuclear Regulatory Commission. NUREG/CR-3478. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/NUREGCR3478.xhtml. March 21, 2024.
United Poultry Concerns. 2022. Intensive poultry production: Fouling the environment. United Poultry Concerns. https://www.upc-online.org/environment/fouling_the_environment.pdf. January 25, 2024.
Urbina-Cano P, Bobadilla-Morales L, Ramirez-Herrera MA, 2006. DNA damage in mouse lymphocytes exposed to curcumin and copper. J Appl Genet 47(4):377–382. 10.1007/BF03194648.17132903
USDA. 2020. What we eat in America, NHANES 2017–2018. Table 1. Nutrient intakes from food and beverages: Mean amounts consumed per individual, by gender and age, in the United States, 2017–2018. U.S. Department of Agriculture. www.ars.usda.gov/nea/bhnrc/fsrg. January 25, 2024.
USDT. 2018. Title 31- Money and finance. Denominations, specifications, and design of coins. U.S. Department of the Treasury. United States Code. 341–361. 31 USC 5112. https://www.govinfo.gov/content/pkg/USCODE-2018-title31/pdf/USCODE-2018-title31-subtitleIV-chap51-subchapII-sec5112.pdf. January 25, 2024.
USGS. 1984. Element concentrations in soils and other surficial materials of the conterminous United States. Washington, DC: U.S. Geological Survey. Professional Paper 1270. https://semspub.epa.gov/work/07/30017546.pdf. January 25, 2024.
USGS. 2009a. Copper - A metal for the ages: U.S. Geological Survey fact sheet 2009–3031. U.S. Geological Survey. https://pubs.usgs.gov/fs/2009/3031/FS2009-3031.pdf. March 21, 2024.
USGS. 2009b. Quality of water from domestic wells in principal aquifers of the United States, 1991–2004: Overview of major findings. Reston, Virginia: US Geological Survey. https://pubs.usgs.gov/circ/circ1332/includes/circ1332.pdf. October 21, 2020.
USGS. 2013. Geochemical and mineralogical data for soils of the conterminous United States. U.S. Geological Survey. Data Series 801. https://pubs.usgs.gov/ds/801/. March 21, 2024.
USGS. 2014. The quality of our Nation's waters: Water quality in principal aquifers of the United States, 1991–2010. Reston, VA: U.S. Geological Survey. Circular 1360. 10.3133/cir1360.
USGS. 2016. National geochemical database: Soil. U.S. Geological Survey. https://www.usgs.gov/centers/gggsc/science/national-geochemical-database#data. January 31, 2024.
USGS. 2017a. 2013–2017 county-level pesticide use estimates. Estimated annual agricultural pesticide use. Pesticide national synthesis project. U.S. Geological Survey. https://water.usgs.gov/nawqa/pnsp/usage/maps/county-level/. August 14, 2020.
USGS. 2017b. Copper [advance release]. 2015 Minerals yearbook. U.S. Geological Survey. https://s3-us-west-2.amazonaws.com/prd-wret/assets/palladium/production/mineral-pubs/copper/myb1-2015-coppe.pdf. October 21, 2020.
USGS. 2020a. Copper data sheet. Mineral commodity summaries. U.S. Geological Survey. https://pubs.usgs.gov/periodicals/mcs2020/mcs2020-copper.pdf. March 21, 2024.
USGS. 2020b. Datasets from groundwater-quality and select quality-control data from the National Water-Quality Assessment Project, January through December 2016, and previously unpublished data from 2013 to 2015. U.S. Geological Survey. 10.5066/P9W4RR74.
USGS. 2022. Copper in January 2022. Mineral industry surveys. U.S Geological Survey. https://d9-wret.s3.us-west-2.amazonaws.com/assets/palladium/production/s3fs-public/media/files/mis-202201-coppe.pdf. January 31, 2024.
Valsami S, Stamoulis K, Lydataki E, 2012. Acute copper sulphate poisoning: a forgotten cause of severe intravascular haemolysis. Br J Haematol 156(3):294. 10.1111/j.1365-2141.2011.08881.x.21981599
Van den Berg GJ, Beynen AC. 1992. Influence of ascorbic acid supplementation on copper metabolism in rats. Br J Nutr 68(3):701–715. 10.1079/bjn19920127.1493135
van den Berghe PV, Klomp LW. 2009. New developments in the regulation of intestinal copper absorption. Nutr Rev 67(11):658–672. 10.1111/j.1753-4887.2009.00250.x.19906252
Varada KR, Harper RG, Wapnir RA. 1993. Development of copper intestinal absorption in the rat. Biochem Med Metab Biol 50(3):277–283. 10.1006/bmmb.1993.1069.8123292
Venugopal V, Gopakumar K. 2017. Shellfish: Nutritive value, health benefits, and consumer safety. Compr Rev Food Sci Food Saf 16(6):1219–1242. 10.1111/1541-4337.12312.33371588
Vieira J, Oliveira PV, Juliano Y, 2012. Urinary copper excretion before and after oral intake of d-penicillamine in parents of patients with Wilson's disease. Dig Liver Dis 44(4):323–327. 10.1016/j.dld.2011.11.001.22169274
Villar TG. 1974. Vineyard sprayer's lung. Clinical aspects. Am Rev Respir Dis 110(5):545–555. 10.1164/arrd.1974.110.5.545.4429251
Villar TG, Nogueira T. 1980. Radiology and respiratory function in "vineyard sprayer's lung". Bronchopneumologie 30(1):61–67.7427765
Vincent M, Hartemann P, Engels-Deutsch M. 2016. Antimicrobial applications of copper. Int J Hyg Environ Health 219(7):585–591. 10.1016/j.ijheh.2016.06.003.27318723
Vong RJ, Baker BM, Brechtel FJ, 1997. Ionic and trace element composition of cloud water collected on the Olympic Peninsula of Washington State. Atmos Environ 31(13):1991–2001. 10.1016/s1352-2310(96)00337-8.
Vyskocil V, Viau C. 1999. Assessment of molybdenum toxicity in humans. J Appl Toxicol 19(3):185–192. 10.1002/(sici)1099-1263(199905/06)19:3<185::aid-jat555>3.0.co;2-z.10362269
Wåhlin P, Berkowicz R, Palmgren F. 2006. Characterisation of traffic-generated particulate matter in Copenhagen. Atmos Environ 40(12):2151–2159. 10.1016/j.atmosenv.2005.11.049.
Wake SA, Mercer JF. 1985. Induction of metallothionein mRNA in rat liver and kidney after copper chloride injection. Biochem J 228(2):425–432. 10.1042/bj2280425.4015627
Walsh FM, Crosson FJ, Bayley M, 1977. Acute copper intoxication. Pathophysiology and therapy with a case report. Am J Dis Child 131(2):149–151. 10.1001/archpedi.1977.02120150031005.835530
Wan F, Zhong G, Ning Z, 2020. Long-term exposure to copper induces autophagy and apoptosis through oxidative stress in rat kidneys. Ecotoxicol Environ Saf 190:110158. 10.1016/j.ecoenv.2019.110158.31918257
Wang X, Wang WX. 2016. Homeostatic regulation of copper in a marine fish simulated by a physiologically based pharmacokinetic model. Environ Pollut 218:1245–1254. 10.1016/j.envpol.2016.08.080.27613316
Wang X, Li X, Xing Y, 2021. Threshold effects of total copper intake on cognitive function in US older adults and the moderating effect of fat and saturated fatty acid intake. J Acad Nutr Diet 121(12):2429–2442. 10.1016/j.jand.2021.06.002.34219046
Wapnir RA. 1998. Copper absorption and bioavailability. Am J Clin Nutr 67(5):1054S–1060S. 10.1093/ajcn/67.5.1054S.9587151
Wapnir RA, Devas G, Solans CV. 1993. Inhibition of intestinal copper absorption by divalent cations and low-molecular-weight ligands in the rat. Biol Trace Elem Res 36(3):291–305. 10.1007/bf02783963.
Wärmländer SKTS, Österlund N, Wallin C, 2019. Metal binding to the amyloid-β peptides in the presence of biomembranes: potential mechanisms of cell toxicity. J Biol Inorg Chem 24(8):1189–1196. 10.1007/s00775-019-01723-9.31562546
Weber PM, O'Reilly S, Pollycove M, 1969. Gastrointestinal absorption of copper: Studies with 64Cu, 95Zr, a whole-body counter and the scintillation camera. J Nucl Med 10(9):591–596.5797847
Wei J, Gianattasio KZ, Bennett EE, 2022. The associations of dietary copper with cognitive outcomes. Am J Epidemiol 191(7):1202–1211. 10.1093/aje/kwac040.35238336
Weiss KC, Linder MC. 1985. Copper transport in rats involving a new plasma protein. Am J Physiol 249(1):E77–E88. 10.1152/ajpendo.1985.249.1.E77.3925789
Weyde KVF, Olsen AK, Duale N, 2021. Gestational blood levels of toxic metal and essential element mixtures and associations with global DNA methylation in pregnant women and their infants. Sci Total Environ 787:147621. 10.1016/j.scitotenv.2021.147621.34000534
Whanger PD, Weswig PH. 1971. Effect of supplementary zinc on the intracellular distribution of hepatic copper in rats. J Nutr 101(8):1093–1097. 10.1093/jn/101.8.1093.5565096
Whitall D, Hively WD, Leight AK, 2010. Pollutant fate and spatio-temporal variability in the Choptank River estuary: Factors influencing water quality. Sci Total Environ 408(9):2096–2108. 10.1016/j.scitotenv.2010.01.006.20171715
WHO. 1996. Copper. Trace elements in human nutrition and health. Geneva, Switzerland: World Health Organization. https://www.who.int/publications/i/item/9241561734. January 25, 2024.
WHO. 2004. Copper in drinking-water, background document for development of WHO guidelines for drinking-water quality. World Health Organization. WHO/SDE/WSH/03.04/88. https://cdn.who.int/media/docs/default-source/wash-documents/wash-chemicals/copper.pdf. March 21, 2024.
WHO. 2010. WHO guidelines for indoor air quality: Selected pollutants. World Health Organization. https://www.who.int/publications/i/item/9789289002134. January 25, 2024.
WHO. 2022. Guidelines for drinking-water quality. Fourth edition incorporating the first and second addenda. Geneva: World Health Organization. https://www.who.int/publications/i/item/9789240045064. September 18, 2023.
Wildemeersch D, Sabbe PJ, Dowsett MG, 2014. Assessment of copper corrosion from frameless copper IUDs after long-term in utero residence. Contraception 90(4):454–459. 10.1016/j.contraception.2014.05.009.25015534
Wilhelm M, Hafner D, Lombeck I, 1991. Monitoring of cadmium, copper, lead and zinc status in young children using toenails: comparison with scalp hair. Sci Total Environ 103(2–3):199–207. 10.1016/0048-9697(91)90145-5.1882232
Wise SA, Zeisler R. 2012. The pilot Environmental Specimen Bank program. Environ Sci Technol 18(10):302A–307A. 10.1021/es00128a712.
Wong PK. 1988. Mutagenicity of heavy metals. Bull Environ Contam Toxicol 40(4):597–603. 10.1007/BF01688386.3285919
Woo SH, Lee DS, Lim SR. 2016. Potential resource and toxicity impacts from metals in waste electronic devices. Integr Environ Assess Manag 12(2):364–370. 10.1002/ieam.1710.27017840
WQP. 2022. Water quality portal data: Copper. Advisory Committee on Water Information (ACWI); Agricultural Research Service (ARS); Environmental Protection Agency (EPA); National Water Quality Monitoring Council (NWQMC); United States Geological Survey (USGS). https://www.waterqualitydata.us/portal/. January 25, 2024.
Wu J, Laird DA, Thompson ML. 1999. Sorption and desorption of copper on soil clay components. J Environ Qual 28(1):334–338. 10.2134/jeq1999.00472425002800010041x.
Wu X, Jackson RT, Khan SA, 2018. Human milk nutrient composition in the United States: Current knowledge, challenges, and research needs. Curr Dev Nutr 2(7):nzy025. 10.1093/cdn/nzy025.30087951
Wu H, Guo H, Liu H, 2020. Copper sulfate-induced endoplasmic reticulum stress promotes hepatic apoptosis by activating CHOP, JNK and caspase-12 signaling pathways. Ecotoxicol Environ Saf 191:110236. 10.1016/j.ecoenv.2020.110236.32001424
Xu R, Meng X, Pang Y, 2022. Associations of maternal exposure to 41 metals/metalloids during early pregnancy with the risk of spontaneous preterm birth: Does oxidative stress or DNA methylation play a crucial role? Environ Int 158:106966. 10.1016/j.envint.2021.106966.34735952
Xue H, Goncalves MLS, Reutlinger M, 1991. Copper(I) in fogwater: Determination and interactions with sulfite. Environ Sci Technol 25(10):1716–1722. 10.1021/es00022a006.
Yadla M, John P, Kanth S, 2015. An unusual case of acute kidney injury due to poisoning with blue stone. Hong Kong J Nephrol 17(2):26–27. 10.1016/j.hkjn.2015.08.002.
Yalcin SS, Yalcin S, Gucus AI. 2015. Zinc and copper concentrations in breast milk during the first nine months of lactation: A longitudinal study. Pediatrics 135:S13–S14. 10.1542/peds.2014-3330X.
Yamamoto K, Ngan MP, Takeda N, 2004. Differential activity of drugs to induce emesis and pica behavior in Suncus murinus (house musk shrew) and rats. Physiol Behav 83(1):151–156. 10.1016/j.physbeh.2004.08.006.15501502
Yamane Y, Sakai K, Umeda T, 1984. Suppressive effect of cupric acetate on DNA alkylation, DNA synthesis and tumorigenesis in the liver of dimethylnitrosamine-treated rats. Gann 75(12):1062–1069.6526221
Yang CC, Wu ML, Deng JF. 2004. Prolonged hemolysis and methemoglobinemia following organic copper fungicide ingestion. Vet Hum Toxicol 46(6):321–323.15587250
Yang L, Chen X, Cheng H, 2022. Dietary copper intake and risk of stroke in adults: A case-control study based on National Health and Nutrition Examination Survey 2013–2018. Nutrients 14(3):409. 10.3390/nu14030409.35276768
Yannoni CC, Piorkowski T. 1995. Profile of lead and copper levels in house plumbing and service pipe. J New Engl Water Works Assoc 109(3):192–210.
Yates BJ, Catanzaro MF, Miller DJ, 2014. Integration of vestibular and emetic gastrointestinal signals that produce nausea and vomiting: potential contributions to motion sickness. Exp Brain Res 232(8):2455–2469. 10.1007/s00221-014-3937-6.24736862
Yeats PA. 1988. The distribution of trace metals in ocean waters. Sci Total Environ 72:131–149. 10.1016/0048-9697(88)90012-5.
Yin T, Zhu X, Xu D, 2021. The association between dietary antioxidant micronutrients and cardiovascular disease in adults in the United States: A cross-sectional study. Front Nutr 8:799095. 10.3389/fnut.2021.799095.35096944
Yu W, Liao J, Yang F, 2021a. Chronic tribasic copper chloride exposure induces rat liver damage by disrupting the mitophagy and apoptosis pathways. Ecotoxicol Environ Saf 212:111968. 10.1016/j.ecoenv.2021.111968.33550083
Yu Z, Koppelman GH, Hoek G, 2021b. Ultrafine particles, particle components and lung function at age 16 years: The PIAMA birth cohort study. Environ Int 157:106792. 10.1016/j.envint.2021.106792.34388675
Yu W, Chang X, Liao J, 2023. Long-term oral tribasic copper chloride exposure impedes cognitive function and disrupts mitochondrial metabolism by inhibiting mitophagy in rats. Environ Pollut 336:122474. 10.1016/j.envpol.2023.122474.37652230
Zhang Y, Dong Z, Yang H, 2020. Effects of dose and duration of dietary copper administration on hepatic lipid peroxidation and ultrastructure alteration in piglets' model. J Trace Elem Med Biol 61:126561. 10.1016/j.jtemb.2020.126561.32480055
Zhang M, Liu C, Li WD, 2022. Individual and mixtures of metal exposures in associations with biomarkers of oxidative stress and global DNA methylation among pregnant women. Chemosphere 293:133662. 10.1016/j.chemosphere.2022.133662.35063557
Zhang Y, Zhou Q, Lu L, 2023a. Copper induces cognitive impairment in mice via modulation of cuproptosis and CREB signaling. Nutrients 15(4):972. 10.3390/nu15040972.36839332
Zhang J, Gu H, Chen S, 2023b. Assessment of heavy metal pollution and preschool children health risk in urban street dusts from different functional areas in a typical industrial and mining city, NW China. Environ Geochem Health 45(10):7199–7214. 10.1007/s10653-023-01623-7.37258900
Zhong W, Ren T, Zhao L. 2015. Determination of Pb (lead), Cd (cadmium), Cr (chromium), Cu (copper), and Ni (nickel) in Chinese tea with high-resolution continuum source graphite furnace atomic absorption spectrometry. J Food Drug Anal 24(1):46–55. 10.1016/j.jfda.2015.04.010.28911408
Zietz BP, Dieter HH, Lakomek M, 2003a. Epidemiological investigation on chronic copper toxicity to children exposed via the public drinking water supply. Sci Total Environ 302(1–3):127–144. 10.1016/s0048-9697(02)00399-6.12526904
Zietz BP, De Vergara JD, Dunkleberg H. 2003b. Copper concentrations in tap water and possible effects on infanťs health - results of a study in Lower Saxony, Germany. Environ Res 92(2):129–138. 10.1016/s0013-9351(03)00037-9.12854693
Zubčić K, Hof PR, Šimić G, 2020. The role of copper in tau-related pathology in Alzheimer's disease. Front Mol Neurosci 13:572308. 10.3389/fnmol.2020.572308.33071757