# VERSION HISTORY

Date | Description
October 2024 | Final toxicological profile released
April 2022 | Draft for public comment toxicological profile released
September 2004 | Final toxicological profile released
October 1990 | Final toxicological profile released