# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding copper in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for copper.

Table 7-1 Regulations and Guidelines Applicable to Copper and Copper Sulfate

Agency | Description | Information | Reference
Air
EPA | RfC | Not evaluated | IRIS 1988
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | No health advisories listed | EPA 2018b
EPA
EPA | National primary drinking water regulations; Copper TT action level^a^ | 1.3 mg/L | EPA 2022d
EPA
EPA | National secondary drinking water regulations^b^; Copper secondary MCL | 1.0 mg/L | EPA 2009a
EPA
EPA | RfD | Not evaluated | IRIS 1988
WHO | Drinking water quality guidelines Copper guideline value | 2 mg/L (2,000 pg/L) | WHO 2022
FDA | Allowable level of copper in bottled water | 1.0 mg/L | FDA 2022
FDA
FDA | Direct food substances affirmed as generally recognized as safe when used as a nutrient supplement or as a processing aid | | FDA 2019a, FDA 2019b
FDA | Copper sulfate | GRAS
FDA | Copper gluconate | GRAS
Cancer
HHS | Carcinogenicity classification | No data | NTP 2021
EPA | Carcinogenicity classification Copper | D^c^ | IRIS 1988
IARC | Carcinogenicity classification Copper 8-hydroxyquinoline | Group 3^d^ | IARC 1987
Occupational
OSHA | PEL (8-hour TWA for general industry, construction and shipyards) | | OSHA 2020a, 2020b, 2020c
OSHA | Copper dusts and mists | 1 mg/m^3^
OSHA | Copper fume | 0.1 mg/m^3^
NIOSH | REL (up to 10-hour TWA) | | NIOSH 2019a, 2019b
| Copper (dust and mists, as Cu) | 1 mg/m^3^
| Copper fume (as Cu) | 0.1 mg/m^3^
| IDLH
| Copper (dust and mists, as Cu) | 100 mg Cu/m^3^
Emergency Criteria
EPA | AEGLs | No data | EPA 2018c
DOE | PACs-air | | DOE 2018
| Copper
| PAC-1^e^ | 3 mg/m^3^
| PAC-2^e^ | 33 mg/m^3^
| PAC-3^e^ | 200 mg/m^3^
| Copper sulfate
| PAC-1^e^ | 7.5 mg/m^3^
| PAC-2^e^ | 9.9 mg/m^3^
| PAC-3^e^ | 59 mg/m^3^
| Copper (II) chloride
| PAC-1^e^ | 6.3 mg/m^3^
| PAC-2^e^ | 69 mg/m^3^
| PAC-3^e^ | 420 mg/m^3^

a A treatment technique (TT) is a required process, triggered by exceedance of the action level, which is intended to reduce the level of a contaminant in drinking water. The copper action level is exceeded if the 90th percentile concentration of copper is >1.3 mg/L.

b National secondary drinking water regulations are contaminants tested on voluntary basis. The levels indicated may cause water to appear cloudy or colored, or to taste or smell, however, it is safe to drink.

c D: not classified.

d Group 3: Not classifiable as to its carcinogenicity to humans.

e Definitions of PAC terminology are available from DOE (2023).

AEGL = acute exposure guideline levels; DOE = Department of Energy; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = Immediately Dangerous to Life of Health; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TT = treatment technique; TWA = time-weighted average; WHO = World Health Organization