# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Copper, atomic number 29 on the periodic table, is a transition metal and a Group 11 essential element that can occur naturally in elemental form. Copper exists in four oxidation states: Cu(0), Cu(I), Cu(II), and Cu(III). The most common oxidation states are cupric Cu(I), with a +1 oxidation state, and cuprous Cu(II), with a +2 oxidation state (Conry 2006). Both types can form stable complex ions (i.e., salts). Cu(II) is classified as a borderline hard acid and can form complexes with hard ligands such as nitrogen-and oxygen-donating ligands as well as chloride- and sulfur-containing species; Cu(I) is considered a soft acid and typically forms salt complexes with softer ligands (Conry 2006). In physiological systems, Cu(II) is reduced to Cu(I) for transport across cellular membranes (Nishito and Kambe 2018). Copper industrial uses include electrical products and equipment, wiring, piping, sheet metal, building material, machinery, and motors. Copper is found in many foods and in some dietary supplements. Copper is essential to human health and among the most abundant trace elements in the human body. Because copper exhibits various oxidation states and can form numerous stable salts, there are many forms of copper. Copper sulfate (CuSO_4_) is an inorganic compound that can occur in nature. It is the most common compound used in commercial applications. It is the most widely used copper salt and is an ingredient in pesticide formulations, and has been used as a micronutrient additive for fertilizer and animal feed (NLM 2024). Copper chloride is another important copper salt. It is used as a catalyst in chemical reactions; in dyeing and printing; and in fungicides, wood preservative, feed additives, and water purification (Budavari et al. 2001; NLM 2024). Copper oxide is used in some paints, glasses, porcelain glazes, and ceramics as a red pigment, and has been used as a fungicide (Conry 2006). Copper nanoparticles are formed through natural processes or can be manmade. They are primarily used as antimicrobial, antibacterial, and antifungal agents. A summary of copper nanoparticle toxicity is in Section 2.21. Information regarding the chemical identity of copper and copper compounds is presented in Table 4-1.

Table 4-1 Chemical Identity of Copper and Copper Compounds

Characteristic | | Information
Chemical Name | Copper | Copper sulfate | Copper chloride
Synonym(s) and Registered trade name(s) | M1; M2; M3; M4; Cuprum; Gold Bronze; 1721 Gold; Bronze powder; Cobre; Cuivre; Rame; Allbri Natural Copper; M3R; M3S; E 115; OFHC CU | Cupric sulfate; Copper (II) sulfate; cupric sulfate anhydrous; copper sulphate; Blue stone; copper monosulfate; Hylinec; Trinagle; Delcup, cupric sulphate; sulfuric acid copper (2+) salt (1:1); monocopper sulfate | Copper(II) chloride; cupric chloride; cupric chloride anhydrous; cupric chloride dihydrate
Chemical formula | Cu | CuSO_4_ | CuCl_2_
SMILES | Cu | [O-]S(=O)(=O)[O-].[Cu+2] | Cl[Cu]Cl
Chemical structure | Cu | [image] | [image]
CAS Registry Number | 7440-50-8 | 7758-98-7 | 7447-39-4

Chemical Name | Copper (II) oxide | Copper gluconate
Synonym(s) and Registered trade name(s) | Cupric oxide; copper oxide; copper monoxide; CuO; oxocopper | Copper(II) gluconate; copper di-D-gluconate; copper (II) D-gluconate; copper(2+) D-gluconate, (1:2)
Chemical formula | CuO | C_12_H_22_CuO_14_
SMILES | [O-2].[Cu+2] | C(C(C(C(C(C(=O)[O-])O)O)O)O)O.C(C(C(C(C(C(=O)[O-])O)O)O)O)O.[Cu+2]
Chemical structure | Cu=O | [image]
CAS Registry Number | 1317-38-0 | 527-09-3

CAS = Chemical Abstracts Service; SMILES = simplified molecular-input line-entry system

Source: NLM 2024

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Copper is a metallic solid that is malleable and has high thermal conductivity, high electrical conductivity, low corrosivity, and alloying ability. Its malleability is attributed to its relatively low number of electrons on its outer shell. The properties of copper typically vary with purity. Metallic copper is naturally a reddish color, and when exposed to oxygen in the air, it forms copper oxide, which is black (Haynes et al. 2015). As copper reacts with carbon dioxide in the air, copper carbonates, which are usually green, form. Copper is positioned below hydrogen in the electromotive-force series (lower reactivity); therefore, it will not displace hydrogen ions in water, and thus has no single displacement interaction with water. It is soluble in dilute acid and in ammonia with the presence of an oxidizing agent. Copper will undergo galvanic corrosion when in contact with other metals. Copper sulfate is typically produced by treating hot copper with sulfuric acid. The resulting material is a white-green solid when anhydrous and blue crystals when hydrated (CuSO_4_.5H_2_O) (Haynes et al. 2015). Copper chloride is produced by reaction of metallic copper with chlorine. It is a yellow-brown powder in the anhydrous form. Information regarding physical and chemical properties of copper and copper compounds is presented in Table 4-2.

Table 4-2 Physical and Chemical Properties of Copper and Copper Compounds

Property | | Information
Chemical name | Copper | Copper (II) sulfate | Copper (II) chloride
Molecular weight | 63.55 g/mol | 159.61 g/mol | 134.45 g/mol
Color | Reddish, lustrous | White, off-white when dehydrated; blue crystals when hydrated | Yellow to brown
Physical state | Solid | Solid | Solid
Melting point | 1,083°C | 590°C | 630°C
Boiling point | 2,595°C | 650°C | 993°C
Density at 20°C/4°C | 8.94 | 3.6 | 3.39
Odor | Odorless | Pleasant odor | Odorless
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Taste threshold | No data | No data | No data
Solubility:
Water | Insoluble | Soluble
Organic solvent(s) | Slightly soluble in dilute acid and ammonia water | Soluble in methanol Insoluble in ethanol | Soluble in acetone, ethanol
Partition coefficients:
Log K_ow_ | No data | No data | No data
Log K_oc_ | No data | No data | No data
Vapor pressure at 20°C | 1 mm Hg at 1,628°C | No data | No data
Henry’s law constant | No data | No data | No data
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability limits | No data | No data | No data
Conversion factors | Since these substances exist in the atmosphere in the particulate state, the concentration is expressed as mg/m^3^.
Explosive limits | No data | No data | No data

Chemical name | Copper (II) oxide | Copper gluconate
Molecular weight | 79.55 g/mol | 453.84 g/mol
Color | Steel-grey to black solid; black to brownish-black amorphous or crystalline powder or granules | Light blue crystalline powder
Physical state | Solid | Solid
Melting point | 1,326°C (decomposes) | 155–157°C (D-form)
Boiling point | 1,026°C (decomposes) | No data
Density at 20°C/4°C | 6.315 at 14°C/4°C | No data
Odor | Odorless | Odorless
Odor threshold:
Water | No data | No data
Air | No data | No data
Taste threshold | No data | No data
Solubility:
Water | Insoluble | 30 g/100 mL water at 25°C
Organic and inorganic solvent(s) | Soluble in acids, and ammonia and ammonium carbonate solutions; soluble in alkali cyanides | Slightly soluble in alcohol; practically insoluble in most organic solvents
Partition coefficients:
Log K_ow_ | No data | No data
Log K_oc_ | No data | No data
Vapor pressure at 20°C | 1 mm Hg at 1,628°C | No data
Henry’s law constant | No data | No data
Autoignition temperature | No data | No data
Flashpoint | No data | No data
Flammability limits | No data | No data
Conversion factors | Since these substances exist in the atmosphere in the particulate state, the concentration is expressed as mg/m^3^.
Explosive limits | No data | No data

Sources: Haynes et al. 2015; NLM 2024