# APPENDIX C FRAMEWORK FOR ATSDR’S SYSTEMATIC REVIEW OF HEALTH EFFECTS DATA FOR COPPER

To increase the transparency of ATSDR’s process of identifying, evaluating, synthesizing, and interpreting the scientific evidence on the health effects associated with exposure to copper, ATSDR utilized a slight modification of NTP’s Office of Health Assessment and Translation (OHAT) systematic review methodology (NTP 2013, 2015; Rooney et al. 2014). ATSDR’s framework is an eight-step process for systematic review with the goal of identifying the potential health hazards of exposure to copper:

- Step 1. Problem Formulation
- Step 2. Literature Search and Screen for Health Effects Studies
- Step 3. Extract Data from Health Effects Studies
- Step 4. Identify Potential Health Effect Outcomes of Concern
- Step 5. Asses the Risk of Bias for Individual Studies
- Step 6. Rate the Confidence in the Body of Evidence for Each Relevant Outcome
- Step 7. Translate Confidence Rating into Level of Evidence of Health Effects
- Step 8. Integrate Evidence to Develop Hazard Identification Conclusions

## C.1 PROBLEM FORMULATION

The objective of the toxicological profile and this systematic review was to identify the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to copper. The inclusion criteria used to identify relevant studies examining the health effects of copper are presented in Table C-1.

Data from human and laboratory animal studies were considered relevant for addressing this objective. Human studies were divided into two broad categories: observational epidemiology studies and controlled exposure studies. The observational epidemiology studies were further divided: cohort studies (retrospective and prospective studies), population studies (with individual data or aggregate data), and case-control studies.

Table C-1 Inclusion Criteria for Identifying Health Effects Studies

Species
Human
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
Health outcome
Death
Systemic effects
Body weight effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects
Renal effects
Dermal effects
Ocular effects
Endocrine effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Other noncancer effects
Cancer

## C.2 LITERATURE SEARCH AND SCREEN FOR HEALTH EFFECTS STUDIES

A literature search and screen was conducted to identify studies examining the health effects of copper. The literature search framework for the toxicological profile is discussed in detail in Appendix B.

### C.2.1 Literature Search

As noted in Appendix B, the current literature search was intended to update the Draft Toxicological Profile for Copper released for public comment in 2022. See Appendix B for the databases searched and the search strategy.

A total of 15,445 records relevant to all sections of the toxicological profile were identified in the literature search (after duplicate removal).

### C.2.2 Literature Screening

As described in Appendix B, a two-step process was used to screen the literature search to identify relevant studies examining the health effects of copper.

Title and Abstract Screen. In the Title and Abstract Screen step, 15,445 records were reviewed; 56 documents were considered to meet the health effects inclusion criteria in Table C-1 and were moved to the next step in the process.

Full Text Screen. In the second step in the literature screening process for the systematic review, a full text review of 174 health effect documents (documents identified in the update literature search and documents cited in older versions of the profile) was performed. From those 174 documents (181 studies), 57 documents (61 studies) were included in the qualitative review.

There are extensive databases of human and animal data pertaining to copper, but the quality of the data varies widely. Studies were selected for inclusion in the toxicological profile if they provided adequate information for hazard identification and/or dose-response assessment. Basic study quality criteria were developed for epidemiological data and for animal studies using oral administration. These criteria were applied to the studies included after full-text screening, and only studies meeting these criteria were considered in the toxicological profile. There were few animal studies of inhalation exposure to copper, so all studies identified were included.

A priori Study Quality Screen for Human Studies. Several hundred human studies were identified in the literature searches. Copper is an essential mineral that occurs naturally in food and water, and humans are exposed to a range of baseline copper doses from these sources. Therefore, the most reliable hazard identification and dose-response information from human studies comes from studies of controlled exposure and/or studies of clearly elevated exposures (e.g., occupational settings where copper is the primary exposure). For this toxicological profile, all human controlled exposure studies examining health outcomes (not mechanistic endpoints) were included. Case reports and case series, while not epidemiological studies, were included in the assessment if there was clear evidence of excess exposure to copper.

For the updated profile, studies of occupational settings were included if:

- Copper was the primary exposure (by exposure concentration or industrial activity, such as copper smelting) or one of few constituents of the exposure mix were included, and exposure measures (air concentrations or biomarkers) demonstrated a differential copper exposure between groups. Examples of studies excluded by this criterion include studies of manganese workers (Ge et al. 2020, 2021, 2022), rare earth miners (Liu et al. 2021c), automotive technicians (Akinwande et al. 2021), and refinery workers (Ajeel et al. 2021).
- The referent group had lower or no exposure to copper or other heavy metals. For example, two studies (Haase et al. 2021, 2022) were excluded because the referent group used in these studies was exposed to lead dust and dust of precious metals.

After applying the criteria, four occupational studies were selected for inclusion.

Studies of populations without quantified exposure to exogenous copper were excluded. Many studies examined associations between various health outcomes and copper concentrations in urine, serum/blood, hair, nails, or other physiological fluids or tissues in the general population. These studies did not distinguish between conditions of copper deficiency, adequacy, and excess, and as such, do not inform hazard identification. In addition, perturbation of copper homeostasis may result from various health conditions, leading to the potential for reverse causation or confounding in these studies.

For the updated profile, human epidemiological studies of the general population (non-occupational settings) were included if they met the following criteria:

- Copper concentration in food, water, or air was measured or estimated for individual subjects in the study (e.g., ecological study designs were not included).
- Exposure was not measured after outcome.
- The statistical analysis of the association considered at least one potential covariate. Studies limited to bivariate analyses (i.e., Pearson or Spearman correlation coefficients), or analyses limited to comparison between copper concentrations/biomarkers in cases and controls were not included.

Applying the criteria above resulted in the selection of 11 studies of general population exposure.

A priori Study Quality Screen for Animal Studies using Oral Administration. Among animal toxicity studies using oral administration identified in the literature searches, the quality of the studies varied widely. For example, some studies did not report the form of copper administered, some reported the dose or concentration inconsistently, and some did not clearly distinguish between mg/kg body weight and mg/kg diet. Many studies administered copper in diet or drinking water without reporting intake levels. Water intake (but not dietary intake) was shown to decrease with increasing copper concentration (NTP 1993), so reference intake rates may overestimate the dose of copper from drinking water studies.

Of the animal studies using oral administration, studies were included in the profile if:

- The form of copper (compound) administered was clearly reported.
- The concentration(s) or dose(s) were consistently reported as either the compound (e.g., mg CuSO_4_/kg) or as copper (mg Cu/kg).
- When reported as mg/kg, the study clearly reported the value as mg/kg body weight or mg/kg diet.
- The dose of copper or copper compound administered was reported or could be reliably estimated. Studies that used drinking water administration but did not provide water intake information were not included.
- Additionally, a number of studies examined animals with genetic defects similar to Wilson’s disease (e.g., Long-Evans Cinnamon rats and Bedlington terrier dogs) were not included.

Applying these criteria resulted in the selection of 82 animal oral toxicity studies for inclusion in the toxicological profile.

## C.3 EXTRACT DATA FROM HEALTH EFFECTS STUDIES

Relevant data extracted from the individual studies selected for inclusion in the systematic review were collected in customized data forms. A summary of the type of data extracted from each study is presented in Table C-2. For references that included more than one experiment or species, data extraction records were created for each experiment or species.

Table C-2 Data Extracted From Individual Studies

Citation
Chemical form
Route of exposure (e.g., inhalation, oral, dermal)
Specific route (e.g., gavage in oil, drinking water)
Species
Strain
Exposure duration category (e.g., acute, intermediate, chronic)
Exposure duration
Frequency of exposure (e.g., 6 hours/day, 5 days/week)
Exposure length
Number of animals or subjects per sex per group
Dose/exposure levels
Parameters monitored
Description of the study design and method
Summary of calculations used to estimate doses (if applicable)
Summary of the study results
Reviewer’s comments on the study
Outcome summary (one entry for each examined outcome)
No-observed-adverse-effect level (NOAEL) value
Lowest-observed-adverse-effect level (LOAEL) value
Effect observed at the LOAEL value

A summary of the extracted data for each study is presented in the Supplemental Documents for copper and overviews of the results of the inhalation, oral and dermal exposure studies are presented in Sections 2.2–2.19 of the profile and in the Levels of Significant Exposures tables in Section 2.1 of the profile (Tables 2-1 and 2-2).

## C.4 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN

Overviews of the potential health effect outcomes for copper identified in human and animal studies are presented in Table C-3 and C-4, respectively. The available human toxicity studies primarily evaluated the gastrointestinal endpoint including in controlled-exposure studies. Observational and controlled-exposure cohort studies and population level studies have examined a wide range of endpoints in humans. Animal studies examined all endpoints following oral exposure to copper. A very limited number of animal studies examined toxicity following inhalation exposure. Gastrointestinal and hepatic effects were considered sensitive outcomes of oral copper exposure, as effects were observed at low doses in humans and animals and are commonly reported in case reports of human exposures. Respiratory effects were considered a sensitive outcome of inhalation copper exposure because they were seen at low exposure levels in animals and reported in some occupational studies of inhalation exposure. Studies examining these potential outcomes were carried through to Steps 4–8 of the systematic review. Case reports and case series, as well as community and occupational health investigations that did not include referent groups, were not included in the formal systematic review due to inherent high risk of bias and low confidence based on study design. However, consistent findings from these studies were considered during the adjustment of the confidence rating (with regards to consistency and/or severity of observed effects). There were 61 studies (published in 57 documents) examining these potential outcomes carried through to Steps 4–8 of the systematic review.

Table C-3 Overview of the Health Outcomes for Copper Evaluated in Human Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other noncancer | Cancer
Inhalation Studies
Cohort | | 3 | 2 | | | | | | | | | 1 | | | | | 1
Cohort | | 1 | 1 | | | | | | | | | 1 | | | | | 1
Case Control | | | | | | | | | | | | 1 | | | 1
Case Control | | | | | | | | | | | | 1 | | | 0
Population | | 5 | 2 | 1 | 1 | | 1 | | 1 | 1 | 1 | | 1 | 1 | | 2
Population | | 4 | 2 | 1 | 1 | | 1 | | 1 | 1 | 1 | | 1 | 1 | | 2
Case Series | | 8 | | 1 | 1 | | 1 | 1 | | | | | 1
Case Series | | 8 | | 1 | 1 | | 1 | 1 | | | | | 1
Oral Studies
Cohort | | | 1 | 1 | | | | | | | | | 1
Cohort | | | 1 | 0 | | | | | | | | | 1
Case Control | 2 | | 1 | 9 | 2 | | 7 | | | | | 1 | 1
Case Control | 0 | | 0 | 8 | 0 | | 0 | | | | | 1 | 1
Population | | | 3 | 1 | 2 | | 1 | | | | | | 2 | | | 1
Population | | | 0 | 0 | 2 | | 0 | | | | | | 1 | | | 0
Case Series | | 9 | 10 | 15 | 20 | 2 | 19 | 19 | 6 | | 3 | 2 | 4
Case Series | | 9 | 10 | 15 | 20 | 2 | 19 | 19 | 6 | | 3 | 2 | 4
Dermal Studies
Cohort
Case Control
Population
Case Series | | | | | 1 | | 1 | | 2 | | | 4
Case Series | | | | | 1 | | 1 | | 2 | | | 4

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

## C.5 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES

### C.5.1 Risk of Bias Assessment

The risk of bias of individual studies was assessed using OHAT’s Risk of Bias Tool (NTP 2015). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies, and animal experimental studies are presented in Tables C-5, C-6, and C-7, respectively. Each risk of bias question was answered on a four-point scale:

- Definitely low risk of bias (++)
- Probably low risk of bias (+)
- Probably high risk of bias (−)
- Definitely high risk of bias (− −)

In general, “definitely low risk of bias” or “definitely high risk of bias” were used if the question could be answered with information explicitly stated in the study report. If the response to the question could be inferred, then “probably low risk of bias” or “probably high risk of bias” responses were typically used.

Table C-4 Overview of the Health Outcomes for Copper Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other noncancer | Cancer
Inhalation Studies
Acute-duration | | 4 | | | | | | | | | | 2
Acute-duration | | 3 | | | | | | | | | | 2
Intermediate-duration | 1 | 3 | | | 1 | | 1 | 1 | | | | 1 | 1
Intermediate-duration | 0 | 1 | | | 0 | | 0 | 0 | | | | 0 | 0
Chronic-duration
Oral Studies
Acute-duration | 1 | | 1 | 2 | | | 4 | 4 | | | | | | 6 | 1
Acute-duration | 1 | | 1 | 2 | | | 4 | 3 | | | | | | 4 | 0
Intermediate-duration | 31 | 8 | 10 | 7 | 10 | 2 | 27 | 16 | | | 6 | 6 | 17 | 22 | 5 | 1
Intermediate-duration | 17 | 1 | 3 | 5 | 8 | 1 | 19 | 12 | | | 0 | 3 | 11 | 16 | 3 | 1
Chronic-duration | 2 | | | | 1 | | 1
Chronic-duration | 0 | | | | 1 | | 0
Dermal Studies
Acute-duration
Intermediate-duration
Chronic-duration

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

Table C-5 Risk of Bias Questionnaire for Observational Epidemiology Studies

Selection bias
Were the comparison groups appropriate?
Confounding bias
Did the study design or analysis account for important confounding and modifying variables?
Attrition/exclusion bias
Were outcome data complete without attrition or exclusion from analysis?
Detection bias
Is there confidence in the exposure characterization?
Is there confidence in outcome assessment?
Selective reporting bias
Were all measured outcomes reported?

Table C-6 Risk of Bias Questionnaire for Human-Controlled Exposure Studies

Selection bias
Was administered dose or exposure level adequately randomized?
Was the allocation to study groups adequately concealed?
Performance bias
Were the research personnel and human subjects blinded to the study group during the study?
Attrition/exclusion bias
Were outcome data complete without attrition or exclusion from analysis?
Detection bias
Is there confidence in the exposure characterization?
Is there confidence in outcome assessment?
Selective reporting bias
Were all measured outcomes reported?

For the copper profile, the OHAT guidance on the question “Is there confidence in the exposure characterization?” was interpreted to only detract modestly from the rating in consideration of reporting of copper purity in studies. Studies were rated as probably low risk of bias (+) on this question if purity was not reported but the study does report that the test article was obtained from a commercial supplier of research chemicals, and if there is nothing in the study suggesting a risk of the test article decomposition during dosing or storage.

After the risk of bias questionnaires were completed for the health effects studies, the studies were assigned to one of three risk of bias tiers based on the responses to the key questions listed below and the responses to the remaining questions.

- Is there confidence in the exposure characterization? (only relevant for observational studies)
- Is there confidence in the outcome assessment?
- Does the study design or analysis account for important confounding and modifying variables? (only relevant for observational studies)

First Tier. Studies placed in the first tier received ratings of “definitely low” or “probably low” risk of bias on the key questions AND received a rating of “definitely low” or “probably low” risk of bias on the responses to at least 50% of the other applicable questions.

Second Tier. A study was placed in the second tier if it did not meet the criteria for the first or third tiers.

Third Tier. Studies placed in the third tier received ratings of “definitely high” or “probably high” risk of bias for the key questions AND received a rating of “definitely high” or “probably high” risk of bias on the response to at least 50% of the other applicable questions.

The results of the risk of bias assessment for the different types of copper health effects studies (observational epidemiology, and animal experimental studies) are presented in Tables C-8, C-9, and C-10, respectively.

Table C-7 Risk of Bias Questionnaire for Experimental Animal Studies

Selection bias
Was administered dose or exposure level adequately randomized?
Was the allocation to study groups adequately concealed?
Performance bias
Were experimental conditions identical across study groups?
Were the research personnel blinded to the study group during the study?
Attrition/exclusion bias
Were outcome data complete without attrition or exclusion from analysis?
Detection bias
Is there confidence in the exposure characterization?
Is there confidence in outcome assessment?
Selective reporting bias
Were all measured outcomes reported?

Table C-8 Summary of Risk of Bias Assessment for Copper––Observational Epidemiology Studies

Reference | Risk of bias criteria and ratings | | | | | | Risk of bias tier
Reference | Selection bias | Confounding bias | Attrition / exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | | | | | | | Risk of bias tier
Reference | Were the comparison groups appropriate? | Did the study design or analysis account for important confounding and modifying variables?* | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization?* | Is there confidence in the outcome assessment?* | Were all measured outcomes reported? | Risk of bias tier
Outcome: Gastrointestinal effects
Cohort studies
Buchanan et al. 1999 | + | + | − | − | − | ++ | Second
Pettersson et al. 2003 | ++ | + | + | + | + | ++ | First
Case-control studies
Buchanan et al. 1999 | + | + | ++ | + | + | ++ | First
Outcome: Hepatic effects (no studies)
Outcome: Respiratory effects
Cohort studies
Boogaard et al. 2013 | ++ | + | − | − | ++ | ++ | Second
Gehring et al. 2015 | ++ | + | + | − | + | ++ | First
Yu et al. 2021b | ++ | + | + | − | + | ++ | First
Cross-sectional studies
Fouad and Ramadan 2022 | + | − | + | − | + | ++ | Second
Saadiani et al. 2023 | + | − | + | − | + | ++ | Second
Mourad and El-Sherif 2022 | + | − | + | − | − | ++ | Second

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; −− = definitely high risk of bias; NA = not applicable *Key question used to assign risk of bias tier

Table C-9 Summary of Risk of Bias Assessment for Copper-Human-Controlled Exposure Studies

Reference | Risk of bias criteria and ratings | | | | | | | Risk of bias tier
Reference | Selection bias | | Performance bias | Attrition / exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | | | | | | | | Risk of bias tier
Reference | Was administered dose or exposure level adequately randomized? | Was the allocation to study groups adequately concealed? | Were the research personnel blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment?* | Were all measured outcomes reported? | Risk of bias tier
Outcome: Gastrointestinal effects (oral only)
Oral acute exposure
Araya et al. 2001 | ++ | ++ | ++ | + | + | + | ++ | First
Araya et al. 2003a | ++ | ++ | ++ | ++ | + | + | ++ | First
Araya et al. 2003c | ++ | ++ | ++ | + | + | + | ++ | First
Gotteland et al. 2001 | ++ | ++ | ++ | ++ | − | + | ++ | First
Olivares et al. 2001 | + | + | + | + | − | + | ++ | First
Pizarro et al. 1999 | ++ | ++ | ++ | ++ | + | + | ++ | First
Pizarro et al. 2001 | ++ | ++ | ++ | ++ | − | + | ++ | First
Oral intermediate exposure
Araya et al. 2003b, 2004 | ++ | ++ | ++ | ++ | − | + | ++ | First
Olivares et al. 1998 | − | − | + | + | − | − | ++ | Second
Pratt et al. 1985 | + | ++ | ++ | + | − | − | − | Second
Outcome: Hepatic effects (oral only)
Oral acute exposure
Pizarro et al. 1999 | ++ | ++ | ++ | ++ | + | + | ++ | First
Pizarro et al. 2001 | ++ | ++ | ++ | + | − | + | ++ | First
Oral intermediate exposure
Araya et al. 2003b, 2004 | ++ | ++ | ++ | ++ | − | + | ++ | First
O'Connor et al. 2003 | ++ | ++ | ++ | ++ | − | + | ++ | First
Olivares et al. 1998 | − | − | + | + | − | − | ++ | Second
Pratt et al. 1985 | + | ++ | ++ | + | − | − | − | Second
Rojas-Sobarzo et al. 2013 | ++ | ++ | ++ | + | ++ | + | ++ | First
Outcome: Respiratory effects (no studies)

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; −− = definitely high risk of bias; NA = not applicable *Key question used to assign risk of bias tier

## C.6 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME

Confidences in the bodies of human and animal evidence were evaluated independently for each potential outcome. ATSDR did not evaluate the confidence in the body of evidence for carcinogenicity; rather, the Agency defaulted to the cancer weight-of-evidence assessment of other agencies including HHS, EPA, and IARC. The confidence in the body of evidence for an association or no association between exposure to copper and a particular outcome was based on the strengths and weaknesses of individual studies. Four descriptors were used to describe the confidence in the body of evidence for effects or when no effect was found:

- High confidence: the true effect is highly likely to be reflected in the apparent relationship
- Moderate confidence: the true effect may be reflected in the apparent relationship
- Low confidence: the true effect may be different from the apparent relationship
- Very low confidence: the true effect is highly likely to be different from the apparent relationship

Confidence in the body of evidence for a particular outcome was rated for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

### C.6.1 Initial Confidence Rating

In ATSDR’s modification to the OHAT approach, the body of evidence for an association (or no association) between exposure to copper and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. The presence of these key features of study design was determined for individual studies using four “yes or no” questions, which were customized for epidemiology, human controlled exposure, or experimental animal study designs. Separate questionnaires were completed for each outcome assessed in a study. The key features for observational epidemiology (cohort, population, and case-control) studies, human controlled exposure, and experimental animal studies are presented in Tables C-11, C-12, and C-13, respectively. The initial confidence in the study was determined based on the number of key features present in the study design:

- High Initial Confidence: Studies in which the responses to the four questions were “yes.”
- Moderate Initial Confidence: Studies in which the responses to only three of the questions were “yes.”
- Low Initial Confidence: Studies in which the responses to only two of the questions were “yes.”
- Very Low Initial Confidence: Studies in which the response to one or none of the questions was “yes.”

Table C-10 Summary of Risk Bias Assessment for Copper-Experimental Animal Studies

Reference | Risk of bias criteria and ratings | | | | | | | | Risk of bias tier
Reference | Selection bias | | Performance bias | | Attrition / exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | | | | | | | | | Risk of bias tier
Reference | Was administered dose or exposure level adequately randomized? | Was the allocation to study groups adequately concealed? | Were experimental conditions identical across study groups? | Were the research personnel blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment?* | Were all measured outcomes reported? | Risk of bias tier
Outcome: Gastrointestinal effects (oral only)
Oral acute exposure
Husain et al. 2021 (rat) | − | + | + | + | + | − | + | + | First
Yamamoto et al. 2004 (shrew) | − | + | + | + | − | − | ++ | ++ | First
Oral intermediate exposure
Chung et al. 2009 (rat) | + | + | + | + | + | − | + | + | First
NTP 1993 (mouse, 15 days, water) | + | + | ++ | + | − | ++ | ++ | ++ | First
NTP 1993 (mouse, 15 days, feed) | + | + | ++ | + | ++ | ++ | ++ | ++ | First
NTP 1993 (rat, 15 days, water) | + | + | ++ | + | − | ++ | ++ | ++ | First
NTP 1993 (rat, 15 days, feed) | + | + | ++ | + | ++ | ++ | ++ | ++ | First
NTP 1993 (mouse, 13 weeks, feed) | + | + | ++ | + | ++ | ++ | ++ | ++ | First
NTP 1993 (rat, 13 weeks, feed) | + | + | ++ | + | ++ | ++ | ++ | ++ | First
Outcome: Hepatic effects
Inhalation acute exposure
Poland et al. 2022 (rat, sulfate) | ++ | + | + | + | ++ | ++ | ++ | ++ | First
Poland et al. 2022 (rat, oxide) | ++ | + | + | + | ++ | ++ | ++ | ++ | First
Inhalation intermediate exposure
Poland et al. 2022 (rat, oxide) | ++ | + | + | + | ++ | ++ | ++ | ++ | First
Oral acute exposure
Alhusaini et al. 2018a (rat) | + | + | − | − | ++ | + | + | ++ | First
Alhusaini et al. 2018b (rat) | − | + | − | − | ++ | + | + | ++ | First
Haywood 1980 (rat) | − | + | + | + | + | − | + | + | First
Haywood and Comerford 1980 (rat) | − | + | + | + | ++ | − | + | + | First
Oral intermediate exposure
Abe et al. 2008 (rat) | + | + | ++ | − | + | + | + | ++ | First
Adele et al. 2023 (rat) | − | + | − | + | ++ | − | + | + | First
Chung et al. 2009 (rat) | + | + | + | + | + | + | + | + | First
Dab et al. 2023 (mouse) | − | + | + | + | ++ | + | + | + | First
Epstein et al. 1982 (rat) | + | + | ++ | − | ++ | − | ++ | ++ | First
Fuentealba et al. 2000 (rat) | − | + | − | + | + | − | + | − | Second
Haywood 1980 (rat) | − | + | + | + | + | − | + | + | First
Haywood and Comerford 1980 (rat) | − | + | + | + | ++ | − | + | + | First
Haywood and Loughran 1985 (rat) | − | + | + | + | + | −− | + | + | First
Kumar et al. 2015, 2016a, 2016b (rat) | + | + | ++ | + | + | + | ++ | ++ | First
Kumar and Sharma 1987 (rat) | + | + | − | + | −− | − | + | ++ | First
Liu et al. 2020a, 2020b, 2021a, 2021b (mouse) | + | + | + | + | + | − | + | − | First
NTP 1993 (mouse, 15 days, water) | + | + | ++ | + | − | ++ | ++ | ++ | First
NTP 1993 (mouse, 15 days, feed) | + | + | ++ | + | ++ | ++ | ++ | ++ | First
NTP 1993 (rat, 15 days, water) | + | + | ++ | + | − | ++ | ++ | ++ | First
NTP 1993 (rat, 15 days, feed) | + | + | ++ | + | ++ | ++ | ++ | ++ | First
NTP 1993 (mouse, 13 weeks, feed) | + | + | ++ | + | ++ | ++ | ++ | ++ | First
NTP 1993 (rat,13 weeks, feed) | + | + | ++ | + | ++ | ++ | ++ | ++ | First
Patwa and Flora 2020 (rat) | − | + | − | + | ++ | + | + | + | First
Rana and Kumar 1980 (rat) | −− | + | − | − | − | − | + | ++ | Second
Sakhaee et al. 2012 (rat) | + | + | ++ | − | + | − | + | ++ | First
Sakhaee et al. 2014 (mouse) | + | + | ++ | + | + | − | + | ++ | First
Seven et al. 2018 (rat) | + | + | − | − | + | + | + | ++ | First
Sugawara et al. 1995 (rat) | + | + | + | + | ++ | −− | + | + | First
Suttle and Mills 1966 (pig, Experiment 1) | ++ | + | ++ | + | ++ | − | ++ | ++ | First
Suttle and Mills 1966 (pig, Experiment 2) | ++ | + | ++ | + | ++ | − | ++ | ++ | First
Temiz et al. 2021 (rat) | + | + | − | + | ++ | − | + | + | First
Wu et al. 2020 (mouse) | − | + | ++ | − | ++ | + | + | ++ | First
Yu et al. 2021a (rat) | + | + | − | + | + | −− | + | + | First
Zhang et al. 2020 (pig) | + | + | + | + | + | − | + | + | First
Oral chronic exposure
Araya et al. 2012 (monkey) | + | + | + | − | ++ | − | + | ++ | First
Outcome: Respiratory effects
Inhalation acute exposure
Poland et al. 2022 (rat, sulfate) | ++ | + | + | + | ++ | ++ | ++ | ++ | First
Poland et al. 2022 (rat, oxide) | ++ | + | + | + | ++ | ++ | ++ | ++ | First
Inhalation intermediate exposure
Poland et al. 2022 (rat, oxide) | ++ | + | + | + | ++ | ++ | ++ | ++ | First
Johansson et al. 1983 (rabbit) | + | + | + | + | + | − | + | + | First
Johansson et al. 1984 (rabbit) | + | + | + | + | + | − | + | + | First
Oral intermediate exposure
Chung et al. 2009 (rat) | + | + | + | + | + | + | + | + | First
Draper et al. 2023 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | + | First
NTP 1993 (mouse, 15 days, water) | + | + | ++ | + | + | ++ | ++ | ++ | First
NTP 1993 (mouse, 15 days, feed) | + | + | ++ | + | ++ | ++ | ++ | ++ | First
NTP 1993 (rat, 15 days, water) | + | + | ++ | + | + | ++ | ++ | ++ | First
NTP 1993 (rat, 15 days, feed) | + | + | ++ | + | ++ | ++ | ++ | ++ | First
NTP 1993 (mouse, 13 weeks, feed) | + | + | ++ | + | ++ | ++ | ++ | ++ | First
NTP 1993 (rat,13 weeks, feed) | + | + | ++ | + | ++ | ++ | ++ | ++ | First

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; −− = definitely high risk of bias; NA = not applicable *Key question used to assign risk of bias tier

Table C-11 Key Features of Study Design for Observational Epidemiology Studies

Exposure was experimentally controlled
Exposure occurred prior to the outcome
Outcome was assessed on individual level rather than at the population level
A comparison group was used

Table C-12 Key Features of Study Design for Human-Controlled Exposure Studies

A comparison group was used or the subjects served as their own control
A sufficient number of subjects were tested
Appropriate methods were used to measure outcomes (i.e., clinically-confirmed outcome versus self- reported)
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

The presence or absence of the key features and the initial confidence levels for studies examining gastrointestinal and neurological health effects observed in the observational epidemiology, controlled-exposure human studies and animal experimental studies are presented in Tables C-14, C-15, and C-16, respectively.

A summary of the initial confidence ratings for each outcome is presented in Table C-17. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence.

Table C-13 Key Features of Study Design for Experimental Animal Studies

A concurrent control group was used
A sufficient number of animals per group were tested
Appropriate parameters were used to assess a potential adverse effect
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

Table C-14 Presence of Key Features of Study Design for Copper—Observational Epidemiology Studies

Reference | Key features | | | | Initial study confidence
Reference | Controlled Exposure | Exposure prior to outcome | Outcome assess on individual level | Comparison group | Initial study confidence
Outcome: Gastrointestinal effects
Cohort studies
Buchanan et al. 1999 | No | Yes | Yes | Yes | Moderate
Pettersson et al. 2003 | No | Yes | Yes | Yes | Moderate
Case-control studies
Buchanan et al. 1999 | No | Yes | Yes | Yes | Moderate
Outcome: Hepatic effects (no studies)
Outcome: Respiratory effects
Cohort studies
Boogaard et al. 2013 | No | Yes | Yes | Yes | Moderate
Gehring et al. 2015 | No | Yes | Yes | Yes | Moderate
Yu et al. 2021b | No | Yes | Yes | Yes | Moderate
Cross-sectional studies
Fouad and Ramadan 2022 | No | Yes | Yes | Yes | Moderate
Saadiani et al. 2023 | No | Yes | Yes | Yes | Moderate
Mourad and El-Sherif 2022 | No | Yes | Yes | Yes | Moderate

Table C-15 Presence of Key Features of Study Design for Copper–Human-Controlled Exposure Studies

Reference | Key features | | | | Initial study confidence
Reference | Concurrent Control Group | Sufficient number of subjects per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Gastrointestinal effects
Oral acute exposure
Araya et al. 2001 | Yes | Yes | Yes | Yes | High
Araya et al. 2003a | Yes | Yes | Yes | Yes | High
Araya et al. 2003c | Yes | Yes | Yes | Yes | High
Gotteland et al. 2001 | Yes | Yes | Yes | Yes | High
Olivares et al. 2001 | Yes | Yes | Yes | Yes | High
Pizarro et al. 1999 | Yes | Yes | Yes | Yes | High
Pizarro et al. 2001 | Yes | Yes | Yes | Yes | High
Oral intermediate exposure
Araya et al. 2003b, 2004 | Yes | Yes | Yes | Yes | High
Olivares et al. 1998 | Yes | Yes | Yes | Yes | High
Pratt et al. 1985 | Yes | No | No | No | Very Low
Outcome: Hepatic effects
Oral acute exposure
Pizarro et al. 1999 | Yes | Yes | No | Yes | Moderate
Pizarro et al. 2001 | Yes | Yes | No | Yes | Moderate
Oral intermediate exposure
Araya et al. 2003b, 2004 | Yes | Yes | No | Yes | Moderate
O’Connor et al. 2003 | Yes | Yes | No | Yes | Moderate
Olivares et al. 1998 | Yes | Yes | No | Yes | Moderate
Pratt et al. 1985 | Yes | No | No | No | Very Low
Rojas-Sobarzo et al. 2013 | Yes | Yes | No | Yes | Moderate
Outcome: Respiratory effects (no studies)

Table C-16 Presence of Key Features of Study Design for Copper–Experimental Animal Studies

Reference | Key features | | | | Initial study confidence
Reference | Concurrent Control Group | Sufficient number of animals per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Gastrointestinal effects
Oral acute exposure
Husain et al. 2021 (rat) | Yes | No | Yes | No | Low
Yamamoto et al. 2004 (shrew) | Yes | No | Yes | Yes | Moderate
Oral intermediate exposure
Chung et al. 2009 (rat) | Yes | Yes | Yes | Yes | High
NTP 1993 (mouse, 15 days, water) | Yes | No | Yes | Yes | Moderate
NTP 1993 (mouse, 15 days, feed) | Yes | Yes | Yes | Yes | High
NTP 1993 (rat, 15 days, water) | Yes | No | Yes | Yes | Moderate
NTP 1993 (rat, 15 days, feed) | Yes | Yes | Yes | Yes | High
NTP 1993 (mouse, 13 weeks, feed) | Yes | Yes | Yes | Yes | High
NTP 1993 (rat,13 weeks, feed) | Yes | Yes | Yes | Yes | High
Outcome: Hepatic effects
Inhalation acute exposure
Poland et al. 2022 (rat, sulfate) | Yes | No | No | No | Very Low
Poland et al. 2022 (rat, oxide) | Yes | No | No | No | Very Low
Inhalation intermediate exposure
Poland et al. 2022 (rat, oxide) | Yes | Yes | Yes | No | Moderate
Oral acute exposure
Alhusaini et al. 2018a (rat) | Yes | No | Yes | Yes | Moderate
Alhusaini et al. 2018b (rat) | Yes | No | Yes | Yes | Moderate
Haywood 1980 (rat) | Yes | No | Yes | No | Low
Haywood and Comerford 1980 (rat) | Yes | No | No | Yes | Low
Oral intermediate exposure
Abe et al. 2008 (rat) | Yes | No | Yes | Yes | Moderate
Adele et al. 2023 (rat) | Yes | No | No | Yes | Low
Chung et al. 2009 (rat) | Yes | Yes | Yes | No | Moderate
Dab et al. 2023 (mouse) | Yes | No | No | Yes | Low
Epstein et al. 1982 (rat) | Yes | No | Yes | Yes | Moderate
Fuentealba et al. 2000 (rat) | Yes | No | Yes | No | Low
Haywood 1980 (rat) | Yes | No | Yes | No | Low
Haywood and Comerford 1980 (rat) | Yes | No | No | Yes | Low
Haywood and Loughran 1985 (rat) | Yes | Yes | Yes | No | Moderate
Kumar et al. 2015, 2016a, 2016b (rat) | Yes | Yes | Yes | Yes | High
Kumar and Sharma 1987 (rat) | Yes | Yes | No | No | Low
Liu et al. 2020a, 2020b, 2021a, 2021b (mouse) | Yes | No | Yes | No | Low
NTP 1993 (mouse, 15 days, water) | Yes | No | Yes | Yes | Moderate
NTP 1993 (mouse, 15 days, feed) | Yes | Yes | Yes | Yes | High
NTP 1993 (rat, 15 days, water) | Yes | No | Yes | Yes | Moderate
NTP 1993 (rat, 15 days, feed) | Yes | Yes | Yes | Yes | High
NTP 1993 (mouse, 13 weeks, feed) | Yes | Yes | Yes | Yes | High
NTP 1993 (rat,13 weeks, feed) | Yes | Yes | Yes | Yes | High
Patwa and Flora 2020 (rat) | Yes | No | Yes | Yes | Moderate
Rana and Kumar 1980 (rat) | Yes | Yes | Yes | Yes | High
Sakhaee et al. 2012 (rat) | Yes | Yes | Yes | Yes | High
Sakhaee et al. 2014 (mouse) | Yes | Yes | No | Yes | Moderate
Seven et al. 2018 (rat) | Yes | No | Yes | Yes | Moderate
Sugawara et al. 1995 (rat) | Yes | No | No | Yes | Low
Suttle and Mills 1966 (pig, Experiment 1) | Yes | No | No | Yes | Low
Suttle and Mills 1966 (pig, Experiment 2) | Yes | No | No | Yes | Low
Temiz et al. 2021 (rat) | Yes | No | Yes | Yes | Moderate
Wu et al. 2020 (mouse) | Yes | Yes | Yes | Yes | High
Yu et al. 2021a (rat) | Yes | Yes | Yes | Yes | High
Zhang et al. 2020 (pig) | Yes | No | Yes | Yes | Moderate
Oral chronic exposure
Araya et al. 2012 (monkey) | Yes | No | Yes | Yes | Moderate
Outcome: Respiratory effects
Inhalation acute exposure
Poland et al. 2022 (rat, sulfate) | Yes | No | Yes | Yes | Moderate
Poland et al. 2022 (rat, oxide) | Yes | No | Yes | Yes | Moderate
Inhalation intermediate exposure
Poland et al. 2022 (rat, oxide) | Yes | Yes | Yes | Yes | High
Johansson et al. 1983 (rabbit) | Yes | No | Yes | No | Low
Johansson et al. 1984 (rabbit) | Yes | No | Yes | No | Low
Oral intermediate exposure
Chung et al. 2009 (rat) | Yes | Yes | Yes | Yes | High
Draper et al. 2023 (rat) | Yes | No | Yes | No | Low
NTP 1993 (mouse, 15 days, water) | Yes | No | Yes | Yes | Moderate
NTP 1993 (mouse, 15 days, feed) | Yes | Yes | Yes | Yes | High
NTP 1993 (rat, 15 days, water) | Yes | No | Yes | Yes | Moderate
NTP 1993 (rat, 15 days, feed) | Yes | Yes | Yes | Yes | High
NTP 1993 (mouse, 13 weeks, feed) | Yes | Yes | Yes | Yes | High
NTP 1993 (rat, 13 weeks, feed) | Yes | Yes | Yes | Yes | High

Table C-17 Initial Confidence Rating for Copper Health Effects Studies

| Initial study confidence | Initial confidence rating
Outcome: Gastrointestinal effects
Oral acute exposure
Animal Studies
Husain et al. 2021 | Low | Moderate
Yamamoto et al. 2004 (shrew) | Moderate | Moderate
Human studies
Araya et al. 2001 | High | High
Araya et al. 2003a | High | High
Araya et al. 2003c | High | High
Gotteland et al. 2001 | High | High
Olivares et al. 2001 | High | High
Pizarro et al. 1999 | High | High
Pizarro et al. 2001 | High | High
Oral intermediate exposure
Animal studies
Chung et al. 2009 | High | High
NTP 1993 (mouse, 15 days, water) | Moderate | High
NTP 1993 (mouse, 15 day, feed) | High | High
NTP 1993 (rat, 15 days, water) | Moderate | High
NTP 1993 (rat, 15 days, feed) | High | High
NTP 1993 (mouse, 13 weeks, feed) | High | High
NTP 1993 (rat,13 weeks, feed) | High | High
Human studies
Araya et al. 2003b, 2004 | High | High
Olivares et al. 1998 | High | High
Pratt et al. 1985 | Very Low | High
Buchanan et al. 1999 | Moderate | High
Pettersson et al. 2003 | Moderate | High
Buchanan et al. 1999 | Moderate | High
Outcome: Hepatic Effects
Inhalation acute exposure
Animal studies
Poland et al. 2022 (rat, sulfate) | Very Low | Very Low
Poland et al. 2022 (rat, oxide) | Very Low | Very Low
Inhalation intermediate exposure
Animal studies
Poland et al. 2022 (rat, oxide) | Moderate | Moderate
Oral acute exposure
Animal studies
Alhusaini et al. 2018a (rat) | Moderate | Moderate
Alhusaini et al. 2018b (rat) | Moderate
Haywood 1980 (rat) | Low
Haywood and Comerford 1980 (rat) | Low
Human studies
Pizarro et al. 1999 | Moderate | Moderate
Pizarro et al. 2001 | Moderate | Moderate
Oral intermediate exposure
Animal studies
Abe et al. 2008 (rat) | Moderate | High
Adele et al. 2023 (rat) | Low | High
Chung et al. 2009 (rat) | Moderate | High
Dab et al. 2023 (mouse) | Low | High
Epstein et al. 1982 (rat) | Moderate | High
Fuentealba et al. 2000 (rat) | Low | High
Haywood 1980 (rat) | Low | High
Haywood and Comerford 1980 (rat) | Low | High
Haywood and Loughran 1985 (rat) | Moderate | High
Kumar et al. 2015, 2016a, 2016b (rat) | High | High
Kumar and Sharma 1987 (rat) | Low | High
Liu et al. 2020a, 2020b, 2021a, 2021b (mouse) | Low | High
NTP 1993 (mouse, 15 days, water) | Moderate | High
NTP 1993 (mouse, 15 days, feed) | High | High
NTP 1993 (rat, 15 days, water) | Moderate | High
NTP 1993 (rat, 15 days, feed) | High | High
NTP 1993 (mouse, 13 weeks, feed) | High | High
NTP 1993 (rat,13 weeks, feed) | High | High
Patwa and Flora 2020 (rat) | Moderate | High
Rana and Kumar 1980 (rat) | High | High
Sakhaee et al. 2012 (rat) | High | High
Sakhaee et al. 2014 (mouse) | Moderate | High
Seven et al. 2018 (rat) | Moderate | High
Sugawara et al. 1995 (rat) | Low | High
Suttle and Mills 1966 (pig, Experiment 1) | Low | High
Suttle and Mills 1966 (pig, Experiment 2) | Low | High
Temiz et al. 2021 (rat) | Moderate | High
Wu et al. 2020 (mouse) | High | High
Yu et al. 2021a (rat) | High | High
Zhang et al. 2020 (pig) | Moderate | High
Human studies
Araya et al. 2003b, 2004 | Moderate | Moderate
O'Connor et al. 2003 | Moderate | Moderate
Olivares et al. 1998 | Moderate | Moderate
Pratt et al. 1985 | Very Low | Moderate
Rojas-Sobarzo et al. 2013 | Moderate | Moderate
Oral chronic exposure
Animal studies
Araya et al. 2012 (monkey) | Moderate | Moderate
Outcome: Respiratory effects
Inhalation acute exposure
Animal studies
Poland et al. 2022 (rat, sulfate) | Moderate | Moderate
Poland et al. 2022 (rat, oxide) | Moderate | Moderate
Inhalation intermediate exposure
Animal studies
Poland et al. 2022 (rat, oxide) | High | High
Johansson et al. 1983 (rabbit) | Low | High
Johansson et al. 1984 (rabbit) | Low | High
Inhalation intermediate exposure
Human studies
Boogaard et al. 2013 | Moderate | Moderate
Gehring et al. 2015 | Moderate | Moderate
Yu et al. 2021b | Moderate | Moderate
Fouad and Ramadan 2022 | Moderate | Moderate
Saadiani et al. 2023 | Moderate | Moderate
Mourad and El-Sherif 2022 | Moderate | Moderate
Oral intermediate exposure
Animal studies
Chung et al. 2009 (rat) | High | High
Draper et al. 2023 (rat) | Low | High
NTP 1993 (mouse, 15 days, water) | Moderate | High
NTP 1993 (mouse, 15 days, feed) | High | High
NTP 1993 (rat, 15 days, water) | Moderate | High
NTP 1993 (rat, 15 days, feed) | High | High
NTP 1993 (mouse, 13 weeks, feed) | High | High
NTP 1993 (rat, 13 weeks, feed) | High | High

### C.6.2 Adjustment of the Confidence Rating

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The nine properties of the body of evidence that were considered are listed below. The summaries of the assessment of the confidence in the body of evidence for gastrointestinal and hepatic effects are presented in Table C-18. If the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. An overview of the confidence in the body of evidence for all health effects associated with copper exposure is presented in Table C-19.

Table C-18 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Outcome: Gastrointestinal effects
Human studies | High | +1 Consistency in the body of evidence | High
Animal studies | High | +1 Consistency in the body of evidence | High
Outcome: Hepatic effects
Human studies | Moderate | −1 Indirectness: length of time between exposure and outcome assessment | Low
Animal studies | High | +1 Consistency in the body of evidence | High
Outcome: Respiratory effects
Human studies | Moderate | −1 Risk of bias | Low
Animal studies | High | None | High

Table C-19 Confidence in the Body of Evidence for Copper

Outcome | Confidence in body of evidence
Outcome | Human studies | Animal studies
Gastrointestinal effects | High | High
Hepatic effects | Low | High
Respiratory effects | Low | High

Five properties of the body of evidence were considered to determine whether the confidence rating should be downgraded:

- Risk of bias. Evaluation of whether there is substantial risk of bias across most of the studies examining the outcome. This evaluation used the risk of bias tier groupings for individual studies examining a particular outcome (Tables C-8, C-9, and C-10). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for risk of bias:
  ○ No downgrade if most studies are in the risk of bias first tier
  ○ Downgrade one confidence level if most studies are in the risk of bias second tier
  ○ Downgrade two confidence levels if most studies are in the risk of bias third tier
- Unexplained inconsistency. Evaluation of whether there is inconsistency or large variability in the magnitude or direction of estimates of effect across studies that cannot be explained. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for unexplained inconsistency:
  ○ No downgrade if there is little inconsistency across studies or if only one study evaluated the outcome
  ○ Downgrade one confidence level if there is variability across studies in the magnitude or direction of the effect
  ○ Downgrade two confidence levels if there is substantial variability across studies in the magnitude or direct of the effect
- Indirectness. Evaluation of four factors that can affect the applicability, generalizability, and relevance of the studies:
  ○ Relevance of the animal model to human health—unless otherwise indicated, studies in rats, mice, and other mammalian species are considered relevant to humans
  ○ Directness of the endpoints to the primary health outcome—examples of secondary outcomes or nonspecific outcomes include organ weight in the absence of histopathology or clinical chemistry findings in the absence of target tissue effects
  ○ Nature of the exposure in human studies and route of administration in animal studies— inhalation, oral, and dermal exposure routes are considered relevant unless there are compelling data to the contrary
  ○ Duration of treatment in animal studies and length of time between exposure and outcome assessment in animal and prospective human studies—this should be considered on an outcome-specific basis
  Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for indirectness:
  ○ No downgrade if none of the factors are considered indirect
  ○ Downgrade one confidence level if one of the factors is considered indirect
  ○ Downgrade two confidence levels if two or more of the factors are considered indirect
- Imprecision. Evaluation of the narrowness of the effect size estimates and whether the studies have adequate statistical power. Data are considered imprecise when the ratio of the upper to lower 95% CIs for most studies is ≥10 for tests of ratio measures (e.g., odds ratios) and ≥100 for absolute measures (e.g., percent control response). Adequate statistical power is determined if the study can detect a potentially biologically meaningful difference between groups (20% change from control response for categorical data or risk ratio of 1.5 for continuous data). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for imprecision:
  ○ No downgrade if there are no serious imprecisions
  ○ Downgrade one confidence level for serious imprecisions
  ○ Downgrade two confidence levels for very serious imprecisions
- Publication bias. Evaluation of the concern that studies with statistically significant results are more likely to be published than studies without statistically significant results.
  ○ Downgrade one level of confidence for cases where there is serious concern with publication bias

Four properties of the body of evidence were considered to determine whether the confidence rating should be upgraded:

- Large magnitude of effect. Evaluation of whether the magnitude of effect is sufficiently large so that it is unlikely to have occurred as a result of bias from potential confounding factors.
  ○ Upgrade one confidence level if there is evidence of a large magnitude of effect in a few studies, provided that the studies have an overall low risk of bias and there is no serious unexplained inconsistency among the studies of similar dose or exposure levels; confidence can also be upgraded if there is one study examining the outcome, provided that the study has an overall low risk of bias
- Dose response. Evaluation of the dose-response relationships measured within a study and across studies. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence of a monotonic dose-response gradient
  ○ Upgrade one confidence level for evidence of a non-monotonic dose-response gradient where there is prior knowledge that supports a non-monotonic dose-response and a nonmonotonic dose-response gradient is observed across studies
- Plausible confounding or other residual biases. This factor primarily applies to human studies and is an evaluation of unmeasured determinants of an outcome such as residual bias towards the null (e.g., “healthy worker” effect) or residual bias suggesting a spurious effect (e.g., recall bias). Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence that residual confounding or bias would underestimate an apparent association or treatment effect (i.e., bias toward the null) or suggest a spurious effect when results suggest no effect
- Consistency in the body of evidence. Evaluation of consistency across animal models and species, consistency across independent studies of different human populations and exposure scenarios, and consistency across human study types. Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level if there is a high degree of consistency in the database

## C.7 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS

In the seventh step of the systematic review of the health effects data for copper, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted. The level of evidence for health effects was rated on a five-point scale:

- High level of evidence: High confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Moderate level of evidence: Moderate confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Low level of evidence: Low confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Evidence of no health effect: High confidence in the body of evidence that exposure to the substance is not associated with the health outcome
- Inadequate evidence: Low or moderate confidence in the body of evidence that exposure to the substance is not associated with the health outcome OR very low confidence in the body of evidence for an association between exposure to the substance and the health outcome

A summary of the level of evidence of health effects for copper is presented in Table C-20.

Table C-20 Level of Evidence of Health Effects for Copper

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human Studies
Gastrointestinal effects | High | Health effect | High
Hepatic effects | Low | No health effect | Inadequate
Respiratory effects | Low | Health effect | Low
Animal Studies
Gastrointestinal effects | High | Health effect | High
Hepatic effects | High | Health effect | High
Respiratory effects | High | Health effect | High

## C.8 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. For health effects, there were four hazard identification conclusion categories:

- Known to be a hazard to humans
- Presumed to be a hazard to humans
- Suspected to be a hazard to humans
- Not classifiable as to the hazard to humans

The initial hazard identification was based on the highest level of evidence in the human studies and the level of evidence in the animal studies; if there were no data for one evidence stream (human or animal), then the hazard identification was based on the one data stream (equivalent to treating the missing evidence stream as having low level of evidence). The hazard identification scheme is presented in Figure C-1 and described below:

- Known: A health effect in this category would have:
  ○ High level of evidence for health effects in human studies AND a high, moderate, or low level of evidence in animal studies.
- Presumed: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND high or moderate level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND high level of evidence in animal studies
- Suspected: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND low level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND moderate level of evidence in animal studies
- Not classifiable: A health effect in this category would have:
  ○ Low level of evidence in human studies AND low level of evidence in animal studies

Figure C-1 Hazard Identification Scheme

Other relevant data such as mechanistic or mode-of-action data were considered to raise or lower the level of the hazard identification conclusion by providing information that supported or opposed biological plausibility.

Two hazard identification conclusion categories were used when the data indicated that there may be no health effect in humans:

- Not identified to be a hazard in humans
- Inadequate to determine hazard to humans

If the human level of evidence conclusion of no health effect was supported by the animal evidence of no health effect, then the hazard identification conclusion category of “not identified” was used. If the human or animal level of evidence was considered inadequate, then a hazard identification conclusion category of “inadequate” was used. As with the hazard identification for health effects, the impact of other relevant data was also considered for no health effect data.

The hazard identification conclusions for copper are listed below and summarized in Table C-21.

Known Health Effects

○ High level of evidence for gastrointestinal effects in humans exposed orally in controlled-exposure studies of acute-duration exposure to copper sulfate in drinking water (Araya et al. 2001, 2003a; Pizarro et al. 1999, 2001) and intermediate-duration exposure to copper sulfate in drinking water or other juice (Araya et al. 2003b, 2003c, 2004; Olivares et al. 2001). Supporting information comes from case reports/series (Banerjee et al. 2023; Bupta et al. 2023; Du and Mou 2019; Franchitto et al. 2008; Galust et al. 2023; Gamakaranage et al. 2011; Griswold et al. 2017; Hassan et al. 2010; Higny et al. 2014; Lubica et al. 2017; Malik and Mansur 2011; Shankar et al. 2023; Tsao et al. 2020) and community health investigations (Knobeloch et al. 1994, 1998).
○ High level of evidence for gastrointestinal effects in mice, rats, and shrews from acute-duration exposure to copper chloride or copper sulfate (Husain et al. 2021; Yamamoto et al. 2004); and intermediate-duration exposure to copper monochloride or copper sulfate pentahydrate (Chung et al. 2009; NTP 1993).

Presumed Health Effects

Respiratory

○ Low level of evidence for respiratory effects in humans exposed via inhalation based on epidemiological studies (Boogaard et al. 2013; Fouad and Ramadan 2022; Gehring et al. 2015; Mourad and El-Sherif 2022; Saadiani et al. 2023; Yu et al. 2021b). Supporting information comes from occupational health investigations (Askergren and Mellgren 1975; Plamenac et al. 1985; Suciu et al. 1981) and case reports of inhalation exposure (Donoso et al. 2007; Pimentel and Marques 1969; Pimentel and Menezes 1975; Stark 1981; Villar 1974; Villar and Nogueira 1980).
○ High level of evidence for respiratory effects in rats exposed by inhalation for acute durations to copper sulfate pentahydrate or dicopper oxide (Poland et al. 2022) and for an intermediate duration to dicopper oxide (Poland et al. 2022). Respiratory effects were also seen in rats exposed orally to copper sulfate pentahydrate for an intermediate duration (Draper et al. 2023).

Hepatic

○ Low level of evidence for hepatic effects in human studies; no changes in hepatic enzyme levels were observed after acute-duration (Pizarro et al. 1999, 2001) or intermediate-duration oral exposure to copper sulfate (Araya et al. 2003b, 2004; O’Connor et al. 2003; Olivares et al. 1998; Rojas-Sobarzo et al. 2013) or copper gluconate (Pratt et al. 1985). Information from occupational health investigations (Suciu et al. 1981), case reports (Du and Mou 2019; Griswold et al. 2017; Gunay et al. 2006; Hassan et al. 2010; Malik and Mansur 2011; Mortazavi and Jafari-Javid 2009; Shankar et al. 2023; Sinkovic et al. 2008; Yadla et al. 2015; Yang et al. 2004), and human mutations that result in copper accumulation suggest that hepatic effects are possible.
○ High level evidence of effects in rats and mice exposed to copper compounds via oral administration for acute (Alhusaini et al. 2018a, 2018b; Haywood 1980; Haywood and Comerford 1980) and intermediate durations (Dab et al. 2023; Epstein et al. 1982; Fuentealba et al. 2000; Haywood 1980; Haywood and Comerford 1980; Haywood and Loughran 1985; Kumar et al. 2015, 2016a, 2016b; Kumar and Sharma 1987; Liu et al. 2020a, 2020b, 2021a, 2021b; NTP 1993; Patwa and Flora 2020; Rana and Kumar 1980; Sakhaee et al. 2012, 2014; Seven et al. 2018; Sugawara et al. 1995; Temiz et al. 2021; Wu et al. 2020; Yu et al. 2021a) and in pigs after intermediate-duration oral exposure (Suttle and Mills 1966).

Table C-21 Hazard Identification Conclusions for Copper

Outcome | Hazard identification
Gastrointestinal effects | Known
Hepatic effects | Presumed
Respiratory effects | Presumed