# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR COPPER

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to copper.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen were conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for copper. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Foreign language studies are reviewed based on available English-language abstracts and/or tables (or summaries in regulatory assessments, such as International Agency for Research on Cancer [IARC] documents). If the study appears critical for hazard identification or MRL derivation, translation into English is requested. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of copper have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of copper are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Health Effects
Species
Human
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
Health outcome
Death
Systemic effects
Body weight effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects
Renal effects
Dermal effects
Ocular effects
Endocrine effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Other noncancer effects
Cancer
Toxicokinetics
Absorption
Distribution
Metabolism
Excretion
PBPK models
Biomarkers
Biomarkers of exposure
Biomarkers of effect
Interactions with other chemicals
Potential for human exposure
Releases to the environment
Air
Water
Soil
Environmental fate
Transport and partitioning
Transformation and degradation
Environmental monitoring
Air
Water
Sediment and soil
Other media
Biomonitoring
General populations
Occupation populations

### B.1.1 Literature Search

The current literature search was intended to update the Draft Toxicological Profile for Copper released for public comment in 2022; thus, the literature search was restricted to studies published between January 2020 and October 2023. The following main databases were searched in October 2023:

- PubMed
- National Technical Reports Library (NTRL)
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for copper. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to copper were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
10/2023 | ((((“Copper/toxicity”[mh] OR “Copper/adverse effects”[mh] OR “Copper/poisoning”[mh] OR “Copper/pharmacokinetics”[mh]) OR (“Copper/blood”[mh] OR “Copper/cerebrospinal fluid”[mh] OR “Copper/urine”[mh]) OR (“Copper/antagonists and inhibitors”[mh]) OR (“Copper/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Copper sulfate/toxicity”[mh] OR “Copper sulfate/adverse effects”[mh] OR “Copper sulfate/poisoning”[mh] OR “Copper sulfate/pharmacokinetics”[mh]) OR (“Copper sulfate/blood”[mh] OR “Copper sulfate/cerebrospinal fluid”[mh] OR “Copper sulfate/urine”[mh]) OR (“Copper sulfate/antagonists and inhibitors”[mh]) OR (“Copper sulfate/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Copper/pharmacology”[majr] OR “Copper sulfate/pharmacology”[majr]) OR ((“Copper”[mh] OR “Copper sulfate”[mh]) AND (“environmental exposure”[mh] OR ci[sh] OR toxicokinetics[mh:noexp] )) OR ((“Copper”[mh] OR “Copper sulfate”[mh]) AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR ((“Copper”[mh] OR “Copper sulfate”[mh]) AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR ((“Copper”[mh] OR “Copper sulfate”[mh]) AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR (142–71-2[rn] OR 10380– 28-6[rn]) OR ((“Copper”[mh] OR “Copper Sulfate”[mh]) AND ((indexingmethod_automated OR indexingmethod_curated) AND (“RNA”[mh] OR “DNA”[mh] OR “DNA Replication”[mh] OR “Salmonella typhimurium”[mh] OR antagonist*[tw] OR inhibitor*[tw] OR “blood”[tw] OR
| “serum”[tw] OR “plasma”[tw] OR pharmacokinetic*[tw] OR toxicokinetic*[tw] OR “pbpk”[tw] OR “poisoned”[tw] OR “poisoning”[tw] OR “urine”[tw] OR “urinary”[tw] OR “toxicity”[sh] OR “occupational diseases”[mh] OR “hazardous substances”[mh] OR “epidemiology”[sh] OR “epidemiologic studies”[mh])))) AND (2022/08/07:3000[mhda]))) OR ((“Copper D- gluconate”[tiab] OR “Copper di-D-gluconate”[tiab] OR “Copper gluconate”[tiab] OR “Copper(2+) D-gluconate, (1:2)”[tiab] OR “Copper(2+) di(D-gluconate)”[tiab] OR “Copper(II)gluconate”[tiab] OR “Cupric gluconate”[tiab] OR “D-Gluconic acid, copper complex”[tiab] OR “D-Gluconic acid, copper salt”[tiab] OR “D-Gluconic acid, copper(2+) salt”[tiab] OR “Gluconic acid, copper salt, D-”[tiab] OR “Gluconic acid, copper(2+) salt”[tiab] OR “Helshas Cu”[tiab] OR “Labicuper”[tiab]) AND (2022/08/07:3000[edat] OR 2022/08/07:3000[crdat])); ((((“Copper”[tw] OR “1721 Gold”[tw] OR “3EC-M3S-HTE”[tw] OR “3EC-M3VLP18”[tw] OR “ANAC 110”[tw] OR “ATS Adocopper IW”[tw] OR “BAC 13B-NK120”[tw] OR “Bronze powder”[tw] OR “C 100 (metal)”[tw] OR “C.I. 77400”[tw] OR “C.I. Pigment Metal 2”[tw] OR “Caswell No. 227”[tw] OR “CDA 101”[tw] OR “CDA 102”[tw] OR “CDA 110”[tw] OR “CDA 122”[tw] OR “CDX (metal)”[tw] OR “CE 1110”[tw] OR “CE 7 (metal)”[tw] OR “CF-T 8GD-SV”[tw] OR “CF-T 9A-HP-STD”[tw] OR “CF-T 9B-THE”[tw] OR “CF-T 9FZ-SV”[tw] OR “CFW 100–156”[tw] OR “CI 77400”[tw] OR “CI Pigment metal 2”[tw] OR “CU M3”[tw] OR “Cu-At-W 250”[tw] OR “Cubrotec 5000”[tw] OR “Cuivre metal”[tw] OR “Cutox 6010”[tw] OR “Cutox 6030”[tw] OR “DD Paste TH 9910”[tw] OR “Double Thin F-NP”[tw] OR “DT GLMP”[tw] OR “E 115 (metal)”[tw] OR “Gold bronze”[tw] OR “GT (metal)”[tw] OR “NDP- III”[tw] OR “NT-TAX-M”[tw] OR “NT-TAX-O”[tw] OR “OFHC Cu”[tw] OR “Paragard T 380a”[tw] OR “Paragard t380a”[tw] OR “Pigment metal 2”[tw] OR “Silcoat FCC-SP 99”[tw] OR “Tatum-T”[tw] OR “Unicoat 2845”[tw] OR “USLP-SE”[tw] OR “All Clear Root Destroyer”[tw] OR “Aqua Maid Permanent Algaecide”[tw] OR “Aquatronics Snail-A-Cide Dri-Pac Snail Powder”[tw] OR “Blue stone”[tw] OR “Blue vitriol”[tw] OR “Bonide Root Destroyer”[tw] OR “Cuivrol”[tw] OR “CuSO4”[tw] OR “Delcup”[tw] OR “EarthTec”[tw] OR “Hylinec”[tw] OR “Incracide 10A”[tw] OR “Incracide E 51”[tw] OR “MAC 570”[tw] OR “Monocopper sulfate”[tw] OR “Roman vitriol”[tw] OR “Trinagle”[tw] OR “CuCl2”[tw] OR “Eriocholcite”[tw] OR “cupric”[tw] OR “cuprous”[tw] OR (“cu”[tiab] NOT (“chronic urticaria”[tiab] OR “cognitively unimpaired”[tiab] OR “callous unemotional”[tiab] OR “cocaine users”[tiab])) ) NOT medline[sb]) AND (2022/08/07:3000[edat] OR 2022/08/07:3000[crdat]))) AND (death OR lethal OR fatal OR fatality OR necrosis OR LC50* OR LD50* OR “body weight” OR “weight loss” OR “weight gain” OR weight-change* OR overweight OR obesity OR inhal* OR “respiratory tract” OR “respiratory organ” OR “respiratory system” OR “respiratory volume” OR “respiratory function” OR “respiratory effect” OR “respiratory organ” OR “respiratory toxicity” OR “pulmonary edema” OR “pulmonary effect” OR “pulmonary system” OR “pulmonary function” OR “pulmonary organ” OR “pulmonary toxicity” OR airway OR trachea OR tracheobronchial OR lung OR lungs OR nose OR nasal OR nasopharyngeal OR larynx OR laryngeal OR pharynx OR bronchial OR bronchi OR bronchioles OR bronchitis OR hemothorax OR alveolar OR alveoli OR irritation OR irritant OR sensitization OR sensitizer OR cilia OR mucocilliary OR cvd OR cardio OR vascular OR “cardiovascular system” OR “cardiovascular function” OR “cardiovascular effect” OR “cardiovascular organ” OR “cardiovascular toxicity” OR “circulatory system” OR “circulatory function” OR “circulatory effect” OR “circulatory organ” OR “circulatory toxicity” OR “cardiac arrest” OR “cardiac palpitation” OR “cardiac arrhythmia” OR “cardiac edema” OR “heart rate” OR “heart failure” OR “heart attack” OR “heart muscle” OR “heart beat” OR “myocardial-infarction” OR “chest pain” OR artery OR arteries OR veins OR venules OR cardiotox* OR “gastro-intestinal” OR gastrointestinal OR “digestive system” OR “digestive function” OR “digestive effect” OR “digestive organ” OR “Intestinal system” OR “intestinal function” OR “intestinal microbiota” OR “intestinal effect” OR “intestinal organ” OR “gi tract” OR “gi disorder” OR abdominal OR esophagus OR stomach OR intestine OR pancreas OR pancreatic OR diarrhea OR nausea OR vomit OR ulcer OR constipation OR emesis OR “gut microbes” OR “gut flora” OR “gut microflora” OR anorexia OR hematological OR hematology OR hemato OR haemato OR blood OR anemia OR cyanosis OR erythrocytopenia OR leukopenia OR thrombocytopenia OR hemoglobin OR erythrocyte OR hematocrit OR “bone marrow” OR reticulocyte OR methemoglobin OR red-blood-cell OR musculoskeletal OR skeletal OR muscle OR muscular OR arthritis OR “altered bone” OR “joint pain” OR “joint-ache” OR “limb pain” OR “limb ache” OR hepatic OR “liver system” OR “liver function” OR “liver effect” OR “liver organ” OR “Liver enzyme” OR “liver weight” OR “liver congestion” OR “liver changes” OR “liver biochemical changes” OR “liver toxicity” OR hepatocytes OR gallbladder OR cirrhosis OR jaundice OR “hepatocellular degeneration” OR “hepatocellular hypertrophy” OR hepatomegaly OR hepatotox* OR “renal system” OR “renal function” OR “renal effect” OR “renal organ” OR “renal tubular” OR “renal toxicity” OR “kidney system” OR “kidney function” OR “Kidney effect” OR “kidney toxicity” OR “urinary system” OR “urinary function” OR “urinary effect” OR “Urinary toxicity” OR “bladder system” OR “bladder effect” OR “bladder function” OR “bladder toxicity” OR “Urine volume” OR “blood urea nitrogen” OR bun OR nephropathy OR nephrotox* OR “dermal system” OR “dermal function” OR “dermal effect” OR “dermal irritation” OR “dermal toxicity” OR “dermal exposure” OR “dermal contact” OR “skin rash” OR “skin itch” OR “skin irritation” OR “skin redness” OR “skin effect” OR “skin necrosis” OR “skin acanthosis” OR “skin exposure” OR “skin contact” OR dermatitis OR psoriasis OR edema OR ulceration OR acne OR ocular OR “eye function” OR “eye effect” OR “eye irritation” OR “eye drainage” OR “eye tearing” OR blindness OR myopia OR cataracts OR “endocrine system” OR “endocrine function” OR “endocrine effect” OR “endocrine gland” OR “endocrine toxicity” OR “hormone changes” OR “hormone excess” OR “hormone deficiency” OR “hormone gland” OR “hormone secretion” OR “hormone toxicity” OR “sella turcica” OR thyroid OR adrenal OR pituitary OR immunological OR immunologic OR immune OR lymphoreticular OR lymph-node OR spleen OR thymus OR macrophage OR leukocyte* OR white-blood-cell OR immunotox* OR neurological OR neurologic OR neurotoxic OR neurotoxicity OR neurodegenerat* OR “nervous system” OR brain OR neurotoxicant OR neurochemistry OR neurophysiology OR neuropathology OR “motor activity” OR motor change* OR behavior-change* OR behavioral-change* OR sensory-change* OR cognitive OR vertigo OR drowsiness OR headache OR ataxia OR reproductive OR “reproduction system” OR “reproduction function” OR “reproduction effect” OR “reproduction toxicity” OR fertility OR “maternal toxicity” OR developmental OR “in utero” OR terata* OR terato* OR embryo* OR fetus* OR foetus* OR fetal* OR foetal* OR prenatal* OR “pre-natal” OR perinatal* OR “post-natal” OR postnatal* OR neonat* OR newborn* OR zygote* OR child OR children OR infant* OR offspring OR elderly OR “altered food consumption” OR “altered water consumption” OR “metabolic effect” OR “metabolic toxicity” OR fever OR cancer OR cancerous OR neoplas* OR tumor OR tumors OR tumour* OR malignan* OR carcinoma OR carcinogen OR carcinogen* OR angiosarcoma OR blastoma OR fibrosarcoma OR glioma OR leukemia OR leukaemia OR lymphoma OR melanoma OR meningioma OR mesothelioma OR myeloma OR neuroblastoma OR osteosarcoma OR sarcoma OR mutation OR mutations OR genotoxicity OR genotoxic OR mutagenicity OR mutagenic OR “mechanism of action” OR “mechanism of absorption” OR “mechanism of distribution” OR “mechanism of excretion” OR “mechanism of metabolism” OR “mechanism of toxic effect” OR “adverse effect” OR “adverse effects” OR poisoning OR morbidity OR inflammation OR antagonist OR inhibitor OR metabolism OR “environmental exposure” OR toxicokinetics OR pharmacokinetics OR “gene expression” OR “population health” OR epidemiology OR epidemiological OR case-control* OR case-referent OR case-report OR case-series OR cohort* OR correlation-stud* OR cross-sectional-stud* OR ecological-studies OR ecological-study OR follow-up-stud* OR longitudinal-stud* OR metaanalyses OR metaanalysis OR meta-analysis OR prospective-stud* OR record-link* OR retrospective- stud* OR seroepidemiologic-stud* OR occupation* OR worker* OR workmen* OR workplace* OR “oral intake” OR “oral feed” OR “oral ingestion” OR “oral exposure” OR “oral administration” OR ingest* OR gavage* OR “drinking-water” OR NHANES OR (human AND (risk OR toxic* OR safety)) OR mammal* OR ape OR apes OR baboon* OR balb OR beagle* OR boar OR boars OR bonobo* OR bovine OR C57 OR C57bl OR callithrix OR canine OR canis OR capra OR capuchin* OR cats OR cattle OR cavia OR chicken OR chickens OR chimpanzee* OR chinchilla* OR cow OR cows OR cricetinae OR dog OR dogs OR equus OR feline OR felis OR ferret OR ferrets OR flying-fox OR Fruit-bat OR gerbil* OR gibbon* OR goat OR goats OR guinea-pig* OR guppy OR hamster OR hamsters OR horse OR horses OR jird OR jirds OR lagomorph* OR leontopithecus OR longevans OR macaque* OR marmoset* OR medaka OR merione OR meriones OR mice OR monkey OR monkeys OR mouse OR muridae OR murinae OR murine OR mustela- putorius OR nomascus OR non-human-primate* OR orangutan* OR pan-paniscus OR pan-troglodytes OR pig OR piglet* OR pigs OR polecat* OR pongopygmaeus OR quail OR rabbit OR rabbits OR rat OR rats OR rhesus OR rodent OR rodentia OR rodents OR saguinus OR sheep OR sheeps OR siamang* OR sow OR sows OR Sprague-Dawley OR swine OR swines OR symphalangus OR tamarin* OR vervet* OR wistar OR wood-mouse OR zebra-fish OR zebrafish); (((“Copper/toxicity”[mh] OR “Copper/adverse effects”[mh] OR “Copper/poisoning”[mh] OR “Copper/pharmacokinetics”[mh]) OR (“Copper/blood”[mh] OR “Copper/cerebrospinal fluid”[mh] OR “Copper/urine”[mh]) OR (“Copper/antagonists and inhibitors”[mh]) OR (“Copper/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Copper sulfate/toxicity”[mh] OR “Copper sulfate/adverse effects”[mh] OR “Copper sulfate/poisoning”[mh] OR “Copper sulfate/pharmacokinetics”[mh]) OR (“Copper sulfate/blood”[mh] OR “Copper sulfate/cerebrospinal fluid”[mh] OR “Copper sulfate/urine”[mh]) OR (“Copper sulfate/antagonists and inhibitors”[mh]) OR (“Copper sulfate/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Copper/pharmacology”[majr] OR “Copper sulfate/pharmacology”[majr]) OR ((“Copper”[mh] OR “Copper sulfate”[mh]) AND (“environmental exposure”[mh] OR ci[sh] OR toxicokinetics[mh:noexp] )) OR ((“Copper”[mh] OR “Copper sulfate”[mh]) AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR ((“Copper”[mh] OR “Copper sulfate”[mh]) AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR ((“Copper”[mh] OR “Copper sulfate”[mh]) AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR ((10125–13-0[rn] OR 10257–54-2[rn] OR 1184–64-1[rn] OR 12019–06-6[rn] OR 12125–21-2[rn] OR 1317–38-0[rn] OR 1317–39-1[rn] OR 1344–67-8[rn] OR 1344–69-0[rn] OR 1344–70-3[rn] OR 17599–81- 4[rn] OR 20427–59-2[rn] OR 527–09-3[rn] OR 7440–50-8[rn] OR 7447–39-4[rn] OR 7492- 68–4[rn] OR 7758–89-6[rn] OR 7758–98-7[rn] OR 7758–99-8[rn] OR 82010–82-0[rn]) NOT (“Copper”[mh] OR “Copper Sulfate”[mh])) OR (142–71-2[rn] OR 10380–28-6[rn]) OR (“Copper D-gluconate”[tiab] OR “Copper di-D-gluconate”[tiab] OR “Copper gluconate”[tiab] OR “Copper(2+) D-gluconate, (1:2)”[tiab] OR “Copper(2+) di(D-gluconate)”[tiab] OR “Copper(II)gluconate”[tiab] OR “Cupric gluconate”[tiab] OR “D-Gluconic acid, copper complex”[tiab] OR “D-Gluconic acid, copper salt”[tiab] OR “D-Gluconic acid, copper(2+) salt”[tiab] OR “Gluconic acid, copper salt, D-”[tiab] OR “Gluconic acid, copper(2+) salt”[tiab] OR “Helshas Cu”[tiab] OR “Labicuper”[tiab])) AND (2020/01/01:3000[mhda] OR 2020/01/01:3000[edat] OR 2020/01/01:3000[crdat] OR 2020/01/01:3000[dp])); ((((“Copper”[tw] OR “1721 Gold”[tw] OR “3EC-M3S-HTE”[tw] OR “3EC-M3VLP18”[tw] OR “ANAC 110”[tw] OR “ATS Adocopper IW”[tw] OR “BAC 13B-NK120”[tw] OR “Bronze powder”[tw] OR “C 100 (metal)”[tw] OR “C.I. 77400”[tw] OR “C.I. Pigment Metal 2”[tw] OR “Caswell No. 227”[tw] OR “CDA 101”[tw] OR “CDA 102”[tw] OR “CDA 110”[tw] OR “CDA 122”[tw] OR “CDX (metal)”[tw] OR “CE 1110”[tw] OR “CE 7 (metal)”[tw] OR “CF-T 8GD- SV”[tw] OR “CF-T 9A-HP-STD”[tw] OR “CF-T 9B-THE”[tw] OR “CF-T 9FZ-SV”[tw] OR “CFW 100–156”[tw] OR “CI 77400”[tw] OR “CI Pigment metal 2”[tw] OR “CU M3”[tw] OR "Cu-At-W 250”[tw] OR “Cubrotec 5000”[tw] OR “Cuivre metal”[tw] OR “Cutox 6010”[tw] OR “Cutox 6030”[tw] OR “DD Paste TH 9910”[tw] OR “Double Thin F-NP”[tw] OR “DT GLMP”[tw] OR “E 115 (metal)”[tw] OR “Gold bronze”[tw] OR “GT (metal)”[tw] OR “NDP- III”[tw] OR “NT-TAX-M”[tw] OR “NT-TAX-O”[tw] OR “OFHC Cu”[tw] OR “Paragard T 380a”[tw] OR “Paragard t380a”[tw] OR “Pigment metal 2”[tw] OR “Silcoat FCC-SP 99”[tw] OR “Tatum-T”[tw] OR “Unicoat 2845”[tw] OR “USLP-SE”[tw] OR “All Clear Root Destroyer”[tw] OR “Aqua Maid Permanent Algaecide”[tw] OR “Aquatronics Snail-A-Cide Dri-Pac Snail Powder”[tw] OR “Blue stone”[tw] OR “Blue vitriol”[tw] OR “Bonide Root Destroyer”[tw] OR “Cuivrol”[tw] OR “CuSO4”[tw] OR “Delcup”[tw] OR “EarthTec”[tw] OR “Hylinec”[tw] OR “Incracide 10A”[tw] OR “Incracide E 51”[tw] OR “MAC 570”[tw] OR “Monocopper sulfate”[tw] OR “Roman vitriol”[tw] OR “Trinagle”[tw] OR “CuCl2”[tw] OR “Eriocholcite”[tw] OR “cupric”[tw] OR “cuprous”[tw] OR (“cu”[tiab] NOT (“chronic urticaria”[tiab] OR “cognitively unimpaired”[tiab] OR “callous unemotional”[tiab] OR “cocaine users”[tiab])) ) NOT medline[sb]) AND (2020/01/01:3000[edat] OR 2020/01/01:3000[crdat] OR 2020/01/01:3000[dp]))) AND (death OR lethal OR fatal OR fatality OR necrosis OR LC50* OR LD50* OR “body weight” OR “weight loss” OR “weight gain” OR weight-change* OR overweight OR obesity OR inhal* OR “respiratory tract” OR “respiratory organ” OR “respiratory system” OR “respiratory volume” OR “respiratory function” OR “respiratory effect” OR “respiratory organ” OR “respiratory toxicity” OR “pulmonary edema” OR “pulmonary effect” OR “pulmonary system” OR “pulmonary function” OR “pulmonary organ” OR “pulmonary toxicity” OR airway OR trachea OR tracheobronchial OR lung OR lungs OR nose OR nasal OR nasopharyngeal OR larynx OR laryngeal OR pharynx OR bronchial OR bronchi OR bronchioles OR bronchitis OR hemothorax OR alveolar OR alveoli OR irritation OR irritant OR sensitization OR sensitizer OR cilia OR mucocilliary OR cvd OR cardio OR vascular OR “cardiovascular system” OR “cardiovascular function” OR “cardiovascular effect” OR “cardiovascular organ” OR “cardiovascular toxicity” OR “circulatory system” OR “circulatory function” OR “circulatory effect” OR “circulatory organ” OR “circulatory toxicity” OR “cardiac arrest” OR “cardiac palpitation” OR “cardiac arrhythmia” OR “cardiac edema” OR “heart rate” OR “heart failure” OR “heart attack” OR “heart muscle” OR “heart beat” OR “myocardial-infarction” OR “chest pain” OR artery OR arteries OR veins OR venules OR cardiotox* OR “gastro- intestinal” OR gastrointestinal OR “digestive system” OR “digestive function” OR “digestive effect” OR “digestive organ” OR “Intestinal system” OR “intestinal function” OR “intestinal microbiota” OR “intestinal effect” OR “intestinal organ” OR “gi tract” OR “gi disorder” OR abdominal OR esophagus OR stomach OR intestine OR pancreas OR pancreatic OR diarrhea OR nausea OR vomit OR ulcer OR constipation OR emesis OR “gut microbes” OR “gut flora” OR “gut microflora” OR anorexia OR hematological OR hematology OR hemato OR haemato OR blood OR anemia OR cyanosis OR erythrocytopenia OR leukopenia OR thrombocytopenia OR hemoglobin OR erythrocyte OR hematocrit OR “bone marrow” OR reticulocyte OR methemoglobin OR red-blood-cell OR musculoskeletal OR skeletal OR muscle OR muscular OR arthritis OR “altered bone” OR “joint pain” OR “joint-ache” OR “limb pain” OR “limb ache” OR hepatic OR “liver system” OR “liver function” OR “liver effect” OR “liver organ” OR “Liver enzyme” OR “liver weight” OR “liver congestion” OR “liver changes” OR “liver biochemical changes” OR “liver toxicity” OR hepatocytes OR gallbladder OR cirrhosis OR jaundice OR “hepatocellular degeneration” OR “hepatocellular hypertrophy” OR hepatomegaly OR hepatotox* OR “renal system” OR “renal function” OR “renal effect” OR “renal organ” OR “renal tubular” OR “renal toxicity” OR “kidney system” OR “kidney function” OR “Kidney effect” OR “kidney toxicity” OR “urinary system” OR “urinary function” OR “urinary effect” OR “Urinary toxicity” OR “bladder system” OR “bladder effect” OR “bladder function” OR “bladder toxicity” OR “Urine volume” OR “blood urea nitrogen” OR bun OR nephropathy OR nephrotox* OR “dermal system” OR “dermal function” OR “dermal effect” OR “dermal irritation” OR “dermal toxicity” OR “dermal exposure” OR “dermal contact” OR “skin rash” OR “skin itch” OR “skin irritation” OR “skin redness” OR “skin effect” OR “skin necrosis” OR “skin acanthosis” OR “skin exposure” OR “skin contact” OR dermatitis OR psoriasis OR edema OR ulceration OR acne OR ocular OR “eye function” OR “eye effect” OR “eye irritation” OR “eye drainage” OR “eye tearing” OR blindness OR myopia OR cataracts OR “endocrine system” OR “endocrine function” OR “endocrine effect” OR “endocrine gland” OR “endocrine toxicity” OR “hormone changes” OR “hormone excess” OR “hormone deficiency” OR “hormone gland” OR “hormone secretion” OR “hormone toxicity” OR “sella turcica” OR thyroid OR adrenal OR pituitary OR immunological OR immunologic OR immune OR lymphoreticular OR lymph-node OR spleen OR thymus OR macrophage OR leukocyte* OR white-blood-cell OR immunotox* OR neurological OR neurologic OR neurotoxic OR neurotoxicity OR neurodegenerat* OR “nervous system” OR brain OR neurotoxicant OR neurochemistry OR neurophysiology OR neuropathology OR “motor activity” OR motor change* OR behavior-change* OR behavioral-change* OR sensory- change* OR cognitive OR vertigo OR drowsiness OR headache OR ataxia OR reproductive OR “reproduction system” OR “reproduction function” OR “reproduction effect” OR “reproduction toxicity” OR fertility OR “maternal toxicity” OR developmental OR “in utero” OR terata* OR terato* OR embryo* OR fetus* OR foetus* OR fetal* OR foetal* OR prenatal* OR “pre-natal” OR perinatal* OR “post-natal” OR postnatal* OR neonat* OR newborn* OR zygote* OR child OR children OR infant* OR offspring OR elderly OR “altered food consumption” OR “altered water consumption” OR “metabolic effect” OR “metabolic toxicity” OR fever OR cancer OR cancerous OR neoplas* OR tumor OR tumors OR tumour* OR malignan* OR carcinoma OR carcinogen OR carcinogen* OR angiosarcoma OR blastoma OR fibrosarcoma OR glioma OR leukemia OR leukaemia OR lymphoma OR melanoma OR meningioma OR mesothelioma OR myeloma OR neuroblastoma OR osteosarcoma OR sarcoma OR mutation OR mutations OR genotoxicity OR genotoxic OR mutagenicity OR mutagenic OR “mechanism of action” OR “mechanism of absorption” OR “mechanism of distribution” OR “mechanism of excretion” OR “mechanism of metabolism” OR “mechanism of toxic effect” OR “adverse effect” OR “adverse effects” OR poisoning OR morbidity OR inflammation OR antagonist OR inhibitor OR metabolism OR “environmental exposure” OR toxicokinetics OR pharmacokinetics OR “gene expression” OR “population health” OR epidemiology OR epidemiological OR case- control* OR case-referent OR case-report OR case-series OR cohort* OR correlation-stud* OR cross-sectional-stud* OR ecological-studies OR ecological-study OR follow-up-stud* OR longitudinal-stud* OR metaanalyses OR metaanalysis OR meta-analysis OR prospective-stud* OR record-link* OR retrospective-stud* OR seroepidemiologic-stud* OR occupation* OR worker* OR workmen* OR workplace* OR “oral intake” OR “oral feed” OR “oral ingestion” OR “oral exposure” OR “oral administration” OR ingest* OR gavage* OR “drinking-water” OR NHANES OR (human AND (risk OR toxic* OR safety)) OR mammal* OR ape OR apes OR baboon* OR balb OR beagle* OR boar OR boars OR bonobo* OR bovine OR C57 OR C57bl OR callithrix OR canine OR canis OR capra OR capuchin* OR cats OR cattle OR cavia OR chicken OR chickens OR chimpanzee* OR chinchilla* OR cow OR cows OR cricetinae OR dog OR dogs OR equus OR feline OR felis OR ferret OR ferrets OR flying-fox OR Fruit-bat OR gerbil* OR gibbon* OR goat OR goats OR guinea- pig* OR guppy OR hamster OR hamsters OR horse OR horses OR jird OR jirds OR lagomorph* OR leontopithecus OR longevans OR macaque* OR marmoset* OR medaka OR merione OR meriones OR mice OR monkey OR monkeys OR mouse OR muridae OR murinae OR murine OR mustela-putorius OR nomascus OR non-human-primate* OR orangutan* OR pan-paniscus OR pan-troglodytes OR pig OR piglet* OR pigs OR polecat* OR pongopygmaeus OR quail OR rabbit OR rabbits OR rat OR rats OR rhesus OR rodent OR rodentia OR rodents OR saguinus OR sheep OR sheeps OR siamang* OR sow OR sows OR Sprague-Dawley OR swine OR swines OR symphalangus OR tamarin* OR vervet* OR wistar OR wood-mouse OR zebra-fish OR zebrafish)
NTRL
10/2023 | Date Published 2019 to 2023, Title or Keyword field copper OR cupric OR cuprous
Toxcenter
10/2023 | FILE ‘TOXCENTER’ ENTERED AT 10:39:30 ON 04 OCT 2023; L1 325170 SEA 7440–50-8; L2 22300 SEA 10125–13-0 OR 10257–54-2 OR 10380–28-6 OR 1184–64-1 OR 12019–06-6 OR 12125–21-2 OR 13005–35-1 OR 1317–38-0 OR 1317–39-1 OR 1344–67-8 OR 1344–69-0; L3 39282 SEA 1344–70-3 OR 142–71-2 OR 17599–81-4 OR 20427–59-2 OR 4180–12-5 OR 527–09-3 OR 7447–39-4 OR 7492–68-4 OR 7758–89-6 OR 7758–98-7 OR 7758–99-8 OR 82010–82-0; L4 366811 SEA L1 OR L2 OR L3; L5 304934 SEA L4 NOT PATENT/DT; L6 17407 SEA L5 AND ED>=20220804; L7 17376 SEA L6 AND PY>2018; ACT TOXQUERY/Q; ---------; L8 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L9 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L10 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L11 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L12 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L13 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L14 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L15 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L16 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L17 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L18 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L19 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L20 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L21 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L22 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L23 QUE (ENDOCRIN? AND DISRUPT?); L24 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L25 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L26 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L27 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L28 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L29 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L30 QUE (NEPHROTOX? OR HEPATOTOX?); L31 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L32 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L33 QUE L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30 OR L31 OR L32; L34 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE; OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE; OR PORCINE OR MONKEY? OR MACAQUE?); L35 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA; OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L36 QUE L33 OR L34 OR L35; L37 QUE (NONHUMAN MAMMALS)/ORGN; L38 QUE L36 OR L37; ---------; L50 7690 SEA L7 AND L38; L51 871 SEA L50 AND MEDLINE/FS; L52 1312 SEA L50 AND BIOSIS/FS; L53 2026 DUP REM L51 L52 (157 DUPLICATES REMOVED); L*** DEL 871 S L50 AND MEDLINE/FS; L*** DEL 871 S L50 AND MEDLINE/FS L54 867 SEA L53; L*** DEL 1312 S L50 AND BIOSIS/FS; L*** DEL 1312 S L50 AND BIOSIS/FS; L55 1159 SEA L53; L56 1159 SEA (L54 OR L55) AND BIOSIS/FS; D SCAN L56; Limited to py 2019-present and entry date 7/2019-present FILE ‘TOXCENTER’ ENTERED AT 09:41:02 ON 04 AUG 2022; CHARGED TO COST=EH038.08.02.LB.04 DIS SAVED; ACT COPPER/A; ---------; L1 ( 306093)SEA FILE=TOXCENTER 7440–50-8; L2 ( 19689)SEA FILE=TOXCENTER 10125–13-0 OR 10257–54-2 OR 10380–28-6 OR 1184–64-1 OR 12019–06-6 OR 12125–21-2 OR 13005–35-1 OR 1317–38-0 OR 1317–39-1 OR 1344–67-8 OR 1344–69-0; L3 ( 35864)SEA FILE=TOXCENTER 1344–70-3 OR 142–71-2 OR 17599–81-4 OR 20427–59-2 OR 4180–12-5 OR 527–09-3 OR 7447–39-4 OR 7492–68-4 OR 7758–89-6 OR 7758–98-7 OR 7758–99-8 OR 82010–82-0; L4 ( 343873)SEA FILE=TOXCENTER L1 OR L2 OR L3; L5 ( 50997)SEA FILE=TOXCENTER L4 AND ED>=20190701; L6 ( 42493)SEA FILE=TOXCENTER L5 NOT PATENT/DT; L7 ( 42493)SEA FILE=TOXCENTER L6 NOT TSCATS/FS; L8 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L9 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L10 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L11 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L12 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L13 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L14 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L15 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L16 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L17 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L18 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L19 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L20 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L21 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L22 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L23 QUE (ENDOCRIN? AND DISRUPT?); L24 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L25 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L26 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L27 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L28 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L29 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L30 QUE (NEPHROTOX? OR HEPATOTOX?); L31 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L32 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L33 QUE L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30 OR L31 OR L32; L34 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L35 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L36 QUE L33 OR L34 OR L35; L37 QUE (NONHUMAN MAMMALS)/ORGN; L38 QUE L36 OR L37; L39 ( 18027)SEA FILE=TOXCENTER L7 AND L38; L40 ( 17269)SEA FILE=TOXCENTER L39 AND PY>2018; L41 ( 2479)SEA FILE=TOXCENTER L40 AND MEDLINE/FS; L42 ( 3474)SEA FILE=TOXCENTER L40 AND BIOSIS/FS; L43 ( 11296)SEA FILE=TOXCENTER L40 AND CAPLUS/FS; L44 ( 20)SEA FILE=TOXCENTER L40 NOT (L41 OR L42 OR L43); L45 ( 15088)DUP REM L41 L42 L44 L43 (2181 DUPLICATES REMOVED); L46 ( 2478)SEA FILE=TOXCENTER L45; L47 ( 3082)SEA FILE=TOXCENTER L45 L48 ( 9510)SEA FILE=TOXCENTER L45; L49 ( 18)SEA FILE=TOXCENTER L45; ---------; L50 12610 SEA FILE=TOXCENTER (L46 OR L47 OR L48 OR L49) NOT MEDLINE/FS; L51 3082 SEA FILE=TOXCENTER L50 AND BIOSIS/FS

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via ChemView
10/2023 | Compounds searched: 7440–50-8; 7758–98-7; 7758–99-8; 10257–54-2; 17599–81-4; 7447–39-4; 1344–67-8; 7758–89-6; 10125–13-0; 1317–39-1; 1317–38-0; 1344–70-3; 12019–06-6; 82010–82-0; 527–09-3; 13005–35-1; 4180–12-5; 142–71-2; 1344–69-0; 12125–21-2; 20427–59-2; 1184–64-1; 7492–68-4; 10380–28-6
NTP
10/2023 | Limited 2010-present; “copper” “cupric” “cuprous”
Regulations.gov
10/2023 | Limited to 2019–present; copper; cupric; cuprous
NPIRS
1/2024 | SEARCH CRITERIA; Active Ingredient: Copper as elemental (CAS #: 7440–50-8) (PC Code: 22501), Copper carbonate hydroxide (CAS #: 1184–64-1) (PC Code: 22901), Copper hydroxide (CAS #: 20427–59-2) (PC Code: 23401), Copper sulfate pentahydrate (CAS #: 7758–99-8) (PC Code: 24401), Copper sulfate monohydrate (CAS #: 10257–54-2) (PC Code: 24402), Copper sulfate (anhydrous) (CAS #: 7758–98-7) (PC Code: 24408), Copper oxide, black (CAS #: 1317–38-0) (PC Code: 42401), Copper 8- hydroxyquinoline (CAS #: 10380–28-6) (PC Code: 24002), Copper oxide (Cu2O) (CAS #: 1317–39-1) (PC Code: 25601), Cuprous and cupric oxide, mixed (CAS #: 82010–82-0) (PC Code: 42403)
| Submission Date Start: 2014–01-01
NIH RePORTER
10/2023 | Search Criteria; Fiscal Year: Active Projects; Text Search: “copper” OR “cupric” OR “cuprous” (advanced) Limit to: Project Title, Project Terms, Project Abstracts
Other | Identified throughout the assessment process

The 2023 results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 15,262
- Number of records identified from other strategies: 183
- Total number of records to undergo literature screening: 15,445

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on copper:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 15,445
- Number of studies considered relevant and moved to the next step: 1,257

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 1,257
- Number of studies cited in the pre-public draft of the toxicological profile: 619
- Total number of studies cited in the profile: 771

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 October 2023 Literature Search Results and Screen for Copper