# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. LOAELs for serious health effects (such as irreparable damage to the liver or kidneys, or serious birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substances than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S106–5, Atlanta, Georgia 30329–4027.

## Copper and compounds Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Copper and compounds
CAS Numbers: | 7440-50-8
Date: | October 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL as available studies are limited and suggested serious effects at the lowest exposure levels.

Rationale for Not Deriving an MRL: Available studies of human inhalation exposure to copper and compounds were not sufficient to identify effect levels. Human studies on acute-duration inhalation exposure that met inclusion criteria include one experimental study of five men exposed to copper-only welding fume (Markert et al. 2016), occupational studies reporting metal fume fever in workers exposed to copper dust or fumes (Armstrong et al. 1983; Gleason 1968), and human case reports of accidental inhalation exposure (Donoso et al. 2007; Gibson et al. 2011). The only endpoint evaluated in the controlled exposure study (Markert et al. 2016) was serum C-reactive protein, which is an inadequate basis for determining a LOAEL or NOAEL. Neither the occupational studies nor case reports provided adequate exposure concentration information, precluding their use for MRL derivation.

Two acute-duration inhalation studies in animals exposed to copper compounds were located (Drummond et al. 1986; Poland et al. 2022). Poland et al. (2022) conducted 2-week studies of rats exposed to copper sulfate pentahydrate or dicopper oxide. In that study, LOAELs of 0.71 and 1.78 mg Cu/m^3^, respectively, were identified for respiratory effects (alveolar histiocytosis, bronchioloalveolar hyperplasia, and/or increased lung weight) (Poland et al. 2022). NOAELs in this study were 0.18 and 0.71 mg Cu/m^3^, respectively.

The second study (Drummond et al. 1986) involved acute-duration inhalation exposure to copper sulfate, and included evaluations of lethality, respiratory, and immunological effects in mice and limited respiratory effects in hamsters. However, the exposure concentrations reported in the study are uncertain; therefore, effect levels could not be determined. Drummond et al. (1986) reported exposure concentrations both in terms of sulfate (reporting values of 0.09, 0.1, 0.43, 0.93, and 2.53 mg SO_4_/m^3^) and in terms of “calculated mg metal/m^3^” (reporting values of 0.12, 0.13, 0.56, 1.21, and 3.3 mg metal/m^3^, respectively). The reported copper concentrations are inconsistent with the concentrations reported in terms of sulfate. For example, the copper concentration (from copper sulfate) corresponding to 2.53 mg SO_4_/m^3^ would be 1.67 mg Cu/m^3^ (calculated as mg SO_4_/m^3^ × [molecular weight of copper/molecular weight of sulfate]). Copper concentrations based on the reported sulfate concentrations would be 0.06, 0.07, 0.28, 0.62, and 1.67 mg Cu/m^3^, respectively. This discrepancy was limited to the copper concentrations, as the aluminum concentrations reported as “mg metal/m^3^” for exposures to aluminum sulfate compounds in the study were consistent with the corresponding sulfate concentrations. It is uncertain whether the study authors incorrectly reported the sulfate concentrations or the copper concentrations for the copper sulfate exposures.

In the mouse studies (Drummond et al. 1986), increased mortality was seen at the lowest exposures, at reported sulfate concentrations of 0.09–0.1 mg SO_4_/m^3^. Copper concentrations corresponding to these sulfate concentrations would be 0.06–0.07 mg Cu/m^3^, much lower than the NOAELs identified in the 2-week rat studies (Poland et al. 2022). Alternatively, if the “calculated mg metal/m^3^” concentrations are correct, mortalities would be at concentrations of 0.12–0.13 mg Cu/m^3^; these concentrations are slightly lower than the NOAEL of 0.18 mg Cu/m^3^ for rats exposed to copper sulfate pentahydrate in the study by Poland et al. (2022). No other studies of mice exposed to copper compounds by inhalation were located. In addition, no rat studies examining immunotoxicity endpoints such as those evaluated by Drummond et al. (1986) were located. In the absence of studies that refute the mortality findings at low exposure concentrations reported by Drummond et al. (1986), the available data are not considered adequate for MRL derivation, because NOAELs in the rat studies were at exposure concentrations higher than those inducing mortality in mice.

Agency Contact (Chemical Managers): Breanna Alman, MPH

## Copper and compounds Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Copper and compounds
CAS Numbers: | 7440-50-8
Date: | October 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL as available studies evaluated limited endpoints and were not sufficient to establish the critical effect of intermediate-duration inhalation exposure.

Rationale for Not Deriving an MRL: One human study of intermediate-duration inhalation exposure met inclusion criteria: a case-control study of general population exposure to copper in particulate matter (Rammah et al. 2019). In this study, no association was observed between risk of stillbirth and modeled copper concentration in PM_2.5_ during pregnancy (Rammah et al. 2019). These data do not provide an adequate basis for MRL derivation. Animal toxicity studies include two studies in rabbits that only identified NOAELs for respiratory and immune effects (Johansson et al. 1983, 1984) and a comprehensive study of rats exposed to dicopper oxide by inhalation for 4 weeks that identified a NOAEL and LOAEL of 0.18 and 0.35 mg Cu/m^3^, respectively, for respiratory effects including alveolar histiocytosis, bronchioloalveolar hyperplasia, and/or increased lung weights (Poland et al. 2022). The available studies examined a limited number of potential endpoints, and there is uncertainty regarding whether the respiratory tract is the most sensitive target tissue. Therefore, an intermediate-duration inhalation MRL could not be derived.

Agency Contact (Chemical Managers): Breanna Alman, MPH

## Copper and compounds Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Copper and compounds
CAS Numbers: | 7440-50-8
Date: | October 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL as available data do not clearly identify a critical effect.

Rationale for Not Deriving an MRL: Human studies of chronic-duration inhalation exposure to copper that met inclusion criteria include occupational exposure studies (Askergren and Mellgren 1975; Finelli et al. 1981; Fouad and Ramadan 2022; Mourad and El-Sherif 2022; Saadiani et al. 2013; Suciu et al. 1981) and cohort studies of general population exposure to copper in airborne particular matter (Boogaard et al. 2013; Gehring et al. 2015; Ostro et al. 2015; Peralta et al. 2021; Yu et al. 2021b). The occupational exposure studies are limited because the workers were simultaneously exposed to several other heavy metals, and it was not possible to discern effects of copper alone.

Boogaard et al. (2013) evaluated the change in spirometry parameters before and after implementation of traffic reduction measures in the Netherlands, and observed improvement in FVC with a decrease of 27.2 ng Cu/m^3^ in mean copper concentration in ambient air. Two cohort studies examined the association between modeled concentrations of copper in ambient particulate matter and cardiovascular outcomes (Ostro et al. 2015; Peralta et al. 2021). In a cohort of 101,884 current and former female teachers and administrators, Ostro et al. (2015) observed an association between increased mortality from ischemic heart disease and increased copper concentration in particulate matter. In a cohort study of 563 older men in Massachusetts (Peralta et al. 2021), copper concentrations in PM_2.5_ were associated with decreased (improved) heart-rate-corrected QT interval. These data are insufficient to identify a critical effect of chronic-duration inhalation exposure to copper.

No chronic-duration inhalation animal studies were located.

Agency Contact (Chemical Managers): Breanna Alman, MPH

## Copper and compounds Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Copper and compounds
CAS Numbers: | 7440-50-8
Date: | October 2024
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL: | 0.02 mg/kg/day
Critical Effect: | Gastrointestinal effects
Reference: | Pizarro et al. 1999
Point of Departure: | BMDL_10_ of 0.055 mg/kg/day
Uncertainty Factor: | 3
LSE Graph Key: | 6
Species: | Human

MRL Summary: An acute-duration oral MRL of 0.02 mg Cu/kg/day was derived for copper based on gastrointestinal effects of abdominal pain, vomiting, and nausea in female adults ingesting copper sulfate in drinking water for 2 weeks (Pizarro et al. 1999). The MRL is based on a benchmark dose lower confidence limit associated with 10% extra risk (BMDL_10_) of 0.055 mg/kg/day, which was divided by a total uncertainty factor of 3 for human variability; a partial uncertainty factor was applied because the direct effects of copper on the gastrointestinal tract are unlikely to be substantially impacted by toxicokinetic differences among individuals.

The acute-duration oral MRL of 0.02 mg Cu/kg/day reflects the intake of administered copper in addition to dietary background. It is intended to protect against gastrointestinal effects in people who receive adequate copper intake from diet and/or supplements. People who have copper deficiency may be given therapeutic doses at or above the MRL.

It should be noted that the acute-duration oral MRL may or may not be adequately protective for people with Wilson’s disease, as the degree of protection will depend on their dietary and water intake levels as well as the degree to which their disease is medically controlled.

Selection of the Critical Effect: Numerous experimental studies and case reports support the identification of the gastrointestinal tract as a sensitive endpoint of toxicity in humans acutely exposed to copper in drinking water or in contaminated beverages (Araya et al. 2001, 2003a, 2003c; Chuttani et al. 1965; Gotteland et al. 2001; Knobeloch et al. 1994; Olivares et al. 2001; Pizarro et al. 1999, 2001; Spitalny et al. 1984).

Controlled exposure studies provide the most reliable information on gastrointestinal effects in humans, including dose-response information. Table A-1 shows NOAEL and LOAEL values for acute-duration controlled oral exposure studies in humans. It should be noted that the NOAEL and LOAEL doses reflect supplemented copper and do not include contributions from dietary intake or tap water. As the table shows, the controlled exposure studies demonstrate LOAELs between 0.012 and 0.1 mg Cu/kg/day for nausea, vomiting, abdominal pain, and/or delayed gastric emptying.

Table A-1 Summary of Gastrointestinal NOAEL and LOAEL Values in Humans after Acute-Duration Oral Exposure to Copper

Number and sex of subjects | Exposure conditions | NOAEL in mg Cu/kg/day | LOAEL in mg Cu/kg/day | Effect | Reference
30 male and 31 female healthy adults (mean ages 28.7 and 32 years, respectively) | Once as 200 mL bolus after overnight fast | 0.006 (2 mg Cu/L) | 0.012 (4 mg Cu/L) | Nausea in 5/53 subjects | Olivares et al. 2001
179 adult men and women (median age ~40 years) | Once as 200 mL bolus after overnight fast | 0.012 (4 mg Cu/L) | 0.018 (6 mg Cu/L) | Increased frequency of nausea in 17/179 subjects | Araya et al. 2001
269 healthy adult women (median ages 27–37 years across groups) | Once as 200 mL bolus after overnight fast | 0.012 (4 mg Cu/L) | 0.018 (6 mg Cu/L) | Nausea in 50/269 subjects | Araya et al. 2003c
15 male and 16 female healthy adults (mean age 32 years) | Once as 200 mL bolus after overnight fast | ND | 0.03 (10 mg Cu/L) | Nausea (6/31 subjects) and vomiting (2/31 subjects) | Gotteland et al. 2001
15 male and 16 female healthy adults (mean ages 37 and 33 years, respectively) | Once as 300 mL bolus after overnight fast | ND | 0.046 (10 mg Cu/L) | Nausea in 9/30 subjects; delayed gastric emptying | Araya et al. 2003a
60 healthy adult women (mean age 32–36 years across groups) | 2 weeks, daily in water (plain, as tea, or with powdered juice mix) | 0.03 (1 mg Cu/L) | 0.07 (3 mg Cu/L) | Abdominal pain, nausea, and/or vomiting | Pizarro et al. 1999
45 healthy adult women (mean age 25.6 years) | 1 week daily in water (plain, as tea, or with powdered juice mix) | ND | 0.1 (5 mg Cu/L) | Nausea, vomiting, and/or abdominal pain | Pizarro et al. 2001

LOAEL = lowest-observed adverse-effect level; NOAEL = no-observed-adverse-effect level; ND = not determined

Animal studies have identified gastrointestinal, hepatic, renal, and reproductive system effects at much higher doses (≥2 mg Cu/kg/day) following acute-duration oral exposure to copper. Since the dietary requirement for copper is much higher in rodents (0.5–1 mg Cu/kg/day) than in humans (0.013 mg Cu/kg/day for a 70-kg human), it is not surprising that rodents tolerate higher doses. Given that there are several well-conducted controlled experiments in humans that identify effect levels lower than any of the animal studies, and laboratory animals’ dietary requirement exceeds the dietary requirement in humans by more than 30-fold, only human studies were considered for MRL derivation. The human studies consistently demonstrate gastrointestinal symptoms of nausea and vomiting as the critical effect of acute-duration oral exposure to copper.

Selection of the Principal Study: The study by Pizarro et al. (1999) was selected for derivation of the acute-duration oral MRL. While Pizarro et al. (1999) did not identify the lowest LOAEL, subjects in the studies by Araya et al. (2001, 2003a, 2003c), Gotteland et al. (2001), and Olivares et al. (2001) were exposed via bolus dosing after an overnight fast, while subjects in the study by Pizarro et al. (1999) consumed the copper-containing water over the course of the day. Bolus dosing may exacerbate gastrointestinal effects that are attributable to direct contact, as the amount of copper in contact with the stomach lining is much higher. In contrast, intermittent consumption of copper-containing water over the day more closely approximates environmental exposure conditions. Furthermore, the subjects in the study by Pizarro et al. (1999) were exposed for 2 weeks, while subjects in the studies by Araya et al. (2001, 2003a, 2003c) and Gotteland et al. (2001) were exposed on a single day. Finally, of the available controlled exposure studies, only Pizarro et al. (1999) provided information on both dietary copper intake and copper concentrations in household tap water. Thus, Pizarro et al. (1999) was selected as the principal study.

Summary of the Principal Study:

Pizarro F, Olivares M, Uauy, R, . 1999. Acute gastrointestinal effects of graded levels of copper in drinking water. Environ Health Perspect 107:117–121.9924006

A group of 60 healthy women in Chile were divided into four exposure sequence groups, with mean ages within each group of 32.9–36.3 years. The mean body weight of the participants was 64 kg. Each group consumed water containing 0, 1, 3, or 5 mg/L ionic copper as copper sulfate pentahydrate (0.0006, 0.0272, 0.0731, and 0.124 mg Cu/kg/day, respectively) for a 2-week period followed by a 1-week rest, followed by the next dose of copper in the sequence. Each group of women was assigned to a different order of copper concentrations to consume over an 11-week period. For example, the first group was assigned to consume the control group drinking water for 2 weeks followed by a 1-week rest period, then drank the water containing 1 mg Cu/L for 2 weeks followed by a 1-week rest. This process continued in the same group with the water containing 3 and 5 mg Cu/L. Ultimately, each dose was tested in all 60 women; therefore, there were 60 women in each dose group, and each woman served as her own control. Each week, the women received a bottle containing copper sulfate solution and were asked to mix the contents of the bottle with 3 L of their drinking water. The subjects recorded daily water consumption and reported any symptoms during each 2-week exposure period. If a participant presented diarrhea, abdominal pain, or vomiting, they were told not to ingest copper-containing water for the next 2 days and consumption began once symptoms disappeared. Blood samples were collected 1 week before the study, at the end of the first 2-week exposure period, and at the end of the study; the blood was analyzed for levels of serum copper, AST, ALT, and GGT activities, and hemoglobin. The average dietary intake of copper in study participants, based on a 24-hour dietary recall, was 1.7 mg Cu/day (0.0266 mg Cu/kg/day using the study-reported average body weight of 64 kg). The study authors measured the copper content of the subjects’ tap water, and found it to be <0.1 mg/L.

Daily doses of supplemental copper (not including dietary or tap water contributions) were calculated using reported daily intake of copper from the copper sulfate solution (0.04, 1.74, 4.68, and 7.94 mg) and the average of the mean reported body weights across the four groups (64 kg). Daily doses were 0.0006, 0.0272, 0.0731, and 0.124 mg Cu/kg/day for exposure concentrations of 0, 1, 3, and 5 mg Cu/L, respectively. No significant alterations in levels of serum copper, ceruloplasmin, hemoglobin, or liver enzymes were observed. Twenty-one subjects reported gastrointestinal symptoms, predominantly nausea, at some point during the study period. Nine of those subjects reported 12 episodes of diarrhea with or without abdominal pain, and the study authors reported no association between copper concentration in water and diarrhea. Eight of these episodes of diarrhea occurred during the 2 weeks of the study, independent of copper concentration. Twelve subjects reported abdominal pain, nausea, and/or vomiting; the incidences were 3/60, 1/60, 10/60, and 9/60 in the 0, 0.0272, 0.0731, and 0.124 mg Cu/kg/day groups, respectively (see Table A-2). There was a significant difference between the incidences at concentrations of ≤1 mg Cu/L (0.0272 mg Cu/kg/day) versus ≥3 mg/L (0.0731 mg Cu/kg/day). No other differences between groups were found.

Table A-2 Incidence of Gastrointestinal Symptoms in Women Exposed to Copper in Drinking Water for 2-Week Periods

Symptoms | Drinking water doses in mg Cu/kg/day
Symptoms | 0.0006 (control) | 0.0272 | 0.0731 | 0.124
Abdominal pain only | 2/60 | 1/60 | 3/60 | 2/60
Vomiting only | 0/60 | 0/60 | 1/60 | 2/60
Nausea only | 1/60 | 0/60 | 6/60 | 5/60
Total symptoms | 3/60 | 1/60 | 10/60 | 9/60

Source: Pizarro et al. 1999

Selection of the Point of Departure for the MRL: The BMDL_10_ of 0.055 mg/kg/day for gastrointestinal symptoms of abdominal pain, nausea, and vomiting in females was selected as the basis for the acute-duration oral MRL.

Incidence data for total gastrointestinal symptoms (abdominal pain, vomiting, and nausea, see Table A-2) were fit to all dichotomous models in EPA’s Benchmark Dose Software (BMDS; version 3.3.2) using a benchmark response (BMR) of 10% extra risk. Adequate model fit was judged by four criteria: chi-square goodness-of-fit p-values (p≥0.1), visual inspection of the dose-response curve, benchmark dose lower confidence limit (BMDL) <10 times the lowest non-zero dose, and scaled residual (>-2 and <+2) at the data point (except the control) closest to the predefined BMR. The dichotomous Hill model was recommended but was not selected, as the number of dose groups in the data should generally be at least one more than the number of parameters in a model. In this case, the dichotomous Hill model uses four parameters and the incidence data have four dose groups. The Multistage Degree 1 was the only viable alternative and the BMDL from this model was selected as the point of departure (POD). Table A-3 presents the benchmark dose (BMD) and BMDL values considered for MRL derivation, and Figure A-1 presents the curve from the chosen model.

Table A-3 Results from BMD Analysis of Incidence of Gastrointestinal Illness in Women Following Exposure to Copper in Drinking Water Daily for 2 Weeks (Pizarro et al. 1999)

Model | BMD_10_^a^ (mg/kg/day) | BMDL_10_^a^ (mg/kg/day) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMD_10_^a^ (mg/kg/day) | BMDL_10_^a^ (mg/kg/day) | p-Value^b^ | AIC | Dose below BMD | Dose above BMD
Dichotomous Hill | 0.051 | 0.032 | 0.29 | 145.93 | −0.72 | 0.18
Gamma^d^ | | | 0.04 | 149.56 | 1.43 | −0.63
Log-Logistic^e^ | | | 0.04 | 149.54 | 1.4 | −0.62
Log-Probit^e^ | | | 0.09 | 147.62 | 1.60 | −0.94
Multistage Degree 3^f^ | | | 0.03 | 149.87 | 1.39 | −0.50
Multistage Degree 2^f^ | | | 0.03 | 149.87 | 1.39 | 0.50
Multistage Degree 1 ^f^ ^,^ ^g^ | 0.089 | 0.055 | 0.11 | 147.92 | 1.25 | −0.35
Weibulld | | | 0.04 | 149.62 | 1.42 | −0.60
Logistic | | | 0.08 | 148.26 | 1.65 | −0.58
Log-Probit | | | 0.04 | 149.16 | 1.35 | −0.67
Probit | | | 0.09 | 148.1 | 1.58 | −0.59
Quantal Linear | 0.089 | 0.055 | 0.11 | 147.92 | 1.25 | −0.35

a BMDLs <10 times the lowest non-zero dose and their corresponding BMDs are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMD.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Selected model. Only the Multistage Degree 1, Quantal Linear, and Dichotomous Hill models provided adequate fit to the data. The dichotomous Hill model had the same number of parameters as the number of dose levels in the data; therefore, it was not selected. The Multistage Degree 1 and Quantal Linear models converged on the same form and this model was selected (Multistage Degree 1).

AIC = Akaike Information Criterion; BMD = benchmark dose (maximum likelihood estimate of the dose associated with the selected benchmark response); BMDL_10_ = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., 10 = dose associated with 10% extra risk)

Figure A-1 Fit of Frequentist Multistage Degree 1 Model to Data on Copper for Gastrointestinal Illness in Female Adults, Daily for 2 Weeks (Pizarro et al. 1999)

Adjustment for Intermittent Exposure: Not applicable.

Uncertainty Factor: The BMDL_10_ is divided by a total uncertainty factor of 3:

- 3 for human variability. A partial uncertainty factor for human variability was applied because the direct effects of copper on the gastrointestinal tract are unlikely to be substantially impacted by toxicokinetic differences among individuals. However, an uncertainty factor for human variability remains necessary because the principal study (Pizarro et al. 1999) was of healthy adult women, and there are some health conditions that may influence sensitivity to these effects. For example, health conditions that reduce the pH of gastric secretions (e.g., acute H. pylori infection, some neuroendocrine tumors or gastrinomas, rebound acid hypersecretion after stopping proton pump inhibitor therapy) may result in higher concentrations of free copper ions in contact with the gastrointestinal tract than those seen in healthy individuals at the same dose. In addition, health conditions that result in damage to the integrity of the gastrointestinal tract (ulcers, acid reflux) may also increase a person’s sensitivity to oral copper exposure. The prevalence of these conditions is relatively high in the United States, so including an uncertainty factor of 3 for human variability is necessary to ensure that the MRL is adequately protective for these susceptible subpopulations.

M R L = (B M D L_10_)/(U F) = (0.055 m g / k g / d a y)/(3) = 0.01833 m g / k g / d a y ( r o u n d e d t o 0.02 m g C u / k g / d a y )

It should be noted that the acute-duration oral MRL may or may not be adequately protective for people with Wilson’s disease, as the degree of protection will depend on their dietary and water intake levels as well as the degree to which their disease is medically controlled.

The acute-duration oral MRL of 0.02 mg Cu/kg/day reflects the intake of administered copper in addition to dietary background. The doses used in BMD modeling were doses of copper from copper sulfate solution provided to the participants in the study by Pizarro et al. (1999), whose average dietary copper intake was estimated^5^ to be ~1.7 mg Cu/day or ~0.027 mg Cu/kg/day. This intake level is similar to estimates of dietary or dietary plus supplement copper intake in the United States (1.0–2.6 mg Cu/day; see Section 5.6, General Population Exposure).

Other Additional Studies or Pertinent Information that Lend Support to this MRL: In addition to the acute-duration controlled human exposure studies, there is an intermediate-duration controlled human exposure study that provides support for the critical effect (Araya et al. 2003b). The concentration-dependence of gastrointestinal symptoms was demonstrated in a study by Araya et al. (2003c), in which volunteers were exposed to the same copper dose in different volumes of water. The study authors observed a higher symptom frequency with higher copper concentrations (lower water volumes) when the intake (dose) was held constant. For example, a dose of 0.8 mg Cu administered in 100 mL of water induced nausea in 13% of subjects, while the same dose in 150 or 200 mL of water induced nausea in 9 and 7% of subjects, respectively (Araya et al. 2003c).

Histological changes in the gastrointestinal tract have been observed in experimental animal studies of intermediate duration, providing additional evidence for the gastrointestinal symptoms exhibited by humans. In a combined repeat-dose and reproductive/developmental toxicity screening study of rats, significant increases in the incidence of squamous cell hyperplasia in the stomach were seen after 30–38 days of gavage exposure to doses ≥3 mg Cu/kg/day in females and ≥13 mg Cu/kg/day in males (Chung et al. 2009). NTP (1993) also observed increased incidences of squamous mucosa hyperplasia of forestomach in male and female rats at doses of 44–46 mg Cu/kg/day for 15 days and 33–34 mg Cu/kg/day for 13 weeks.

In animals exposed orally to copper for acute and intermediate durations, other effects (body weight, hepatic, renal, reproductive, and neurological) occurred at much higher doses (≥2 mg Cu/kg/day) (e.g., Al-Musawi et al. 2022; Guo et al. 2021; Husain et al. 2023; Kumar et al. 2019; Temiz et al. 2021).

Agency Contact (Chemical Managers): Breanna Alman, MPH

## Copper and compounds Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Copper and compounds
CAS Numbers: | 7440-50-8
Date: | October 2024
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.02 mg/kg/day (adopted acute-duration MRL)
Critical Effect: | See acute-duration oral MRL
Reference: | Pizarro et al. 1999 (see acute-duration oral MRL)
Point of Departure: | See acute-duration oral MRL
Uncertainty Factor: | See acute-duration oral MRL
LSE Graph Key: | 6
Species: | Human

MRL Summary: The acute-duration oral MRL of 0.02 mg Cu/kg/day was adopted as the intermediate-duration oral MRL. The intermediate-duration database was assessed for suitability for MRL derivation, but the study with the lowest LOAEL (Araya et al. 2003b, 2004) yielded a higher BMDL (0.11 mg Cu/kg/day) for gastrointestinal symptoms in humans than the BMDL (0.055 mg Cu/kg/day for the same effect in humans; Pizarro et al. 1999) used as the POD for the acute-duration oral MRL. Additionally, the critical effect of gastrointestinal symptoms may result in part from a direct contact effect dependent on the concentration of copper present at a given time in the stomach rather than duration of exposure. Therefore, the acute-duration MRL is expected to be protective for intermediate-duration exposure scenarios.

Selection of the Critical Effect: See worksheet for acute-duration oral MRL.

Selection of the Principal Study: See worksheet for acute-duration oral MRL.

Summary of the Principal Study: See worksheet for acute-duration oral MRL.

Selection of the Point of Departure for the MRL: See worksheet for acute-duration oral MRL.

Calculations: See worksheet for acute-duration oral MRL.

Uncertainty Factor: See worksheet for acute-duration oral MRL.

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Gastrointestinal effects were recorded in a controlled experiment in humans exposed to copper in drinking water for 2 months (Araya et al. 2003b, 2004). In Araya et al. (2003b, 2004), significant increases in the proportion of subjects reporting at least one gastrointestinal symptom (nausea, vomiting, diarrhea, or abdominal pain) were seen at doses of 0.11 and 0.17 mg Cu/kg/day (corresponding to water concentrations of 4 and 6 mg Cu/L, respectively). A study in infants reported no increase in the reporting of gastrointestinal symptoms following daily exposure to doses up to 0.319 mg Cu/kg/day for 9 months (Olivares et al. 1998).

Histological changes in the gastrointestinal tract have been observed in experimental animal studies, providing additional evidence for the gastrointestinal symptoms exhibited by humans. In a combined repeat-dose and reproductive/developmental toxicity screening study of rats, significant increases in the incidence of squamous cell hyperplasia in the stomach were seen after 30–38 days of gavage exposure to doses ≥3 mg Cu/kg/day in females and ≥13 mg Cu/kg/day in males (Chung et al. 2009). NTP (1993) also observed increased incidences of squamous mucosa hyperplasia of forestomach in male and female rats at doses of 44–46 mg Cu/kg/day for 15 days and 33–34 mg Cu/kg/day for 13 weeks.

As shown in Table A-4, animal studies of intermediate-duration oral exposure to copper have also identified hepatic, body weight, neurological, and reproductive system effects at doses ≥2.3 mg Cu/kg/day (Guo et al. 2021; Kline et al. 1971; Liu et al. 2020a, 2020b, 2021a, 2021b; Temiz et al. 2021).

Table A-4 Summary of Lowest LOAEL Values for Health Effects Following Intermediate-Duration Oral Exposure to Copper

Species (sex) | Frequency/ duration | NOAEL (mg Cu/kg/day) | LOAEL (mg Cu/kg/day) | Effect | Reference
Gastrointestinal effects
Human; 1,365 adult men and women (mean ages 37–38 years) | 2 months daily in water used for consumption, beverages, and soups | 0.055 (2 mg Cu/L) | 0.11 (4 mg Cu/L) | Increased incidence of gastrointestinal symptoms | Araya et al. 2003b, 2004
Human; 7 men and women (mean age 42 years) | 12 weeks, daily by capsule | 0.15 | ND | No difference in gastrointestinal symptoms incidence | Pratt et al. 1985
Human; 80 exposed and 48 unexposed male and female infants | 9 months (from 3 to 12 months of age) in water used for consumption and formula | 0.319 (2 mg/L) | ND | No gastrointestinal symptoms observed | Olivares et al. 1998
Rat (F) | 38 days Daily (gavage) | 0.83 | 3 | Increased incidence of squamous cell hyperplasia in the stomach | Chung et al. 2009
Body weight effects
Pig (NS) | 88 days (feed) | 1.7 | 2.3 | 17% reduction in body weight gain | Kline et al. 1971
Mouse (M and F) | 42 days daily (gavage) | ND | 4 | Terminal body weight decreased 15% | Liu et al. 2020a, 2020b, 2021a, 2021b
Neurological effects
Rat (M) | 16 weeks daily (gavage) | ND | 2.6 | Decreased locomotor activity and neuromuscular coordination, decreased passive avoidance response, less exploration time | Kumar et al. 2019
Hepatic effects
Human; 11 men and 11 women (mean ages 33.5 and 29 years, respectively) | 6 weeks, daily in food | | ND | No effect on serum enzyme levels | O’Connor et al. 2003
Human; 7 men and women (mean age 42 years) | 12 weeks, daily by capsule | 0.15 | ND | No effect on serum enzyme levels | Pratt et al. 1985
1,365 adult men and women (mean ages 37–38 years) | 2 months daily in water used for consumption, beverages, and soups | 0.17 | ND | No effect on serum enzyme levels | Araya et al. 2003b, 2004
80 exposed and 48 unexposed male and female infants | 9 months (from 3 to 12 months of age) in water used for consumption and formula | 0.319 | ND | No effect on serum bilirubin or AST, ALT, or GGT activities | Olivares et al. 1998
Rat (M) | 28 days 2 times/week (gavage) | ND | 3.9 | Increased serum AST, ALT, and LDH centrilobular and vacuolar degeneration, dilatation of sinusoid, focal necrosis, and inflammatory cell infiltration in all or most animals | Temiz et al. 2021
Reproductive effects
Mouse (M) | 42 days daily (gavage) | ND | 3.9 | Increased sperm malformations and decreased sperm motility and concentration | Guo et al. 2021

ALT = alanine aminotransferase; AST = aspartate aminotransferase; F = female(s); GGT = γ-glutamyl transferase; LDH = lactate dehydrogenase; LOAEL = lowest-observed-adverse-effect level; M = male(s); ND = not determined; NOAEL = no-observed-adverse-effect level; NS = not specified

The study by Araya et al. (2003b, 2004) identified the lowest NOAEL and corresponding LOAEL for adverse health outcomes (gastrointestinal symptoms) and was considered for possible use in deriving the intermediate-duration oral MRL. Araya et al. (2004) provided more detail on the copper dosing and gastrointestinal symptoms, so information from this publication was used. For groups given measured concentrations of 0.05, 2.02, 3.71, or 5.77 mg Cu/L in drinking water, corresponding daily copper intakes provided by Araya et al. (2004) were 0.08, 3.6, 6.9, and 11 mg/day, respectively. To calculate the dose, a reference body weight of 65 kg for all adults (the midpoint between the default body weights for adult men [70 kg] and women [60 kg]) was used, resulting in doses of 0.001, 0.056, 0.11, and 0.17 mg Cu/kg/day. Incidences of at least one gastrointestinal symptom were 40/343, 50/327, 65/355, and 67/340 for the control through high dose groups, respectively (Araya et al. 2004).

BMD modeling was applied to the incidence data for gastrointestinal symptoms reported by Araya et al. (2004). The data were fit to all available dichotomous models in EPA’s BMDS (version 3.3.2) using the extra risk option. Adequate model fit was judged by four criteria: chi-square goodness-of-fit p-values (p≥0.1), visual inspection of the dose-response curve, BMDL <10 times the lowest non-zero dose, and scaled residual (>-2 and <+2) at the data point (except the control) closest to the predefined BMR. Among the recommended, viable models providing adequate fit to the data, the BMDL from the model with the lowest Akaike Information Criterion (AIC) was selected as the POD. The results of the BMD modeling for incidence of gastrointestinal symptoms in adults are presented in Table A-5.

Table A-5 Results from BMD Analysis of Incidence of Gastrointestinal Illness in Adults Following Exposure to Copper in Drinking Water Daily for 2 Months (Araya et al. 2004)

Model | BMD_10_^a^ (mg Cu/kg/day) | BMDL_10_^a^ (mg Cu/kg/day) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMD_10_^a^ (mg Cu/kg/day) | BMDL_10_^a^ (mg Cu/kg/day) | p-Value^b^ | AIC | Dose below BMD | Dose above BMD
Dichotomous Hill | 0.26 | 0.059 | NA | 1,210.26 | −0.000012 | NR
Gamma^d^ | 0.18 | 0.12 | 0.84 | 1,206.62 | −0.35 | NR
Log-Logistic ^e^ ^,^ ^f^ | 0.18 | 0.11 | 0.86 | 1,206.56 | −0.33 | NR
Log-Probit^e^ | 0.18 | 0.14 | 0.29 | 1,208.75 | −0.57 | NR
Multistage Degree 3^g^ | 0.18 | 0.12 | 0.84 | 1,206.62 | −0.35 | NR
Multistage Degree 2^g^ | 0.18 | 0.12 | 0.84 | 1,206.62 | −0.35 | NR
Multistage Degree 1^g^ | 0.18 | 0.12 | 0.84 | 1,206.62 | −0.35 | NR
Weibull^d^ | 0.18 | 0.12 | 0.84 | 1,206.62 | −0.35 | NR
Logistic | 0.18 | 0.13 | 0.71 | 1,206.95 | −0.40 | NR
Log-Probit | 0.19 | 0 | 0.81 | 1,208.32 | −0.10 | NR
Probit | 0.18 | 0.13 | 0.73 | 1,206.90 | −0.39 | NR
Quantal Linear | 0.18 | 0.12 | 0.84 | 1206.62 | −0.35 | NR

a BMDLs <10 times the lowest non-zero dose and their corresponding BMDs are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMD; also, the largest residual at any dose.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Selected model. All models provided adequate fit to the data (chi-square goodness-of-fit p-values ≥0.1). BMDLs were sufficiently close (differed by <3-fold); therefore, the model with the lowest AIC was selected (Log-Logistic).

g Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMD = benchmark dose (maximum likelihood estimate of the dose associated with the selected benchmark response); BMDL_10_ = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., 10 = dose associated with 10% extra risk); NR = BMD is higher than the highest dose tested; residual not available.

The selected model was the Log-Logistic model, which resulted in a BMDL of 0.11 mg Cu/kg/day. This BMDL is higher than the BMDL of 0.055 mg Cu/kg/day for same endpoint in the acute-duration human study by Pizarro et al. (1999) that was used as the POD for the acute-duration oral MRL. Therefore, ATSDR adopted the acute-duration oral MRL of 0.02 mg Cu/kg/day for intermediate-duration exposure. As noted previously, the critical effect of gastrointestinal symptoms may result from a direct contact effect that depends more on the concentration of copper present at a given time in the gastrointestinal system than on exposure duration. The concentration-dependence of gastrointestinal symptoms was demonstrated in a study by Araya et al. (2003c), in which volunteers were exposed to the same copper dose in different volumes of water. The study authors observed a higher symptom frequency with higher copper concentrations (lower water volumes) when the intake (dose) was held constant. For example, a dose of 0.8 mg copper administered in 100 mL of water induced nausea in 13% of subjects, while the same dose in 150 or 200 mL of water induced nausea in 9 and 7% of subjects, respectively (Araya et al. 2003c). Therefore, the acute-duration MRL is expected to be protective for intermediate-duration exposure scenarios.

Agency Contact (Chemical Managers): Breanna Alman, MPH

## Copper and compounds Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Copper and compounds
CAS Numbers: | 7440-50-8
Date: | October 2024
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of chronic-duration oral MRL because available studies do not clearly identify the critical effects.

Rationale for Not Deriving an MRL: Human studies that met inclusion criteria did not provide sufficient dose-response information to examine the chronic-duration oral toxicity of copper. Two large prospective cohort studies used estimates of dietary copper intake based on food frequency questionnaires to examine associations with dementia (Wei et al. 2022, United States) and hypertension (He et al. 2022, China). Wei et al. (2022) estimated intake of copper from diet and supplements at enrollment in the cohort (1987–1989) and again a few years later (1993–1995) based on responses to a validated food frequency questionnaire administered by an interviewer. Subjects were followed for 20 years; an increase in dietary copper intake of 1 mg Cu/day was associated with increased risk of incident dementia. He et al. (2022) estimated dietary intake at baseline using three consecutive 24-hour recall surveys administered by a nutritionist, coupled with household food inventories on the same days; the participants were followed for a median duration of 6.1 years. Estimated copper intake ≥1.57 mg/day was associated with an increase in risk of incident hypertension (He et al. 2022). Both studies are limited because they do not account for either changes in diet over time or copper intake from water or local sources.

Three animal studies of chronic-duration oral exposure were located, but included only limited toxicological evaluations. One study in mice exposed for 850 days evaluated only survival and body weight and no other health outcomes (Massie and Aiello 1984). In the remaining two experiments, young or adult monkeys were exposed to copper in milk (young) or feed (both) for 3 years (Araya et al. 2012). These studies evaluated body weight, limited hematology and serum chemistry endpoints, and liver histopathology, and identified NOAELs of 5.5 and 7.5 mg Cu/kg/day (Araya et al. 2012). Neither the human studies nor the animal studies provide sufficient information to determine the critical effects of chronic-duration oral exposure to copper.

Agency Contact (Chemical Managers): Breanna Alman, MPH

5 For the four groups of subjects (receiving copper dosing in different sequences), Pizarro et al. (1999) reported average copper intakes of 1.4, 1.7, 1.8, and 1.9 mg Cu/day from food based on 24-hour diet recall. The average intake across groups was 1.725 mg Cu/day; this value was divided by the reported average body weight of 64 kg to estimate the dietary intake of 0.027 mg Cu/kg/day.